# Bibliography

Committee on Performance Measurement. HEDIS 3. 0: Health Plan Employer Data and Information Set. Washington, D.C.: National Committee for Quality Assurance. 1997.
The Medical Outcomes & Guidelines Sourcebook: A Progress Report and Resource Guide on Medical Outcomes Research and Practice Guidelines: Developments, Data, and Documentation. New York, NY: Faulkner & Gray. 1997.
National Library of Healthcare Indicators: Health Plan and Network Edition. Oakbrook Terrace, IL: Joint Commission on Accreditation of Healthcare Organizations. 1997.
Palmer RH, Clark LE, Lawthers AG, Edwards JE, Fowles J, Garnick D, Weiner J. DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality, Final Report, Volumes I, II, and III. Boston, MA: Harvard School of Public Health. 1994.
Toepp MC, Kuznets N, Herrera S. Directory of Clinical Practice Guidelines: Titles, Sources, and Updates. Chicago, IL: American Medical Association. 1998.
U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd ed. Alexandria, VA: International Medical Publishing. 1996.

### Acute Pain Management/Management of Cancer Pain

The management of chronic pain in patients with breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Society of Palliative Care Physicians. Canadian Association of Radiation Oncologists. CMAJ 1998 158Suppl 3:S71 81 9484281
Payne R Practice guidelines for cancer pain therapy. Issues pertinent to the revision of national guidelines Oncology (Huntingt) 1998 12(11A):169 75 10028511
Practice guidelines for acute pain management in the perioperative setting. A report by the American Society of Anesthesiologists Task Force on Pain Management, Acute Pain Section. Anesthesiology 1995 82(4):1071 81 7717542
Practice guidelines for cancer pain management. A report by the American Society of Anesthesiologists Task Force on Pain Management, Cancer Pain Section. Anesthesiology 1996 84(5):1243 57 8624021
Practice guidelines for chronic pain management. A report by the American Society of Anesthesiologists Task Force on Pain Management, Chronic Pain Section. Anesthesiology 1997 86(4):995 1004 9105246

### Urinary Incontinence in Adults

Abstracts of Cochrane Reviews -- Overview of Cochrane Incontinence Group. Cochrane Library 1998Issue 3.
Abrams P, Freeman R, Anderstrom C, et al Tolterodine, a new antimuscarinic agent: as effective but better tolerated than oxybutynin in patients with an overactive bladder Br J Urol 1998 Jun 81(6):801 10 9666761
Atan A, Konety BR, Erickson JR, et al Tolterodine for overactive bladder: time to onset of action, preferred dosage, and 9-month follow-up Tech Urol 1999 Jun 5(2):67 70 10458657
Baker J, Norton P Evaluation of absorbent products for women with mild to moderate urinary incontinence Appl Nurs Res 1996 Feb 9(1):29 33 8633892
Bellin P, Smith J, Poll W, et al Results of a multicenter trial of the CapSure (Re/Stor) Continence shield on women with stress urinary incontinence Urology 1998 May 51(5):697 706 9610582
Berghmans LC, Hendriks HJ, De Bie RA, et al Conservative treatment of urge urinary incontinence in women: a systematic review of randomized clinical trials BJU Int 2000 Feb 85(3):254 63 10671878
Branch LG, Walker LA, Wetle TT, et al Urinary incontinence knowledge among community-dwelling people 65 years of age and older J Am Geriatr Soc 1994 Dec 42(12):1257 62 7983288
Brown JS, Grady D, Ouslander JG, et al Prevalence of urinary incontinence and associated risk factors in postmenopausal womenHeart & Estrogen/Progestin Replacement Study (HERS) Research Group.Obstet Gynecol 1999 Jul 94(1):66 70 10389720
Brown JS, Posner SF, Stewart AL Urge incontinence: new health-related quality of life measures [see comments] J Am Geriatr Soc 1999 Aug 47(8):980 8 10443860
Brown JS, Seeley DG, Fong J, et al Urinary incontinence in older women: who is at risk? Study of Osteoporotic Fractures Research Group Obstet Gynecol 1996 May 87(5 Pt 1):715 21 8677073
Brubaker L, Benson JT, Bent A, et al Transvaginal electrical stimulation for female urinary incontinence Am J Obstet Gynecol 1997 Sep 177(3):536 40 9322620
Burgio KL, Ives DG, Locher JL, et al Treatment seeking for urinary incontinence in older adults J Am Geriatr Soc 1994 Feb 42(2):208 12 8126338
Chapple CR Muscarinic receptor antagonists in the treatment of overactive bladder [see comments] Urology 2000 May 55(5A Suppl):33 46 Discussion 50 10767450
Crooks VC, Schnelle JF, Ouslander JP, et al Use of the Minimum Data Set to rate incontinence severity J Am Geriatr Soc 1995 Dec 43(12):1363 9 7490387
Cruise PA, Schnelle JF, Alessi CA, et al The nighttime environment and incontinence care practices in nursing homes J Am Geriatr Soc 1998 Feb 46(2):181 6 9475446
Drutz HP, Appell RA, Gleason D, et al Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder Int Urogynecol J Pelvic Floor Dysfunct 1999 10(5):283 9 10543335
DuBeau CE, Kiely DK, Resnick NM Quality of life impact of urge incontinence in older persons: a new measure and conceptual structure [see comments] J Am Geriatr Soc 1999 Aug 47(8):989 94 10443861
DuBeau CE, Yalla SV, Resnick NM Improving the utility of urine flow rate to exclude outlet obstruction in men with voiding symptoms J Am Geriatr Soc 1998 Sep 46(9):1118 24 9736105
Dumoulin C, Seaborne DE, Quirion-DeGirardi C, et al Pelvic-floor rehabilitation, Part 2: Pelvic-floor reeducation with interferential currents and exercise in the treatment of genuine stress incontinence in postpartum women -- a cohort study Phys Ther 1995 Dec 75(12):1075 81 7501710
Fantl JA, Bump RC, Robinson D, et al Efficacy of estrogen supplementation in the treatment of urinary incontinence. The Continence Program for Women Research Group Obstet Gynecol 1996 Nov 88(5):745 9 8885906
Fantl JA, Cardozo L, McClish DK Estrogen therapy in the management of urinary incontinence in postmenopausal women: a meta-analysis. First report of the Hormones and Urogenital Therapy Committee Obstet Gynecol 1994 Jan 83(1):12 8 8272292
Fried GW, Goetz G, Potts-Nulty S, et al A behavioral approach to the treatment of urinary incontinence in a disabled population Arch Phys Med Rehabil 1995 Dec 76(12):1120 4 8540787
Gallo M, Sasso KC Key components of patient education for pelvic floor stimulation in the treatment of urinary incontinence Urol Nurs 1997 Mar 17(1):10 6 9110900
Guay DR Tolterodine, a new antimuscarinic drug for treatment of bladder overactivity [see comments] Pharmacotherapy 1999 Mar 19(3):267 80 10221366
Johnson TM 2nd, Kincade JE, Bernard SL, et al The association of urinary incontinence with poor self-rated health [see comments] J Am Geriatr Soc 1998 Jun 46(6):693 9 9625183
Kobelt G, Jonsson L, Mattiasson A Cost-effectiveness of new treatments for overactive bladder: the example of tolterodine, a new muscarinic agent: a Markov model Neurourol Urodyn 1998 17(6):599 611 9829424
Kralj B Conservative treatment of female stress urinary incontinence with functional electrical stimulation Eur J Obstet Gynecol Reprod Biol 1999 Jul 85(1):53 6 10428322
Larsson G, Hallen B, Nilvebrant L Tolterodine in the treatment of overactive bladder: analysis of the pooled phase II efficacy and safety data Urology 1999 May 53(5):990 8 10223495
Lekan-Rutledge D, Palmer MH, Belyea M In their own words: nursing assistants' perceptions of barriers to implementation of prompted voiding in long-term care Gerontologist 1998 Jun 38(3):370 8 9640857
McClish DK, Fantl JA, Wyman JF, et al Bladder training in older women with urinary incontinence: relationship between outcome and changes in urodynamic observations Obstet Gynecol 1991 Feb 77(2):281 6 1988894
McDowell BJ, Engberg S, Sereika S, et al Effectiveness of behavioral therapy to treat incontinence in homebound older adults J Am Geriatr Soc 1999 Mar 47(3):309 18 10078893
Miller JL, Bavendam T Treatment with the Reliance urinary control insert: one-year experience J Endourol 1996 Jun 10(3):287 92 8740394
Miller JM, Ashton-Miller JA, DeLancey JO A pelvic muscle precontraction can reduce cough-related urine loss in selected women with mild SUI J Am Geriatr Soc 1998 Jul 46(7):870 4 9670874
Nygaard IE, Kreder KJ, Lepic MM, et al Efficacy of pelvic floor muscle exercises in women with stress, urge, and mixed urinary incontinence Am J Obstet Gynecol 1996 Jan 174(1 Pt 1):120 5 8571994
Ouslander JG, Buxton WG, Al-Samarrai NR, et al Nighttime urinary incontinence and sleep disruption among nursing home residents J Am Geriatr Soc 1998 Apr 46(4):463 6 9560069
Ouslander JG, Nasr SZ, Miller M, et al Arginine vasopressin levels in nursing home residents with nighttime urinary incontinence [published erratum appears in J Am Geriatr Soc 1999 Apr;47(4):481] J Am Geriatr Soc 1998 Oct 46(10):1274 9 9777911
Ouslander JG, Schapira M, Schnelle JF, et al Does eradicating bacteriuria affect the severity of chronic urinary incontinence in nursing home residents? [see comments] Ann Intern Med 1995 May 15 122(10):749 54 7717597
Ouslander JG, Schnelle JF, Uman G, et al Does oxybutynin add to the effectiveness of prompted voiding for urinary incontinence among nursing home residents? A placebo-controlled trial J Am Geriatr Soc 1995 Jun 43(6):610 7 7775717
Ouslander JG, Simmons S, Schnelle J, et al Effects of prompted voiding on fecal continence among nursing home residents J Am Geriatr Soc 1996 Apr 44(4):424 8 8636590
Ouslander JG, Simmons S, Tuico E, et al Use of a portable ultrasound device to measure post-void residual volume among incontinent nursing home residents J Am Geriatr Soc 1994 Nov 42(11):1189 92 7963206
Palmer MH Nurses' knowledge and beliefs about continence interventions in long-term care J Adv Nurs 1995 Jun 21(6):1065 72 7665769
Reynard JM, Cannon A, Yang Q, et al A novel therapy for nocturnal polyuria: a double-blind randomized trial of frusemide against placebo [see comments] Br J Urol 1998 Feb 81(2):215 8 9488061
Richardson DA, Miller KL, Siegel SW, et al Pelvic floor electrical stimulation: a comparison of daily and every-other-day therapy for genuine stress incontinence Urology 1996 Jul 48(1):110 8 8693630
Roberts RO, Jacobsen SJ, Rhodes T, et al Urinary incontinence in a community-based cohort: prevalence and healthcare-seeking J Am Geriatr Soc 1998 Apr 46(4):467 72 9560070
Sampselle CM, Wyman JF, Thomas KK, et al Continence for women: a test of AWHONN's evidence-based protocol in clinical practice. Association of Women's Health Obstetric and Neonatal Nurses J Obstet Gynecol Neonatal Nurs 2000 Jan-Feb 29(1):18 26 10660273
Sampselle CM, Wyman JF, Thomas KK, et al Continence for women: evaluation of AWHONN's third research utilization project. Association of Women's Health Obstetric and Neonatal Nurses J Obstet Gynecol Neonatal Nurs 2000 Jan-Feb 29(1):9 17 10660272
Sand PK, Richardson DA, Staskin DR, et al Pelvic floor electrical stimulation in the treatment of genuine stress incontinence: a multicenter, placebo-controlled trial Am J Obstet Gynecol 1995 Jul 173(1):72 9 7631730
Schnelle JF, Keeler E, Hays RD, et al A cost and value analysis of two interventions with incontinent nursing home residents J Am Geriatr Soc 1995 Oct 43(10):1112 7 7560701
Schnelle JF, MacRae PG, Ouslander JG, et al Functional Incidental Training, mobility performance, and incontinence care with nursing home residents [see comments] J Am Geriatr Soc 1995 Dec 43(12):1356 62 7490386
Sherman RA, Davis GD, Wong MF Behavioral treatment of exercise-induced urinary incontinence among female soldiers Mil Med 1997 Oct 162(10):690 4 9339085
Shinopulos NM, Dann JA, Smith JJ 3rd Patient selection and education for use of the CapSure (Re/Stor) continence shield Urol Nurs 1999 Jun 19(2):135 40 10633764
Smith DB A continence care approach for long-term care facilities Geriatr Nurs 1998 Mar-Apr 19(2):81 6 9611505
Smith JJ 3rd Intravaginal stimulation randomized trial J Urol 1996 Jan 155(1):127 30 7490809
Snyder M, Pearson V, Hanscom J, et al Barriers to progress in urinary incontinence: achieving quality assessments Geriatr Nurs 1998 Mar-Apr 19(2):77 80 9611504
Staskin D, Bavendam T, Miller J, et al Effectiveness of a urinary control insert in the management of stress urinary incontinence: early results of a multicenter study Urology 1996 May 47(5):629 36 8650857
Sullivan J, Abrams P Pharmacological management of incontinence Eur Urol 1999 36Suppl 1:89 95 10393480
Sultana CJ, Campbell JW, Pisanelli WS, et al Morbidity and mortality of incontinence surgery in elderly women: an analysis of Medicare data [see comments] Am J Obstet Gynecol 1997 Feb 176(2):344 8 9065179
Thom DH, van den Eeden SK, Brown JS Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life Obstet Gynecol 1997 Dec 90(6):983 9 9397116
Van Kampen M, De Weerdt W, Van Poppel H, et al Effect of pelvic-floor re-education on duration and degree of incontinence after radical prostatectomy: a randomised controlled trial Lancet 2000 Jan 8 355(9198):98 102 10675166
Wagner TH, Hu TW Economic costs of urinary incontinence in 1995 Urology 1998 Mar 51(3):355 61 9610584
Yamanishi T, Yasuda K, Sakakibara R, et al Pelvic floor electrical stimulation in the treatment of stress incontinence: an investigational study and a placebo controlled double-blind trial J Urol 1997 Dec 158(6):2127 31 9366328
Yono M, Yoshida M, Wada Y, et al Pharmacological effects of tolterodine on human isolated urinary bladder Eur J Pharmacol 1999 Mar 5 368(2-3):223 30 10193658

### Pressure Ulcer in Adults/Treatment of Pressure Ulcers

Krasner D The AHCPR pressure ulcer infection control recommendations revisited Ostomy Wound Manage 1999 45(1A Suppl):88S 91S quiz 92S 93S 10085979
Ovington LG Dressings and adjunctive therapies: AHCPR guidelines revisited Ostomy Wound Manage 1999 45(1A Suppl):94S 106S quiz 107S 108S 10085980
Pressure ulcers in adults: prediction and prevention. AGS Clinical Practice Committee J Am Geriatr Soc 1996 44(9):1118 9 8790244
van Rijswijk L, Braden BJ Pressure ulcer patient and wound assessment: an AHCPR clinical practice guideline update Ostomy Wound Manage 1999 45(1A Suppl):56S 67S quiz 68S 69S 10085976

### Depression in Primary Care

Anfinson TJ, Kathol RG Screening laboratory evaluation in psychiatric patients: a review Gen Hosp Psychiatry 1992 Jul 14(4):248 57 1505746
Bongers PM, de Winter CR, Kompier MA, et al Psychosocial factors at work and musculoskeletal disease Scand J Work Environ Health 1993 Oct 19(5):297 312 8296178
Eccles M, Freemantle N, Mason J North of England evidence-based guideline development project: summary version of guidelines for the choice of antidepressants for depression in primary care. North of England Anti-depressant Guideline Development Group Fam Pract 1999 16(2):103 11 10381013
Fava M, Mulroy R, Alpert J, et al Emergence of adverse events following discontinuation of treatment with extended-release venlafaxine Am J Psychiatry 1997 Dec 154(12):1760 2 9396960
Fava GA, Rafanelli C, Grandi S, et al Six-year outcome for cognitive behavioral treatment of residual symptoms in major depression Am J Psychiatry 1998 Oct 155(10):1443 5 9766780
Fava GA, Rafanelli C, Grandi S, et al Prevention of recurrent depression with cognitive behavioral therapy: preliminary findings [see comments] Arch Gen Psychiatry 1998 Sep 55(9):816 20 9736008
Lima MS, Moncrieff. J "Abstract of Review: A Comparison of Drugs Versus Placebo for the Treatment of Dysthymia: A Systematic Review. (Cochrane Review)." In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Long TD, Kathol RG Critical review of data supporting affective disorder caused by nonpsychotropic medication Ann Clin Psychiatry 1993 Dec 5(4):259 70 7906178
Noyes R, Holt CS, Kathol RG Somatization. Diagnosis and management Arch Fam Med 1995 Sep 4(9):790 5 7647946
Noyes R, Kathol RG, Fisher MM, et al Psychiatric comorbidity among patients with hypochondriasis Gen Hosp Psychiatry 1994 Mar 16(2):78 87 8039697
Rosenbaum JF, Fava M, Hoog SL, et al Selective serotonin reuptake inhibitor discontinuation syndrome: a randomized clinical trial [see comments] Biol Psychiatry 1998 Jul 15 44(2):77 87 9646889
Rosenbaum JF, Zajecka J Clinical management of antidepressant discontinuation [see comments] J Clin Psychiatry 1997 58Suppl 7:37 40 9219493
Schulberg HC, Pilkonis PA, Houck P The severity of major depression and choice of treatment in primary care practice J Consult Clin Psychol 1998 Dec 66(6):932 8 9874906
Sharpe M. Non-pharmacological approaches to treatment. Ciba Found Symp. 1993;173:298-308. Discussion. 308. 17. [pmid: 8491104].
Sharpe M, Chalder T, Palmer I, et al Chronic fatigue syndrome. A practical guide to assessment and management Gen Hosp Psychiatry 1997 May 19(3):185 99 9218987
Sharpe M, Hawton K, Simkin S, et al Cognitive behaviour therapy for the chronic fatigue syndrome: a randomized controlled trial [see comments] BMJ 1996 Jan 6 312(7022):22 6 8555852
Stevens AB, Burgio LD, Bailey E, et al Teaching and maintaining behavior management skills with nursing assistants in a nursing home Gerontologist 1998 Jun 38(3):379 84 9640858
Schulberg HC, Katon W, Simon GE, et al Treating major depression in primary care practice: an update of the Agency for Health Care Policy and Research Practice Guidelines Arch Gen Psychiatry 1998 55(12):1121 7 9862556
Sherbourne C, Wells K, Sturm R Measuring health outcomes for depression Evaluation and the Health Professions 1997 20(1):47 64
Sturm R, Wells K. How can care for depression become more cost-effective?. JAMA. 1995;273:51-58. [pmid: 7996651].
Wells K, Rogers W, et al. Quality of care for depressed elderly pre-post prospective payment system: differences in response across treatment settings". Med Care. 1994;32:257-276. [pmid: 8145602].
Wells K, Sturm R., Sherbourne C, et al. Caring for depression: a RAND study. Cambridge, MA: Harvard University Press. 1996.

### Cataract in Adults

O'Day DM Socioeconomics viewpoint: the need for an update of the clinical practice guideline on cataract Arch Ophthalmol 1995 113(6):718 20 7786210
Smeeth L, Iliffe S Community Screening for Visual Impairment in the Elderly (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Steinberg EP. Cataract Patient Outcome Research Team Final Report. AHCPR Publication No. 96-N002. Rockville, MD: Agency for Health Care Policy and Research. November 1995.

### Sickle Cell Disease

American Academy of Pediatrics publishes guidelines on the management of sickle cell disease. American Family Physician 1997 55(5):1973 74+1976 9105214
Ambrus JL, Reddington TM, Meky NN, et al Stiff red cell syndrome. A review of the treatment of sickle cell disease with pentoxifylline J Med 1993 24(1):1 9 8501400
Ballas SK Complications of sickle cell anemia in adults: Guidelines for effective management Cleveland Clinic Journal of Medicine 1999 66(1):48 58 9926631
Charache S, et al. Effect of hydroxyurea on the frequency of painful crises in sickle cell anemia. N Engl J Med. 1995;332:1317-22. [pmid: 7715639].
Payne R Pain management in sickle cell anemia Anesthesiology Clinics of North America 1997 15(2):305 18
Prielipp RC Clinical guidelines [11] (multiple letters) Anesthesia and Analgesia 2000 90(2):50 3 10624976
Walters MC, et al. Bone marrow transplant for sickle cell disease. N Engl J Med. 1996;335:369-76. [pmid: 8663884].

### Benign Prostatic Hyperplasia

Lepor H, Williford WO, Barry MJ, et al The efficacy of terazosin, finasteride, or both in benign prostatic hyperplasia. Veterans Affairs Cooperative Studies Benign Prostatic Hyperplasia Study Group [see comments] N Engl J Med 1996 Aug 22 335(8):533 9 8684407
Wasson JH, Reda DJ, Bruskewitz RC, et al A comparison of transurethral surgery with watchful waiting for moderate symptoms of benign prostatic hyperplasia. The Veterans Affairs Cooperative Study Group on Transurethral Resection of the Prostate [see comments] N Engl J Med 1995 Jan 12 332(2):75 9 7527493

### Unstable Angina

Antman EM, McCabe CH, Gurfinkel EP, et al Enoxaparin prevents death and cardiac ischemic events in unstable angina/non-Q-wave myocardial infarction. Results of the thrombolysis in myocardial infarction (TIMI) 11B trial [see comments] Circulation 1999 Oct 12 100(15):1593 601 10517729
Antman EM, Tanasijevic MJ, Thompson B, et al Cardiac-specific troponin I levels to predict the risk of mortality in patients with acute coronary syndromes [see comments] N Engl J Med 1996 Oct 31 335(18):1342 9 8857017
Caro JJ, Migliaccio-Walle K Generalizing the results of clinical trials to actual practice: the example of clopidogrel therapy for the prevention of vascular events. CAPRA (CAPRIE Actual Practice Rates Analysis) Study Group. Clopidogrel versus Aspirin in Patients at Risk of Ischaemic Events Am J Med 1999 Dec 107(6):568 72 10625025
Cohen M, Demers C, Gurfinkel EP, et al A comparison of low-molecular-weight heparin with unfractionated heparin for unstable coronary artery disease. Efficacy and Safety of Subcutaneous Enoxaparin in Non-Q-Wave Coronary Events Study Group [see comments] N Engl J Med 1997 Aug 14 337(7):447 52 9250846
A comparison of aspirin plus tirofiban with aspirin plus heparin for unstable angina. Platelet Receptor Inhibition in Ischemic Syndrome Management (PRISM) Study Investigators [see comments]. N Engl J Med 1998 May 21 338(21):1498 505 9599104
Comparison of two treatment durations (6 days and 14 days) of a low molecular weight heparin with a 6-day treatment of unfractionated heparin in the initial management of unstable angina or non-Q wave myocardial infarction: FRAX. I.S. (FRAxiparine in Ischaemic Syndrome) [see comments]. Eur Heart J 1999 Nov 20(21):1553 62 10529323
DeLong ER, Pryor DB. Final Report - Ischemic Heart Disease-Patient Outcomes Research Team, Project no. (IHD PORT). 5 PO1 HS 06503-05. Rockville, MD: Agency for Health Care Planning and Research. August 1997.
Ellerbeck EF, Jencks SF, Radford MJ, et al. Quality of Care for Medicare Patients with Acute Myocardial Infarction. JAMA. 1995;273:1509-14. [pmid: 7739077].
Gibbons RJ, Chatterjee K, Daley J, et al ACC/AHA/ACP-ASIM guidelines for the management of patients with chronic stable angina: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Patients With Chronic Stable Angina) J Am Coll Cardiol 1999 33(7):2092 197 10362225
Hettiarachchi RJ, Prins MH, Lensing AW, et al Low molecular weight heparin versus unfractionated heparin in the initial treatment of venous thromboembolism [see comments] Curr Opin Pulm Med 1998 Jul 4(4):220 5 10813237
Inhibition of platelet glycoprotein IIb/IIIa with eptifibatide in patients with acute coronary syndromes. The PURSUIT Trial Investigators. Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression Using Integrilin Therapy [see comments] N Engl J Med 1998 Aug 13 339(7):436 43 9705684
Inhibition of the platelet glycoprotein IIb/IIIa receptor with tirofiban in unstable angina and non-Q-wave myocardial infarction. Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms (PRISM-PLUS) Study Investigators [see comments] [published erratum appears in N Engl J Med 1998 Aug 6;339(6):415]. N Engl J Med 1998 May 21 338(21):1488 97 9599103
Kaul S, Shah PK Low molecular weight heparin in acute coronary syndrome: evidence for superior or equivalent efficacy compared with unfractionated heparin? J Am Coll Cardiol 2000 Jun 35(7):1699 712 10841215
Klein W, Buchwald A, Hillis SE, et al Comparison of low-molecular-weight heparin with unfractionated heparin acutely and with placebo for 6 weeks in the management of unstable coronary artery disease. Fragmin in unstable coronary artery disease study (FRIC) [see comments] [published erratum appears in Circulation 1998 Feb 3;97(4):413] Circulation 1997 Jul 1 96(1):61 8 9236418
McNeil BJ. The consequences of variation in treatment for acute myocardial infarction, Patient Outcomes Research Team (PORT) -- Final Report. No: RO1 HS 06341. AHCPR Publication No. 95-NOO7. Rockville, MD: Agency for Health Care Planning and Research. July 28, 1995.
A randomised, blinded, trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). CAPRIE Steering Committee [see comments]. Lancet 1996 Nov 16 348(9038):1329 39 8918275
Randomised placebo-controlled trial of abciximab before and during coronary intervention in refractory unstable angina: the CAPTURE Study [see comments] [published erratum appears in Lancet 1997 Sep 6;350(9079):744]. Lancet 1997 May 17 349(9063):1429 35 9164316

### Heart Failure

ACC/AHA collaborate on guidelines for the evaluation and management of heart failure. Am Fam Physician 1996 53(6):2196 8 8623726
Adams KF Jr, Ellis ML, Williamson KM, Patterson JH The AHCPR clinical practice guideline for heart failure revisited Ann Pharmacother 1997 31(10):1197 204 9337446
Al-Khadra AS, Salem DN, Rand WM, et al Warfarin anticoagulation and survival: a cohort analysis from the Studies of Left Ventricular Dysfunction J Am Coll Cardiol 1998 Mar 15 31(4):749 53 9525542
Aliot E [The best of arrhythmias in 1999] Arch Mal Coeur Vaiss 2000 Jan 93(1 Spec No):25 31 10721445
Bleske BE, Gilbert EM, Munger MA Carvedilol: therapeutic application and practice guidelines Pharmacotherapy 1998 18(4):729 37 9692647
Borduas F, Carrier R, Drouin D, Deslauriers D, Tremblay G An interactive workshop: An effective means of integrating the Canadian Cardiovascular Society clinical practice guidelines on congestive heart failure into Canadian family physicians' practice Can J Cardiol 1998 14(7):911 6 9706275
Buxton AE, Fisher JD, Josephson ME, et al Prevention of sudden death in patients with coronary artery disease: the Multicenter Unsustained Tachycardia Trial (MUSTT) Prog Cardiovasc Dis 1993 Nov-Dec 36(3):215 26 8234775
Buxton AE, Lee KL, Fisher JD, et al A randomized study of the prevention of sudden death in patients with coronary artery disease. Multicenter Unsustained Tachycardia Trial Investigators [see comments] [published erratum appears in N Engl J Med 2000 Apr 27;342(17):1300] N Engl J Med 1999 Dec 16 341(25):1882 90 10601507
Cannom DS A critical appraisal of indications for the implantable cardioverter defibrillator (ICD) Clin Cardiol 1992 May 15(5):369 72 1623658
Cleland JGF, Erdmann E. Ferrari R., et al Guidelines for the diagnosis of heart failure European Heart Journal 1995 16(6):741 751 7588917
Coats AJ Exercise training for heart failure: coming of age Circulation 1999 99(9):1138 40 10069779
Cohn JN Heart failure: future treatment approaches Am J Hypertens 2000 May 13(5 Pt 2):74S 78S 10830793
Consensus recommendations for the management of chronic heart failure. On behalf of the membership of the advisory council to improve outcomes nationwide in heart failure. Am J Cardiol 1999 83(2A):1A 38A 10072251
Desnos M [The best of cardiac failure in 1999] Arch Mal Coeur Vaiss 2000 Jan 93(1 Spec No):19 23 10721444
Domanski MJ, Sakseena S, Epstein AE, et al Relative effectiveness of the implantable cardioverter-defibrillator and antiarrhythmic drugs in patients with varying degrees of left ventricular dysfunction who have survived malignant ventricular arrhythmias. AVID Investigators. Antiarrhythmics Versus Implantable Notes: Comments: [Comment] J Am Coll Cardiol 1999 Oct 34(4):1096 8 10520796
Eccles M, Freemantle N., Mason J North of England evidence based development project: Guideline for angiotensin converting enzyme inhibitors in primary care management of adults with symptomatic heart failure British Medical Journal 1998 316(7141):1369 1375 9563995 1113074
The effect of digoxin on mortality and morbidity in patients with heart failure. The Digitalis Investigation Group [see comments]. N Engl J Med 1997 Feb 20 336(8):525 33 9036306
Effectiveness of spironolactone added to an angiotensin-converting enzyme inhibitor and a loop diuretic for severe chronic congestive heart failure (the Randomized Aldactone Evaluation Study [RALES]). Am J Cardiol 1996 Oct 15 78(8):902 7 8888663
Francis GS Treatment of the patient with heart failure: Recommendations of the ACC/AHA Task Force for the Evaluation and Management of Heart Failure Prevention and Management of Congestive Heart Failure 1996 2(2):14 16
Gheorghiade M, Benatar D, Konstam MA, Stoukides CA, Bonow RO Pharmacotherapy for systolic dysfunction: a review of randomized clinical trials Am J Cardiol 1997 80(8B):14H 27H 9372994
Guidelines for the evaluation and management of heart failure. Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Evaluation and Management of Heart Failure). J Am Coll Cardiol 1995 26(5):1376 98 7594057
Heart failure clinical guideline. South African Medical Association Heart Failure Working Group. S Afr Med J 1998 88(9 Pt 2):1133 55 9798509
Heart failure drugs: what's new? Drug Ther Bull 2000 Apr 38(4):25 7 10845239
Heart failure: evaluation and treatment of patient's with left ventricular systolic dysfunction. Agency for Health Care Policy and Research (AHCPR). J Am Geriatr Soc 1998 46(4):525 9 9560080
Heart failure management: New consensus recommendations. Journal of Critical Illness 1999 14(7):375 376
Heart Failure Society of America (HFSA) practice guidelines. HFSA guidelines for management of patients with heart failure caused by left ventricular systolic dysfunction -- pharmacological approaches. J Card Fail 1999 5(4):357 82 10634677
HFSA guidelines for management of patients with heart failure caused by left ventricular systolic dysfunction -- pharmacological approaches. Heart Failure Society of America. Pharmacotherapy 2000 20(5):495 522 10809338
Hunt SA, Bristow MR, Kubo SH, O'Connell JB, Young JB Guidelines for training in adult cardiovascular medicine. Core Cardiology Training Symposium (COCATS). Task Force 8: training in heart failure and transplantation J Am Coll Cardiol 1995 25(1):29 31 7798519
Jessup M, Brozena S New approaches in the management of patients with chronic congestive heart failure Drugs of Today 1999 35(11):849 55 12973376
Johnstone DE, Abdulla A, Arnold JM, et al Diagnosis and management of heart failure. Canadian Cardiovascular Society Can J Cardiol 1994 10(6):613 31, 635-54 8044722
Klein HU, Reek S The MUSTT study: evaluating testing and treatment J Interv Card Electrophysiol 2000 Jan 4Suppl 1:45 50 10590488
Konstam MA, Remme WJ Treatment guidelines in heart failure Prog Cardiovasc Dis 1998 41(1 Suppl 1):65 72 9715825
Krum H Beta-blockers in heart failure. The 'new wave' of clinical trials Drugs 1999 Aug 58(2):203 10 10473016
Landmark study challenges current drug treatment practices in heart failure. American Journal of Managed Care 1998 4(6 SUPPL):
Margolis A, Bray BE, Gilbert EM, Warner HR. Computerized practice guidelines for heart failure management: the HeartMan system. Proc Annu Symp Comput Appl Med Care. 1995:228-32. [pmid: 8563274].
McKelvie RS, Teo KK, McCartney N, Humen D, Montague T, Yusuf S Effects of exercise training in patients with congestive heart failure: a critical review J Am Coll Cardiol 1995 25(3):789 96 7860930
Mulvagh SL Myocardial perfusion by contrast echocardiography: diagnosis of coronary artery disease using contrast-enhanced stress echocardiography and assessment of coronary anatomy and flow reserve Coron Artery Dis 2000 May 11(3):243 51 10832558
New Zealand guidelines for the management of chronic heart failure The National Heart Foundation of New Zealand Cardiac Society of Australia and New Zealand and the Royal New Zealand College of General Practitioners Working Party N Z Med J 1997 110(1040):99 107 9137313
O'Connor CM, Carson PE, Miller AB, et al Effect of amlodipine on mode of death among patients with advanced heart failure in the PRAISE trial. Prospective Randomized Amlodipine Survival Evaluation Am J Cardiol 1998 Oct 1 82(7):881 7 9781971
Ohman EM, Armstrong PW, Christenson RH, et al Cardiac troponin T levels for risk stratification in acute myocardial ischemia. GUSTO IIA Investigators [see comments] N Engl J Med 1996 Oct 31 335(18):1333 41 8857016
Packer M, Cohn J.N., Abraham W.T., et al Consensus recommendations for the management of chronic heart failure: Introduction Am J Cardiol 1999 83(2 A):1A 38A 10072251
Pitt B, Poole-Wilson PA, Segal R, et al Effect of losartan compared with captopril on mortality in patients with symptomatic heart failure: randomised trial -- the Losartan Heart Failure Survival Study ELITE II. [comments appear in Lancet 2000 May 6;355(9215):1568-9] Lancet 2000 May 6 355(9215):1582 7 10821361
Pitt B, Zannad F, Remme WJ, et al The effect of spironolactone on morbidity and mortality in patients with severe heart failure. Randomized Aldactone Evaluation Study Investigators [see comments] N Engl J Med 1999 Sep 2 341(10):709 17 10471456
Presbury D, Chetty M, Dalby AJ, et al Heart failure clinical guideline South African Medical Journal 1998 88(9 II):1135 1155
Ryden L, Hobbs FDR Proceedings of a roundtable meeting on evidence-based management of heart failure: ACE inhibitors and ATinf 1 receptor blockers, New Orlean, U.S.A., 6 March 1999: Foreword European Heart Journal, Supplement 1999 1(Q):Q1 Q2
Schrier RW, Abdallah JG, Weinberger HH, et al Therapy of heart failure Kidney Int 2000 Apr 57(4):1418 25 10760077
Sullivan M Exercise training in heart failure: an intervention whose time has come J Card Fail 1997 3(1):13 4 9110250
Teerlink JR, Massie BM Beta-adrenergic blocker mortality trials in congestive heart failure Am J Cardiol 1999 Nov 4 84(9A):94R 102R 10568667
The treatment of heart failure. Task Force of the Working Group on Heart Failure of the European Society of Cardiology. Eur Heart J 1997 18(5):736 53 9152644
van Guldener C, Donker AJ [Anti-aldosterone therapy in severe heart failure] Ned Tijdschr Geneeskd 1999 Aug 21 143(34):1724 6 10494316
Williams JrJF, Bristow M. R., Fowler M.B., et al Guidelines for the evaluation and management of heart failure 1995 26(5):1376 98 7594057
Young J Heart failure: highlights from new consensus guidelines. [comments appear in J Am Coll Cardiol 1999 Oct;34(4):1090-5] Cleve Clin J Med 2000 67(1):13 6 Defibrillators 10645672

### Otitis Media with Effusion

Bluestone CD, Klein JO Clinical practice guideline on otitis media with effusion in young children: strengths and weaknesses Otolaryngol Head Neck Surg 1995 112(4):507 11 7700654
Calandra LM Otitis media with effusion. Outlining strategies and controversies Adv Nurse Pract 1998 6(2):67 70 9555285
Glue ear guidelines: time to act on the evidence [editorial] [see comments]. Lancet 1992 340(8831)1324 5
Grundfast KM Management of otitis media and the New Agency for Health Care Policy and Research Guideline Arch Otolaryngol Head Neck Surg 1994 120(8):797 8 8049038
Healy GB Quick reference guide for clinicians. Managing otitis media with effusion in young children: a commentary Arch Otolaryngol Head Neck Surg 1994 120(10):1049 50 7917186
Lous J Otitis media and reading achievement: a review International Journal of Pediatric Otorhinolaryngology 1995 32(2):105 21 7657465
Managing otitis media with effusion in young children. American Academy of Pediatrics The Otitis Media Guideline Panel. Pediatric 1994 94(5):766 73
Managing otitis media with effusion in young children. Otitis Media Guideline Panel Am Fam Physician 1994 50(5):1003 10 7942399
Martin BD, Macdonald SM The management of ear disease: guidelines for Aboriginal health care programs Int J Circumpolar Health 1998 57Suppl 1:268 75 Otitis media with effusion in children [editorial] Lancet 1990 336(8706)p23 4 10093288
Paparella MM, Schachern P. New developments in treating otitis media. Ann Otol Rhinol Laryngol Suppl. 1994;163:7-10. [pmid: 8179274].
Ramos O, Lifshitz F Management of otitis media with effusion in the next century International Pediatrics 1999 14(4):196 197
Rosenfeld RM An evidence-based approach to treating otitis media Pediatr Clin North Am 1996 43(6):1165 81 8973506
Roush J, Henderson F Medical and audiological management of otitis media: Consensus and controversy Seminars in Hearing 1995 16(1):105 112
Vernon-Feagans L. Impact of Otitis Media on Speech, Language, Cognition, and Behavior. London: B.C. Decker Inc. 1999.

### Quality Determinants of Mammography

Bassett LW Determinants of quality in mammography Surg Oncol Clin N Am 1997 6(2):213 32 9115493
Bianchi S, Sapino A, Bussolati G [Guidelines concerning breast pathology in the course of mammographic screening programs. Working group on "Breast pathology in mammographic screening programs" of the European Communities] Pathologica 1997 89(3):234 55 9380418
Bosmans H, Carton AK, Deprez T, et al Confrontation of mammography systems in Flanders with the European Guidelines for Quality Assurance in mammography screening. Analysis of initial results JBR-BTR 1999 82(6):288 93 Breast cancer screening for women in their 40s: NIH consensus development conference statement Consultant 1997 37(8):2189 2198 10670170
Breast-cancer screening with mammography in women aged 40-49 years. Swedish Cancer Society and the Swedish National Board of Health and Welfare. Int J Cancer 1996 68(6):693 9 8980168
Ciatto S Controversies regarding screening mammography Crit Rev Oncol Hematol 1997 26(1):55 9 Contention over mammography in the US Annals of Oncology 1997 8(5):410 411 9246541
Del Turco MR. A critical review of screening for breast cancer. Recent Results Cancer Res. 1996;140:123-30. [pmid: 8787055].
Douek M, Davidson T, Taylor I Breast cancer imaging -- what are the optimal modalities? Eur J Surg Oncol 1998 24(6):573 82 9870737
Eastman P NCI adopts new mammography screening guidelines for women J Natl Cancer Inst 1997 89(8):538 9 9106638
Endo T [Recent improvement of mammographic diagnosis] Nippon Geka Gakkai Zasshi 1996 97(5):333 7 8709933
Ernster VL Mammography screening for women aged 40 through 49 -- a guidelines saga and a clarion call for informed decision making Am J Public Health 1997 87(7):1103 6 9240097 1380881
European recommendations for quality assurance in the setting of mammographic screening for breast cancer. Report of pathologists of the working group "Breast Cancer Screening" of the European Union. Ann Pathol 1996 16(5):315 33 9004719
Feig SA, D'Orsi CJ, Hendrick RE, et al American College of Radiology guidelines for breast cancer screening AJR Am J Roentgenol 1998 171(1):29 33 9648758
Feig SA Mammographic screening of women aged 40-49 years. Benefit, risk, and cost considerations Cancer 1995 76(10 Suppl):2097 106 8635007
Ferrini R, Mannino E, Ramsdell E, Hill L Screening mammography for breast cancer: American College of Preventive Medicine practice policy statement Am J Prev Med 1996 12(5):340 1 8909643
Fintor L, Alciati MH, Fischer R Legislative and regulatory mandates for mammography quality assurance J Public Health Policy 1995 16(1):81 107 7738160
Gordis L, Berry D.A., Chu S.Y., et al National Institutes of Health Consensus Development Conference statement: Breast cancer screening for women ages 40-49, January 21-23, 1997 Journal of the National Cancer Institute 1997 89(14):1015 1026 9230883
Hall FM Technologic advances in breast imaging. Current and future strategies, controversies, and opportunities Surg Oncol Clin N Am 1997 6(2):403 9 9115505
Healy BP Screening mammography for women in their forties: the Panel of Babel J Womens Health 1997 6(1):1 3 9065366
Hunt KA, Rosen EL, Sickles EA Outcome analysis for women undergoing annual versus biennial screening mammography: a review of 24,211 examinations AJR Am J Roentgenol 1999 173(2):285 9 10430120
Investigation of lesions detected by mammography The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists CMAJ 1998 158Suppl 3:S9 14 9484273
Kerlikowske K, Grady D, Rubin SM, et al Efficacy of screening mammography: A meta-analysis JAMA 1995 273(2):149 154 7799496
Kopans DB An overview of the breast cancer screening controversy J Natl Cancer Inst Monogr 1997(22):1 3 9709266
Kopans DB Mammography screening and the controversy concerning women aged 40 to 49 Radiol Clin North Am 1995 33(6):1273 90 7480670
Kopans DB The breast cancer screening controversy and the National Institutes of Health Consensus Development Conference on Breast Cancer Screening for Women Ages 40-49 Radiology 1999 210(1):4 9 9885578
Kopans DB Updated results of the trials of screening mammography Surg Oncol Clin N Am 1997 6(2):233 63 9115494
Larsson LG Controversies in screening with mammography Acta Oncol 1997 36(7):675 9 9490082
Leitch AM, Dodd GD, Costanza M, et al American Cancer Society guidelines for the early detection of breast cancer: update 1997 CA Cancer J Clin 1997 47(3):150 3 9152172
Leitch AM Controversies in breast cancer screening Cancer 1995 76(10 Suppl):2064 9 8635001
Linver MN, Osuch JR, Brenner RJ, Smith RA The mammography audit: a primer for the mammography quality standards act (MQSA) AJR Am J Roentgenol 1995 165(1):19 25 7785586
Meissner HI, Breen N, Coyne C, Legler JM, Green DT, Edwards BK Breast and cervical cancer screening interventions: an assessment of the literature Cancer Epidemiol Biomarkers Prev 1998 7(10):951 61 9796642
Mettler FA, Upton AC, Kelsey CA, Ashby RN, Rosenberg RD, Linver MN Benefits versus risks from mammography: a critical reassessment Cancer 1996 77(5):903 9 8608482
Mettlin C, Murphy GP Breast cancer screening in premenopausal women: current recommendations and opportunities for research Ann Med 1995 27(4):461 5 8519507
Miller AB Controversies in breast cancer screening Cancer Prev Control 1997 1(1):73 9 9765730
Morton E, Tambor E, Rimer BK, Tessaro I, Farrell D, Siegler IC Impact of National Cancer Institute revised mammography screening guidelines on women 40-49 Womens Health Issues 1996 6(5):246 54 8870503
Mushlin AI, Kouides RW, Shapiro DE Estimating the accuracy of screening mammography: a meta-analysis Am J Prev Med 1998 14(2):143 53 9631167
National Institutes of Health Consensus Conference on Breast Cancer Screening for Women Ages 40-49. Proceedings. Bethesda, Maryland, USA. January 21-23, 1997 J Natl Cancer Inst Monogr 1997(22):vii xviii, 1-156 9741961
National Institutes of Health Consensus Development Conference Statement: Breast Cancer Screening for Women Ages 40-49, January 21-23, 1997. National Institutes of Health Consensus Development Panel. J Natl Cancer Inst 1997 89(14):1015 26 9230883
National Institute of Health Consensus Statement. Breast cancer screening for women ages 40-49. NIH Consens Statement 1997 15(1):1 35
NCCN practice guidelines. Screening for and evaluation of suspicious breast lesions. National Comprehensive Cancer Network. Oncology (Huntingt) 1998 12(11A):89 138 10028505
NCI and NIH consensus panel issue recommendations on mammography for women ages 40 to 49. Am Fam Physician 1997 55(7):2536 9 9166150
Newman J Recent advances in breast cancer imaging Radiol Technol 1999 71(1):35 54 quiz 55 7 10546286
Recommended breast cancer surveillance guidelines. American Society of Clinical Oncology J Clin Oncol 1997 15(5):2149 56 9164230
Reynolds HE Advances in breast imaging Hematol Oncol Clin North Am 1999 13(2):333 48 10363134
Rickard MT Current issues in mammographic breast cancer screening Hosp Med 1999 60(5):325 8 10396406
Rogers LF The mammography muddle AJR Am J Roentgenol 1997 168(5):115 1 9129402
Sabel M, Aichinger H Recent developments in breast imaging Phys Med Biol 1996 41(3):315 68 8778818
Salzmann P, Kerlikowske K, Phillips K Cost-effectiveness of extending screening mammography guidelines to include women 40 to 49 years of age Ann Intern Med 1997 127(11):955 65 9412300
Samuels TH Breast imaging. A look at current and future technologies Postgrad Med 1998 104(5):91 4, 97-101 9823387
Shapiro S, Coleman EA, Broeders M, et al Breast cancer screening programmes in 22 countries: current policies, administration and guidelines. International Breast Cancer Screening Network (IBSN) and the European Network of Pilot Projects for Breast Cancer Screening Int J Epidemiol 1998 27(5):735 42 9839727
Simonetti G, Cossu E, Montanaro M, Caschili C, Giuliani V What's new in mammography Eur J Radiol 1998 27Suppl 2:S234 41 9652528
Sloane JP, Amendoeira I, Apostolikas N, et al [Guidelines for pathology -- supplement to European guidelines for quality assurance in mammography screening. Report by the Pathology Working Group of the European Community] Pathologe 1997 18(1):71 88 9157408
Smith TJ, Davidson NE, Schapira DV, et al American Society of Clinical Oncology 1998 update of recommended breast cancer surveillance guidelines J Clin Oncol 1999 17(3):1080 2 10071303
Taylor D, Adamson R Review of mammography Aust Fam Physician 1995 24(5):809 12, 816-7, 819-23 7794144
Tournemaine N, Bertrand F., Stines J Breast imaging at RSNA 97: Congress report: <ORIGINAL> L'IMAGERIE DU SEIN AU RSNA 1997 Sein 1998 8(2):93 99
Vanel D Full-size digitized mammography will probably be a major step forward in breast imaging Eur J Radiol 1999 31(1):
Venta LA, Goodhartz LA Age and interval for screening mammography: whom do you believe? Semin Surg Oncol 1996 12(5):281 9 8873315
Woolf SH, Dickey LL Differing perspectives on preventive care guidelines: a new look at the mammography controversy Am J Prev Med 1999 17(4):260 8 10606194
Woolf SH, Lawrence RS Preserving scientific debate and patient choice: lessons from the Consensus Panel on Mammography Screening. National Institutes of Health JAMA 1997 278(23):2105 8 9403427
Zaers J, van Woudenberg S, Brix G [Quality assurance in roentgen mammography. Comparison of recommended EUREF guidelines with relevant German regulations] Radiologe 1997 37(8):617 20 9411478

### Acute Low Back Problems

Cohen JE, Goel V, Frank JW, et al Group education interventions for people with low back pain. An overview of the literature Spine 1994 19(11):1214 22 8073312
Crombez G, Vervaet L, Baeyens F, et al Do pain expectancies cause pain in chronic low back patients? A clinical investigation Behav Res Ther 1996 Nov-Dec 34(11-12):919 25 8990543
Daltroy LH, Iversen MD, Larson MG, et al A controlled trial of an educational program to prevent low back injuries [see comments] N Engl J Med 1997 Jul 31 337(5):322 8 9233870
de Jong RH Backfire: AHCPR practice guideline for acute low back pain J S C Med Assoc 1995 91(11):465 8 8544439
Deyo RA Drug therapy for back pain. Which drugs help which patients? [discussion appears in Spine 1996;21(24) 2849-50] Spine 1996 21(24)2840 9 9112708
Faas A Exercises: which ones are worth trying, for which patients, and when?[discussion appears in Spine 1996;21(24): 2878-9] Spine 1996 21(24)2874 8 9112711
Frank J, Sinclair S, Hogg-Johnson S, et al Preventing disability from work-related low-back pain. New evidence gives new hope -- if we can just get all the players onside CMAJ 1998 158(12):1625 31 9645178 1229415
Gatchel RJ, Polatin PB, Kinney RK Predicting outcome of chronic back pain using clinical predictors of psychopathology: a prospective analysis Health Psychol 1995 Sep 14(5):415 20 7498112
Hazard RG, Haugh L.D., Reid S., et al Early physician notification of patient disability risk and clinical guidelines after low back injury: a randomized, controlled trial Spine 1997 22(24):2951 8 9431632
Hazard RG, Haugh LD, Reid S, et al Early prediction of chronic disability after occupational low back injury Spine 1996 Apr 15 21(8):945 51 8726198
Hellsing AL, Linton SJ, Bryngelsson IL Musculoskeletal health surveillance. Eight simple, self-administered tests to add to symptom registration: a preliminary report Spine 1997 Dec 15 22(24):2977 82 9431635
Jackson J, Emerson L, Johnston B, et al Biofeedback: a noninvasive treatment for incontinence after radical prostatectomy Urol Nurs 1996 Jun 16(2):50 4 8826153
Leino PI, Hanninen V Psychosocial factors at work in relation to back and limb disorders Scand J Work Environ Health 1995 Apr 21(2):134 42 7618059
Linton SJ, Hallden K Can we screen for problematic back pain? A screening questionnaire for predicting outcome in acute and subacute back pain Clin J Pain 1998 Sep 14(3):209 15 9758070
Maher C, Latimer J., Refshauge K Prescription of activity for low back pain: What works? Australian Journal of Physiotherapy 1999 45(2):121 32 11676757
Pohjolainen T, Jekunen A, Autio L, et al Treatment of Acute Low Back Pain With the COX-2-Selective Anti-Inflammatory Drug Nimesulide: results of a Randomized, Double-Blind Comparative Trial VersusIbuprofen Spine 2000 Jun 15 25(12):1579 85 10851109
Vlaeyen JW, Kole-Snijders AM, Boeren RG, et al Fear of movement/(re)injury in chronic low back pain and its relation to behavioral performance Pain 1995 Sep 62(3):363 72 8657437
Waddell G, Newton M, Henderson I, et al A Fear-Avoidance Beliefs Questionnaire (FABQ) and the role of fear-avoidance beliefs in chronic low back pain and disability Pain 1993 Feb 52(2):157 68 8455963

### Stroke and Post-Stroke Rehabilitation

a'Rogvi-Hansen B, Boysen G Abstract of Review: Glycerol Treatment in Acute Ischaemic Stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Adams DS Stroke rehabilitation: indications, outcomes, recent developments J La State Med Soc 1996 148(11):498 502 8990790
Asia Pacific Consensus Forum on Stroke Management. Stroke 1998 29(8):1730 6 9707219
Asplund K, et al Abstract of review: haemodilution in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Bath FJ, et al Abstract of review: nitric oxide donors (Nitrates), l-arginine, or nitric oxide synthase inhibitors in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software 9756604
Bath P, Bath F Abstract of review: prostacyclin and analogues in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Bath PMW, et al Abstract of review: pentoxifylline, propentofylline and pertifylline in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Bereczki D and Fekete I Abstract of review: vinpocetine in acute ischaemic stroke (Cochrane Review)." In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Bereczki D, et al Mannitol in acute ischaemic stroke and cerebral parenchymal haemorrhage. (Cochrane Review)." In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Black-Schaffer RM, Kirsteins AE, Harvey RL Stroke rehabilitation. 2. Co-morbidities and complications Arch Phys Med Rehabil 1999 80(5 Suppl 1):S8 16 10326898
Blood Pressure in Acute Stroke Collaboration (BASC). BP management in acute stroke. Part 1: assessment of trials designed to alter blood pressure (Cochrane Review). In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Boult C, Brummel-Smith K Post-stroke rehabilitation guidelines. The Clinical Practice Committee of the American Geriatrics Society J Am Geriatr Soc 1997 45(7):881 3 9215343
Cadilhac D The changing face of stroke. Medical management revolution Aust Nurs 1998 5(11):18 21
Candelise L, Ciccone A Abstract of review: gangliosides in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software 9742986
Cifu DX, Stewart DG Factors affecting functional outcome after stroke: a critical review of rehabilitation interventions Archives of Physical Medicine and Rehabilitation 1999 80(5 Suppl 1)pS35 9 10326901
Cina CS, et al Carotid erndarterectomy in patients with symptomatic carotid stenosis. (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Correia M, et al Antioxidant therapy versus control in acute stroke. (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, et al Abstract of review: a comparison of different types of patch in corotid patch angioplasty (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, et al Abstract of review: patch angioplasty compared to primary closure in carotid endarterectomy (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, et al Abstract of review: routine or selective carotid artery shunting during darotid endarterectomy and the different methods of monitoring in selective shunting (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, et al Anticoagulant therapy compared to control in patients with acute presumed ischemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, et al Antiplatelet therapy compared to control in acute presumed ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Counsell C, Sandercock S Abstract of review: low-molecular-weight heparins or heparinoids compared to standard unfractionated heparin in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Crawley F, Brown MM Abstract of review: percutaneous transluminal angioplasty and stenting for treatment of carotid artery stenosis (Cochrane Review)." In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Crawley F, Brown MM Abstract of review: percutaneous transluminal angioplasty and stenting for vertebral artery stenosis (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Dekker R, Drost EA, Groothoff JW,et al Effects of day-hospital rehabilitation in stroke patients: a review of randomized clinical trials Scand J Rehabil Med 1998 30(2):87 94 9606770
Felgin VL, et al Corticosteroid therapy in patients with primary intracerebral haemorrhage (PICH). (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Flick CL Stroke rehabilitation. 4. Stroke outcome and psychosocial consequences Arch Phys Med Rehabil 1999 80(5 Suppl 1):S21 6 10326900
Gordon MT Developing clinical guidelines for the management of patients with stroke. Scottish Intercollegiate Guidelines Network (SIGN) Int J Lang Commun Disord 1998 33Suppl:152 7 10343682
Gresham GE, Duncan P.W., Stason W.B., et al Post-stroke rehabilitation: assessment, referral, and patient management: quick reference guide for clinicians Journal of Geriatric Drug Therapy 1996 11(2):7 44
Harper G Treatment of stroke in older patients. A state of the art review Drugs Aging 1995 6(1):29 44 7696777
Hoenig H, Horner RD, Duncan PW, Clipp E, Hamilton B New horizons in stroke rehabilitation research J Rehabil Res Dev 1999 36(1):19 31 10659891
Horn J, et al "Calcium Antagonists in Acute Ischemic Stroke. (Cochrane Review)." In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
How do stroke units improve patient outcomes? A collaborative systematic review of the randomized trials. Stroke Unit Trialists Collaboration. Stroke 1997 28(11):2139 44 9368554
Johnsen SP, Husted S.E., Thomassen A Management of acute ischaemic stroke. Recommended practice guidelines as a component of disease management Disease Management and Health 1999 5(6):311 27
Keith RA Rehabilitation after stroke: cost-effectiveness analyses J R Soc Med 1996 89(11):631 3 9135592 1295999
Kerr JE, et al Management of dysphagia in acute stroke. (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Kirsteins AE, Black-Schaffer RM, Harvey RL Stroke rehabilitation. 3. Rehabilitation management Arch Phys Med Rehabil 1999 80(5 Suppl 1):S17 20 10326899
Koudstaal P Secondary prevention following a stroke or transient ischaemic attack in patients with nonrheumatic atrial fibrillation: anticoagulant versus antiplatelet therapy (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Koudstaal P Secondary prevention following stroke or transient ischaemic attack in patients with nonrheumatic atrial fibrillation: anticoagulant therapy versus control (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Koudstaal P Secondary prevention following stroke or transient ischaemic attack in patients with nonrheumatic atrial fibrillation: antiplatelet therapy versus control (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Kraft GH A new century approach to stroke management and rehabilitation: Foreword Physical Medicine and Rehabilitation Clinics of North America 1999 10(4):xiii xiv
Lafferty G Community-based alternatives to hospital rehabilitation services: a review of the evidence and suggestions for approaching future evaluations Reviews in Clinical Gerontology 1996 6(2):183 194
Lai SM, Duncan PW Evaluation of the American Heart Association Stroke Outcome Classification Stroke 1999 30(9):1840 3 10471433
Langhorne P, et al Alternative systems to hospital care: part (1) services to prevent hospital admission of acute stroke patients. (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Liu M, et al Abstract of review: fibrinogen depleting agents in acute ischaemic stoke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Liu M, et al Anticoagulation versus no anticoagulation following non-embolic ischaemic stroke or transient ischaemic attack (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Liu M, Wardlaw J Thrombolysis in acute ischaemic stroke: direct randomised comparisons of different Doses, Routes of Administration and Agents. (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Mohiuddin AA, et al Theophylline, aminophylline, caffeine and analogues, in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Odderson IR, Halar E.M A new century approach to stroke management and rehabilitation: Preface Physical Medicine and Rehabilitation Clinics of North America 1999 10(4):xv xvi
Prasad K, Shrivasta A Abstract of review: surgical treatment in patients with primary supratentorial intracerebral haemorrhage (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Qizilbash N, et al Corticosteroids following acute resumed ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Riddoch MJ, Humphreys GW, Bateman A Stroke. Issues in recovery and rehabilitation Physiotherapy 1995 81(11):689 694
Stewart DG Stroke rehabilitation. 1. Epidemiologic aspects and acute management Arch Phys Med Rehabil 1999 80(5 Suppl 1):S4 7 10326897
Stroke Unit Trialists' Collaboration. organised inpatient (stroke unit) care after stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Tangkanakul C, et al Abstract of review: carotid endarterectomy performed under local anesthetic compared to general anesthetic (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Taub E New discovery equals change in clinical practice J Rehabil Res Dev 1999 36(3):vii viii 10659797
Trombly C Clinical practice guidelines for post-stroke rehabilitation and occupational therapy practice Am J Occup Ther 1995 49(7):711 4 7573343
Ward MJ Ongoing dilemmas: medical rehabilitation for stroke. An overview WMJ 1997 96(12):49 52 9433177
Wardlaw JM, et al Thrombolytic therapy versus control in acute ischaemic stroke (Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Young JB, Gladman J.R.F Future directions in stroke rehabilitation Reviews in Clinical Gerontology 1995 5(3):329 37

### Cardiac Rehabilitation

Bailey C New guidelines for cardiac rehab Colo Nurse 1996 96(3):9 10 9400113
Balady GJ, Jette D., Scheer J., et al Changes in exercise capacity following cardiac rehabilitation in patients stratified according to age and gender: results of the Massachusetts Association of Cardiovascular and Pulmonary Rehabilitation Multicenter Database Journal of Cardiopulmonary Rehabilitation 1996 16(1):38 46 8907441
Blumenthal JA, Jiang W, Babyak MA, et al Stress management and exercise training in cardiac patients with myocardial ischemia. Effects on prognosis and evaluation of mechanisms Arch Intern Med 1997 Oct 27 157(19):2213 23 9342998
Deedwania PC, Amsterdam EA, Vagelos RH Evidence-based, cost-effective risk stratification and management after myocardial infarction Archi Inter Med 1997 157(3):273 280
DeLong ER, Pryor DB. Final report -- Ischemic heart disease -- Patient Outcomes Research Team Project," (IHD PORT) 5 PO1 HS 06503-05. Rockville, MD: Agency for Health Care Planning and Research. August 1997.
Frasure-Smith N, Lesperance F, Prince RH, et al Randomised trial of home-based psychosocial nursing intervention for patients recovering from myocardial infarction [see comments] Lancet 1997 Aug 16 350(9076):473 9 9274583
Gordon NF, Haskell WL Comprehensive cardiovascular disease risk reduction in a cardiac rehabilitation setting Am J Cardiol 1997 80(8B):69H 73H 9373003
Gotto AM, Grundy SM Lowering LDL cholesterol: questions from recent meta-analyses and subset analyses of clinical trial DataIssues from the Interdisciplinary Council on Reducing the Risk for Coronary Heart Disease, ninth Council meeting Circulation 1999 Mar 2 99(8):E1 7 10051310
Hill MN, Russell RP Revision of guidelines for high blood pressure management: JNC IV. Joint National Committee on Detection, Evaluation and Treatment of High Blood Pressure Md Med J 1988 Sep 37(9):698 701 3173007
Mayou R Rehabilitation after heart attack BMJ 1996 313(7071):1498 9 8978216 2353078
McConnell TR Exercise prescription: When the guidelines do not work J Cardiopulm Rehabil 1996 16(1):34 37 8907440
Summerbell CD, Glasziou P The long-term effect of advice on low-fat diets (Protocol for Cochrane Review) In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Thompson DR, Bowman GS, Kitson AL,et al Cardiac rehabilitation in the United Kingdom: guidelines and audit standards. National Institute for Nursing, the British Cardiac Society and the Royal College of Physicians of London Heart 1996 75(1):89 93 8624882 484231
Verrill D, Ashley R, Witt K, Forkner T Recommended guidelines for monitoring and supervision of North Carolina phase II/III cardiac rehabilitation programs. A position paper by the North Carolina Cardiopulmonary Rehabilitation Association J Cardiopulm Rehabil 1996 16(1):9 24 8907438
Wenger NK, Sivarajan Froclicher E, Kent Smith L, et al Cardiac rehabilitation as secondary prevention: Quick reference guide for clinicians Journal of Pharmaceutical Care in Pain and Symptom Control 1996 4(4):101 125
Wenger NK Rehabilitation of the elderly cardiac patient: Recommendations of the clinical practice guideline cardiac rehabilitation American Journal of Geriatric Cardiology 1996 5(3):20 22 11416377
Wolski SA New guidelines for cardiac rehab Nurs Spectr (Wash DC) 1996 6(4):1 4

### Alzheimer's Disease and Related Dementias

Birks J, Flicker L The efficacy and safety of selegiline for the symptomatic treatment of alzhiemer's disease: A systematic review of the evidence In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software 9751027
Flicker L, Grimley Evans J The efficacy of piracetam in patients with dementia or cognitive impairment In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Forsyth E, Ritzline PD An overview of the etiology, diagnosis, and treatment of Alzheimer disease Phys Ther 1998 78(12):1325 31 9859951
Gauthier S Update on diagnostic methods, natural history and outcome variables in Alzheimer's disease Dement Geriatr Cogn Disord 1998 9(Suppl) 3:2 7 9853196
Higgins JPT, Flicker L The efficacy of lecithin in the treatment of dementia and cognitive impairment In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Olin J, Schneider L, Novit A, Luczak S Efficacy of hydergine for dementia In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Qizilbash N, Birks J, Lopez Arrieta J, Lewington S, Szeto S The efficacy of tacrine in alzheimer's disease In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Qizilbash N, Lopez A, Birks J Nimodipine in the treatment of primary degenerative, mixed and vascular dementia In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Richards SS, Hendrie HC Diagnosis, management, and treatment of Alzheimer disease: a guide for the internist Arch Intern Med 1999 159(8):789 98 10219924
Spector A, Orrell M Reality orientation for dementia: A review of the evidence of effectiveness In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Spector A, Orrell M "Reminiscence therapy for dementia: A review of the evidence of effectiveness In: The Cochrane LibraryIssue 3,1998 Oxford: Update Software
Sramek JJ, Cutler NR Recent developments in the drug treatment of Alzheimer's disease Drugs Aging 1999 14(5):359 73 10408736
Whitehouse PJ, Reidenbach F Guidelines for early identification of Alzheimer Disease Alzheimer Dis Assoc Disord 1997 11(2):61 2 9194951