# References

1 Cohn JN, Johnson G, Ziesche S, et al A comparison of enalapril with hydralazine-isosorbide dinitrate in the treatment of chronic congestive heart failure N Engl J Med 1991 325(5):303 10 2057035
2 Fonarow GC, Chelimsky-Fallick C, Stevenson LW, et al. Effect of direct vasodilation vs angiotensin-converting enzyme inhibition on mortality in advanced heart failure: The Hy-C trial. J Am Coll Cardiol. 1992;19:842-50. [pmid: 1545080].
3 Fields WS, Maslenikov V, Meyer JS, et al. Joint study of extracranial arterial occlusion, V: Progress report of prognosis following surgery or nonsurgical treatment for transient cerebral ischemic attacks and cervical carotid artery lesions. JAMA. 1970;211:1993-2003. [pmid: 5467158].
4 Beneficial effect of carotid endarterectomy in symptomatic patients with high-grade carotid stenosis. N Engl J Med. 1991;325:445-53. [pmid: 1852179].
5 MRC European Carotid Surgery Trial: Interim results for symptomatic patients with severe (70-99%) or with mild (0-29%) carotid stenosis. Lancet. 1991;337:1235-43. [pmid: 1674060].
6 Capbell SE, Walker AE, Grimshaw JM, et al. The prevalence of prophylaxis for venous thromboembolism in acute hospital trusts (abstract). J Epidemiol Community Health. 1999;53:66-9. [pmid: 10396466]. [pmcid: 1756831].
7 Eccles M, Freemantle N, Mason J North of England evidence-based guideline development project: summary version of guidelines for the choice of antidepressants for depression in primary careNorth of England Anti-depressant Guideline Development Group.Fam Pract 1999 16(2):103 11 10381013
8 Packer M, Bristow MR, Cohn JN, et al The effect of carvedilol on morbidity and mortality in patients with chronic heart failureCarvedilol Heart Failure Study Group U.S.N Engl J Med 1996 334(21):1349 55 8614419
9 CIBIS-II Investigators and Committee The cardiac Insufficiency Bisoprolol Study II (CIBIS-II): a randomized trial Lancet 1999 353(9146):9 13 10023943
10 Heidenreich PA, Lee TT, Massie BM Effect of beta-blockade on mortality in patients with heart failure: a meta-analysis of randomized clinical trials J Am Coll Cardiol 1997 90(1):27 34 9207617
11 Cluzeau FA, Littlejohns P, Grimshaw JM, Feder G, Moran SE Development and application of a generic methodology to assess the quality of clinical guidelines Int J Qual Health Care 1999 11(1):21 8 10411286
12 Shaneyfelt TM, May-Smith MF, Rothwangl J. Are guidelines following guidelines? The methodological quality of clinical practice guidelines in the peer-reviewed medical literature. JAMA. 1999;281:1900-05. [pmid: 10349893].
13 Cook D, Giacomini M. The trials and tribulations of clinical practice guidelines. JAMA. 1999;281:1950-51. [pmid: 10349901].