# Preface

Practice guidelines can play an important role in improving the quality of health care by ensuring that practitioners and patients base their decisions about appropriate health care for specific clinical circumstances on systematically developed evidence. During the first half of the 1990s, the Agency for Health Care Policy and Research (AHCPR), the predecessor of the Agency for Healthcare Research and Quality (AHRQ), prepared a series of clinical practice guidelines for use by the health care community and patients. Subsequently, AHRQ decided to focus instead on the preparation of evidence-based practice reports, evaluating the science base on topics that could serve in the creation of clinical practice guidelines by professional societies and other organizations.

AHRQ, through its Evidence-based Practice Centers (EPCs), sponsors the development of evidence reports and technology assessments to assist public- and private-sector organizations in their efforts to improve the quality of health care in the United States. The reports and assessments provide organizations with comprehensive, science-based information on common, costly medical conditions and new health care technologies. The EPCs systematically review the relevant scientific literature on topics assigned to them by AHRQ and conduct additional analyses when appropriate prior to developing their reports and assessments.

At present, clinical practice guidelines -- which often draw on AHRQ's EPC reports -- are made available through the National Guideline Clearinghouse, sponsored by AHRQ in partnership with the American Medical Association and the American Association of Health Plans. The guidelines in the Clearinghouse are considered current if less than 5 years old and representative of the scientific evidence in the field. Once AHRQ stopped developing guidelines, the existing agency guidelines were in danger of becoming obsolete as new evidence accumulated. The review published herein was commissioned in early 1999 to determine to what degree the earlier AHRQ clinical practice guidelines remained scientifically current. As a result of the EPC's findings, AHRQ made the decision to take all but three guidelines out of active circulation, and to encourage other organizations to develop guidelines addressing the same issues. Because of the overwhelming popularity of these guidelines in the ! clinical community, and the presence within each guideline of substantial content that was independent of clinical advances, AHRQ has archived the guidelines for historical reference. All of these guidelines are accessible through the AHRQ Web site (http://www.ahrq.gov).

The Agency expects that the technical reviews such as this one will inform the health care community by providing important information concerning the processes used to improve the quality of evidence-based research and its applications.

We welcome written comments on this technical review. They may be sent to: Director, Center for Practice and Technology Assessment, Agency for Healthcare Research and Quality, 6010 Executive Blvd., Suite 300, Rockville, MD 20852.

- Carolyn Clancy, M.D.
  Acting Director
  Agency for Healthcare Research and Quality
- Robert Graham, M.D.
  Director, Center for Practice and Technology Assessment
  Agency for Healthcare Research and Quality