# Conclusions

New information has made seven, or almost half, of the AHRQ clinical practice guidelines sufficiently obsolete that we recommend they be withdrawn. For an additional six guidelines (35%), we believe that clinicians should be made aware of important new evidence that has developed, however, the information is not sufficient to warrant withdrawal of the entire guideline. For these guidelines, we recommend retaining the original guideline with the new evidence appended to it, either electronically or as a paper insert. We judged three of the guidelines as valid and continuing to represent good care, and for one guideline we could not reach a conclusion.

We used a combination of limited literature searches and a survey of expert opinion to identify new evidence. These were complementary techniques in this evaluation, as some evidence identified using one method was not identified using the other method. For most of the guidelines, we received an acceptable response rate to our survey, which is a testimony to the dedication of those members of the original guideline panel as they took the time to complete the survey without compensation. The limited literature searches were easier to implement than a full literature search, but more difficult to implement than the survey of experts, particularly for those clinical areas where we were less familiar with the literature. It is likely that an updated limited literature search by the original guideline development team could be implemented more easily. Both methods, survey and limited literature search, could be improved, and our initial experience with these techniques have be! en a valuable learning lesson.

Another lesson from this project is empiric evidence of the rate at which guidelines go out of date. Over a four-to-eight year period, three quarters of the AHRQ guidelines were judged to be sufficiently out of date as to recommend withdrawal, or to require that new evidence be appended. In almost all of the cases, the significant new information concerned improvements in therapy. Guideline programs need to have systems in place to regularly assess their guidelines for current validity.