# Results

## Expert Opinion

We received replies from the panel chair(s) for sixteen of the seventeen clinical practice guidelines. One panel chair did not respond to our contacts despite several attempts. A second panel chair responded that he had just completed an update of the guideline in question and did not respond further to our attempts at gaining additional information. For the remaining fifteen clinical practice guidelines, we received input from the panel chair(s) about which of their respective panel members should be contacted to assess the current validity of their practice guideline statements. For one of the two practice guidelines for which we did not receive this information, we contacted the Evidence-based Practice Center that had participated in the literature review for the "guideline update" process, and asked the lead member of the task order team to complete the survey concerning validity. For the remaining clinical practice guideline, we used information from one of the membe! rs of the guideline development team to determine which statements to send to which experts.

A few of the panel chairs also responded to our question about which disciplines possibly should have been represented on their panel but were not. These are listed by guideline in Table 6. The resources available for this project did not permit us to identify and seek input from experts in these disciplines regarding the current validity of the guidelines.

Table 6. Relevant Clinical Disciplines not Represented on the Original Panel as listed by the expert panel chairs

Guidelines | Discipline
Acute Pain Management | Social Worker Sociologist Clinical Epidemiologist Pharmacoeconomist
Urinary Incontinence in Adults | Physical Therapist
Pressure Ulcers in Adults | None
Depression | None
Cataract in Adults | None
Sickle Cell | Molecular Biologist
Benign Prostatic Hyperplasia | None
Cancer Pain | Social Worker Sociologist Clinical Epidemiologist
Unstable Angina | None
Heart Failure | None
Otitis Media with Effusion | None
Mammography | None
Acute Low Back Problems | None
Treatment of Pressure Ulcers | Nutrition Consultant
Post-Stroke Rehabilitation | Clinical Neuropsychology Home Care and Extended Care Facility Administrator
Cardiac Rehabilitation | None
Early Alzheimer's | None

We then sent out the individual guideline statements to their respective experts. We were unable to attain current contact information for some of the recommended experts, and in a few instances the panelists were deceased. In total, we surveyed 175 experts. Five surveys were returned with the notation that the panelist was no longer at the given address and no forwarding address was known. Four panelists declined to participate in the survey. Of the remaining 170 outstanding surveys 121 (71%) were returned. The number of responses varied by guideline. Table 7 lists the number of surveys sent and the number returned by guideline. For all but three guidelines more than 60% of the surveys were returned.

Table 7. Distribution and Response Rates of Guideline Documents

Title | Number Sent Out | Returned as Unlocateable ^1^ | Returned Not Willing to Participate | Returned Complete | Response Rate
Acute Pain Management | 15 | 0 | 0 | 12 | 80%
Urinary Incontinence in Adults | 12 | 1 | 1 | 8 | 80%
Pressure Ulcers in Adults | 7 | 0 | 0 | 5 | 71%
Depression in Primary Care (vols. 1 & 2) | 9 | 0 | 0 | 8 | 89%
Cataracts in Adults | 8 | 1 | 0 | 4 | 57%
Sickle Cell Disease | 7 | 2 | 0 | 5 | 100%
Benign Prostatic Hyperplasia | 9 | 1 | 1 | 6 | 86%
Management of Cancer Pain | 22 | 0 | 0 | 16 | 73%
Unstable Angina | 1 | 0 | 0 | 1 | 100%
Heart Failure | 12 | 0 | 0 | 9 | 75%
Otitis Media with Effusion | 11 | 0 | 0 | 9 | 82%
Quality Determinants of Mammography | 8 | 0 | 2 | 2 | 33%
Acute Low Back Problems in Adults | 11 | 0 | 0 | 7 | 64%
Treatment of Pressure Ulcers | 11 | 0 | 0 | 7 | 64%
Post-Stroke Rehabilitation | 13 | 0 | 0 | 13 | 100%
Cardiac Rehabilitation | 12 | 1 | 0 | 9 | 82%
Alzheimer's Disease and Related Dementias | 7 | 0 | 0 | 2 | 29%

1 includes deceased and moved/ no forwarding address

We were also able to obtain assessments of the validity of the practice guideline statement from 8 non-panel experts for 7 of the guidelines. We contacted outside experts for the remaining guidelines, but we received no response and the time and resources available for this project did not allow us to continue to pursue outside input.

Table 8 reports the collated results of the responses to the two questions regarding the presence of new evidence sufficient to invalidate an existing guideline statement and whether any new guideline statements should be present. Most practice guideline statements were judged to be still valid. Practice guidelines statements concerning therapeutics were more likely to have been judged invalid than were statements concerning other aspects of diagnosis or management.

Table 8. Results of Assessment of Validity

ACUTE PAIN MANAGEMENT
Guideline Heading sub heading(s) | Number of Experts | | | Is there new evidence of sufficient importance to invalidate the guideline statement? | | Are there new guidelines statements that should be present?
Guideline Heading sub heading(s) | Recommended to Review the Statement | Received the Statement | Replied Regarding the Statement | Yes | No | Yes | No
Promise patients attentive analgesic care | 6 | 6 | 6 | 1 | 5 | 2 | 4
Chart and display assessment of pain and relief | 8 | 8 | 6 | 1 | 5 | 1 | 5
Define pain and relief levels to trigger a review | 6 | 5 | 4 | 0 | 4 | 0 | 4
Survey patient satisfaction | 7 | 6 | 6 | 0 | 5 | 1 | 4
Analgesic drug treatment should comply with several basic principles non-opioid "peripherally acting" analgesics | 5 | 5 | 5 | 1 | 4 | 2 | 2
Analgesic drug treatment should comply with several basic principles opioid analgesics | 5 | 5 | 5 | 1 | 4 | 1 | 4
Specialized analgesic technologies | 4 | 4 | 4 | 1 | 3 | 2 | 2
Nonpharmacological interventions | 7 | 7 | 5 | 1 | 3 | 1 | 3
Monitor the efficacy of pain treatment | 8 | 8 | 7 | 0 | 7 | 4 | 3
panel chairs 2 panelists 18 panelist not designated to receive any statements 2 panelists unlocateable/deceased 2 panelists did not respond 3 panelists did respond 11
URINARY INCONTINENCE IN ADULTS
Identifying and evaluating urinary incontinence | 7 | 7 | 4 | 1 | 3 | 1 | 2
Identifying and evaluating urinary incontinence basic evaluation: components supplementary assessments | 6 | 5 | 3 | 0 | 3 | 0 | 2
Identifying and evaluating urinary incontinence further evaluation | 7 | 7 | 4 | 0 | 4 | 0 | 3
Identifying and evaluating urinary incontinence further evaluation specialized tests | 6 | 6 | 3 | 0 | 3 | 0 | 2
Treatment of urinary incontinence behavioral techniques | 6 | 5 | 4 | 1 | 3 | 2 | 1
Treatment of urinary incontinence pharmacologic treatment urge incontinence | 7 | 5 | 3 | 1 | 2 | 3 | 0
Treatment of urinary incontinence pharmacologic treatment stress incontinence | 5 | 4 | 3 | 0 | 3 | 1 | 1
Treatment of urinary incontinence surgical treatment | 6 | 5 | 2 | 0 | 2 | 0 | 2
Treatment of urinary incontinence surgical treatment other measures and supportive devices | 7 | 5 | 4 | 1 | 2 | 2 | 1
Chronic intractable urinary incontinence | 7 | 5 | 5 | 2 | 3 | 2 | 2
Chronic intractable urinary incontinence other measures and supportive care | 7 | 4 | 4 | 1 | 3 | 1 | 2
Education | 8 | 5 | 4 | 1 | 2 | 1 | 1
panel chairs 1 panelists 16 panelist not designated to receive any statements 0 panelists unlocateable/retired/deceased 5 panelists did not respond 2 panelist unwilling to participate 1 panelists did respond 8
PRESSURE ULCERS IN ADULTS
Risk assessment tools and risk factors | 4 | 3 | 3 | 0 | 2 | 0 | 1
Skin care and early treatment | 4 | 4 | 3 | 0 | 3 | 0 | 2
Mechanical loading and support surfaces | 4 | 3 | 3 | 0 | 3 | 0 | 3
Education | 3 | 2 | 1 | 0 | 0 | 0 | 0
panel chairs 1 panelists 13 panelist not designated to receive any statements 5 panelists unlocateable/deceased 1 panelists did not respond 2 panelists did respond 5
DEPRESSION IN PRIMARY CARE (VOL. 1)
Overview of mood disorders | 3 | 3 | 2 | 0 | 2 | 0 | 2
Overview of mood disorders major depressive disorder | 3 | 3 | 2 | 0 | 2 | 0 | 2
Overview of mood disorders dysrthymic disorder | 3 | 3 | 3 | 0 | 3 | 0 | 2
Overview of mood disorders depression not otherwise specified | 3 | 3 | 2 | 0 | 2 | 1 | 1
Overview of mood disorders bipolar disorders | 3 | 3 | 2 | 0 | 2 | 0 | 2
Overview of mood disorders mood disorders in special age populations | 2 | 2 | 2 | 0 | 2 | 0 | 1
Depression co-occurring with other psychiatric conditions | 4 | 4 | 3 | 1 | 1 | 1 | 0
Depression co-occurring with other psychiatric conditions alcohol/drug abuse or dependency | 2 | 2 | 1 | 0 | 0 | 0 | 0
Depression co-occurring with other psychiatric conditions anxiety disorders | 3 | 3 | 3 | 0 | 3 | 0 | 2
Depression co-occurring with other psychiatric conditions eating disorders | 4 | 4 | 4 | 0 | 4 | 0 | 3
Depression co-occurring with other psychiatric conditions obsessive/compulsive disorders | 4 | 4 | 3 | 0 | 3 | 0 | 3
Depression co-occurring with other psychiatric conditions somatization disorder | 4 | 4 | 4 | 1 | 3 | 1 | 3
Depression co-occurring with other psychiatric conditions personality disorders | 3 | 3 | 3 | 0 | 3 | 0 | 2
Depression co-occurring with other psychiatric conditions grief and adjustment reactions | 3 | 3 | 3 | 0 | 3 | 0 | 1
Depression co-occurring with other general medical disorders | 2 | 2 | 2 | 0 | 2 | 1 | 1
Depression co-occurring with other general medical disorders stroke | 2 | 2 | 2 | 0 | 2 | 0 | 2
Depression co-occurring with other general medical disorders fibromyalgia | 2 | 2 | 2 | 2 | 0 | 2 | 0
Depression associated with medications | 2 | 2 | 2 | 2 | 0 | 1 | 1
Detection of depression | 4 | 4 | 3 | 0 | 3 | 0 | 3
Detection of depression differential diagnosis of depression | 2 | 2 | 2 | 2 | 0 | 2 | 0
Detection of depression ongoing clinical reassessment | 3 | 3 | 3 | 0 | 3 | 0 | 3
DEPRESSION IN PRIMARY CARE (VOL. 2)
Aims of treatment | 2 | 2 | 2 | 0 | 2 | 0 | 2
Clinical management | 3 | 3 | 3 | 0 | 3 | 0 | 3
Strategic planning for acute phase treatment indications for acute phase treatment | 1 | 1 | 1 | 0 | 1 | 0 | 1
Strategic planning for acute phase treatment treatment section | 2 | 2 | 1 | 0 | 1 | 1 | 0
Acute phase management with medication indications for acute phase medication | 4 | 4 | 3 | 1 | 2 | 0 | 2
Acute phase management with medication antidepressant medication selection | 3 | 3 | 3 | 0 | 3 | 0 | 3
Acute phase management with medication failure to respond | 2 | 2 | 1 | 0 | 1 | 0 | 1
Acute phase management with psychotherapy | 2 | 2 | 2 | 0 | 2 | 1 | 1
Acute phase management with medication and psychotherapy | 4 | 4 | 4 | 1 | 3 | 1 | 3
Acute phase management with ECT | 2 | 2 | 1 | 0 | 1 | 1 | 0
Special situations the suicidal patient | 2 | 2 | 1 | 0 | 1 | 0 | 0
Special situations geriatric depression | 3 | 3 | 2 | 0 | 2 | 0 | 2
Special situations seasonal depression | 2 | 2 | 1 | 0 | 1 | 0 | 1
Special situations depression and other nonpsychiatric medical disorders | 2 | 2 | 2 | 0 | 2 | 0 | 2
Special situations depression and other psychiatric disorders | 3 | 3 | 3 | 1 | 2 | 0 | 2
Continuation and maintenance treatment options objectives and indications for continuation treatment | 3 | 3 | 2 | 0 | 2 | 0 | 2
Continuation and maintenance treatment options objectives and indications for maintenance treatment | 4 | 4 | 3 | 0 | 3 | 1 | 2
Continuation and maintenance treatment options continuation/maintenance phase management with medication | 4 | 4 | 3 | 1 | 2 | 1 | 2
Continuation and maintenance treatment options continuation/maintenance phase management with psychotherapy symptom breakthrough | 4 | 4 | 3 | 0 | 3 | 0 | 3
Continuation and maintenance treatment options continuation/maintenance phase management with psychotherapy evidence for efficacy | 4 | 4 | 3 | 3 | 0 | 2 | 1
panel chairs 2 panelists 12 panelist not designated to receive any statements 1 panelists unlocateable/retired/deceased 2 panelists did not respond 1 panelists did respond 8
Setting and providers of care | 3 | 3 | 2 | 0 | 1 | 1 | 0
Preoperative ophthalmic testing in patients with cataract | 3 | 2 | 2 | 0 | 2 | 0 | 2
Treatment | 6 | 6 | 4 | 3 | 1 | 2 | 0
Postoperative care | 3 | 2 | 2 | 1 | 1 | 1 | 1
Rehabilitation | 4 | 2 | 2 | 0 | 2 | 0 | 1
Posterior capsular opacification and yag capsulotomy | 2 | 0 | 0 | 0 | 1 | 1 | 0
panel chairs 1 panelists 18 panelist not designated to receive any statements 6 panelists unlocateable/retired/deceased 4 panelists did not respond 3 panelists did respond 4 non-panel expert 1
Introduction | 5 | 4 | 4 | 0 | 2 | 0 | 2
Laboratory screening for sickle cell disease | 2 | 2 | 2 | 0 | 2 | 0 | 2
Laboratory screening for sickle cell disease sample collection | 2 | 1 | 1 | 0 | 1 | 0 | 1
Laboratory screening for sickle cell disease reporting | 3 | 3 | 3 | 0 | 2 | 0 | 2
Laboratory screening for sickle cell disease quality assurance and quality control | 3 | 2 | 2 | 0 | 2 | 0 | 2
Medical management of newborns and infants with sickle cell disease | 3 | 3 | 2 | 0 | 2 | 0 | 2
Medical management of newborns and infants with sickle cell disease penicillin prophylaxis | 3 | 3 | 2 | 0 | 1 | 0 | 1
Medical management of newborns and infants with sickle cell disease diagnosis and management of complications | 3 | 3 | 2 | 0 | 2 | 0 | 2
Medical management of newborns and infants with sickle cell disease health maintenance | 3 | 3 | 2 | 0 | 1 | 0 | 1
Educating and counseling parents of newborns with sickle cell disease trait qualifications for sickle cell educators | 3 | 0 | 0 | 0 | 0 | 0 | 0
Educating and counseling parents of newborns with sickle cell disease trait counselor qualifications | 2 | 1 | 1 | 0 | 1 | 0 | 1
panel chairs 1 panelists 13 panelist not designated to receive any statements 5 panelists unlocateable/deceased 2 panelists did not respond 0 panelists did respond 5
Initial evaluations | 5 | 4 | 3 | 0 | 2 | 2 | 1
Symptom assessment | 4 | 4 | 3 | 1 | 2 | 1 | 2
Tests not recommended | 5 | 5 | 5 | 3 | 2 | 3 | 2
BPH treatment summary | 5 | 4 | 3 | 2 | 1 | 1 | 2
Indirect treatment outcomes | 4 | 3 | 2 | 2 | 0 | 2 | 0
Direct treatment outcomes symptom improvement | 7 | 5 | 4 | 3 | 1 | 2 | 2
Direct treatment outcomes complications | 5 | 4 | 3 | 1 | 2 | 1 | 2
Direct treatment outcomes surgical morbidity | 5 | 4 | 3 | 0 | 3 | 0 | 3
Direct treatment outcomes sexual dysfunction | 4 | 4 | 3 | 1 | 2 | 0 | 3
Direct treatment outcomes mortality | 6 | 5 | 4 | 3 | 1 | 1 | 3
Treatment preference analysis | 3 | 3 | 3 | 0 | 3 | 0 | 3
panel chairs 1 panelists 13 panelist not designated to receive any statements 3 panelists unlocateable/retired/deceased 2 panelists did not respond 1 panelists unwilling to participate 1 panelists did respond 6 non-panel expert 1
Overview | 10 | 9 | 7 | 1 | 5 | 3 | 4
Assessment of pain: the patient with cancer | 8 | 7 | 6 | 0 | 6 | 0 | 5
Pharmacologic management | 6 | 6 | 3 | 2 | 0 | 3 | 0
Non-pharmacologic management physical and psychological modalities | 7 | 7 | 4 | 0 | 4 | 0 | 4
Non-pharmacologic intervention invasive therapies | 7 | 7 | 6 | 3 | 3 | 1 | 4
Procedure related pain in adults and children | 6 | 5 | 2 | 1 | 1 | 1 | 1
Pain in special populations | 10 | 9 | 4 | 0 | 3 | 1 | 2
Monitoring the quality of pain management | 5 | 5 | 5 | 1 | 3 | 1 | 3
panel chairs 2 panelists 25 panelist not designated to receive any statements 1 panelists unlocateable/deceased 2 panelists did not respond 7 panelists did respond 15
Prevention in asymptomatic patients | 5 | 5 | 4 | 4 | 0 | 3 | 1
Initial evaluation physical examination | 7 | 7 | 6 | 0 | 6 | 1 | 5
Initial evaluation diagnostic testing | 6 | 6 | 5 | 2 | 3 | 3 | 2
Initial evaluation hospital admission and discharge criteria | 7 | 7 | 5 | 0 | 5 | 1 | 4
Assessment of left ventricular function | 6 | 6 | 5 | 1 | 4 | 1 | 4
Patient and family education and counseling | 6 | 6 | 4 | 0 | 4 | 1 | 3
Pharmacologic management initial pharmacologic management | 6 | 6 | 4 | 3 | 1 | 4 | 0
Pharmacologic management additional pharmacologic management | 7 | 7 | 6 | 5 | 1 | 5 | 0
The role of revascularization patient counseling and decisionmaking | 6 | 6 | 6 | 0 | 6 | 0 | 6
The role of revascularization physiologic testing for ischemia | 7 | 7 | 7 | 3 | 4 | 1 | 6
The role of revascularization evaluation for heart transplantation | 6 | 6 | 6 | 0 | 6 | 0 | 6
Assessment of outcomes and patient follow-up | 6 | 6 | 5 | 0 | 5 | 0 | 5
panel chairs 2 panelists 16 panelist not designated to receive any statements 3 panelists unlocateable/retired/deceased 1 panelists did not respond 3 panelists did respond 9 non-panel expert 1
Clinical outcomes addressed | 4 | 4 | 4 | 1 | 3 | 2 | 2
Diagnosis and hearing evaluation | 6 | 6 | 4 | 0 | 4 | 0 | 4
Control of environmental risk factors | 5 | 5 | 4 | 0 | 4 | 2 | 2
Pharmaceutical therapies | 5 | 5 | 4 | 2 | 2 | 1 | 2
Surgical therapies | 5 | 5 | 4 | 1 | 3 | 1 | 3
Allergy | 5 | 5 | 4 | 0 | 4 | 0 | 4
Other therapies | 5 | 5 | 4 | 0 | 4 | 0 | 4
panel chairs 2 panelists 19 panelist not designated to receive any statements 5 panelists unlocateable/retired/deceased 3 panelists did not respond 2 panelists did respond 9 non-panel expert 1
Activities before the examination responsibilities of facility schedulers and receptionists | 2 | 1 | 1 | 0 | 1 | 0 | 1
Activities before the examination responsibilities of facility | 3 | 3 | 1 | 0 | 1 | 0 | 1
Activities before the examination responsibilities of women | 3 | 3 | 1 | 0 | 1 | 0 | 1
Activities during the examination communication responsibilities of radiologic technology | 2 | 2 | 0 | 0 | 0 | 0 | 0
Activities during the examination breast compression | 3 | 3 | 0 | 0 | 0 | 0 | 0
Activities during the examination screening and diagnostic views | 2 | 2 | 1 | 0 | 1 | 0 | 1
Activities during the examination positioning techniques | 3 | 3 | 1 | 0 | 1 | 0 | 1
Activities during the examination women who have had breast-conserving surgery | 2 | 2 | 1 | 0 | 1 | 0 | 1
Activities during the examination women with implants | 1 | 1 | 1 | 0 | 1 | 0 | 1
Activities during the examination technique factor selection | 2 | 2 | 0 | 0 | 0 | 0 | 0
Activities after the examination communicating results | 2 | 2 | 1 | 1 | 0 | 0 | 1
Activities after the examination follow-up, tracking, and monitoring | 3 | 3 | 1 | 0 | 1 | 0 | 1
Activities after the examination mammography report | 4 | 4 | 1 | 0 | 1 | 0 | 1
Activities after the examination record-keeping | 3 | 3 | 1 | 0 | 1 | 0 | 1
Responsibilities of the mammography facility x-ray equipment specifications | 2 | 2 | 0 | 0 | 0 | 0 | 0
Responsibilities of the mammography facility image receptor specifications | 3 | 3 | 1 | 1 | 0 | 0 | 1
Responsibilities of the mammography facility processor specifications and operating conditions | 2 | 2 | 0 | 0 | 0 | 0 | 0
Responsibilities of the mammography facility film-viewing equipment specifications and positioning | 2 | 2 | 0 | 0 | 0 | 0 | 0
Responsibilities of the mammography facility quality control test and responsibilities | 3 | 3 | 1 | 0 | 1 | 0 | 1
Responsibilities of the mammography facility film labeling, retention, and lending | 3 | 3 | 1 | 0 | 1 | 0 | 1
Responsibilities of the mammography facility medical audit | 2 | 2 | 1 | 0 | 1 | 0 | 1
Mammography personnel interpreting physicians | 3 | 3 | 1 | 0 | 1 | 0 | 1
Mammography personnel radiologic technologists | 2 | 2 | 1 | 0 | 1 | 1 | 0
Mammography personnel medical physicists | 2 | 2 | 0 | 0 | 0 | 0 | 0
Mammography personnel equipment service personnel | 2 | 2 | 0 | 0 | 0 | 0 | 0
Referring providers breast cancer screening and diagnosis | 2 | 2 | 1 | 0 | 1 | 0 | 1
Referring providers diagnostic mammography | 2 | 2 | 1 | 0 | 1 | 0 | 1
Referring providers women with breast implants | 3 | 3 | 2 | 0 | 2 | 0 | 2
Referring providers mammography views, compression, and positioning | 3 | 3 | 1 | 0 | 1 | 0 | 1
Referring providers women under 40 | 2 | 2 | 1 | 1 | 0 | 1 | 0
Referring providers communicating results | 3 | 3 | 2 | 0 | 2 | 0 | 2
Referring providers recordkeeping | 2 | 2 | 1 | 0 | 1 | 0 | 1
Referring providers adverse consequences of mammography | 3 | 3 | 1 | 0 | 1 | 0 | 1
Referring providers mammography standards | 3 | 3 | 0 | 0 | 0 | 0 | 0
Adverse consequences and other problems false reassurance and delay in diagnosis | 4 | 4 | 2 | 0 | 2 | 0 | 2
Adverse consequences and other problems costs | 2 | 2 | 1 | 0 | 1 | 0 | 1
Other breast imaging modalities digital mammography | 3 | 3 | 1 | 0 | 1 | 0 | 1
panel chairs 2 panelists 15 panelist not designated to receive any statements 6 panelists unlocateable/retired/deceased 2 panelists did not respond 4 panelist unwilling to participate 1 panelists did respond 2
Initial assessment methods | 5 | 5 | 4 | 0 | 3 | 1 | 2
Clinical care methods patient information | 5 | 5 | 3 | 1 | 1 | 0 | 2
Clinical care methods symptom control methods | 6 | 6 | 5 | 1 | 3 | 0 | 2
Clinical care methods activity modification | 4 | 4 | 3 | 0 | 3 | 0 | 3
Special studies and diagnostic considerations tests for evidence of physiologic dysfunction | 3 | 3 | 3 | 0 | 3 | 0 | 3
Special studies and diagnostic considerations tests to provide anatomic definition | 3 | 3 | 4 | 0 | 3 | 0 | 3
Special studies and diagnostic considerations surgical information | 4 | 4 | 3 | 0 | 2 | 1 | 1
Special studies and diagnostic considerations assessment of psychosocial factors | 3 | 3 | 3 | 0 | 2 | 0 | 2
panel chairs 1 panelists 23 panelist not designated to receive any statements 10 panelists unlocateable/retired/deceased 2 panelists did not respond 4 panelists did respond 7 non-panel expert 1
Assessment assessing the pressure ulcer | 3 | 1 | 0 | 0 | 0 | 0 | 0
Assessment assessing the individual with a pressure ulcer | 2 | 1 | 0 | 0 | 0 | 0 | 0
Assessment assessing the individual with a pressure ulcer nutritional assessment and measurement | 3 | 1 | 1 | 0 | 1 | 0 | 0
Assessment assessing the individual with a pressure ulcer pain assessment and management | 4 | 2 | 1 | 0 | 1 | 0 | 1
Assessment assessing the individual with a pressure ulcer psychosocial assessment and management | 4 | 3 | 2 | 0 | 2 | 1 | 1
Managing tissue loads | 4 | 3 | 1 | 0 | 1 | 1 | 0
Ulcer care | 4 | 3 | 2 | 0 | 2 | 0 | 2
Managing bacterial colonization and infection | 4 | 4 | 2 | 0 | 2 | 0 | 2
Operative repair of pressure ulcers | 4 | 3 | 2 | 0 | 2 | 1 | 1
Education and quality improvement | 4 | 2 | 1 | 0 | 1 | 0 | 1
panel chairs 1 panelists 20 panelist not designated to receive any statements 5 panelists unlocateable/retired/deceased 4 panelists did not respond 4 panelists did respond 7
Assessment methods for patients with strokes | 4 | 4 | 4 | 0 | 3 | 1 | 2
Rehabilitation during acute care for stroke | 5 | 5 | 4 | 0 | 3 | 1 | 2
Screening for rehabilitation and choice of a setting | 6 | 6 | 5 | 0 | 4 | 0 | 4
Managing rehabilitation transition from the acute care hospital | 6 | 6 | 5 | 0 | 4 | 0 | 3
Managing rehabilitation managing the rehabilitation process | 8 | 7 | 6 | 0 | 6 | 1 | 3
Managing rehabilitation managing comorbidities and acute illnesses | 5 | 4 | 3 | 0 | 3 | 1 | 2
Managing rehabilitation managing sensorimotor deficits and impaired mobility | 3 | 3 | 2 | 0 | 2 | 1 | 0
Managing rehabilitation preventing and treating complications | 5 | 4 | 4 | 0 | 3 | 0 | 3
Managing rehabilitation managing cognitive and perceptual deficits | 3 | 3 | 3 | 0 | 2 | 0 | 1
Managing rehabilitation managing emotional disorders | 4 | 4 | 4 | 0 | 3 | 0 | 1
Managing rehabilitation treating speech and language disorders | 3 | 2 | 1 | 0 | 1 | 1 | 0
Managing rehabilitation discharge | 6 | 5 | 5 | 0 | 4 | 0 | 4
Transition to the community | 5 | 4 | 3 | 0 | 2 | 0 | 1
panel chairs 2 panelists 18 panelist not designated to receive any statements 3 panelists unlocateable/retired/deceased 2 panelists did not respond 0 panelists did respond 13 non-panel expert 1
Effects of cardiac rehabilitation exercise training exercise tolerance | 2 | 2 | 2 | 0 | 2 | 0 | 2
Effects of cardiac rehabilitation exercise training strength training | 2 | 1 | 1 | 0 | 1 | 0 | 0
Effects of cardiac rehabilitation exercise training exercise habits | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation exercise training symptoms | 2 | 2 | 2 | 0 | 2 | 0 | 0
Effects of cardiac rehabilitation exercise training smoking | 2 | 2 | 1 | 0 | 1 | 0 | 0
Effects of cardiac rehabilitation exercise training lipids | 2 | 1 | 1 | 0 | 1 | 1 | 0
Effects of cardiac rehabilitation exercise training body weight | 3 | 2 | 2 | 0 | 2 | 1 | 1
Effects of cardiac rehabilitation exercise training blood pressure | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation exercise training psychological well-being | 2 | 1 | 1 | 1 | 0 | 0 | 0
Effects of cardiac rehabilitation exercise training social adjustment and functioning | 2 | 1 | 1 | 1 | 0 | 0 | 0
Effects of cardiac rehabilitation exercise training return to work | 2 | 1 | 1 | 0 | 1 | 1 | 0
Effects of cardiac rehabilitation exercise training morbidity and safety issues | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation exercise training mortality and safety issues | 2 | 2 | 2 | 0 | 2 | 0 | 1
Effects of cardiac rehabilitation exercise training pathophysiologic measures | 2 | 2 | 2 | 0 | 2 | 0 | 2
Effects of cardiac rehabilitation exercise training Patients with heart failure and cardiac transplantations | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation exercise training elderly patients | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions smoking | 2 | 2 | 1 | 0 | 1 | 1 | 0
Effects of cardiac rehabilitation education, counseling and behavioral interventions lipids | 4 | 3 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions body weight | 4 | 3 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions blood pressure | 3 | 2 | 2 | 1 | 1 | 1 | 0
Effects of cardiac rehabilitation education, counseling and behavioral interventions exercise tolerance | 2 | 1 | 1 | 0 | 1 | 0 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions symptoms | 3 | 3 | 3 | 0 | 3 | 1 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions return to work | 3 | 3 | 2 | 0 | 2 | 0 | 2
Effects of cardiac rehabilitation education, counseling and behavioral interventions stress and psychological well-being | 2 | 2 | 1 | 0 | 1 | 0 | 0
Effects of cardiac rehabilitation education, counseling and behavioral interventions morbidity | 3 | 3 | 2 | 1 | 1 | 0 | 1
Effects of cardiac rehabilitation education, counseling and behavioral interventions mortality | 2 | 2 | 1 | 1 | 0 | 1 | 0
Organizational issues alternate approaches to the delivery of cardiac rehabilitation services | 3 | 2 | 1 | 0 | 1 | 0 | 1
Organizational issues adherence | 2 | 2 | 2 | 1 | 1 | 0 | 0
Organizational issues cost | 2 | 2 | 2 | 0 | 2 | 0 | 1
panel chairs 1 panelists 20 panelist not designated to receive any statements 4 panelists unlocateable/retired/deceased 5 panelists did not respond 2 panelists did respond 9
Risk factors and causes of dementia | 3 | 1 | 1 | 0 | 1 | 1 | 0
Recommendations for recognition and initial assessment of dementia assessing for delirium and depression | 3 | 1 | 1 | 0 | 1 | 0 | 1
Recommendations for recognition and initial assessment of dementia interpretation of findings and recommended actions | 4 | 0 | 0 | 0 | 0 | 0 | 0
Recommendations for recognition and initial assessment of dementia neurophychological testing | 4 | 1 | 1 | 0 | 1 | 0 | 1
panel chairs 1 panelists 17 panelist not designated to receive any statements 10 panelists unlocateable/retired/deceased 0 panelists did not respond 5 panelists did respond 2

## Limited Literature Searches

Table 9 lists the number of titles identified in the limited literature searches by guideline. Table 10 lists the number of abstracts and articles reviewed by guideline. We retrieved 5,860 titles during our initial search, which focused on review articles and editorials. We identified 1,232 titles when our search was focused on key specialty journals and journals of major general interest. Overall, we reviewed a total of 6,994 titles. From these titles, 610 were selected for further review based on their potential for providing new information relating to the respective guideline areas. Abstracts were obtained and reviewed for all 610 of these titles. From these, 173 full-text articles were retrieved and reviewed by our physician reviewers. In addition, 159 guidelines were also retrieved and reviewed.

Table 9. Titles Identified in the Limited Literature Searches Listed by Guideline

Guideline | Titles Retrieved on Initial Search | Titles Retrieved from Specialty Journals (See Table 3) | Titles Retrieved from Major Journals | Total Number of Titles Reviewed ^1^
Acute Pain Management (including Cancer Pain) | 460 | 37 | 430 | 460
Urinary Incontinence | 45 | na | na | 45
Pressure Ulcers (in Adults and Treatment of) | 104 | na | na | 104
Cataract in Adults | 28 | na | na | 28
Depression in Primary Care | 250 | 42 | 4 | 250
Sickle Cell Disease | 490 | na | na | 490
Benign Prostatic Hyperplasia | 780 | na | na | 780
Unstable Angina | 693 | na | na | 693
Heart Failure | 509 | 380 | 206 | 509
Otitis Media with Effusion | 168 | 17 | 4 | 168
Mammography | 1394 | na | na | 1394
Acute Low Back Problems | 143 | 10 | 5 | 143
Post-Stroke Rehabilitation | 406 | 32 | 21 | 406
Cardiac Rehabilitation | 65 | 24 | 9 | 65
Alzheimer's Disease and Related Dementias | 325 | 7 | 4 | 336
Total | 5860 | 549 | 683 | 6994

1 Due to the structure and terminology of the search strategy, these totals may contain some duplicate titles.

na = no search was performed under this criteria

Table 10. Number of Abstracts and Articles Reviewed Listed by Guideline

Condition | Number of Abstracts Reviewed ^1^ | Number of Articles Reviewed ^1^
Acute Pain Management | 23 | 2
Urinary Incontinence in Adults | 87 | 3
Pressure Ulcers (in Adults and Treatment of) | 39 | 4
Depression in Primary Care | 35 | 7
Cataract in Adults | 16 | 1
Sickle Cell Disease | 15 | 8
Benign Prostatic Hyperplasia | 56 | 2
Management of Cancer Pain | 11 | 3
Unstable Angina | 56 | 10
Heart Failure | 100 | 39
Otitis Media with Effusion | 43 | 18
Mammography | 116 | 61
Acute Low Back Problems in Adults | 52 | 8
Post-Stroke Rehabilitation | 45 | 26
Cardiac Rehabilitation | 21 | 11
Alzheimer's Disease and Related Dementias | 16 | 5
Cardiac/Coronary (General) | 30 | 0
Clinical Practice Guidelines (General) | 5 | 0
TOTAL | 766 | 208

1 Includes articles suggested as evidence by experts

With the addition of evidence suggested by the experts, we reviewed 766 abstracts and 208 articles.