# Methodology

## Conceptual Model

The first task was to develop a conceptual model for assessing the validity of existing practice guidelines. There has been no published attempt to define the underlining criteria upon which to base decisions about the current validity of guidelines, nor is there an operational method for doing so. In order to develop a conceptual model, the authors first enlisted the participation of a small group of experts in clinical practice guidelines. This included:

- Martin Eccles, Professor of Clinical Effectiveness at the University of Newcastle-upon-Tyne.
- Jeremy Grimshaw, MD, Professor of Health Services Research at the University of Aberdeen.
- Steven Woolf, MD, MPH, a professor of family practice at the Virginia Commonwealth University.

The group, including Paul G. Shekelle, interacted via a series of teleconferences and electronic mail.

Based on these discussions, the authors consider that there are six situations that may require a guideline to be updated (or withdrawn) relating to changes in evidence, changes in the values placed on evidence, changes in resources available for health care, or change in performance:

1. Changes in the available interventions. In the interval since the guideline was developed, new preventive, diagnostic, or treatment interventions may have emerged that complement or supersede other interventions. For example, a guideline on heart failure would need to reflect the new role of ACE inhibitors over the combination of hydralazine and isosorbide dinitrate.^1, 2^
2. Changes in the evidence on the existing benefits and harms of interventions. New evidence may require that estimates of benefits and harms for existing interventions be updated. For example, the surgical risk of carotid endarterectomy has fallen substantially over the past 30 years, altering the risk-benefit ratio in favor of performing the operation for selected patients with symptomatic high-grade carotid stenosis.^3-5^
3. Changes in the outcomes that are considered important. New evidence may identify as important outcomes that were previously unappreciated or wholly unrecognized. For example, there is increasing recognition of quality of life and level of resources required for management as important outcomes of health care.
4. Changes in the evidence that current practice is optimal. Practice guidelines are developed to help narrow the gap between ideal and current clinical practice. It is conceivable that over time this gap could narrow to the point that a clinical practice guideline is unlikely to help any further and therefore could be withdrawn. For example, a national survey of surgical specialties in Scotland two years following the dissemination of a national guideline^ 6 ^ found that 90% of patients received appropriate deep vein thromboprophylaxis; given this performance it is arguable that the guideline could have been withdrawn.
5. Changes in the values placed on outcomes. The values that individuals or society place on different outcomes may change over time. For example, little weight has been given to cost issues in most guidelines. However, within the UK, new guidelines developed by the National Institute of Clinical Excellence will explicitly address economic issues.
6. Changes in the resources available for health care. Resource issues play an important role when practice guidelines involve costly interventions. Guidelines developed by or for governments or organizations that pay for health services may need to be updated to permit increased delivery of services if the level of available resources increases over time. Similarly, recommendations for or against specific services may need to be adjusted to reflect changes in cost. For example, the British government's recent pledge to increase NHS spending could change the cost-effectiveness threshold for determining whether some services are recommended. Similarly, the recent expiration of the patent on fluoxetine, which is expected to decrease in price through competition, may change policy in the guideline for antidepressant medications.^ 7 ^

### A model for assessing whether a guideline needs updating

How can we assess whether there have been sufficient changes in any of these factors to warrant updating a guideline? In answering that question, reviewers need to focus on dealing with changes in evidence and performance. Changes in the values placed on outcomes occur as societal norms change. Measuring these values and how they change over time is complex and not dealt with here. When changes occur in the availability of resources for health care or the costs of interventions, a generic policy on updating is unlikely to be helpful, because policy makers in disparate health care systems consider different factors when deciding whether services remain affordable.

The authors deal with identifying when new information on interventions, outcomes and performance justifies changing a guideline. This process includes two stages: (1) identifying significant new evidence, and (2) assessing whether the new evidence warrants updating or withdrawal. Ideally, the most thorough way to identify significant new evidence would be to conduct a new systematic review (including a search for evidence about current performance), but such a process would be costly and time consuming. It would be tantamount to completing the first step of updating, rather than determining whether updating was even necessary. Many guideline programs do not have the resources to achieve this gold standard. A more timely and efficient screening process is needed.

The authors suggest that the combination of limited literature searching and the guidance of experts from relevant disciplines is a more pragmatic way to help identify potentially significant new evidence (including current performance). The authors reason that evidence sufficient to invalidate an existing practice guideline would, in general, be of a magnitude that it is known to experts in the field or has been published as significant articles in major general interest or specialty medical journals. Questioning experts from relevant disciplines about possible new evidence, accompanied by a search of the major relevant medical journals, should then suffice to identify the presence or absence of important new evidence.

The authors propose a model based on expert opinion and limited literature reviews to assess when guidelines need updating (Figure 1). The process begins by identifying individual guideline statements within the guideline under review. Next, a multidisciplinary group of clinical experts is identified to review each guideline statement. The same experts do not necessarily assess each statement. Indeed, it is unlikely that an individual expert or experts from a single clinical discipline would possess sufficient knowledge to review all aspects of a broad guideline. The experts are not necessarily clinical specialists or consultants, as generalists with expertise in critical appraisal and non-clinical experts also may be involved.

Potential experts for this task could be recruited from the original panel of experts who created the guideline. The authors also favor including additional outside experts as they offer broader input. The guideline panel chair could be asked to suggest original panel members who are knowledgeable about particular guideline statements and relevant clinical experts who did not serve on the panel but should be included in reevaluating an existing guideline statement.

Figure 1. Model for Assessing When Guidelines Need Updating

The clinical experts are then asked two questions. First, are they aware of new evidence or developments in the field relevant to the guideline statement? If the answer is yes, then the expert is asked whether the evidence is sufficient to invalidate the guideline statement. This judgment of "sufficiency" should be based on the criteria presented above (new interventions, new data on benefits and harms, new outcomes, or evidence that the guideline is no longer needed). The expert is asked to provide supporting references for any new evidence.

Supplementing this process are limited literature searches which should be focused and expedient starting from the point in time when the literature search for the original guideline panel ended and should be restricted to the major general interest and specialty medical journals. The searches initially could focus on review articles, editorials, and commentaries, reasoning that an editorial or commentary frequently would accompany new evidence that is sufficient to change practice. A second search could be performed for newly published guidelines on the same topic, for example by searching the National Guidelines Clearinghouse (www.guidelines.gov). Yet another option for a limited search would be a Science Citation Index search on key articles, perhaps even the original clinical practice guideline itself, reasoning that new studies sufficient to change practice would reference either the prior practice guideline or previous major s! tudies. The authors recommend that these alternative search methods undergo formal comparison to determine the optimal approach and to weigh the relative accuracy and expediency of searches versus consultation with experts in determining whether important new evidence has emerged.

The second question that the authors believe experts should be asked is whether there is a need to address new issues in the guideline that were not covered previously, assuming that the issues fall within the original scope of the guideline. If the answer is yes, then the clinical experts should specify the issues.

The above mechanisms identify potential new evidence and new topic areas for the individual statements that comprise a clinical practice guideline. The next step is to assess whether the new evidence or topic areas are of sufficient importance that they invalidate the existing guideline statement. In some cases, the new information is prima facie evidence that the guideline statement is invalid, for example a large clinical trial reports that an existing therapy is without benefit. For other situations, however, this assessment necessarily will involve judgment. Because deciding whether new information is sufficient to disqualify a guideline involves considerations that reach beyond the domain of experts, the authors propose that this judgment be informed not only by input from the multidisciplinary experts in the survey process described above but also from clinical generalists with expertise in guideline development.

### How far from ideal is too far to retain an existing guideline?

Within any individual guideline there will be some recommendations that need updating and others that will remain current. How many recommendations will require updating before whole practice guideline needs to be updated or withdrawn? Consider the existing AHCPR guideline on heart failure, which includes 37 individual recommendations. Developed prior to the publication of the major clinical trials that established the efficacy of beta blockers for certain types of heart failure,^8-10^ it includes one statement about beta blockers, describing their use as "investigational." If the existing 37 practice guideline statements are still valid, does the absence of stronger recommendations for beta blockers make the guideline sufficiently far from "ideal" to compel updating or withdrawal?

Not all statements within a practice guideline are of equal clinical importance. In considering whether to update a guideline on a surgical procedure, for example, should greater weight be given to new evidence that the preoperative electrocardiogram recommended in the earlier guideline does not improve outcomes, or to new evidence that the operation itself is ineffective?

The authors believe that judging how far a guideline can deviate from ideal currency and still be considered acceptable inherently is subjective and can only be resolved by opinion. In some cases this will be straightforward, as when key recommendations or the majority of recommendations are out-of-date, with new evidence demonstrating that they are inappropriate, ineffective, or superceded by new interventions. In other cases, more difficult value judgments may be entailed to decide whether the departure from ideal currency reaches beyond an arbitrary threshold. The strength of the supporting evidence could be a guide in such circumstances.

### Implications for future guideline development

The problems associated with assessing the validity of guideline statements are compounded by the current inadequacies in reporting the methods by which guidelines are developed^11-13^ and the inflexibility of current publication formats. It is currently recommended that guidelines detail the evidence and rationale supporting each recommendation. If this was done more consistently, subsequent updating could be facilitated by specifying the type of new information (size of new clinical trial, magnitude of result, amount of new resources, changes in the costs of interventions, etc.) that could trigger a change in the recommendations. For example, if guideline developers believe that the effect size of an intervention is too small to justify a recommendation, they could suggest what magnitude of effect should be demonstrated to warrant a new look at the evidence. Such information would allow future evaluations of the applica! bility of existing guidelines to be more efficiently targeted towards identifying evidence of a magnitude sufficient to consider updating.

The paper formats in which most guidelines currently are published make it difficult to withdraw or update specific statements. However the increasingly widespread publication of guidelines in electronic format, such as the Scottish Intercollegiate Guideline Network (http://www.show.scot.nhs.uk) or the National Institute for Clinical Excellence (http://www.nice.org.uk), could facilitate a modular approach in which specific statements could be easily removed or replaced as new evidence emerges. Even if guideline statements are not replaced with new ones, an electronic format makes it easy to append comments about important content areas that the guideline does not address.

## Operational Method

The Agency requested that the authors assess the validity of the seventeen guidelines listed in Table 1.

Table 1. AHRQ Guidelines Assessed for Current Validity

Acute Pain Management: Operative or Medical Procedures and Trauma

Urinary Incontinence in Adults: Acute and Chronic Management - 1996 Update

Pressure Ulcers in Adults: Prediction and Prevention

Depression in Primary Care: Volume 1. Detection and Diagnosis

Depression in Primary Care: Volume 2. Treatment of Major Depression

Cataract in Adults: Management of Functional Impairment

Sickle Cell Disease: Screening, Diagnosis, Management, and Counseling in Newborns and Infants

Benign Prostatic Hyperplasia: Diagnosis and Treatment

Management of Cancer Pain

Unstable Angina: Diagnosis and Management

Heart Failure: Evaluation and Care of Patients with Left-Ventricular Systolic Dysfunction

Otitis Media with Effusion

Quality Determinants of Mammography

Acute Low Back Problems in Adults

Treatment of Pressure Ulcers

Post-Stroke Rehabilitation

Cardiac Rehabilitation

Recognition and Initial Assessment of Alzheimer's Disease and Related Dementias

### Survey of experts

The authors sent to the chair(s) of each of the clinical practice guideline expert panels a survey requesting their assistance in identifying the members of their panel who they believed were most qualified to assess the current validity of each of the individual guideline statements within their respective clinical practice guidelines. A sample of this questionnaire is reproduced in Appendix A. The authors used this information to assign individual guideline statements to these experts, who were then sent a second survey that assessed the statements' current validity. The authors asked them a series of three questions based on our conceptual model: (1) are you aware of new evidence or developments in the field relevant to this guideline statement? (2) is the new evidence or development of sufficient importance to invalidate the guideline statement? and (3) are there new guideline statements (within the boundaries of the original guideline) that shoul! d be present? Respondents were told to consider validity within the context of our conceptual model; namely, new interventions whether they be preventive, diagnostic or treatment may have improved or replaced those interventions listed in the guideline statement; new evidence may have altered the relationship between the benefits and harms of existing interventions; outcomes not considered important at the time the original guideline statement was developed now may be important; or there may have been changes in the values placed on the outcomes considered when the original guideline statement was developed. A portion of one of the surveys is reproduced in Appendix B. A second round of mailings was sent to non-respondents.

For each clinical practice guideline the authors also attempted to obtain an evaluation of validity from at least one expert not associated with the original practice guideline panel.

### Limited literature searches

For each clinical practice guideline the authors conducted limited literature searches for significant new evidence that may have an effect on the validity of the guideline statements (Table 2). These limited literature searches were restricted to review articles and editorials about the particular guideline topic. After screening large numbers of titles retrieved by the searches for Benign Prostatic Hyperplasia, Sickle Cell Disease, and Unstable Angina, for the searches for Acute Pain Management, Depression in Primary Care (vols. 1 and 2), Management of Cancer Pain, Heart Failure, Otitis Media with Effusion, Acute Low Back Problems in Adults, Post-Stroke Rehabilitation, Cardiac Rehabilitation, and Recognition and Initial Assessment of Alzheimer's Disease and Related Dementias, the authors further restricted the search to key journals which would be those most likely to have published evidence of sufficient magnitude to warrant the revision of an exist! ing practice guideline. Key journals included the 5 major general interest publications (Annals of Internal Medicine, British Medical Journal, Journal of the American Medical Association, Lancet, and New England Journal of Medicine), and key specialty journals for each topic identified by local experts in the field. Table 3 lists the practice guideline topics and the respective key specialty journals the authors searched. For the remaining three guideline topics (Urinary Incontinence, Cataract, and Pressure Ulcers) the authors did not restrict our search to specific journals as an unrestricted search yielded a manageable number of titles.

Table 2. Search Methodology for Limited Literature Search

SEARCH #1A - ACUTE PAIN MANAGEMENT (INCLUDING CANCER PAIN) PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE^®^ EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: pain OR palliative care! OR palliative therapy! AND practice guideline? OR Document type = practice guideline OR guideline AND Document types =review literature OR review of reported cases OR review, academic OR review, multicase OR review, tutorial OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 460

SEARCH #1B - ACUTE PAIN MANAGEMENT (INCLUDING CANCER PAIN) Same as search #1A, except that the following journals were added as limiters: Pain Anesthesia and Analgesia Anesthesiology NUMBER OF ITEMS RETRIEVED: 37

SEARCH #1C - ACUTE PAIN MANAGEMENT (INCLUDING CANCER PAIN) PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: pain OR palliative care! OR palliative therapy! AND Document types = review? OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 430

SEARCH #2A - URINARY INCONTINENCE IN ADULTS PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: urinary incontinence OR urine incontinence AND practice guidelines OR Document type = practice guideline OR guideline AND human AND English NUMBER OF ITEMS RETRIEVED: 45

SEARCH #2B - URINARY INCONTINENCE IN ADULTS PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: urinary incontinence OR urine incontinence AND practice guidelines OR Document type = practice guideline OR guideline OR review OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 890

SEARCH #3 - PRESSURE ULCERS (Treatment of and IN ADULTS) PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: decubitus ulcer OR decubitis OR pressure ulcer? OR pressure sore? OR bed sore? OR bedsore? AND practice guidelines OR Document type = practice guideline OR guideline OR reviews OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 104

SEARCH #4A - DEPRESSION IN PRIMARY CARE PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1991-current SEARCH STRATEGY: depression (in title and subject heading fields) OR depressive disorder! OR antidepressive agents! OR affective neurosis! AND Primary health care! OR physicians, family AND Document type = review? OR editorial? NUMBER OF ITEMS RETRIEVED: 250

SEARCH #4B - DEPRESSION IN PRIMARY CARE PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1991-current SEARCH STRATEGY: depression (in title and subject heading fields) OR depressive disorder! OR antidepressive agents! OR affective neurosis! AND Primary health care! OR physicians, family AND THE FOLLOWING JOURNALS: Archives of General Psychiatry American Journal of Psychiatry Journal of Consulting and Clinical Psychology NUMBER OF ITEMS RETRIEVED: 42 If we remove "Primary health care" NUMBER OF ITEMS RETRIEVED: 181

SEARCH #4C - DEPRESSION IN PRIMARY CARE PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1991-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: depression (in title and subject heading fields) OR depressive disorder! OR antidepressive agents! OR affective neurosis! AND Primary health care! OR physicians, family AND Document type = review? OR editorial? NOT case report? NUMBER OF ITEMS RETRIEVED: 4 If we remove "Primary health care" NUMBER OF ITEMS RETRIEVED: 184

SEARCH #5A - CATARACTS IN ADULTS PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: cataract! OR cataract extraction! AND practice guidelines OR Document type = practice guideline OR guideline AND human AND English NUMBER OF ITEMS RETRIEVED: 28

SEARCH #5B - CATARACTS IN ADULTS PERFORMED FEBRUARY 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current SEARCH STRATEGY: cataract! OR cataract extraction! AND practice guidelines OR Document type = practice guideline OR guideline OR review OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 1241

SEARCH #6: SICKLE CELL DISEASE PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1991-current SEARCH STRATEGY: sickle cell trait OR sickle cell anemia! AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial NUMBER OF ITEMS RETRIEVED: 490

SEARCH #7: BENIGN PROSTATIC HYPERPLASIA PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: prostatic hyperplasia OR benign prostatic hyperplasia AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 780

SEARCH #8: UNSTABLE ANGINA PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: angina, unstable OR unstable angina pectoris! AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 693

SEARCH #9A - HEART FAILURE PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: heart failure, congestive! OR heart failure! AND practice guideline? OR Document type = practice guideline OR guideline AND human AND English NUMBER OF ITEMS RETRIEVED: 509

SEARCH #9B - HEART FAILURE PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: heart failure, congestive! OR heart failure! AND Document type = review OR review literature OR review, academic OR editorial AND THE FOLLOWING JOURNALS: Circulation Journal of the American College of Cardiology American Journal of Cardiology AND human AND English NUMBER OF ITEMS RETRIEVED: 380

SERACH #9C - HEART FAILURE PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: heart failure, congestive! OR heart failure! AND Document types = review? OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 206

SEARCH #10A - OTITIS MEDIA WITH EFFUSION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: otitis media with effusion OR [otitis media! and effusion] AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 168

SEARCH #10B - OTITIS MEDIA WITH EFFUSION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: otitis media with effusion OR [otitis media! and effusion] AND Document type = review? OR editorial AND THE FOLLOWING JOURNALS: Pediatrics Journal of Pediatrics Archives of Otolaryngology - Head and Neck Surgery International Journal of Pediatric Otorhinolaryngology Archives of Pediatrics and Adolescent Medicine Proceedings of the International Symposium on Recent Advances in Otitis Media Research NUMBER OF ITEMS RETRIEVED: 17

SEARCH # 10C - OTITIS MEDIA WITH EFFUSION PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1990-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: otitis media with effusion AND Document types = review? OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 4

SEARCH #11 - QUALITY DETERMINANTS OF MAMMOGRAPHY PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: mammography! AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial NUMBER OF ITEMS RETRIEVED: 1394

SEARCH #12A - ACUTE LOW BACK PROBLEMS IN ADULTS PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: low back pain AND acute AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND human AND English NUMBER OF ITEMS RETRIEVED: 143

SEARCH #12B - ACUTE LOW BACK PROBLEMS IN ADULTS PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current SEARCH STRATEGY: low back pain AND acute AND Document type = review? OR editorial AND THE FOLLOWING JOURNALS: Spine Journal of Bone and Joint Surgery Journal of Spinal Disorders Clinical Orthopaedics and Related Research Journal of General Internal Medicine Pain Clinical Journal of Pain NUMBER OF ITEMS RETRIEVED: 10

SEARCH #12C - ACUTE LOW BACK PROBLEMS IN ADULTS PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1992-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: low back pain AND acute AND Document types = review? OR editorial AND human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 5

SEARCH #13A - POST-STROKE REHABILITATION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current SEARCH STRATEGY: cerebrovascular disorders!--rehabilitation OR stroke--rehabilitation OR [stroke? and rehabilitation!} AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND English NUMBER OF ITEMS RETRIEVED: 406

SEARCH #13B - POST-STROKE REHABILITATION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current SEARCH STRATEGY: cerebrovascular disorders!--rehabilitation OR stroke--rehabilitation OR [stroke? and rehabilitation!} AND Document type = review? OR editorial AND THE FOLLOWING JOURNALS Archives of Physical Medicine and Rehabilitation Stroke Neurology Annals of Neurology NUMBER OF ITEMS RETRIEVED: 32

SEARCH #13C - POST-STROKE REHABILITATION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: cerebrovascular disorders!--rehabilitation OR [cerebrovascular disorders! and (rehabilitation! or rehabilitation)] OR stroke--rehabilitation OR [stroke? and rehabilitation!} AND Document types = review? OR editorial? AND Human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 21

SEARCH #14A - CARDIAC REHABILITATION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current SEARCH STRATEGY: cardiac care facilities OR coronary disease!--rehabilitation OR heart disease(s)!--rehabilitation OR myocardial diseases!--rehabilitation OR [heart disease! AND rehabilitation] AND practice guideline? OR Document type = practice guideline OR guideline AND English NUMBER OF ITEMS RETRIEVED: 65

SEARCH #14B - CARDIAC REHABILITATION PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current SEARCH STRATEGY: cardiac care facilities OR coronary disease!--rehabilitation OR heart disease(s)!--rehabilitation OR myocardial diseases!--rehabilitation OR [heart disease! AND rehabilitation] AND Document type = review OR review literature OR review, academic OR editorial AND THE FOLLOWING JOURNALS Journal of Cardiac Failure Journal of Cardiac Rehabilitation Journal of the American College of Cardiology American Journal of Cardiology Circulation NUMBER OF ITEMS RETRIEVED: 24

SEARCH 14C - CARDIAC REHABILITATION PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: cardiac care facilities OR coronary disease!--rehabilitation OR heart disease(s)!--rehabilitation OR myocardial diseases!--rehabilitation OR [heart disease! AND rehabilitation] AND Document types = review? OR editorial? AND Human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 9

SEARCH #15A - ALZHEIMER'S DISEASE AND RELATED DEMENTIAS PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1995-current SEARCH STRATEGY: Alzheimer disease AND early AND practice guideline? OR Document type = practice guideline OR guideline OR review OR review literature OR review, academic OR editorial AND English NUMBER OF ITEMS RETRIEVED: 325 If we remove "early" NUMBER OF ITEMS RETRIEVED: 3427

SEARCH #15B - EARLY ALZHEIMER'S DISEASE AND RELATED DEMENTIAS PERFORMED APRIL 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1993-current SEARCH STRATEGY: Alzheimer disease AND early AND Document type = review OR review literature OR review, academic OR editorial AND THE FOLLOWING JOURNALS Archives of Neurology Neurology NUMBER OF ITEMS RETRIEVED: 7 If we remove "early" NUMBER OF ITEMS RETRIEVED: 68

SEARCH #15C - EARLY ALZHEIMER'S DISEASE AND RELATED DEMENTIAS PERFORMED JUNE 2000 DATABASES SEARCHED: MEDLINE EMBASE TIME PERIOD COVERED: 1995-current THE FOLLOWING JOURNALS WERE ADDED AS LIMITERS: Annals of Internal Medicine British Medical Journal Journal of the American Medical Association Lancet New England Journal of Medicine SEARCH STRATEGY: Alzheimer disease AND early AND Document types = review? OR editorial? AND Human AND English NOT case report? NUMBER OF ITEMS RETRIEVED: 4 If we remove "early" NUMBER OF ITEMS RETRIEVED: 68

Table 3. Key Specialty Journals Used in Search Strategy

Guideline | Key Specialty Journals
Acute Pain Management: Operative or Medical Procedures and Trauma | Pain Anesthesiology Anesthesia and Anagesia
Depression in Primary Care: Vols. 1 & 2 | Archives of General Psychiatry Patient Outcome Research Team study (being made available through RAND) American Journal of Psychiatry Journal of Consulting Clinical Psychology
Management of Cancer Pain | Pain Journal Pain Symptom Manage
Heart Failure: Evaluation and Care of Patients with Left-Ventricular Systolic Dysfunction | Circulation Journal American College of Cardiology American Journal of Cardiology
Otitis Media with Effusion | Pediatrics Journal of Pediatrics Archives of Otolaryngol Head Neck Surgery Int J Pediatr Arch Pediatr Adolesc Med Proceedings of the International Symposium on Recent Advances in Otitis Media Research
Acute Low Back Problems in Adults | Spine J Bone Joint Surg J Spinal Disorders Clin Orthop J Gen Intern Med Pain Clin J Pain
Post-Stroke Rehabilitation | Archives of PM&R Stroke Neurology Annals of Neurology
Cardiac Rehabilitation | Journal of Cardiac Failure Circulation Journal American College of Cardiology Am J Cardiology
Recognition and Initial Assessment of Alzheimer's Disease and Related Dementias | Arch of Neurology Neurology

The authors sought to define the starting point in time for each search by using the end date for the original AHCPR guideline search. However, review of the published guidelines identified this date in only 5 of the 17 guidelines (29%). For the remaining guidelines, the authors conservatively chose as the starting point 2 years prior to the publication date of the guideline, as in the 5 guidelines for which the authors did have data this was the "lag period" between the end of the search and publication. Table 4 lists each guideline, the date of publication, and the date of the end of the original search strategy, if reported. One or two physicians trained in evidence-based medicine reviewed the literature searches. Titles, abstracts and articles were reviewed sequentially, seeking new evidence regarding the guideline statements.

Table 4. Publication Dates and Lit Search End Dates for AHCPR Guidelines

Guideline Key Journals | Pub Date of AHCPR Guidelines | End of Literature Search for AHCPR Guidelines
Acute Pain Management: Operative or Medical Procedures and Trauma | February 1992 | na
Urinary Incontinence in Adults: Acute and Chronic Management - 1996 Update | March 1996 update to 1992 | na
Pressure Ulcers in Adults: Prediction and Prevention | May 1992 | August 1990
Cataract in Adults: Management of Functional Impairment | February 1993 | January 26, 1991 MEDLINE^®^; March 1991 SciSearch^®^; Sept. 1, 1990 Psych Abstracts, Dissertation Abstracts; August 1, 1990 CINAHL, CATLINE^®^, Health
Depression in Primary Care: Volume 1. Detection and Diagnosis Volume 2. Treatment of Major Depression | April 1993 | na
Sickle Cell Disease: Screening, Diagnosis, Management, and Counseling in Newborns and Infants | April 1993 | na
Benign Prostatic Hyperplasia: Diagnosis and Treatment | February 1994 | na
Management of Cancer Pain | March 1994 | na
Unstable Angina: Diagnosis and Management | May 1994 (amended) | na
Heart Failure: Evaluation and Care of Patients with Left-Ventricular Systolic Dysfunction | June 1994 | (February 1992)
Otitis Media with Effusion | July 1994 | na
Quality Determinants of Mammography | October 1994 | 1980-1992
Acute Low Back Problems in Adults | December 1994 | na
Treatment of Pressure Ulcers | December 1994 | May 1, 1993
Post-Stroke Rehabilitation | May 1995 | na
Cardiac Rehabilitation | October 1995 | na
Recognition and Initial Assessment of Alzheimer's Disease and Related Dementias | November 1996 | August 1995

na = literature search end date not specified in the publication

The authors also searched for practice guidelines that had been published after the release of the original AHCPR documents and that were related to the same conditions. These guidelines were reviewed seeking evidence relevant to the current validity of the AHCPR guideline statements. Because clinical practice guidelines are seldom referenced in the traditional scientific databases, the authors employed a number of other search strategies to locate these materials. Primarily the authors utilized the National Guideline Clearinghouse (www.guidelines.gov) on the Internet to identify any materials relating to the conditions covered in the AHCPR guidelines. When possible, the authors downloaded the appropriate guidelines from the National Guideline Clearinghouse Web site or from the publishing organizations' Web sites. When this was not feasible, the authors reviewed the Summary Statements that the National Guideline Clearinghouse provid! ed for each guideline.

For most of the conditions, the authors also searched the following sources:

- CONQUEST 1.1 (A Computerized Needs-Oriented Quality Measurement Evaluation System)
- DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality
- Directory of Clinical Practice Guide to Clinical and Preventive Services
- HEDIS 3.0: Health Plan Employer Data and Information Set
- National Library of Health Care Indicators
- The Medical Outcomes & Guidelines Sourcebook

In addition, the authors requested practice guidelines from the following agencies and organizations:

- Administration on Aging (AOA)
- Centers for Disease Control and Prevention (CDC)
- Department of Health and Human Services (DHHS)
- Department of Veterans' Affairs (DVA)
- Foundation for Accountability (FACCT)
- Health Care Financing Administration (HCFA)
- HCFA/Qualidigm, formerly Connecticut Peer Review Organization (CPRO)
- Joint Commission on Accreditation of Healthcare Organizations (JCAHO)
- National Committee for Quality Assurance (NCQA)
- National Institutes of Health (NIH)

Finally, the authors identified guidelines from professional societies, disease societies, medical organizations, medical associations, and patient advocacy groups. When possible, the authors located these groups on the Internet and downloaded the guidelines; otherwise, the authors phoned or wrote to them to request the materials. For all of the searches, the authors identified only those guidelines that had been published after the AHCPR guidelines. A comprehensive listing of the guidelines that the authors reviewed can be found in Table 5.

Table 5. Guidelines Published after AHCPR Guidelines Publication Dates

Acute Pain Management; 1. Acute Post-Operative Pain Management. In: AMRRC-AHCPR Guideline Criteria Project: Develop, Apply, and Evaluate Medical Review Criteria and Educational Outreach Based upon Practice Guidelines, Volume II. Washington, D.C.: American Medical Review Research Center, 1995.; 2. Acute Pain and Cancer Pain, A Position Statement from the American Academy of Pain Medicine, American Academy of Pain Medicine, 1998.; 3. American Geriatrics Society Panel on Chronic Pain in Older Persons, Clinical Practice Guidelines, The Management of Chronic Pain in Older Persons, JAGS. 1998;46:635-651.; 4. American Society of Anesthesiologists. Practice Guidelines for Acute Pain in the Perioperative Setting, Anesthesiology. 1995;82:1071-81.; 5. American Society of Anesthesiologists. Practice Guidelines for Cancer Pain Management, Anesthesiology. 1996;84:1243-1257.; 6. American Society of Anesthesiologists. Practice Guidelines for Chronic Pain Management, Anesthesiology. 1997;86:995-1004.; 7. Chronic Pain Management in the Long-Term Care Setting. Columbia, MD: American Medical Directors Association, 1999.; 8. Integration of Behavioral and Relaxation Approaches into the Treatment of Chronic Pain and Insomnia. National Institutes of Health. Technology Assessment Conference Statement, October 16-18, 1995.; 9. Management of Pain Using Dangerous Drugs and Controlled Substances, Agency for Health Care Administration, State of Florida, October 25, 1996.; 10. Model Guidelines for the Use of Controlled Substances for the Treatment of Pain, May 1998. Federation of States Medical Board of the United States, Inc. www.fsmb.org/pain.htm.; 11. The Necessity for Early Evaluation and Treatment of the Chronic Pain Patient. A Consensus Statement from the American Academy of Pain Medicine, American Academy of Pain Medicine, 1997.; 12. Quality Improvement Guidelines for the Treatment of Acute Pain and Cancer Pain. Consensus Statement, American Pain Society, JAMA. 1995;274(23):1874-1880.; 13. The Use of Opioids for the Treatment of Chronic Pain. A Consensus Statement from the American Academy of Pain Medicine and the American Pain Society, American Academy of Pain Medicine and American Pain Society, 1997.; 14. Young D. Research-Based Protocol: Acute Pain Management, The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1997.
Urinary Incontinence in Adults; 1. The Geriatric Patient, Reference Guide, 7th Edition. American Board of Family Practice, 1998, pp. 30-35.; 2. Lyons S, Pringle Specht J. Research-Based Protocol: Prompted Voiding for Persons with Urinary Incontinence, The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1999.; 3. McCormick K, Palmer M. Urinary Incontinence in Older Adults. In: Fitzpatrick J, Taunton RL, Jacox A, eds. Annual Review of Nursing Research, Volume 10. New York: Springer Publishing Company, pp. 25-53.; 4. Ouslander JG, et al. Urinary Incontinence Clinical Practice Guideline. American Medical Directors Association, 1996.; 5. The Surgical Management of Female Stress Urinary Incontinence, American Urological Association, June 1997.; 6. Urinary Tract Infection, Reference Guide, 5th Edition. American Board of Family Practice, 1997.
Pressure Ulcers in Adults: Prediction and Prevention; 1. American Diabetes Association. Position Statement: Preventive Foot Care in Patients with Diabetes, Diabetes Care. 2000;23(1):S55-S56.; 2. Folkedahl B, Frantz R, Goode C. Prevention of Pressure Ulcers. The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1997.; 3. Laouri M, Mittman B, et al. Developing Quality and Utilization Review Criteria for Pressure Ulcers in Adults: Phase II Final Report, March 1995. RAND. PM-403-AHCPR.; 4. Lower Extremity Ulceration. American Society of Plastic and Reconstructive Surgeons, 1998.; 5. National Pressure Ulcer Advisory Panel. NPUAP Statement on Reverse Staging of Pressure Ulcers, The NPUAP Report. September 1995;4(3). www.npuap.org.; 6. National Pressure Ulcer Advisory Panel. Minimum Data Set-2 (MDS-2) & Skin Ulcer Assessment. The NUPUAP Report. April 1996;4(3). www.npuap.org.; 7. Pressure Sores, American Society of Plastic and Reconstructive Surgery, 1996.; 8. Pressure Ulcers Clinical Practice Guideline. American Medical Directors Association, 1996.; 9. Stage I Assessment in Darkly Pigmented Skin, 1998. National Pressure Ulcer Advisory Panel. www.npuap.org.; 10. Statement on Pressure Ulcer Prevention, National Pressure Ulcer Advisory Panel, 1992. www.npuap.org.; 11. Venous Leg Ulcer Guideline. University of Pennsylvania, 1997.
Depression in Primary Care; 1. Comorbidity. Practice Based Report of the AMA Council on Scientific Affairs (Report A-91). American Medical Association.; 2. Depression. Columbia, MD: The American Medical Directors Association, 1996.; 3. Depression. University of Michigan Health System, 1998.; 4. Depressive Disorders, Reference Guide, 7th Edition. Lexington, KY: American Board of Family Practice, 1998.; 5. Early Detection of Depression. Canadian Task Force on the Periodic Health Examination, Health Canada, January 1994.; 6. FACCT Quality Measures - Major Depressive Disorder. Foundation for Accountability. www.facct.org/measures/existing_measures/mdd.html.; 7. The Geriatric Patient, Reference Guide, 7th Edition. Lexington, KY: American Board of Family Practice, 1998, pp. 18-19, 30-31.; 8. Major Depression, Panic Disorder and Generalized Anxiety Disorder in Adults in Primary Care. Institute for Clinical Systems Improvement. March 1999.; 9. Meredith L, Wells K, Camp P. Clinician Specialty and Treatment Style for Depressed Outpatients With and Without Medical Comorbidities. RAND, DRU-492-1-AHCPR, June 1994.; 10. Practice Guideline for Major Depressive Disorder in Adults. Am J Psychiatry 1993;150(4 Suppl):1-26.; 11. Practice Parameters for the Assessment and Treatment of Children and Adolescents with Depressive Disorders. J Am Acad Child Adolesc Psychiatry. 1998;37(10 Suppl):63S-83S.; 12. Schulberg HC, Katon W, Simon GE, Rush AJ. Treating Major Depression in Primary Care Practice: An Update of the Agency for Health Care Policy and Research Practice Guidelines. Arch Gen Psychiatry. 1998;55:1121-1127.; 13. Scotton Piven ML. Research-Based Protocol: Detection of Depression in the Cognitively Intact Older Adult, The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1998.; 14. Screening for Depression. In: U.S. Preventive Services Task Force, Guide to Clinical Preventive Services, 2nd Edition. Alexandria, Virginia: International Medical Publishing, 1996.; 15. Veterans Health Administration Clinical Guideline for Major Depressive Disorder, MDD with Post Traumatic Stress Disorder, and MDD with Substance Abuse, Department of Veterans Affairs, 1997.; 16. Work Group on Major Depressive Disorder. Practice Guideline for the treatment of Patients with Major Depression, 2nd Edition. The American Psychiatric Association, April 2000. www.psych.org/clin_res/Depression2e.book.html.
Cataract in Adults; 1. Care of the Adult Patient with Cataract. American Optomertic Association, 1996.; 2. Cataract in the Adult Eye. American Academy of Ophthalmology, 1996.; 3. Laouri M, Mittman B, et al. Developing Quality and Utilization Review Crieria for Management of Cataract in Adults: Phase II Final Report. Santa Monica, CA: RAND, April 1995, PM-404-AHCPR.; 4. Lee PP, et al. Cataract Surgery: A Literature Review and Ratings of Appropriateness and Cruciality. Santa Monica, CA: RAND, 1993.; 5. Preferred Practice Pattern: Comprehensive Adult Eye Evaluation. American Academy of Ophthalmology, 1996.; 6. Screening for Visual Impairment. In: U.S. Preventive Services Task Force, Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996.
Sickle Cell Disease No guidelines were identified. Benign Prostatic Hyperplasia; 1. Coley CM, Barry MJ, Mulley AG. Position Paper, Clinical Guideline: Part III. Screening for Prostate Cancer, Ann Intern Med. 1997;126:480-484.
Management of Cancer Pain; 1. Acute Pain and Cancer Pain. A Position Statement from the American Academy of Pain Medicine, American Academy of Pain Medicine, 1998.; 2. American Society of Anesthesiologists. Practice Guidelines for Cancer Pain Management, Anesthesiology. 1996;84:1243-1257.; 3. Quality Improvement Guidelines for the Treatment of Acute Pain and Cancer Pain. Consensus Statement, American Pain Society, JAMA. 1995;274(23):1874-1880.
Unstable Angina; 1. Coronary Artery Disease, Reference Guide, 6th Edition. Lexington, KY: American Board of Family Practice, 1997.; 2. Dracup K, et al. National Heart Attack Alert Program. Educational Strategies to Prevent Prehospital Delay in Patients at High Risk for Acute Myocardial Infarction, US Department of Health and Human Services. Public Health Service. National Institutes of Health. National Heart, Lung, and Blood Institute. NIH Publication No. 97-3787. Bethesda, MD: National Institutes of Health, September 1997.; 3. Dracup K, et al. The Physician's Role in Minimizing Prehospital Delay in Patients at High Risk for Acute MI: Recommendations from the National Heart Attack Alert Program, Ann Intern Med. 1997;126:645-651.; 4. Grundy SM, et al. Primary Prevention of Coronary Heart Disease: Guidance from Framingham, A Statement for Healthcare Professionals from the AHA Task Force on Risk Reduction. American Heart Association, July 1997. http://www.amhrt.org/Scientific/statements/1998/059801.html; 5. Hirsch J, Fuster V. Guide to Anticoagulant Therapy Pt. 1: Heparin, Circulation. 1994;89: 1449-1468.; 6. Ischemic Heart Disease Profile. In: Palmer RH, Clark LE, Lawthers AG, et al. DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality, Final Report, Volume III. Boston, MA: Harvard School of Public Health, 1994.; 7. Monitoring Quality of Primary Care: A Self-Assessment Workbook. In: Palmer RH, Clark LE, Lawthers AG, et al. DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality, Final Report, Volume III. Boston, MA: Harvard School of Public Health, 1994.; 8. Mosea L, et al. Cardiovascular Disease in Women, A Statement for Healthcare Professionals from the American Heart Association. Circulation. 1997;96:2468-2482.; 9. Quality Improvement/Clinical Guidelines: Beta Blockers After Myocardial Infarction, Humana. www.humana.com/provider/guidelines/beta.html.; 10. Ryan TJ, et al. ACC/AHA Guidelines for the Management of Patients with Acute Myocardial Infarction, A Report of the ACC/AHA Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction). Circulation. 1996;94:2341-2350.; 11. Screening for Asymptomatic Coronary Artery Disease. In: U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996.; 12. Selker HP, et al. An Evaluation of Technologies for Identifying Acute Cardiac Ischemia in the Emergency Department, Executive Summary of a National Heart Attack Alert Program Working Group Report. Ann Emerg Med. 1997;29:1-12.; 13. Swan HJC, et al. ACC Position Statement -- Preventive Cardiology and Atherosclerotic Disease, J American College of Cardiol. 1994;24:838.
Heart Failure; 1. Congestive Heart Failure Profile. In: Palmer RH, Clark LE, Lawthers AG, et al. DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality, Final Report, Volume 3. Boston, MA: Harvard School of Public Health, 1994.; 2. Monitoring Quality of Primary Care: A Self-Assessment Workbook, DEMPAQ Record Review Criteria, Congestive Heart Failure. In Palmer RH, Clark LE, Lawthers AG, Edwards JE, Fowles J, Garnick D, Weiner J. DEMPAQ: A Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality, Final Report, Volume 3. Boston, MA: Harvard School of Public Health, 1994.; 3. ACC/AHA Task Force Report. Guidelines for the Evaluation and Management of Heart Failure, Task Force on Practice Guidelines. Circulation. 1995;92:2764-2784.; 4. Data Fact Sheet: Congestive Heart Failure in the US: A New Epidemic? The National Heart, Lung, and Blood Institute, September 1996.; 5. Heart Failure Clinical Practice Guideline. Columbia, MD: American Medical Directors Association, 1996.; 6. Cardiovascular Disease in Women, American Heart Association Statement, 1997. www.amhrt.org.; 7. Chronic Heart Failure, Reference Guide, 6th Edition. Lexington, KY: American Board of Family Practice, 1997.; 8. Consensus Recommendations for the Management of Chronic Heart Failure, The American Journal of Cardiology. 1999;83(2A):1A-38A.; 9. Diagnosis and Treatment of Heart Failure Due to Left Ventricular Systolic Dysfunction: A National Clinical Guideline, Scottish Intercollegiate Guidelines Network, Feburary 1999.; 10. Health Care Guideline: Congestive Heart Failure in Adults, Institute for Clinical Systems Improvement, 1999.; 11. Heart Failure Society of America (HFSA) Practice Guidelines: HFSA Guidelines for Management of Patients with Heart Failure Caused by Left Ventricular Systolic Dysfunction -- Pharmacological Approaches, Heart Failure Society of America, 1999.; 12. Krumholz HM, Baker DW, Ashton CM, et al. AHA/ACC Conference Proceedings: Evaluating Quality of Care for Patients with Heart Failure, Circulation. 2000;101:e122-e140.; 13. Quality Improvement/Clinical Guidelines: Management of Congestive Heart Failure, Humana. www.humana.com/providers/guidelines/heart.html.
Otitis Media with Effusion; 1. Acute Otitis Media: Management and Surveillance in an Era of Pneumococcal Resistance. Pediatr Infect Dis J. 1999;18(1):1-9.; 2. American Academy of Pediatrics. The Otitis Media Guideline Panel, Managing Otitis Media with Effusion in Young Children. Pediatrics. 1994;94(5):766-773.; 3. Evidence Based Clinical Practice Guideline for Medical Management of Otitis Media in Children 2 Months to 6 Years of Age. Children's Hospital Medical Center. Cincinnati. OH. 1999.; 4. Health Care Guideline: Diagnosis and Treatment of Otitis Media in Children. Institute for Clinical Systems Improvement. 1999.
Quality Determinants of Mammography; 1. ACR Standard for the Performance of Screening Mammography. American College of Radiology. 1995.; 2. ACR Standard for the Performance of Diagnostic Mammography. American College of Radiology. 1998.; 3. ACS Guidelines for the Early Detection of Breast Cancer: Update 1997. CA Cancer J Clin. 1997;47(3):150-53.; 4. American College of Radiology Guidelines for Breast Cancer Screening. Am J Roentgenol. 1998;171(1):29-33.; 5. Ferrini R, Mannino E, Ramsdell E, Hill L. Screening Mammography for Breast Cancer. Am J Prev Med. 1996;12(5):340-341.; 6. Breast Cancer Screening for Women Ages 40-49. NIH Conses Statement. 1997;15(1):1-35.; 7. Expert Panel on Women's Imaging Breast Work Group. Appropriateness Criteria: Calcifications. American College of Radiology. September 1999.; 8. Expert Panel on Women's Imaging Breast Work Group. Appropriateness Criteria for Workup of Palpable Breast Mass. American College of Radiology. September 1999.; 9. Expert Panel on Women's Imgaing Breast Work Group. Appropriateness Criteria: Nonpalpable Breast Mass. American College of Radiology. September 1999.; 10. Expert Panel on Women's Imaging Breast Work Group. Appropriateness Criteria: Stage 1 Breast Carcinoma. American College of Radiology. September 1999.; 11. Health Care Guideline: Breast Cancer Diagnosis. Institute for Clinical Systems Improvement, April 1998.; 12. Recommended Breast Cancer Surveillance Guidelines. J Clin Oncol. 1997;15(5):2149-2156. www.asco.org.; 13. Screening for Breast Cancer. In: Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996.; 14. Smith TJ, Davidson NE, Schapira DV, et al. American Society of Clinical Oncology 1998 Update of Recommended Breast Cancer Surveillance Guidelines. J Clin Oncol. 1999;17:1080-1082. www.asco.org.
Acute Low Back Problems in Adults; 1. Adult Low Back Pain. Institute for Clinical Systems Improvement. November 1998.; 2. Appropriateness Criteria for Uncomplicated Low Back Pain. American College of Radiology. September 1996.; 3. Counselling to Prevent Low Back Pain. In: U.S. Preventive Services Task Force, Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996, pp. 699-710.; 4. Ellenberger C. MR Imaging of the Low Back Syndrome. Neurology. 1994;44:594-600.; 5. Guideline for Hospitalization for Low Back Pain. Washington State Department of Labor and Industries. June 1999.; 6. Review of the Literature on Spinal Ultrasound for the Evaluation of Back Pain and Radicular Disorders: Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology. 1998;51(2):343-344.; 7. Universe of Florida Patients with Low Back Pain or Injury. State of Florida, Agency for Health Care Administration. February 1996.
Pressure Ulcer Treatment; 1. The Care of Patients with Chronic Leg Ulcer, A National Clinical Guideline. Scottish Intercollegiate Guidelines Network, July 1998.; 2. Folkedahl B, Frantz R, Goode C. Research-Based Protocol: Treatment of Pressure Ulcers. The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1997.; 3. Lower Extremity Ulceration. American Society of Plastic and Reconstructive Surgeons, 1998.; 4. Mittman L, et al. Developing Quality and Utilization Review Criteria for Pressure Ulcers in Adults: Phase II Final Report, March 1995. RAND. PM-403-AHCPR.; 5. National Pressure Ulcer Advisory Panel. Minimum Data Set-2 (MDS-2) & Skin Ulcer Assessment, The NUPUAP Report. April 1996;4(3). www.npuap.org.; 6. National Pressure Ulcer Advisory Panel. NPUAP Statement on Reverse Staging of Pressure Ulcers, The NPUAP Report. September 1995;4(3). www.npuap.org.; 7. Pressure Sores. American Society of Plastic and Reconstructive Surgery, 1996.; 8. Pressure Ulcers Clinical Practice Guideline. American Medical Directors Association, 1996.; 9. Pressure Ulcer Therapy Companion. American Medical Directors Association, 1999.; 10. Stage I Assessment in Darkly Pigmented Skin. National Pressure Ulcer Advisory Panel, 1998. www.npuap.org.; 11. Venous Leg Ulcer Guideline. University of Pennsylvania, 1997.
Stroke and Post-Stroke Rehabilitation; 1. Adams HP. Guidelines for Thrombolytic Therapy for Acute Stroke: A Supplement to the Guidelines for the Management of Patients with Acute Ischemic Stroke, A Statement for Healthcare Professionals from a Special Writing Group of the Stroke Council, American Heart Association. Circulation. 1996:94:1167-1174.; 2. Biller J, et al. Guidelines for the Carotid Endarterectomy, A Statement for Healthcare Professionals From a Special Writing Group of the Stroke Council, American Heart Association, 1997. www.amhrt.org/Scientific/statements/1998/029801.html.; 3. Biller J, et al. American Heart Association Guidelines for Carotid Endardarectomy. A Statement for Healthcare Professionals from a Special Writing Group of the Stroke Council, American Heart Association. Circulation. 1998;97:501-509.; 4. Culebras A, et al. Practice Guidelines for the Use of Imaging in Transient Ischemic Attacks and Acute Stroke, A Report of the Stroke Council, American Heart Association. Stroke. 1997;28:1480-1497.; 5. Grundy SM, et al. Guide to Primary Prevention of CV Diseases, American Heart Association Medical/Scientific Statement. Circulation. 1997;95:2329-2331.; 6. Helgason CM and Wolf PA. AHA Medical/Scientific Statement: American Heart Association Prevention Conference IV: Prevention and Rehabilitation of Stroke, Circulation. 1997;96:701-707.; 7. Helgason CM, Wolf PA. American Heart Association Prevention Conference IV: Prevention and Rehabilitation of Stroke Executive Summary, Circulation. 1997;96:701-707.; 8. Hennekens CH, et al. Aspirin as a Therapeutic Agent in CV Disease, A Statement from Health Care Professionals from the American Heart Association. Circulation. 1997;96: 2751-2753.; 9. Kelly-Hayes M, Robertson JT, Broderick JP, et al. AHA Scientific Statement: The American Heart Association Stroke Outcome Classification, Stroke. 1998;29:1274-1280.; 10. Management of Patients with Stroke. I: Assessment, Investigation, Immediate Management and Secondary Prevention. A National Clinical Guideline Recommended for Use in Scotland by the Scottish Intercollegiate Guidelines Network, Scottish Intercollegiate Guidelines Network, Pilot Edition, May 1997.; 11. Management of Patients with Stroke. II: Management of Carotid Stenosis and Carotid Endarterectomy. A National Clinical Guideline Recommended for Use in Scotland by the Scottish Intercollegiate Guidelines Network, Scottish Intercollegiate Guidelines Network, Pilot Edition, May 1997.; 12. Management of Patients with Stroke. III: Identification and Management of Dysphagia. A National Clinical Guideline Recommended for Use in Scotland by the Scottish Intercollegiate Guidelines Network, Scottish Intercollegiate Guidelines Network, Pilot Edition, November 1997.; 13. Management of Patients with Stroke. IV: Rehabilitation, Prevention and Management of Complications, and Discharge Planning. A National Clinical Guideline Recommended for Use in Scotland by the Scottish Intercollegiate Guidelines Network, Scottish Intercollegiate Guidelines Network, Pilot Edition, April 1998.; 14. Practice Advisory: Thrombolytic Therapy for Acute Ischemic Stroke - Summary Statement, Neurology. 1996;47:835-839.; 15. Report of the Quality Standards Subcommittee of the American Academy of Neurology. Practice Advisory: Thrombolytic Therapy for Acute Ischemic Stroke - Summary Statement, Neurology. 1996;47:835-839.; 16. Screening for Asymptomatic Carotid Artery Stenosis. In: U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996.
Cardiac Rehabilitation; 1. Balady GJ, Fletcher BJ, Froelicher ES, et al. Cardiac Rehabilitation Programs: A Statement for Healthcare Professionals from the American Heart Association, 1994. www.americanheart.org/Scientific/statements/1994/099402.html.; 2. Coronary Artery Disease, Reference Guide, 6th Edition. Lexington, KY: American Board of Family Practice, 1997.; 3. Gibbons RJ, et al. AHA Medical/Scientific Statement. ACC/AHA Guidelines for Exercise Testing: Executive Summary and Full Report. A Report to the ACC/AHA Task Force on Practice Guidelines (Committee on Exercise Testing), J Am Coll Cardiol. 1997;30:260-315.; 4. Grundy SM, et al. Primary Prevention of Coronary Heart Disease: Guidance from Framingham, A Statement for Healthcare Professionals from the AHA Task Force on Risk Reduction. American Heart Association, July 1997. http://www.amhrt.org/Scientific/statements/1998/059801.html.; 5. Guidelines for Perioperative Cardiovascular Evaluation for Noncardiac Surgery. American Heart Association and American College of Cardiology, Circulation. 1996;93:1278-1317.; 6. Mosea L, et al. Cardiovascular Disease in Women. AHA Medical/Scientific Statement, Circulation. 1997;96:2468-2482. www.amhrt.org.; 7. Prystowsky EN, et al. Management of Patients with Atrial Fibrillation. A Statement for Healthcare Professionals from the Subcommittee on Electrocardiography and Electrophysiology, American Heart Association, October 19, 1995.; 8. Quality Improvement/Clinical Guidelines: Beta Blockers After Myocardial Infarction. Humana. www.humana.com/provider/guidelines/beta.html.; 9. Ryan TJ, et al. ACC/AHA Guidelines for the Management of Patients with Acute Myocardial Infarction, A Report of the ACC/AHA Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction). Circulation. 1996;94:2341-2350.
Early Alzheimer's Disease; 1. The American Academy of Neurology Ethics and Humanities Subcommittee. Ethical Issues in the Management of the Demented Patient, Neurology. 1996;46:1180-1183.; 2. American Psychiatric Association. Practice Guideline for the Treatment of Patients with Alzheimer's Disease and Other Dementias of Late Life. Washington, DC: American Psychiatric Press, Inc. 1996.; 3. American Psychological Association, Presidential Task Force on the Assessment of Age-Consistent Memory Decline and Dementia. Guidelines for the Evaluation of Dementia and Age-Related Cognitive Decline. American Psychological Association, February 1998.; 4. California Workgroup on Guidelines for Alzheimer's Disease Management. New Guidelines for Alzheimer's Disease Management, Medical Board of California Action Report. 1999;70:8-9.; 5. Dementia. American College of Radiology Appropriateness Criteria.; 6. Dementia Clinical Practice Guideline. Columbia, MD: American Medical Directors Association, 1998.; 7. Dementia Identification and Assessment: Guidelines for Primary Care Practitioners, U.S. Department of Veterans Affairs, Washington, DC and University HealthSystem Consortium, Oakbrook, IL, 1997.; 8. Eccles M, Clarke J, Livingstone M, et al. North of England Evidence Based Guidelines Development Project: Guideline for the Primary Care Management of Dementia. BMJ.1998;317:802-8.; 9. The Geriatric Patient, Reference Guide, 7th Edition. Lexington, KY: American Board of Family Practice, 1998, pp. 27-29.; 10. Guidelines for Alzheimer's Disease Management. Los Angeles Alzheimer's Association, January 1999.; 11. Hall GR. Research-Based Protocol: Alzheimer's Disease and Chronic Dementing Illnesses. The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1996.; 12. Hall GR and Buckwalter K. Research-Based Protocol: Bathing Persons with Dementia. The University of Iowa Gerontological Nursing Interventions Research Center, Research Development and Dissemination Core, 1996.; 13. Interventions in the Management of Behavioural and Psychological Aspects of Dementia: A National Clinical Guideline Recommended for Use in Scotland by the Scottish Intercollegiate Guidelines Network, Scottish Intercollegiate Guidelines Network, February 1998.; 14. Screening for Dementia. In: U.S. Preventive Services Task Force, Guide to Clinical Preventive Services, 2nd Edition. Alexandria, VA: International Medical Publishing, 1996.; 15. Use of Restraints for Patients in Nursing Homes, Report 4 of the Council of Scientific Affairs (A-97). American Medical Association, 1997.

## Analysis

The responses from the surveys were collated. The authors only considered seriously those responses where a guideline statement was judged as invalid if the expert who reviewed the statement supplied supporting evidence. When the supporting evidence was published references, these were retrieved and a physician trained in evidence-based medicine reviewed them to assess the influence of the new evidence on the validity of the guideline statement.

Two physicians trained in evidence-based medicine reviewed the evidence that the limited literature searches identified. They assessed whether any new evidence called into question the validity of the guideline statements or the need to create new guidelines statements.

The process described above identified evidence about the current validity of the individual statement within each guideline. In order to make a judgment about retaining or withdrawing the entire guideline, the authors reviewed all of the evidence for each entire guideline. Based on our judgements, the authors assigned the guidelines into one of the following categories:

- Withdraw. New evidence called into question one or more key diagnostic or therapeutic recommendations, or new evidence suggested the need for new key diagnostic or therapeutic guideline recommendations.
- Retain, append new evidence. All key diagnostic or therapeutic recommendations were still valid, but new evidence supported changes to other recommendations, or supported greater refinement of existing recommendations.
- Retain. The guideline continued to represent good clinical care.