# Appendix D. Acronyms and Abbreviations

ACE | Angiotensin-converting enzyme
AHCPR | Agency for Health Care Policy and Research
AHRQ | Agency for Healthcare Research and Quality
AOA | Administration on Aging
CDC | Centers for Disease Control and Prevention
CONQUEST | Computerized Needs-Oriented Quality Measurement Evaluation System
CPRO | formerly Connecticut Peer Review Organization
DEMPAQ | Develop and Evaluate Methods to Promote Ambulatory Care Quality
DHHS | Department of Health and Human Services
DVA | Department of Veterans' Affairs
FACCT | Foundation for Accountability
HCFA | Health Care Financing Administration
HEDIS | Health Plan Employer Data and Information Set
JCAHO | Joint Commission on Accreditation of Healthcare Organizations
NCQA | National Committee for Quality Assurance
NHS | National Health Service
NIH | National Institutes of Health
UK | United Kingdom