# Appendix C. Contributors

From the Southern California Evidence-based Practice Center

- Statistician
- Sally Morton, PhD

- Librarian
- Roberta Shanman, MLS

- Task Order Manager/ Staff Assistant
- Shannon Rhodes

- Medical Editor/ Research Assistant
- Rena Hasenfeld