# Appendix B. Excerpt of Survey Sent to Panel Members

This is a sample page from a longer document.

## INITIAL EVALUATION

### Diagnostic Testing

Practitioners should perform a chest x-ray; ECG; complete blood count (CBC); serum electrolytes, serum creatinine, serum albumin, liver function test; and urinalysis for all patients with suspected or clinically evident heart failure. A T4 and thyroid-stimulating hormone (TSH) level should also be checked in all patients over the age of 65 with heart failure and no obvious etiology and in patients who have atrial fibrillation or other signs or symptoms of thyroid disease.

#### Screening for Arrhythmias

Screening evaluation for arrhythmias, such as ambulatory electrocardiographic (Holter) recording, is not routinely warranted.

Patients with a history of syncope possible due to ventricular arrhythmias should be referred immediately to a practitioner with expertise in arrhythmias.

#### Atrial Fibrillation

Patients with left-atrial diameters of less than 50 mm and less than a 1-year history of atrial fibrillation should be cardioverted. Patients should be anticoagulated for 3 weeks before cardioversion.

Question 1: Are you aware of new evidence or developments in the field relevant to this guideline statement? | > [image] Yes > > [image] No | Is the new evidence or development of sufficient importance to invalidate the guideline statement? | > [image] Yes > > [image] No | Please list references ________________________ ________________________ ________________________
Question 2: Are there new guideline statements (within the boundaries of the original guideline) that should be present? | > [image] Yes > > [image] No | Please list content area/ references ________________________ ________________________ ________________________