# Appendixes

Appendix A. Questionnaire Sent to Panel Chair(s)

Appendix B. Excerpt of Survey Sent to Panel Members

Appendix C. Contributors

Appendix D. Acronyms and Abbreviations