# Acronyms Used in This Report

AHIMA | American Health Information Management Association
AHRQ | Agency for Healthcare Research and Quality
AIDS | Acquired Immune Deficiency Syndrome
AMI | Acute Myocardial Infarction
APR-DRG | All-Patient Refined-Diagnostic Related Group
CABG | Coronary Artery Bypass Graft
CC | Comorbidities or complications
CHF | Congestive Heart Failure
CMA | California Medical Association
CMS | Centers for Medicare and Medicaid Services
CNS | Central Nervous System
COPD | Chronic Obstruction Pulmonary Disease
CSP | Complications Screening Program
DNR | Do Not Resuscitate
DRG | Diagnostic Related Groups
DVT | Deep Vein Thrombosis
E-Codes | External cause-of-injury codes
EPC | Evidence-based Practice Center
HCUP | Healthcare Cost and Utilization Project
HIV | Human Immunodeficiency Virus
ICD-9-CM | International Classification of Diseases 9th Revision Clinical Modification
IV | Intravenous (catheter)
IVC | Intra Vena Cava
JCAHO | Joint Commission for the Accreditation of Healthcare Organizations
MDC | Major Diagnostic Categories
MSA | Metropolitan Statistical Area
MSX | Multivariate Signal Extraction
NCHS | National Center for Health Statistics
NIS | Nationwide Inpatient Sample
NQF | National Quality Forum
NQR | National Quality Report
NSQIP | National Surgical Quality Improvement Program (VA)
OB | Obstetric
OR | Operating Room
PE | Pulmonary Embolism
PO | Postoperative
PICC | Peripherally Inserted Central Catheter
PSI | Patient Safety Indicator
PTCA | Percutaneous Transluminal Coronary Angioplasty
QI | Quality Indicator
SID | State Inpatient Databases
VA | (Department of) Veterans Affairs
VBAC | Vaginal Birth After Cesarean
UCSF | University of California at San Francisco
UTI | Urinary Tract Infection