# References

1 Kohn L, Corrigan J, Donaldson M, Committee on Quality of Health Care in America IoM, editors. To Err Is Human: Building a Safer Health System. Washington, D.C.: National Academy Press; 1999.
2 Shojania KG, Duncan BW, McDonald KM, Wachter RM. Making Health Care Safer: A Critical Analysis of Patient Safety Practices. Evidence Report/Technology Assessment No. 43 (Prepared by the University of California at San Francisco-Stanford Evidence-based Practice Center under Contract No. 290-97-0013). Rockville, MD: Agency for Healthcare Research and Quality; 2001. Report No.: AHRQ Publication No. 01-E058.
3 Davies S, Geppert J, McClellan M, McDonald KM, Romano PS, Shojania KG. Refinement of the HCUP Quality Indicators. Technical Review Number 4. Rockville, MD: (Prepared by UCSF-Stanford Evidence-based Practic Center under Contract No. 290-97-0013) Agency for Healthcare Research and Quality; 2001. Report No.: 01-0035.
4 Measuring the Quality of Health Care: A statement of the National Roundtable on Healthcare Quality Division of Healthcare Services: National Academy Press; 1999.
5 Envisioning the National Health Care Quality Report. Washington D.C.: Institute of Medicine; 2001.
6 Brennan TA, Leape LL, Laird NM, Hebert L, Localio AR, Lawthers AG, et al. Incidence of adverse events and negligence in hospitalized patients. Results of the Harvard Medical Practice Study I. N Engl J Med. 1991;324(6):370-6. [pmid: 1987460].
7 Iezzoni LI, Foley SM, Heeren T, Daley J, Duncan CC, Fisher ES, et al. A method for screening the quality of hospital care using administrative data: preliminary validation results. QRB Qual Rev Bull. 1992;18(11):361-71. [pmid: 1465294].
8 EMBASE. In. The Netherlands: Elsevier Science Publishers B.V.
9 MEDLINE [database online]. In. Bethesda (MD): National Library of Medicine.
10 Iezzoni LI, Daley J, Heeren T, Foley SM, Fisher ES, Duncan C, et al. Identifying complications of care using administrative data. Med Care. 1994;32(7):700-15. [pmid: 8028405].
11 Iezzoni LI, Daley J, Heeren T, Foley SM, Hughes JS, Fisher ES, et al. Using administrative data to screen hospitals for high complication rates. Inquiry. 1994;31(1):40-55. [pmid: 8168908].
12 Kalish RL, Daley J, Duncan CC, Davis RB, Coffman GA, Iezzoni LI. Costs of potential complications of care for major surgery patients. Am J Med Qual. 1995;10(1):48-54. [pmid: 7727988].
13 Lawthers A, McCarthy E, Davis R, Peterson L, Palmer R, Iezzoni L. Identification of in-hospital complications from claims data: is it valid?. Medical Care. 2000;38(8):785-795. [pmid: 10929991].
14 McCarthy EP, Iezzoni LI, Davis RB, Palmer RH, Cahalane M, Hamel MB, et al. Does clinical evidence support ICD-9-CM diagnosis coding of complications?. Med Care. 2000;38(8):868-876. [pmid: 10929998].
15 Weingart SN, Iezzoni LI, Davis RB, Palmer RH, Cahalane M, Hamel MB, et al. Use of administrative data to find substandard care: validation of the complications screening program. Med Care. 2000;38(8):796-806. [pmid: 10929992].
16 Iezzoni LI, Davis RB, Palmer RH, Cahalane M, Hamel MB, Mukamal K, et al. Does the Complications Screening Program flag cases with process of care problems? Using explicit criteria to judge processes. Int J Qual Health Care. 1999;11(2):107-18. [pmid: 10442841].
17 Miller M, Elixhauser A, Zhan C, Meyer G. Patient Safety Indicators: Using Administrative Data to Identify Potential Patient Safety Concerns. Health Services Research. 2001;36(6 Part II):110-132. [pmid: 16148964]. [pmcid: 1383610].
18 Green L, Lewis F. Measurement and Evaluation in Health Education and Health Promotion. Mountain View, CA: Mayfield Publishing Company; 1998.
19 Fitch K, Bernstein SJ, Aguilar MD, Burnand B, LaCalle JR, Lazaro P, et al. The RAND/UCLA Appropriateness Method User's Manual.: RAND; 2001.
20 Campbell SM, Roland MO, Shekelle PG, Cantrill JA, Buetow SA, Cragg DK. Development of review criteria for assessing the quality of management of stable angina, adult asthma, and non-insulin dependent diabetes mellitus in general practice. Qual Health Care. 1999;8(1):6-15. [pmid: 10557672]. [pmcid: 2483627].
21 Campbell SM, Roland MO, Quayle JA, Buetow SA, Shekelle PG. Quality indicators for general practice: which ones can general practitioners and health authority managers agree are important and how useful are they?. J Public Health Med. 1998;20(4):414-21. [pmid: 9923948].
22 Sanderson C, Dixon J. Conditions for which onset or hospital admission is potentially preventable by timely and effective ambulatory care. J Health Serv Res Policy. 2000;5(4):222-30. [pmid: 11184959].
23 Hofer TP, Hayward RA, Greenfield S, Wagner EH, Kaplan SH, Manning WG. The unreliability of individual physician “report cards” for assessing the costs and quality of care of a chronic disease. JAMA. 1999;281(22):2098-105. [pmid: 10367820].
24 Christiansen CL, Morris CN. Improving the statistical approach to health care provider profiling. Ann Intern Med. 1997;127(8 Pt 2):764-8. [pmid: 9382395].
25 Thomas EJ, Orav EJ, Brennan TA. Hospital ownership and preventable adverse events. J Gen Intern Med. 2000;15(4):211-9. [pmid: 10759995]. [pmcid: 1495442].
26 Thomas EJ, Brennan TA. Incidence and types of preventable adverse events in elderly patients: population based review of medical records. BMJ. 2000;320(7237):741-4. [pmid: 10720355]. [pmcid: 27315].
27 Mills D, editor. Report on the Medical Insurance Feasibility Study. San Francisco, CA: California Medical Association; 1977.
28 Hiatt HH, Barnes BA, Brennan TA, Laird NM, Lawthers AG, Leape LL, et al. A study of medical injury and medical malpractice. N Engl J Med. 1989;321(7):480-4. [pmid: 2761585].
29 Andrews LB, Stocking C, Krizek T, Gottlieb L, Krizek C, Vargish T, et al. An alternative strategy for studying adverse events in medical care. Lancet. 1997;349(9048):309-13. [pmid: 9024373].
30 Rosen AK, Geraci JM, Ash AS, McNiff KJ, Moskowitz MA. Postoperative adverse events of common surgical procedures in the Medicare population. Med Care. 1992;30(9):753-65. [pmid: 1518309].
31 Silber JH, Williams SV, Krakauer H, Schwartz JS. Hospital and patient characteristics associated with death after surgery. A study of adverse occurrence and failure to rescue. Med Care. 1992;30(7):615-29. [pmid: 1614231].
32 Silber JH, Rosenbaum PR, Schwartz JS, Ross RN, Williams SV. Evaluation of the complication rate as a measure of quality of care in coronary artery bypass graft surgery. JAMA. 1995;274(4):317-23. [pmid: 7609261].
33 Rosen A, Ash A, McNiff K, Moskowitz M. The importance of severity of illness adjustment in predicting adverse outcomes in the Medicare population. J Clin Epidemiol. 1995;48:631-643. [pmid: 7730920].
34 Geraci JM, Ashton CM, Kuykendall DH, Johnson ML, Wu L. In-hospital complications among survivors of admission for congestive heart failure, chronic obstructive pulmonary disease, or diabetes mellitus. J Gen Intern Med. 1995;10(6):307-14. [pmid: 7562121].
35 Hartz AJ, Kuhn EM, Kayser KL, Pryor DP, Green R, Rimm AA. Assessing providers of coronary revascularization: a method for peer review organizations. Am J Public Health. 1992;82(12):1631-40. [pmid: 1456338]. [pmcid: 1694540].
36 Geraci JM, Ashton CM, Kuykendall DH, Johnson ML, Souchek J, del Junco D, et al. The association of quality of care and occurrence of in-hospital, treatment-related complications. Med Care. 1999;37(2):140-8. [pmid: 10024118].
37 Daley J, Khuri SF, Henderson W, Hur K, Gibbs JO, Barbour G, et al. Risk adjustment of the postoperative morbidity rate for the comparative assessment of the quality of surgical care: results of the National Veterans Affairs Surgical Risk Study. J Am Coll Surg. 1997;185(4):328-40. [pmid: 9328381].
38 Bates DW, Cullen DJ, Laird N, Petersen LA, Small SD, Servi D, et al. Incidence of adverse drug events and potential adverse drug events. Implications for prevention. ADE Prevention Study Group. Jama. 1995;274(1):29-34. [pmid: 7791255].
39 Classen DC, Pestotnik SL, Evans RS, Lloyd JF, Burke JP. Adverse drug events in hospitalized patients. Excess length of stay, extra costs, and attributable mortality [see comments]. Jama. 1997;277(4):301-6. [pmid: 9002492].
40 Mitchell JB, Ballard DJ, Whisnant JP, Ammering CJ, Matchar DB, Samsa GP. Using physician claims to identify postoperative complications of carotid endarterectomy. Health Serv Res. 1996;31(2):141-52. [pmid: 8675436]. [pmcid: 1070110].
41 Myers ER, Steege JF. Risk adjustment for complications of hysterectomy: limitations of routinely collected administrative data. Am J Obstet Gynecol. 1999;181(3):567-75. [pmid: 10486465].
42 Romano PS, Campa DR, Rainwater JA. Elective cervical discectomy in California: postoperative in-hospital complications and their risk factors. Spine. 1997;22(22):2677-92. [pmid: 9399456].
43 Ghali WA, Hall RE, Ash AS, Rosen AK, Moskowitz MA. Evaluation of complication rates after coronary artery bypass surgery using administrative data. Methods Inf Med. 1998;37(2):192-200. [pmid: 9656664].
44 Iezzoni LI, Heeren T, Foley SM, Daley J, Hughes J, Coffman GA. Chronic conditions and risk of in-hospital death. Health Serv Res. 1994;29(4):435-60. [pmid: 7928371]. [pmcid: 1070016].
45 DesHarnais SI, McMahon LF Jr, Wroblewski RT, Hogan AJ. Measuring hospital performance. The development and validation of risk-adjusted indexes of mortality, readmissions, and complications. Med Care. 1990;28(12):1127-41. [pmid: 2250497].
46 DesHarnais S, McMahon LF Jr, Wroblewski R. Measuring outcomes of hospital care using multiple risk-adjusted indexes. Health Serv Res. 1991;26(4):425-45. [pmid: 1917500]. [pmcid: 1069835].
47 Brailer DJ, Kroch E, Pauly MV, Huang J. Comorbidity-adjusted complication risk: a new outcome quality measure. Med Care. 1996;34(5):490-505. [pmid: 8614170].
48 DiPiro JT, Martindale RG, Bakst A, Vacani PF, Watson P, Miller MT. Infection in surgical patients: effects on mortality, hospitalization, and postdischarge care. Am J Health Syst Pharm. 1998;55(8):777-81. [pmid: 9568240].
49 HCIA-Sachs LLC. Hospital Compliance and DRG Upcoding. 2000.
50 100 Top Hospitals: Benchmarks for Success. Baltimore, MD: HCIA Sachs, LLC; 2000.
51 Keeler E, Kahn K, Bentow S. Assessing quality of care for hospitalized Medicare patients with hip fracture using coded diagnoses from the Medicare Provider Analysis and Review File. Springfield, VA: NTIS; 1991.
52 Brennan TA, Hebert LE, Laird NM, Lawthers A, Thorpe KE, Leape LL, et al. Hospital characteristics associated with adverse events and substandard care. JAMA. 1991;265(24):3265-9. [pmid: 2046108].
53 Allison J, Kiefe C, Weissman N, Person S, Rouscult M, Canto J, et al. Relationship of Hospital Teaching Status With Quality of Care and Mortality for Medicare Patients with Acute MI. JAMA. 2000;284(10):1256-1262. [pmid: 10979112].
54 Kahn KL, Rogers WH, Rubenstein LV, Sherwood MJ, Reinisch EJ, Keeler EB, et al. Measuring quality of care with explicit process criteria before and after implementation of the DRG-based prospective payment system. JAMA. 1990;264(15):1969-73. [pmid: 2120476].
55 Rubenstein LV, Kahn KL, Reinisch EJ, Sherwood MJ, Rogers WH, Kamberg C, et al. Changes in quality of care for five diseases measured by implicit review, 1981 to 1986. JAMA. 1990;264(15):1974-9. [pmid: 2214062].
56 Meehan TP, Fine MJ, Krumholz HM, Scinto JD, Galusha DH, Mockalis JT, et al. Quality of care, process, and outcomes in elderly patients with pneumonia. JAMA. 1997;278(23):2080-4. [pmid: 9403422].
57 Meehan TP, Hennen J, Radford MJ, Petrillo MK, Elstein P, Ballard DJ. Process and outcome of care for acute myocardial infarction among Medicare beneficiaries in Connecticut: a quality improvement demonstration project. Ann Intern Med. 1995;122(12):928-36. [pmid: 7755229].
58 Krumholz HM, Radford MJ, Wang Y, Chen J, Heiat A, Marciniak TA. National use and effectiveness of beta-blockers for the treatment of elderly patients after acute myocardial infarction: National Cooperative Cardiovascular Project [Published erratum appears in JAMA 1999;281(1):37]. JAMA 1998;280(7):623–9.
59 Krumholz HM, Radford MJ, Ellerbeck EF, Hennen J, Meehan TP, Petrillo M, et al. Aspirin in the treatment of acute myocardial infarction in elderly Medicare beneficiaries. Patterns of use and outcomes. Circulation. 1995;92(10):2841-7. [pmid: 7586250].
60 Daley J, Forbes MG, Young GJ, Charns MP, Gibbs JO, Hur K, et al. Validating risk-adjusted surgical outcomes: site visit assessment of process and structure. National VA Surgical Risk Study. J Am Coll Surg. 1997;185(4):341-51. [pmid: 9328382].
61 Krumholz HM, Rathore SS, Chen J, Wang Y, Radford MJ. Evaluation of a consumer-oriented internet health care report card: the risk of quality ratings based on mortality data. Jama. 2002;287(10):1277-87. [pmid: 11886319].
62 Thomas JW, Holloway JJ, Guire KE. Validating risk-adjusted mortality as an indicator for quality of care. Inquiry. 1993;30(1):6-22. [pmid: 8454316].
63 Ashton CM, Kuykendall DH, Johnson ML, Wray NP, Wu L. The association between the quality of inpatient care and early readmission. Ann Intern Med. 1995;122(6):415-21. [pmid: 7856989].
64 Benbassat J, Taragin M. Hospital readmissions as a measure of quality of health care: advantages and limitations. Arch Intern Med. 2000;160(8):1074-81. [pmid: 10789599].
65 Weissman JS, Ayanian JZ, Chasan-Taber S, Sherwood MJ, Roth C, Epstein AM. Hospital readmissions and quality of care. Med Care. 1999;37(5):490-501. [pmid: 10335751].
66 Hartz AJ, Kuhn EM. Comparing hospitals that perform coronary artery bypass surgery: the effect of outcome measures and data sources. Am J Public Health. 1994;84(10):1609-14. [pmid: 7943479]. [pmcid: 1615096].
67 Hartz AJ, Kuhn EM, Pryor DB, Krakauer H, Young M, Heudebert G, et al. Mortality after coronary angioplasty and coronary artery bypass surgery (the national Medicare experience). Am J Cardiol. 1992;70(2):179-85. [pmid: 1626504].
68 Silber J, Rosenbaum P, Ross R. Comparing the contributions of groups of predictors: Which outcomes vary with hospital rather than patient characteristics?. J Am Stat Assoc. 1995;90:7-18.
69 Silber JH, Rosenbaum PR. A spurious correlation between hospital mortality and complication rates: the importance of severity adjustment. Med Care. 1997;35(10 Suppl):OS77-92. [pmid: 9339779].
70 Khuri S, Najjar S, Daley J, Krasnicka B, Hossain M, Henderson W, et al. Comparison of Surgical Outcomes Between Teaching and Nonteaching Hospitals in the Department of Veterans Affairs. Annals of Surgery. 2001;234(3):370-383. [pmid: 11524590]. [pmcid: 1422028].
71 Goldman L, Caldera DL, Nussbaum SR, Southwick FS, Krogstad D, Murray B, et al. Multifactorial index of cardiac risk in noncardiac surgical procedures. N Engl J Med. 1977;297(16):845-50. [pmid: 904659].
72 Detsky AS, Abrams HB, Forbath N, Scott JG, Hilliard JR. Cardiac assessment for patients undergoing noncardiac surgery. A multifactorial clinical risk index. Arch Intern Med. 1986;146(11):2131-4. [pmid: 3778043].
73 Wong T, Detsky AS. Preoperative cardiac risk assessment for patients having peripheral vascular surgery. Ann Intern Med. 1992;116(9):743-53. [pmid: 1558348].
74 Forrest JB, Rehder K, Cahalan MK, Goldsmith CH. Multicenter study of general anesthesia. III. Predictors of severe perioperative adverse outcomes. Anesthesiology. 1992;76(1):3-15. [pmid: 1729933].
75 Klotz HP, Candinas D, Platz A, Horvath A, Dindo D, Schlumpf R, et al. Preoperative risk assessment in elective general surgery. Br J Surg. 1996;83(12):1788-91. [pmid: 9038571].
76 Smetana GW. Preoperative pulmonary evaluation. N Engl J Med. 1999;340(12):937-44. [pmid: 10089188].
77 Lee TH, Marcantonio ER, Mangione CM, Thomas EJ, Polanczyk CA, Cook EF, et al. Derivation and prospective validation of a simple index for prediction of cardiac risk of major noncardiac surgery [In Process Citation]. Circulation. 1999;100(10):1043-9. [pmid: 10477528].
78 Keita-Perse O, Gaynes RP. Severity of illness scoring systems to adjust nosocomial infection rates: a review and commentary. Am J Infect Control. 1996;24(6):429-34. [pmid: 8974168].
79 Magovern JA, Sakert T, Magovern GJ, Benckart DH, Burkholder JA, Liebler GA, et al. A model that predicts morbidity and mortality after coronary artery bypass graft surgery. J Am Coll Cardiol. 1996;28(5):1147-53. [pmid: 8890808].
80 Brook RH, Park RE, Chassin MR, Kosecoff J, Keesey J, Solomon DH. Carotid endarterectomy for elderly patients: predicting complications. Ann Intern Med. 1990;113(10):747-53. [pmid: 2240877].
81 Goldstein LB, McCrory DC, Landsman PB, Samsa GP, Ancukiewicz M, Oddone EZ, et al. Multicenter review of preoperative risk factors for carotid endarterectomy in patients with ipsilateral symptoms. Stroke. 1994;25(6):1116-21. [pmid: 8202967].
82 McCrory DC, Goldstein LB, Samsa GP, Oddone EZ, Landsman PB, Moore WS, et al. Predicting complications of carotid endarterectomy. Stroke. 1993;24(9):1285-91. [pmid: 8362419].
83 Musser DJ, Nicholas GG, Reed JF 3rd. Death and adverse cardiac events after carotid endarterectomy. J Vasc Surg. 1994;19(4):615-22. [pmid: 8164276].
84 Block PC, Peterson ED, Krone R, Kesler K, Hannan E, O'Connor GT, et al. Identification of variables needed to risk adjust outcomes of coronary interventions: evidence-based guidelines for efficient data collection. J Am Coll Cardiol. 1998;32(1):275-82. [pmid: 9669281].
85 Hannan EL, Kilburn H Jr, Lindsey ML, Lewis R. Clinical versus administrative data bases for CABG surgery. Does it matter?. Med Care. 1992;30(10):892-907. [pmid: 1405795].
86 Hannan EL, Racz MJ, Jollis JG, Peterson ED. Using Medicare claims data to assess provider quality for CABG surgery: does it work well enough?. Health Serv Res. 1997;31(6):659-78. [pmid: 9018210]. [pmcid: 1070152].
87 Pine M, Norusis M, Jones B, Rosenthal GE. Predictions of hospital mortality rates: a comparison of data sources. Ann Intern Med. 1997;126(5):347-54. [pmid: 9054278].
88 Pine M, al e. International Journal for Quality in Health Care 1998;10(6):491–501.
89 Smith DW, Pine M, Bailey RC, Jones B, Brewster A, Krakauer H. Using clinical variables to estimate the risk of patient mortality. Med Care. 1991;29(11):1108-29. [pmid: 1943271].
90 Green J, Wintfeld N, Sharkey P, Passman LJ. The importance of severity of illness in assessing hospital mortality. JAMA. 1990;263(2):241-6. [pmid: 2403601].
91 Hartz AJ, Guse C, Sigmann P, Krakauer H, Goldman RS, Hagen TC. Severity of illness measures derived from the Uniform Clinical Data Set (UCDSS). Med Care. 1994;32(9):881-901. [pmid: 8090042].
92 Coding Clinic for ICD-9-CM 1990;7(2):24.
93 Romano P. Can Administrative Data be Used to Ascertain Clinically Significant Postoperative Complications. American Journal of Medical Quality Press.
94 Clagett GP, Anderson FA Jr, Geerts W, Heit JA, Knudson M, Lieberman JR, et al. Prevention of venous thromboembolism. Chest. 1998;114(5 Suppl):531S-560S. [pmid: 9822062].
95 Hooker JA, Lachiewicz PF, Kelley SS. Efficacy of prophylaxis against thromboembolism with intermittent pneumatic compression after primary and revision total hip arthroplasty. J Bone Joint Surg Am. 1999;81(5):690-6. [pmid: 10360697].
96 Maxwell GL, Myers ER, Clarke-Pearson DL. Cost-effectiveness of deep venous thrombosis prophylaxis in gynecologic oncology surgery. Obstet Gynecol. 2000;95(2):206-14. [pmid: 10674581].
97 O'Brien BJ, Anderson DR, Goeree R. Cost-effectiveness of enoxaparin versus warfarin prophylaxis against deep-vein thrombosis after total hip replacement. CMAJ. 1994;150(7):1083-90. [pmid: 8137188]. [pmcid: 1486381].
98 Palmer AJ, Koppenhagen K, Kirchhof B, Weber U, Bergemann R. Efficacy and safety of low molecular weight heparin, unfractionated heparin and warfarin for thrombo-embolism prophylaxis in orthopaedic surgery: a meta-analysis of randomised clinical trials. Haemostasis. 1997;27(2):75-84. [pmid: 9212355].
99 Koch A, Bouges S, Ziegler S, Dinkel H, Daures JP, Victor N. Low molecular weight heparin and unfractionated heparin in thrombosis prophylaxis after major surgical intervention: update of previous meta-analyses. Br J Surg. 1997;84(6):750-9. [pmid: 9189079].
100 Morrison RS, Chassin MR, Siu AL. The medical consultant's role in caring for patients with hip fracture. Ann Intern Med 1998;128(12 Pt 1):1010–20. Published erratum appears in Ann Intern Med 1998;129(9):755.
101 Planes A, Vochelle N, Fafola M. Venous thromboembolic prophylaxis in orthopedic surgery: knee surgery. Semin Thromb Hemost. 1999;25(Suppl 3):73-7. [pmid: 10549719].
102 Lassen MR, Backs S, Borris LC, Kaltoft-Sorenson M, Coff-Ganes H, Jeppesen E. Deep-vein thrombosis prophylaxis in orthopedic surgery: hip surgery. Semin Thromb Hemost. 1999;25(Suppl 3):79-82. [pmid: 10549720].
103 Barker FG 2nd. Efficacy of prophylactic antibiotics for craniotomy: a meta-analysis. Neurosurgery. 1994;35(3):484-92. [pmid: 7646627].
104 Tanos V, Rojansky N. Prophylactic antibiotics in abdominal hysterectomy. J Am Coll Surg. 1994;179(5):593-600. [pmid: 7952465].
105 Waddell TK, Rotstein OD. Antimicrobial prophylaxis in surgery. Committee on Antimicrobial Agents, Canadian Infectious Disease Society. CMAJ. 1994;151(7):925-31. [pmid: 7922928]. [pmcid: 1337278].
106 Deacon JM, Pagliaro AJ, Zelicof SB, Horowitz HW. Prophylactic use of antibiotics for procedures after total joint replacement. J Bone Joint Surg Am. 1996;78(11):1755-70. [pmid: 8934495].
107 Sawaya GF, Grady D, Kerlikowske K, Grimes DA. Antibiotics at the time of induced abortion: the case for universal prophylaxis based on a meta-analysis. Obstet Gynecol. 1996;87(5 Pt 2):884-90. [pmid: 8677129].
108 Song F, Glenny AM. Antimicrobial prophylaxis in colorectal surgery: a systematic review of randomized controlled trials. Br J Surg 1998;85(9):1232–41. Published erratum appears in Br J Surg 1999;86(2):280.
109 Gillespie WJ, Walenkamp G. Antibiotic prophylaxis for surgery for proximal femoral and other closed long bone fractures (Cochrane Review). In: The Cochrane Library, Issue 2, 2000. Oxford: Update Software; 2000.
110 Smaill F, Hofmeyr GJ. Antibiotic prophylaxis for cesarean section (Cochrane Review). In: The Cochrane Library, Issue 2. Oxford: Update Software.; 2000.
111 Perioperative total parenteral nutrition in surgical patients. The Veterans Affairs Total Parenteral Nutrition Cooperative Study Group. N Engl J Med 1991;325(8):525–32.
112 Campos AC, Meguid MM. A critical appraisal of the usefulness of perioperative nutritional support. Am J Clin Nutr. 1992;55(1):117-30. [pmid: 1728811].
113 Bastow MD, Rawlings J, Allison SP. Benefits of supplementary tube feeding after fractured neck of femur: a randomised controlled trial. Br Med J (Clin Res Ed). 1983;287(6405):1589-92.
114 Ferguson TB Jr, Coombs LP, Peterson ED. Preoperative beta-blocker use and mortality and morbidity following CABG surgery in North America. Jama. 2002;287(17):2221-7. [pmid: 11980522].
116 Mangano DT, Layug EL, Wallace A, Tateo I. Effect of atenolol on mortality and cardiovascular morbidity after noncardiac surgery. Multicenter Study of Perioperative Ischemia Research Group [published erratum appears in N Engl J Med 1997 Apr 3;336(14):1039]. N Engl J Med 1996;335(23):1713–20.
116 Poldermans D, Boersma E, Bax JJ, Thomson IR, van de Ven LL, Blankensteijn JD, et al. The effect of bisoprolol on perioperative mortality and myocardial infarction in high-risk patients undergoing vascular surgery. Dutch Echocardiographic Cardiac Risk Evaluation Applying Stress Echocardiography Study Group. N Engl J Med. 1999;341(24):1789-94. [pmid: 10588963].
117 Bertrand M, Legrand V, Boland J, al. e. Randomized multicenter comparison of conventional anticoagulation versus antiplatelet therapy in unplanned and elective coronary stenting: the Full Anticoagulation Versus Aspirin and Ticlopidine (FANTASTIC) Study. Circulation 1998;98:1597–1603.
118 Leon M, Baim D, Popma J, al. e. A clinical trial comparing three anti-thrombotic regimens following coronary artery stenting. N Engl J Med. 1998;339:1665–1671.
119 Ashton CM, Kuykendall DH, Johnson ML, Wray NP. An empirical assessment of the validity of explicit and implicit process-of-care criteria for quality assessment. Med Care. 1999;37(8):798-808. [pmid: 10448722].
120 Camacho LA, Rubin HR. Assessment of the validity and reliability of three systems of medical record screening for quality of care assessment. Med Care. 1998;36(5):748-51. [pmid: 9596065].
121 Gibbs J, Clark K, Khuri S, Henderson W, Hur K, Daley J. Validating risk-adjusted surgical outcomes: chart review of process of care. Int J Qual Health Care. 2001;13(3):187-96. [pmid: 11476143].
122 Dubois RW, Rogers WH, Moxley JHD, Draper D, Brook RH. Hospital inpatient mortality. Is it a predictor of quality?. N Engl J Med. 1987;317(26):1674-80. [pmid: 3683509].
123 Bates DW, O'Neil AC, Petersen LA, Lee TH, Brennan TA. Evaluation of screening criteria for adverse events in medical patients. Med Care. 1995;33(5):452-62. [pmid: 7739271].
124 Thomas EJ, Studdert DM, Brennan TA. The reliability of medical record review for estimating adverse event rates. Ann Intern Med. 2002;136(11):812-6. [pmid: 12044129].
125 Hofer TP, Bernstein SJ, DeMonner S, Hayward RA. Discussion between reviewers does not improve reliability of peer review of hospital quality. Med Care. 2000;38(2):152-61. [pmid: 10659689].
126 Kovner C, Gergen PJ. Nurse staffing levels and adverse events following surgery in U.S. hospitals. Image J Nurs Sch. 1998;30(4):315-21. [pmid: 9866290].
127 Ritchie JL, Phillips KA, Luft HS. Coronary angioplasty. Statewide experience in California. Circulation. 1993;88(6):2735-43. [pmid: 8252686].
128 Ritchie JL, Maynard C, Chapko MK, Every NR, Martin DC. Association between percutaneous transluminal coronary angioplasty volumes and outcomes in the Healthcare Cost and Utilization Project 1993-1994. Am J Cardiol. 1999;83(4):493-7. [pmid: 10073849].
129 Ho V. Evolution of the volume-outcome relation for hospitals performing coronary angioplasty. Circulation. 2000;101(15):1806-11. [pmid: 10769281].
130 Maynard C, Every NR, Chapko MK, Ritchie JL. Institutional volumes and coronary angioplasty outcomes before and after the introduction of stenting. Eff Clin Pract. 1999;2(3):108-13. [pmid: 10538258].
131 Jollis JG, Peterson ED, DeLong ER, Mark DB, Collins SR, Muhlbaier LH, et al. The relation between the volume of coronary angioplasty procedures at hospitals treating Medicare beneficiaries and short-term mortality. N Engl J Med. 1994;331(24):1625-9. [pmid: 7969344].
132 Jollis JG, Peterson ED, Nelson CL, Stafford JA, DeLong ER, Muhlbaier LH, et al. Relationship between physician and hospital coronary angioplasty volume and outcome in elderly patients. Circulation. 1997;95(11):2485-91. [pmid: 9184578].
133 Hannan EL, Racz M, Ryan TJ, McCallister BD, Johnson LW, Arani DT, et al. Coronary angioplasty volume-outcome relationships for hospitals and cardiologists. JAMA. 1997;277(11):892-8. [pmid: 9062327].
134 McGrath PD, Wennberg DE, Malenka DJ, Kellett MA Jr, Ryan TJ Jr, JR OM, et al. Operator volume and outcomes in 12,998 percutaneous coronary interventions. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. 1998;31(3):570-6. [pmid: 9502637].
135 McGrath PD, Wennberg DE, Dickens JD Jr, Siewers AE, Lucas FL, Malenka DJ, et al. Relation between operator and hospital volume and outcomes following percutaneous coronary interventions in the era of the coronary stent. Jama. 2000;284(24):3139-44. [pmid: 11135777].
136 Cebul RD, Snow RJ, Pine R, Hertzer NR, Norris DG. Indications, outcomes, and provider volumes for carotid endarterectomy. JAMA. 1998;279(16):1282-7. [pmid: 9565009].
137 Needleman J, Buerhaus PI, Mattke S, Stewart M, Zelevinsky K. Nurse Staffing and Patient Outcomes in Hospitals. Boston, MA: Health Resources Services Administration; 2001 February 28. Report No.: 230-99-0021.
138 Lichtig LK, Knauf RA, Milholland DK. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. 1999;29(2):25-33. [pmid: 10029799].
139 Hannan EL, Bernard HR, O'Donnell JF, Kilburn H Jr. A methodology for targeting hospital cases for quality of care record reviews. Am J Public Health. 1989;79(4):430-6. [pmid: 2494893]. [pmcid: 1349969].
140 Nursing-Sensitive Quality Indicators for Acute Care Settings and ANA's Safety & Quality Initiative. In: American Nurses Association; 1999.
141 Geraci JM, Ashton CM, Kuykendall DH, Johnson ML, Wu L. International Classification of Diseases, 9th Revision, Clinical Modification codes in discharge abstracts are poor measures of complication occurrence in medical inpatients. Med Care. 1997;35(6):589-602. [pmid: 9191704].
142 Berlowitz D, Brand H, Perkins C. Geriatric Syndromes as Outcome Measures of Hospital Care: Can Administrative Data Be Used?. JAGS. 1999;47:692-696.
143 Silber JH, Rosenbaum PR, Williams SV, Ross RN, Schwartz JS. The relationship between choice of outcome measure and hospital rank in general surgical procedures: implications for quality assessment. Int J Qual Health Care. 1997;9(3):193-200. [pmid: 9209916].
144 Johantgen M, Elixhauser A, Bali JK, Goldfarb M, Harris DR. Quality indicators using hospital discharge data: state and national applications. Jt Comm J Qual Improv 1998;24(2):88–105. Published erratum appears in Jt Comm J Qual Improv 1998;24(6):341.
145 Iezzoni L, Lawthers A, Petersen L, McCarthy E, Palmer R, Cahalane M, et al. Project to validate the Complications Screening Program: Health Care Financing Administration; 1998 March 31. Report No.: HCFA Contract 500-94-0055.
146 Hawker GA, Coyte PC, Wright JG, Paul JE, Bombardier C. Accuracy of administrative data for assessing outcomes after knee replacement surgery. J Clin Epidemiol. 1997;50(3):265-73. [pmid: 9120525].
147 Faciszewski T, Johnson L, Noren C, Smith MD. Administrative databases' complication coding in anterior spinal fusion procedures. What does it mean?. Spine. 1995;20(16):1783-8. [pmid: 7502134].
148 Best W, Khuri S, Phelan M, Hur K, Henderson W, Demakis J, et al. Identifying Patient Preoperative Risk Factors and Postoperative Adverse Events in Administrative Databases: Results from the Department of Veterans Affairs National Surgical Quality Improvement Program. J Am Coll Surg. 2002;194(3):257-266. [pmid: 11893128].
149 Dicker R, Han L, Macone J. Quality of Care Surveillance Using Administrative Data, 1996. In: Quality Resume No. 2. Baltimore, MD: HCFA; 1998.
150 White RH, Romano PS, Zhou H, Rodrigo J, Bargar W. Incidence and time course of thromboembolic outcomes following total hip or knee arthroplasty. Arch Intern Med. 1998;158(14):1525-31. [pmid: 9679793].
151 Barbour GL. Usefulness of a discharge diagnosis of sepsis in detecting iatrogenic infection and quality of care problems. Am J Med Qual. 1993;8(1):2-5. [pmid: 8334375].
152 Massanari RM, Wilkerson K, Streed SA, Hierholzer WJ Jr. Reliability of reporting nosocomial infections in the discharge abstract and implications for receipt of revenues under prospective reimbursement. Am J Public Health. 1987;77(5):561-4. [pmid: 3105338]. [pmcid: 1647025].
153 Belio-Blasco C, Torres-Fernandez-Gil MA, Echeverria-Echarri JL, Gomez-Lopez LI. Evaluation of two retrospective active surveillance methods for the detection of nosocomial infection in surgical patients. Infect Control Hosp Epidemiol. 2000;21(1):24-7. [pmid: 10656350].
154 Taylor B. Common bile duct injury during laparoscopic cholecystectomy in Ontario: does ICD-9 coding indicate true incidence?. CMAJ. 1998;158(4):481-5. [pmid: 9627560]. [pmcid: 1228921].
155 Valinsky LJ, Hockey RL, Hobbs MS, Fletcher DR, Pikora TJ, Parsons RW, et al. Finding bile duct injuries using record linkage: a validated study of complications following cholecystectomy. J Clin Epidemiol. 1999;52(9):893-901. [pmid: 10529030].
156 Hughes C, Harley E, Milmoe G, Bala R, Martorella A. Birth trauma in the head and neck. Arch Otolaryngol Head Neck Surg. 1999;125:193-199. [pmid: 10037286].
157 Towner D, Castro MA, Eby-Wilkens E, Gilbert WM. Effect of mode of delivery in nulliparous women on neonatal intracranial injury. N Engl J Med. 1999;341(23):1709-14. [pmid: 10580069].
158 Handa VL, Danielsen BH, Gilbert WM. Obstetric anal sphincter lacerations. Obstet Gynecol. 2001;98(2):225-30. [pmid: 11506837].
159 Needleman J, Buerhaus P, Mattke S, Stewart M, Zelevinsky K. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. 2002;346(22):1715-22. [pmid: 12037152].
160 Malenka DJ, McGrath PD, Wennberg DE, Ryan TJ Jr, Kellett MA Jr, Shubrooks SJ Jr, et al. The relationship between operator volume and outcomes after percutaneous coronary interventions in high volume hospitals in 1994-1996: the northern New England experience. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. 1999;34(5):1471-80. [pmid: 10551694].
161 Fisher ES, Whaley FS, Krushat WM, Malenka DJ, Fleming C, Baron JA, et al. The accuracy of Medicare's hospital claims data: progress has been made, but problems remain. Am J Public Health. 1992;82(2):243-8. [pmid: 1739155]. [pmcid: 1694279].
162 Weiss J, Nannini A, Fogerty S, al e. Use of hospital discharge data to monitor uterine rupture - Massachusetts, 1990-1997. MMWR 2000;49(12):245–248.
163 Romano P. Unpublished report to the California Office of Statewide Health Planning and Development; 2001 March.
164 Lydon-Rochelle M, Holt V, Easterling T, Martin D. Risk of uterine rupture during labor among women with a prior cesarean delivery. N Engl J Med. 2001;345:3-8. [pmid: 11439945].
165 Gregory KD, Korst LM, Cane P, Platt LD, Kahn K. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-9. [pmid: 10576187].
166 Coding Clinic for ICD-9-CM 1990;7(3):13.
167 Kroll DA, Caplan RA, Posner K, Ward RJ, Cheney FW. Nerve injury associated with anesthesia. Anesthesiology. 1990;73(2):202-7. [pmid: 2382845].
168 Serious Reportable Events in Healthcare. Consensus Report. Washington D.C.: National Forum for Health Care Quality Measurement and Reporting; 2002.