# Acknowledgments

The investigators would like to acknowledge the following individuals and organizations for their aid in this report: Doug Staiger, Dept. of Economics, Dartmouth College for his help in developing statistical methods; Ros McNally, National Primary Care Research and Development Centre, University of Manchester, who aided in the EMBASE^®^ literature search; American Health Information Management Association for providing ICD-9-CM coding expertise; the various professional organizations listed in this report and their staff for submitting nominations for the clinical review panels; the clinical panelists, listed in Appendix B. The investigators also acknowledge the contributions of Anne Elixhauser, Ph.D., and Marlene Miller, M.D., M.Sc., Agency for Healthcare Research and Quality (AHRQ), and Margaret Coopey, R.N., M.G.A., M.S.A., AHRQ Task Order Officer.