# Conclusions

This project took a four pronged approach to the identification, development and evaluation of PSIs. First, literature was reviewed for general background about patient safety measures that are or could be specified from administrative data. Second, a diverse group of clinicians assessed the face validity of potential PSIs, using an adaptation of the RAND/UCLA Appropriateness methods. Third, professionals who abstract the medical records to assign ICD-9-CM codes and other resources on coding were consulted for specific concerns about whether the intent of an indicator could be implemented well based on current coding guidelines. Finally, the most promising measures were statistically analyzed using routinely collected discharge data from hospitals in order to determine rates, examine effects of risk and reliability adjustments, and to make comparisons among the indicators.

When examining the results of this report, it is useful to return to the original framework in which two types of potential indicators were discussed. The first type of indicator is that which is likely to reflect medical error. These indicators are difficult to define using administrative data. Few adverse events are clear cut enough for this designation, with most having a variety of causes in addition to potential medical error leading to the adverse event, including underlying patient health and factors that do not vary systematically. As expected, physician panelists rated few indicators as very likely to reflect medical error. Six indicators were rated as such by most panelists: “Decubitus ulcer,” “Iatrogenic pneumothorax,” “Transfusion reaction,” “Complications of anesthesia,” “Foreign body accidentally left during procedure,” and “In-hospital fracture.” However, two of these indicators could not be defined using administrative data exactly as the panel specified in order to reduce contamination with less preventable complications (“Iatrogenic pneumothorax,” and “In-hospital fracture”), and two suffer from serious concerns regarding coding, presence on admission and heterogeneous severity included within the code (“Decubitus ulcer” and “Complications of anesthesia”). Thus, only two indicators remained that could be defined as “most likely to reflect medical error,” those being “Transfusion reaction” and “Foreign body left in during a procedure.” As is expected for indicators of this type, these indicators proved to be very rare with less than 1 per 10,000 cases at risk. Application of statistical tests of precision was limited by the fact that these indicators had no systematic variation. This confirms that these indicators are best used as case-finding indicators, or as area indicators to examine prevalence of these errors, as the rates of these indicators are mostly driven by non-systematic variation.

All other indicators that were rated as acceptable by panelists, fall into that more broad category of indicators which do not clearly identify medical error, but may reflect some quality concerns, including a potential for medical error. In general these indicators fall somewhere on a spectrum of preventability, with not every case being avoidable given optimal quality of care. Some indicators have a higher degree of preventability than others, but factors such as provider case mix and non-systematic variation may influence the overall preventability inherent in an indicator. For this reason it is impossible to “rank” these indicators as “more likely to reflect medical error” to “less likely to reflect medical error”, although panelists' ratings of preventability may provide some guidance from one source of face validity. In addition, the source of “error” may vary by provider and over time, reinforcing the screening use of these indicators - some may be primarily caused by human error and others by system problems. Because of these variations within each indicator, a single case “flagged” by any of these indicators may or may not have been preventable through optimal care, and thus these indicators are less efficient as case finding tools.

Despite the relative difficulty of these indicators in identifying specific cases where medical error may have occured, they can be rather useful when examining rates of events. Inasmuch as rates are somewhat stable over time and represent systematic differences, these differences are likely to reflect true differences in the occurrence of a complication in patient populations. Individual complexities of each case influence the overall rate of a complication much less than the specific outcome for that case, and thus, non-systematic differences in patient complexity are more likely to be “washed out.” Systematic differences due to causes besides true quality problems (e.g., case mix or coding practices) remain a concern for these indicators, as such bias may cause good quality providers to appear poor. Adequate risk adjustment, or refraining from comparing dissimilar providers would aid in this problem, but perfect methods are unlikely even with the best of data. In addition, while these indicators demonstrated some systematic variation, much of the variation between providers remains at the discharge level. This means that small differences between providers, even with perfect risk adjustment, may not actually reflect true differences in performance for these indicators. However, larger differences and differences that persist over time are more likely to reflect true differences, and are useful in identifying probable areas of concern for further investigation. Simply put, because of the nature of these indicators, they should not be used as a metric of absolute performance (e.g., for grading of providers or public reporting that compares providers). However, these indicators may be particularly useful as a low cost screen for potential quality and safety problems. Where a provider has a higher rate for a particular indicator than a benchmark, an extraction of additional information on the patients flagged by the indicator would likely lead to either of two positive outcomes - 1.) reassurance that there is not a quality problem, but a data gathering inadequacy that perhaps could be improved at the local or national level to improve the ability to detect quality problems, or 2.) identification of the source of the high rate that requires improvement in processes or systems of care, which would benefit the quality of care for future patients.

During the course of the study, it became apparent that the obstetric indicators should be viewed differently than the other non-obstetric indicators. In general, these indicators had a higher rate, more variation, and thus higher precision. Risk adjustment available for these indicators was minimal, and thus, systematic bias related to case mix could not be assessed. Finally, examination of the panel results and comparison of decisions made by non-obstetric panels with those made by the obstetric panels suggested that the obstetric indicators included complications expressly rejected by the other panels. The complications may have less association with medical error or process failures, although this assertion cannot be verified with this study.

For the best-performing subset of PSIs, this project has demonstrated that rates of adverse events differs substantially and significantly across hospitals. The literature review and the findings from the clinical panels provide evidence to suggest that a number of discharge-based PSIs may be useful screens for organizations, purchasers, and policymakers to identify potential safety problems at the hospital level, as well as to document systematic area level differences in potential patient safety problems.

## Potential Uses of PSIs

At the national or state level, these indicators could be used to monitor the frequency of potential patient safety problems, to determine whether the rates are increasing or decreasing over time, and to explore large variations among settings of care. As noted by panelists, not all indicators are equally poised to identify potential patient safety problems. This report was intended to provide evidence on the development and face validity of these indicators, and the evidence available does not allow for fine tuned classifications of indicators which are very likely to detect patient safety problems from those that are less likely. Future research will provide additional evidence that will inform the best uses of these indicators.

While the indicators were primarily developed at the hospital level, some were also implemented to provide an analogous area level measure, and analyses show that additional cases are in fact identified that correspond to care received at one institution, and the potentially iatrogenic complication addressed in another hospital. Clearly, the locus of control and the ability to study the potential underlying causes for an adverse event is simpler in the case of the hospital level PSIs. However, trends over time in area rates, as well as aggregations of the hospital level rates are likely to reveal points of leverage outside of individual institutions. No measure is ideally suited to every purpose. Methods of aggregating across groups of PSIs still need to be tested. This report provides the background for “safe” use of a tool that has the potential to guide prevention of medical error, reductions of potentially preventable complications, and quality improvement in general. Table 20 summarizes additional information on uses of the PSIs.

Table 20 Use of Patient Safety Indicators

User | Inappropriate Use Scenario | Appropriate Use Scenario | Potential Uses
Case-finding indicators
Provider | A hospital uses the transfusion reaction indicator to punish a physician involved in the incident. | A hospital identifies a case of transfusion reaction occurring in-hospital. They undertake a root-cause analysis to highlight potential problems that may be resolved in order to prevent future events. | Identification of events for further investigation.
| PROBLEM: Flagging of the case does not necessarily guarantee that a medical error has occurred at the physician or system level. Further such punishment may reduce voluntary reporting of errors.
Public Health | A public health organization uses provider level indicators for use in formal evaluation of providers in area. | A state health department uses the area level indicator for foreign body to survey the incidence of such events in that state. | Surveillance of events.
| PROBLEM: Flagging of cases does not ensure medical error and such use may decrease reporting.
Research | Researchers compare rates of case-based indicators to identify providers with more medical error to those with less. | Researchers use these indicators to identify cases in a large database where events related to medical error may have occurred. They examine the characteristics of patients flagged compared to matched patients not flagged. | Flagging of cases for use in research studies.
| PROBLEM: Lack of signal between providers makes such comparisons unreliable.
Rate-based indicators
Provider | A hospital uses an indicator to identify differences in rates between physicians within the hospital. | A teaching hospital observes that their rate of decubitus ulcer is consistently higher than the peer group average for other teaching hospitals in their region. After ruling out such explanations as differences in coding or screening practices, and assuring that case mix is comparable to other teaching hospitals, the hospital uses resources such as peer-reviewed literature and government reports to identify processes of care or system failures that may account for the higher rate. | Surveillance of rates for internal quality improvement investigations.
| PROBLEM: The number of cases by physician is likely to be zero or very small. Even if such rates are used for purely quality improvement initiatives, physician level rates for most indicators are likely to be unreliable.
Public Health | A state health department publishes the rate for each indicator by provider in a report to highlight quality concerns by provider. | A state health department uses the area level infection due to medical care indicator to examine the overall rate of this indicator in the state. They compare the result of the area level indicator to the provider level indicator to determine how many of these complications occur post-discharge or on an outpatient basis, and are serious enough to require hospitalization later. | Surveillance of rates. Examination of area rates over time, by region, by hospital type.
| PROBLEM: These indicators are not designed to be used for public reporting by provider, and such use may lead to incorrect conclusions about provider quality.
Research | Researchers use quality indicators as a definitive measurement of quality. | Researchers use quality indicators to examine the relationship between high rates on PSIs with high rates on other quality measures, such as mortality measures. | Use with other measures of quality to determine relationships of PSIs with structural, process or other aspects of care.
| PROBLEM: Many factors besides quality may contribute to rate differences.

Because the PSIs are intended for use as an initial, efficient screen to target areas for further data exploration, the primary goal is to find indicators that guide those interested in quality improvement and patient safety to areas where there are systematic differences between hospitals or geographic areas. These systematic differences may relate to underlying processes or structures that an organization could change to improve patient care and safety. These errors may be attributed to human error on the part of physicians or nurses, or system deficiencies or both. On the other hand, the systematic differences will sometimes correspond to coding practices, patient characteristics not captured by administrative data, or other factors. These will be dead ends to some degree. In the application of these PSIs, users will have an opportunity to determine how well patient safety problems are identified at the level of groups of patients. Sharing experiences with these PSIs, researchers and health care practitioners will have a chance to build on the information highlighted in this report about each indicator, as well as the set of PSIs.

Thus, application of these indicators to a variety of settings and additional data gathering will accomplish two vital next steps for patient safety. First, these attempts will shed light on which indicators and under what circumstances PSIs provide useful information. Second, in those cases where potentially preventable errors are identified with relative ease through these tools, health care providers and managers will have an opportunity to implement potential preventative strategies ranging from technologies to processes to new ways of organizing care. The effectiveness of these strategies can be assessed at many levels, including the effects on the PSI rates.

## Relationship of This Project to Other Quality Initiatives

This report is one of many efforts to clarify the problem of patient safety in the national health care system. Together these efforts are likely to provide a more complete picture of medical error. Other indicator or measurement sets have been developed, some of which were used in the development of this measure set. Table 21 describes these measures and their relationship to the PSIs.

Table 21 Relationship of PSIs to Other Indicator Sets

| Description | Relationship to PSIs
VA National Surgical Quality Improvement Program (NSQIP) ^148^ | An ongoing QI program by VA since 1994. Standardized data collection on adverse events following surgery. | Data collection utilizes standardized definitions which include clinical criteria in some cases. Although definitions differ, some indicators are similar to the PSIs. Adverse events have been added over the years. Data on post operative pneumonia, AMI, neurologic deficit, renal failure, DVT, PE, wound dehiscence, and systemic sepsis capture some of the same complications as potential PSIs, but operationalizations are vastly different.
Miller et al PSIs (published in Health Services Research) ^17^ | A set of 12 PSIs and a summary measure designed to maximize potential of identifying medical error through administrative data. | PSIs were designed as case finding tools for the most part. PSIs were used as a starting point for the PSIs in this report, although final definitions differ between the two sets. Some PSIs were rejected by the panels. Details are available in Appendix H.
Complications Screening Program ^7^ | A set of indicators designed to flag complications that occur in-hospital (e.g., in-hospital hip fracture, post-operative pneumonia). This set has been validated and studied widely. | The CSP indicators that have been shown to be adequate in identifying in hospital complications were used as a starting point for the PSIs in this report, although final definitions differ between the two sets. Some CSP indicators were rejected by the panel. Details are available in Appendix H.
National Quality Forum's (NQF) reportable events ^5^ | A set of case-finding tools designed to flag cases of potential medical error. These events are defined to be serious adverse events resulting in death or disability (e.g., wrong site surgery, serious medication error). | The NQFs reportable events are based on detailed clinical information, unlike the PSIs. Most of the reportable events are not identifiable using administrative data. Definitions of foreign body accidentally left during a procedure, transfusion reaction, and decubitus ulcer are included, but differ from PSI definitions.
National Quality Report (NQR) ^168^ | A Congressionally mandated report outlining the nationwide state of healthcare quality. This report will not compare providers. The first set of indicators and the accompanying report are due in 2003. | The NQR is separate from the PSIs, although some PSIs are likely to be considered for the report. The report will cover additional topics besides patient safety, and will utilize a variety of data sources.

Another USCF-Stanford Evidence-based Practice Center report evaluated the practices that may improve patient safety in a hospital setting. Some practices evaluated in the report are designed to reduce the events measured in some indicators. Table 22 outlines the overlap between these reports. As users of the PSIs identify potential safety problems, references to scientific evaluations such as Making Health Care Safer: A Critical Analysis of Patient Safety Practices ^2^ will be vital in determining appropriate interventions and potential failures in processes.

Table 22 Indicator Level Practices Included in Making Health Care Safer ^a^

Indicator Name | Corresponding chapter in practices report | Practices reviewed
Complications of anesthesia | None | None
Death in low mortality DRGs | None | None
Decubitus ulcer | Prevention of Pressure Ulcers in Older Patients (Chapter 27) | Pressure relieving devices
Failure to rescue | None | None
Foreign body accidentally left during procedure | The Retained Surgical Sponge (Chapter 22) | Sponge and instrument counts
Iatrogenic pneumothorax | Ultrasound Guidance of Central Vein Catheterization (Chapter 21) | Ultrasound guidance of central vein catheterization
Infection due to medical care | Prevention of Intravascular Catheter-Associated Infections (Chapter 16) | Maximum barrier precautions during central venous catheter insertion, use of central venous catheters coated with antibacterial or antiseptic agents, use of chlorhexidine gluconate at the central venous catheter insertion site, other practices.
Postoperative hip fracture | Prevention of Falls in Hospitalized or Institutionalized Older People (Chapter 26) | ID bracelets for high-risk patients, interventions that decrease the use of physical restraints, bed alarms, special floor materials to reduce injuries, hip protectors.
Postoperative hemorrhage or hematoma | None | None
Postoperative physiological and metabolic derangement | None | None
Postoperative respiratory failure | None | None
Postoperative pulmonary embolism or deep venous thrombosis | Prevention of Venous Thromboembolism (Chapter 31) | Graduated elastic stockings, intermittent pneumatic compression, low dose unfractionated heparin, low molecular weight heparin, warfarin and aspirin.
Postoperative wound dehiscence | Prevention of Surgical Site Infections (Chapter 20) | (Wound dehiscence only accounts for some of the outcomes considered in this chapter.)
| | Prophylactic antibiotics, perioperative normothermia, supplemental perioperative oxygen, perioperative glucose control.
Postoperative sepsis | None | None
Technical difficulty with procedure | None | None
Transfusion reaction | None (Mentioned in context of Chapter 43. Prevention of Misidentifications, a major cause of transfusion reactions) | None
Birth trauma - injury to neonate | None | None
Obstetric trauma (all delivery types) | None | None
Obstetric wound complications - c-section | Prevention of Surgical Site Infections (Chapter 20) | Reviewed in the context of all surgical wounds. See notation for wound dehiscence.
Post-partum urinary tract infection | Prevention of Nosocomial Urinary Tract Infections (Chapter 15) | Reviewed in the context of all hospitalized patients.

a This table outlines practices reviewed in the EPC Evidence Report, Making Health Care Safer: A Critical Review of Patient Safety Practices.^2^ This report was written independently of indicator development, therefore chapters listed may only briefly address the adverse event described by the indicator, and may not examine practices for the entire population at risk.

## Limitations and Future Research

The methodology of this report included several key choices that led to some limitations. The goal of this study was to identify and evaluate indicators that could be constructed using administrative data, because these data are readily available and less costly than more detailed clinical data. We chose to limit our search to indicators that could be operationalized currently, instead of identifying indicators which have the potential for being operationalized with administrative data in the future. As a result, those patient safety concerns addressed in this indicator set are only a subset of the most prevalent, important or preventable problems. Many important concerns cannot currently be monitored well using administrative data (e.g., adverse drug events). As administrative data improves, many more important and potentially more useful indicators are likely to emerge.

Just as administrative data limited specific indicators chosen, the use of administrative data tends to favor specific types of indicators. The PSIs evaluated in this report contain a large proportion of surgical indicators, rather than medical or psychiatric. This is not to imply that patient safety is not a concern outside of surgery, rather, these indicators tend to be more feasible to define using administrative data for surgical populations. Medical complications are often difficult to distinguish from comorbidities that are present on admission. ^13^ In addition medical populations tend to be more heterogeneous than surgical, especially elective surgical populations, making it difficult to account for case-mix. Panelists often felt that indicators were more likely to reflect preventable events when limited to elective surgical admissions. As data become better, the addition of patient safety indicators for the medical and psychiatric populations will be critical.

The intended purpose of these indicators guided the choices made in specifying them. Specifically, tradeoffs between specificity (e.g., the likelihood that the indicator will not flag cases that do not qualify as a patient safety event) and sensitivity (e.g., the likelihood that the indicator will flag cases that do qualify as a patient safety event) were considered in conjunction with the use or misuse of these indicators as they move into the public sector. Many complications included in these indicators are more likely in some specified subpopulation. For instance, decubitus ulcers are more likely in patients with paralysis. Since they are more likely to occur, complications in these populations may also be less preventable or be more likely to be present on admission. Nonetheless, interventions to prevent complications may be particularly important in these high risk groups - it is these very patients for which providers need to be particularly vigilant in preventing that complication from occurring. The inclusion of high risk patients, given the limitations of these indicators, would ultimately mean a decrease in the specificity of these indicators, or the ability to have a high yield of patients in whom true safety problems are present. However, to exclude these patients, as was done for many indicators, would sacrifice the sensitivity of these indicators, or the ability to identify as many patients as possible for whom true safety problems may be present.

The evaluation of indicators included in this report reflects only part of the validity testing needed. The structured panel review was intended to assess the face validity of the indicators. However, limitations of such a review should be noted. Several panels were utilized in the review of the indicators; thus panel level differences may be present, leading to differences in the evaluation of indicators. Further, panelists were not required to support opinion with empirical evidence from the literature, thus panelists' review represents the opinions of these clinicians. Also, panelists may have interpreted the questions about characteristics of the indicators differently, which is particularly problematic for small sample sizes. Finally, although children were included in the population at risk for most indicators, clinicians that care for children were not included in the non-obstetric panels. Team members that specialize in pediatrics (PSR, MM) advised regarding the applicability of these indicators along the way. However, further panelist review and research into the applicability of these indicators to children is necessary. The empirical analyses were intended to demonstrate the precision and bias of the indicator; these tests are more descriptive then evaluative in nature. The tests of precision are affected by the frequency of an event; thus higher frequency indicators tend to have higher precision. This does not imply that these indicators are in fact superior to other indicators. In addition, bias tests were not intended to rule out all potential bias, as indicators that are not affected by risk adjustment may be biased in a way that is not captured by the limited risk adjustment utilized in this study. This is a particular problem for obstetric indicators, where risk adjustment often only accounted for the age of the mother, as other appropriate risk adjustment factors were generally not available in the data.

These initial evaluations of these indicators demonstrated that they are promising, both in terms of face validity and relative precision. Further research should continue to explore the validity of these indicators, such as the construct validity of these indicators. This research should validate the indicators using other data, such as detailed chart data. Validation should focus on the sensitivity and specificity of these indicators in detecting the occurrence of a complication, the extent to which failures in processes of care at the system or individual level are captured using these indicators, the relationship of these indicators with other measures of quality, such as mortality, and explorations of bias and risk adjustment. A recent study examined the relationship between ICD-9-CM identified complications and those identified through standardized clinical data collection. ^148^ Similar efforts, comparing these PSIs with other measures of patient safety using other data sources will shed additional light on the comparative validity of these indicators. Research may also utilize additional data elements, such as “present on admission coding” available in some states to identify the ability of these indicators to detect complications occurring in-hospital. All validity research must include thoughtful deliberations about the standard of validity for these types of indicators. Given that these indicators are intended for screening purposes, a lower standard of construct validity (the ability of these indicators to detect patient safety problems) may be appropriate than indicators intended as definitive measures.

In addition to research aimed at validating these PSIs, future research should focus on the appropriate and practical application of these indicators. Effort should be put forth in establishing appropriate and potentially flexible benchmarks for the PSIs, such as means, medians, modes, or points of inflection (i.e., point where the slope of the distribution changes) of peer group, regional or statewide providers. Careful attention should also be paid to the understanding of these indicators by clinicians and other end users to ensure that data are appropriately interpreted and fully utilized.

The future of patient safety measurement depends in part on the improvement of administrative data. The addition of timing variables may prove particularly useful. In identifying complications it is necessary to determine whether or not a complication was present on admission, or occurred during the hospitalization. While some of the complications that are present on admission may indeed reflect adverse events of care in a previous hospitalization or outpatient care, many may reflect comorbidities instead of complications. Some states have included a “sixth digit,” present on admission designation. These are promising for use in quality indicators. Additional timing distinctions were mentioned during the panel discussions. Specifically, for some complications, occurring in close temporal proximity to surgery or admission was more or less desirable than timing that was more remote. For instance, panelists suggested that aspirations leading to pneumonia that occurred during or immediately after surgery were potentially preventable complications, but that aspirations that occur later in the hospitalization were less preventable. Thus, while administrative data do not currently contain such distinctions, the timing of an adverse event may prove to be a useful data element.

The second area of data improvement would be to allow the linking of hospital data over time and with outpatient data. Many complications may not occur or be diagnosed until after discharge, especially when length of stays are relatively short. Presumably these complications either result in another admission, or are diagnosed and treated on an outpatient basis. For example, the area-level indicators “Infection due to medical care” identified almost twice as many complications as the provider-level indicator, suggesting that many infections occur after discharge or following outpatient care and eventually result in hospitalization. Currently, these complications are not detected by the provider-level PSIs, potentially producing misleading results. The inclusion of complications that occur after discharge would increase the sensitivity of the PSIs.

As highlighted during the structured panel review, it is essential that users understand the limitations and benefits of these indicators in practical use. Clarification about data, vigilance in ensuring the proper use of these indicators, updating indicators to reflect new evidence and practices, and continuous, open communication between clinicians, medical coders and users of these indicators will be essential for their continued success.

The current development and evaluation effort will best be augmented by a continuous communication loop between users of these measures, researchers interested in improving these measures, and policy makers with influence over the resources aimed at data collection. Surely, some indicators will be more useful than others, based on further information and research about them. The conclusions of the companion technical report on quality indicators from the EPC, and published by AHRQ [http://www.achq.gov/data/hcup/qirefine.htm], offers further pertinent detail about future research and activities aimed at improvements in the ability to measure the consequences - intended and unintended—of medical care.