# Results

The results are presented in four sections. Within each section, the indicators are presented within their final designated set - Accepted or Experimental, in alphabetical order. Non-obstetric indicators are followed by obstetric indicators, also in alphabetical order. The results for each of the rejected indicators are contained in Appendix F. The first section presents the results of the literature review. The second section presents the overall results of the clinician review; the third section also reports the results for the clinician review, but for specific indicators. The final section contains the comparative empirical results.

Obstetric indicators are grouped together in the results presentations to convey a number of differences from the other PSIs more clearly. First, the obstetric indicators, for the most part, were created after a review of the ICD-9-CM codes. There is little or no precedent for using most of these indicators, and little literature based evidence discussing these complications as measures of quality of care. In addition, little evidence of the coding validity of obstetric codes exists. Second, at the end of the clinician review it appeared that the obstetric panels treated similar complications differently from the other panels. For example, the diagnosis code for wound dehiscence was rejected by the multi-specialty panel, due to the ambiguity of the code. The obstetric panel, however, accepted the ambiguity of the parallel code for cesarean wound dehiscence. Third, an entirely different set of physicians and nurses, as well as only a subset of hospitals provide obstetric care. Fourth, empirical analyses found that obstetric PSIs on average tend to have considerably higher rates than non-obstetric PSIs. In addition, DRG and comorbidity risk adjustment is likely inadequate for these indicators (DRGs are split only by delivery type and the presence or absence of any complication or comorbidity, and the comorbidities examined in the risk adjustment are rare in this population and potentially not the most important comorbidities for which to risk adjust). A factor analysis found that these indicators tend to load onto one factor, while non-obstetric indicators appear to load on a separate factor, for the most part. Because of these considerations, the obstetric indicators are presented separately in this report, following the non-obstetric indicators in each subsection.

## Section 3A. Literature Review Results

### Background

In the context of widespread current interest in measuring and improving patient safety, potential quality indicators related to potentially preventable complications of medical care merit special attention. In this section, we review the literature on the application of administrative data to screening for such complications

The seminal studies that defined the epidemiology of medical errors ^6,^ ^25,^ ^26^ were based on a methodology that was pioneered by the California Medical Association (CMA) in 1976. ^27^ Specially trained nurses and medical records administrators screened inpatient records for any of 18 possible indicators of an adverse event. ^28^ Records that met one or more of these criteria were then reviewed independently by two board-certified physicians to identify “injuries due to medical management”; all differences were reconciled by a third independent reviewer. Injuries “caused by the failure to meet standards reasonably expected of the average physician...” were labeled as “negligent” adverse events. Another seminal study employed “ethnographers trained in qualitative observational research” who prospectively identified “situations in which an inappropriate decision was made...” by attending all rounds, nursing sign-outs, case conferences, and other “organized settings in which health care providers discussed adverse events.” ^29^ Neither of these methodologies use ICD-9-CM codes to identify adverse events. Another set of studies defined postoperative adverse events based on unusual occurrences and key clinical findings that are included in a proprietary clinical data system. ^30^ – ^33^ Some investigators have defined adverse events de novo, based on clinical experience and prior literature. ^34^ – ^37^ Others have estimated the incidence of adverse drug events using various pharmacy-based surveillance systems. ^38,^ ^39^

By contrast, relatively few studies have evaluated ICD-9-CM diagnosis or procedure codes as a method for finding adverse events or medical errors. Numerous investigators have proposed various ICD-9-CM definitions of adverse events or medical errors; some are limited to specific conditions or procedures ^40^ – ^43^ while others are applicable to broad groups of hospitalized patients. ^10,^ ^11,^ ^44^ – ^48^ However, most of these investigators initially validated their measures principally by assessing content validity ^7^ or by demonstrating that they were associated with substantially higher mortality, longer lengths of stay, and higher charges at the patient level, ^40,^ ^47,^ ^48^ even after adjusting for demographic characteristics and comorbidities. ^10,^ ^12^ Brailer et al. ^47^ also found a strong association at the patient level (at 6 hospitals) between their proprietary (CareScience, Inc.), comorbidity-adjusted complication measure and a composite measure of 15 different adverse events (based on Maryland Hospital Association indicators). Among these 15 categories, inpatient mortality and unscheduled return to the operating room or special care unit (among others) were strongly associated with comorbidity-adjusted complications. Several other proprietary systems (e.g., Risk adjusted Major Complications, HealthGrades, Inc.; CareEnhance Resource Management Systems, McKesson Health Solutions; Disease Staging, MEDSTAT, Santa Barbara CA; Performance Measurement, QuadraMed, Larkspur CA; Intelligent Disease Analysis, MedAI Inc., Orlando FL) that estimate crude or risk adjusted complication rates based on administrative data have never been publicly validated.

Although these early studies generally supported the validity of using administrative data to ascertain adverse events, they also identified several sources of concern:

1 The ratio of observed to predicted complications, based on ICD-9-CM codes (predominantly 997.xx through 999.9x) from 776 acute care hospitals, increased substantially between 1983 and 1984, reflecting the impact of prospective payment on the reporting of complications. ^45^ Conversely, recent evidence suggests a significant decrease between 1997 and 1998 in the coding of acute posthemorrhagic anemia and selected other complications among Medicare inpatients undergoing hip and femur procedures (perhaps in response to the Office of the Inspector General's aggressive compliance program). ^49^ Proprietary data from Solucient, LLC also suggest a sudden 35% decrease in risk adjusted complications across nearly 3,000 hospitals between 1998 and 1999. ^50^
2 Unlike analogous ratios for mortality and readmissions, hospitals' ratios of observed to predicted complications varied significantly by region and hospital case-mix index; such associations would not be expected for a valid measure. ^45^ In other studies, ICD-9-CM coded complications were more frequent at large hospitals than at smaller hospitals, ^10^ and complication rates were higher at large hospitals and academic medical centers. ^11,^ ^41^ These findings contradict numerous studies suggesting better outcomes and processes of care, for at least some conditions, at high-volume and teaching hospitals. ^51^ – ^53^ The most plausible explanations for this finding (i.e., greater unmeasured severity of illness, more frequent use of invasive therapies, and more aggressive coding of complications at teaching hospitals) suggest the possibility of substantial bias in comparing performance across hospitals of different types.
3 There was minimal association between measures of risk adjusted complications and other outcome measures (e.g., rates of death, readmission, and major morbidity) at the hospital level (Spearman r=-0.01 to -0.05, ^46^ ; partial r=0.09–0.11 ^47^ ; Spearman r=-0.01 for surgical patients, r=-0.12 for medical patients). ^11^ Although this finding has been interpreted as “desirable because (complications measures are) intended to provide information not captured by other outcome measures”, ^47^ it is concerning that complication measures correlate so poorly with somewhat better validated measures of quality. ^54^ – ^65^ Two studies of adverse events after coronary artery bypass surgery represent notable exceptions to these findings. Specifically, risk adjusted death rates were significantly correlated with risk adjusted complication rates, according to Ghali et al. (r=0.73–0.74 [p<0.01] ^43^ ), and risk adjusted “major nonfatal” complication rates, according to Hartz et al. (r=0.31 and r=0.79 [p=0.035], before and after eliminating a single outlier.) ^66^
4 Logistic regression models to predict complications, using information available from administrative data, are generally weaker than models to predict death or readmission, with receiver operating curve areas or c-statistics (measuring the model's ability to discriminate between patients with and without adverse outcomes) of 0.6–0.7 ^10,^ ^41^ – ^43^ and R-squared statistics (correlating observed and expected complication rates at the hospital level) of 0.42–0.48 ^45^ or 0.16 (for medical cases) to 0.42 (for major surgery). ^11^ The difficulty of predicting complications suggests that underlying patient characteristics or other unmeasured factors may introduce even more bias than in comparative evaluations of other outcomes.

It should be noted that problems 2–4 above may not be unique to administrative data, but may apply to clinically derived measures of complications as well. For example, two studies by the same researchers, using different data sources, found no correlations between risk adjusted complication measures and hospital/operator volume for PTCA and CABG. ^35,^ ^67^ Studies based on MedisGroups ^32^ ^68^ data have confirmed that complications, adjusting for patient risk, are more frequent at large hospitals, hospitals with approved residency training programs, hospitals with high nurse-to-bed ratios and high proportions of board-certified anesthesiologists, and hospitals that offer subspecialty services (e.g., magnetic resonance imaging, bone marrow transplantation) - precisely the hospitals that would be expected to provide better care. There was essentially no association at the hospital level between measures of risk adjusted complications and risk adjusted mortality for CABG (r=0.07, p=0.58), ^32^ and a weak association (r=0.21, 95% CI 0.04–0.38) ^69^ for elective adult general surgery after full risk adjustment (i.e., r=0.55, 95% CI 0.38–0.72 without risk adjustment). Similarly, the Department of Veterans' Affairs (VA) National VA Surgical Risk Study found significantly higher risk adjusted, 30-day postoperative morbidity at teaching hospitals than at non-teaching hospitals for general, orthopedic, urologic, and vascular (but not thoracic, neurologic, or otolaryngologic) surgery, ^70^ and essentially no association with risk adjusted mortality at the hospital level (r=-0.01 overall, range r=-0.03 for neurosurgery to r=0.28 for otolaryngologic surgery). ^60^ Finally, discrimination in predicting complications has also been relatively weak (c<0.79) in these detailed clinical data systems. ^31,^ ^33,^ ^60,^ ^69^

### General Issues in Using Complications To Screen for Quality Problems

The companion technical report on the development of the AHRQ Quality Indicators describes three ^3^ areas important to the evaluation of a measure (i.e., precision, minimum bias and construct validity) that are pertinent to potential PSIs.

#### Precision

As with mortality rates, variations in complication rates may reflect random variation. However, the higher incidence of most complications compared to mortality reduces random variation, and provides an important incentive for using complication rates as quality measures. In addition, precision may be less important for PSIs than for other types of QIs. To the extent that these indicators capture preventable iatrogenesis, the precision with which prevalence is estimated at the provider level may be unimportant. The primary intended use of these indicators is not to compare performance across providers, but instead to assess the overall performance of the health care system at the regional, state, or national level, and to provide a screening tool that providers can use to identify cases that merit internal review.

It should be noted that the ICD-9-CM codes that are most likely to represent preventable adverse events are also relatively rare (see detailed reviews below). The ICD-9-CM codes for general complications are more common, but are subject to considerable coding error and may include a mix of preventable and non-preventable events. Efforts to focus on ICD-9-CM coded complications that are likely to reflect medical errors will inevitably increase random variation across providers.

#### Minimum Bias

All quality indicators, including the proposed PSIs, are susceptible to bias of three general types: selection effects, confounding, and misclas­sification. Selection bias arises when the sample available for quality measurement is not representative of the target population. In the current context, this problem arises principally for conditions that may be treated, or procedures that may be performed, in either inpatient or outpatient (short-stay) settings. For these conditions and procedures, HCUP data may not adequately represent the population of interest. For example, in areas where freestanding birthing centers have a substantial market share, PSI rates based on HCUP data are likely to be biased.

Confounding arises in comparing PSI rates across hospitals, health systems, or regions because of differences in patients' underlying risk of these events. Patients who undergo certain procedures, or have certain diagnoses, are inherently at higher risk of experiencing adverse events, including adverse events due to medical error. Age is also a known risk factor for medical error, although its effect may be explained by the greater clinical complexity of care for elderly patients and their greater exposure to potential hazards. ^6,^ ^26^ Well-established clinical prediction rules allow risk adjustment for patients experiencing perioperative cardiac and pulmonary complications ^71^ – ^77^ , but risk adjustment systems remain relatively unstudied for most other complications ^78^ . Specific clinical prediction rules have been developed for morbidity after coronary artery bypass surgery, ^79^ carotid endarterectomy, ^80^ – ^83^ , and percutaneous coronary interventions, ^84^ but not for many other high-risk procedures. In general, clinical factors such as the serum albumin level and functional status ^37^ are clearly associated with the risk of adverse events among both medical and surgical inpatients. These factors potentially confound the observed associations between hospital categories and adverse event rates, ^25,^ ^52^ as well as the performance ranking of individual hospitals. For example, Hartz et al. ^35^ reported that the Wisconsin hospital with the highest unadjusted rate of major complications after Coronary Artery Bypass Graft (CABG) had an adjusted relative odds of 0.98, placing it right in the middle after risk adjustment.

Multiple studies have explored the relative performance of risk adjustment models for mortality, using administrative versus clinical data (or proprietary systems based on such data). ^85^ – ^90^ Although there is less evidence regarding the relative performance of risk adjustment models for adverse events, the same findings are likely to apply. For example, Hartz et al. reported c statistics of 0.71 using ICD-9-CM codes, and 0.80 using clinical variables, to predict adverse outcomes after stroke among Medicare patients. ^91^ Substantial opportunity for confounding bias therefore exists when provider-specific adverse event rates are compared.

Misclassification bias is likely to result from variation in coding practices across hospitals. As detailed below, we carefully reviewed the available literature to select PSIs for which the positive predictive value of coding appears to be at least 75%. However, there is less evidence on sensitivity (i.e., undercoding) than on predictive value (i.e., overcoding), so several of the accepted and experimental indicators may suffer from significant undercoding. Based on current guidelines that only require coding of “conditions that affect patient care in terms of requiring clinical evaluation... therapeutic treatment...diagnostic procedures...extended length of hospital stay...increased nursing care and/or monitoring,” ^92^ we avoided including potentially inconsequential diagnoses in the PSI definitions. However, we could not always do so, due to the ambiguity of ICD-9-CM. One recent study suggests that the sensitivity of coding postoperative complications after elective back surgery varies markedly across hospitals, such that about half of the difference in risk-adjusted complication rates between low and high outlier hospitals is attributable to reporting variation. ^93^

#### Construct Validity

The literature identifies only a small number of explicit processes of care that have proven beneficial in randomized, placebo-controlled trials for preventing certain complications: (1) thromboembolism prophylaxis for most major surgeries ^94^ – ^102^ ; (2) perioperative antibiotics for a smaller but still substantial number of surgical procedures ^103^ – ^110^ ; (3) perioperative nutritional support for severely malnourished patients requiring laparotomy, thoracotomy ^111,^ ^112^ and hip fracture repair ^113^ ; (4) perioperative beta blockers to prevent cardiac complications among high-risk patients undergoing cardiac, ^114^ noncardiac ^115^ or vascular ^116^ surgery; and (5) antiplatelet agents to prevent early restenosis after percutaneous coronary interventions. ^117,^ ^118^ Other potential interventions to improve patient safety have been thoroughly reviewed in a recent report. ^2^ To our knowledge, no additional studies to date have linked these specific processes of care with differences in risk adjusted rates of adverse outcomes across hospitals or physicians.

Given the small number of evidence-based processes-of-care related to the prevention of adverse events, one could argue for broad explicit review criteria that incorporate standards of care based on expert recommendations, rather than insisting on processes strongly supported by evidence. Condition-specific provider adherence measures of this type have been associated with the risk of in-hospital complications among adults admitted for diabetes and chronic obstructive pulmonary disease (COPD), but not congestive heart failure (CHF). ^36^ Iezzoni and colleagues developed a similar set of review instruments to compare Medicare cases flagged by the Complications Screening Program (CSP) in California and Connecticut in 1994 with unflagged cases. ^16^ Even with this broader look at processes of care, flagged cases did not differ significantly from unflagged cases in terms of the prevalence of generic quality problems. Specifically, 53% of 351 flagged surgical cases demonstrated one or more of 17 process-of-care problems, versus 46% of 140 unflagged surgical cases. Among medical cases, 5% of both flagged and unflagged cases demonstrated one or more process-of-care problems. None of the specific flags proved useful in identifying patients with a higher risk of these generic process deficiencies, except deep vein thrombosis/pulmonary embolism (DVT/PE) (11% flagged versus 4% unflagged, p=0.09) and miscellaneous complications (62% flagged versus 46% unflagged, p=0.06).

Implicit review is based upon global assessment of quality of care by physician peers. ^119^ In another recent evaluation of the Complications Screening Program, Weingart and colleagues ^15^ compared flagged and unflagged cases on the prevalence of quality problems identified by implicit review. Physician reviewers identified potential quality problems in 29.5% of flagged surgical cases and 15.7% of flagged medical cases, compared with 2.1% of unflagged medical and surgical controls. However, substantial variation across specific screens was noted. Potential quality problems were identified in 50% of surgical cases flagged for DVT/PE, but only 5% of surgical cases flagged for postoperative pneumonia. Potential quality problems were identified in less than 20% of medical cases flagged by each screen, except for post-procedural hemorrhage or hematoma (31%). Of two other studies involving structured implicit review by physicians as a “gold standard” for quality assessment, one confirmed the potential value of various morbidity-based screening tools based on nurse/staff review, ^120^ but another found that quality of care was equal between patients with and without complications, and between hospitals with low and high risk adjusted complication rates. ^121^ In neither of these studies did the authors report the predictive validity of specific adverse outcome measures.

Part of the difficulty with linking adverse events and processes of care relates to the inherent lack of reproducibility in implicit assessments of quality. For instance, a well-known study in the 1980s examining deaths due to pneumonia, myocardial infarction and stroke reported inter-rater reliability for physicians' judgment of “preventable death” as 0.11, 0.51 and 0.55, respectively ^122^ . (The first value falls in the range conventionally regarded as “poor,” while the other two values indicate “moderate” agreement.) In the Harvard Medical Practice Study, physician reviewers exhibited substantial agreement in identifying the presence of adverse events (kappa=0.61), but only “fair” agreement in identifying negligent care (kappa=0.24). ^6^ Two later studies reported moderate agreement among physician reviewers for the presence of an adverse event (kappa = 0.41–0.57), but only fair agreement for the judgment of preventability (kappa = 0.30) ^123^ or negligence (kappa = 0.19–0.24). ^124^ Weingart et al. reported borderline poor agreement among physician reviewers about both the presence of a CSP complication (kappa=0.22) and a potential quality problem (kappa = 0.22). ^15^ Agreement was somewhat better in the National VA Surgical Risk Study, in which physicians used a 5-point scale to rate overall quality of care (ICC=0.40–0.56). ^121^ A more recent study examined the impact of discussion between reviewers on agreement in assessing preventability of adverse events. ^125^ The authors created 7 different pairs among 13 reviewers participating in the study. They showed that discussion between the two physicians in a pair substantially improved their assessment of an adverse event as iatrogenic from (kappa = 0.46 to 0.71). However, the agreement across pairs remained relatively unchanged by discussion (kappa = 0.36 before to 0.40 after discussion).

In the absence of identifiable differences in processes-of-care in most cases studied, residual variation in complication rates after risk adjustment presumably reflects either unmeasured processes of care or differences in patients' baseline risk of complications that are not captured through risk adjustment. By definition, these concepts are difficult to measure, making it difficult to establish the construct validity of many potential PSIs.

Finally, correlations between adverse events and structural characteristics of hospitals have been cited as evidence of construct validity. However, these findings are often difficult to interpret because of uncertainty about which structural characteristics are truly associated with better care. Structural characteristics are also often difficult to modify; hence, identifying them has limited value for quality improvement. In evaluating the Complications Screening Program, Iezzoni and colleagues found that large hospitals, hospitals performing open heart surgery, and members of the Council of Teaching Hospitals (COTH) had 10–33% more complications than expected across most risk pools, whereas small hospitals, hospitals without open heart surgery facilities, and nonmembers of COTH, had 4–26% fewer complications than expected. ^11^ Similarly, patients at hospitals with fewer than 100 beds consistently had a 22–49% lower risk of complications than patients at hospitals with 500 or more beds. ^10^ A study of factors associated with adverse events after surgery, based on AHRQ's original HCUP Quality Indicators, revealed associations between four of these nine indicators and registered nurse staffing (as detailed below), including three of the five indicators that were judged a priori to be “nurse-sensitive.” ^126^ Differences in risk-adjusted QI rates across regions and hospital ownership categories were also noted. In evaluating a Risk-Adjusted Complications Index (RACI) based on administrative data, DesHarnais and colleagues found that hospitals' risk-adjusted complication rates were positively associated with their range of services, but not with their ownership, size, or teaching status. ^46^ Conversely, Myers found significantly higher complication rates after hysterectomy at teaching hospitals than at nonteaching hospitals. ^41^ These findings are probably attributable to bias from unmeasured case mix or differential reporting of complications. Studies based on chart review have suggested that major teaching hospitals experience more complications than nonteaching hospitals, but they are better at “rescuing” patients after complications, and relatively few of their complications (especially adverse drug events) are due to negligence. ^25,^ ^32,^ ^52^ Patient volume should be inversely associated with valid outcome rates, at least for procedures requiring technical skill, but the literature on this topic has generally focused on mortality and resource use, with complications of percutaneous coronary interventions ^127^ – ^135^ and stroke after endarterectomy the notable exceptions. ^136^ With the exception of a few recent studies on nurse staffing and hospital outcomes, ^126,^ ^137,^ ^138^ analyses of structural aspects of care have not been particularly helpful in establishing the construct validity of morbidity indicators based on administrative data, or suggesting interventions to improve patient outcomes.

### Specific Review of the Evidence for Indicators

The potential patient safety indicators identified through literature and coding reviews are listed in Appendix A. These indicators were assigned to one of three categories: Accepted PSIs, Experimental PSIs and Rejected PSIs. Those in the last category were removed from further analyses based on evidence of poor coding or construct validity, poor ratings by panelists, or inability to implement the desired specification after receiving expert coding input. Indicators in the Accepted indicator set were rated favorably by clinical panels as being useful screens for potentially preventable complications. Finally, those in the Experimental indicator set fell between the other two categories, and underwent less extensive empirical analyses. This set is not recommended without considerable further testing, as described in Section 3B, Indicator Selection.

This section reviews the literature on the derivation and validity of each indicator, or the ICD-9-CM codes upon which it is based. We briefly compare the definitions reported in the literature with the final PSI definition. More detailed descriptions of the definitions, and explanations of differences, are presented in section 3D, Detailed Clinician Panel Results by Indicator. Literature reviews were performed on all indicators including those that were rejected based on poor panel ratings, and some that were rejected for other reasons. Literature reviews for those indicators are not presented in this section, but are presented in Appendix F. For each indicator, we report separately on whether it is coded accurately (“coding validity”) and whether it is empirically associated with substandard quality or errors in processes of care (“construct validity”).

The literature review results are provided to help researchers and providers assess the usefulness of each indicator in their own epidemiologic or quality improvement work. It was beyond the scope of this project to review clinical studies linking specific processes of care to specific, prospectively ascertained complications. Much of this literature has been summarized in a recent AHRQ report on evidence-based practices to prevent medical errors. ^2^ For example, numerous randomized controlled trials have proven that thromboembolism prophylaxis reduces the risk of postoperative DVT/PE, and therefore that higher DVT/PE rates are likely to be associated with poorer quality of care. This literature review focuses instead on the validity of complication indicators based on ICD-9-CM diagnosis and/or procedure codes. Tables 9 and 10 summarize the strength of evidence for each Accepted and Experimental indicator respectively.

Table 9 Summary of Strength of Evidence in Literature for Accepted Indicators

Indicator | Coding^a,^ ^b^ | Construct Explicit Process^a,^ ^b^ | Construct Implicit Process^a,^ ^b^ | Construct Staffing^a,^ ^b^
Complications of anesthesia | 0 | 0 | 0 | 0
Death in low mortality DRGs | + | 0 | + | 0
Decubitus ulcer | - | 0 | 0 | ±
Failure to rescue | + | 0 | 0 | ++
Foreign body left in during procedure | 0 | 0 | 0 | 0
Iatrogenic penumothorax | 0 | 0 | 0 | 0
Infection due to medical care | 0 | 0 | 0 | 0
Postoperative hip fracture | + | + | + | 0
Postoperative hemorrhage or hematoma | ± | ± | + | 0
Postoperative physiologic and metabolic derangements | - | 0 | 0 | -
Postoperative respiratory failure | + | ± | + | ±
Postoperative PE or DVT | + | + | + | ±
Postoperative sepsis | ± | 0 | 0 | -
Technical difficulty with procedure | ± | 0 | 0 | 0
Transfusion reaction | 0 | 0 | 0 | 0
Postoperative wound dehiscence | 0 | 0 | 0 | 0
Birth trauma | - | 0 | 0 | 0
Obstetric trauma - vaginal delivery with instrumentation | + | 0 | 0 | 0
Obstetric trauma - vaginal delivery without instrumentation | + | 0 | 0 | 0
Obstetric trauma - cesarean delivery | + | 0 | 0 | 0

a Level of evidence

(-) Published evidence suggests that the indicator lacks validity in this domain (i.e., less than 50% sensitivity or predictive value; explicit or implicit process failure rates no more frequent than among control patients).

(0) No published evidence regarding this domain of validity.

(±) Published evidence suggests that the indicator may be valid in this domain, but different studies offer conflicting results (although study quality may account for these conflicts).

(+) Published evidence suggests that the indicator IS valid, or is likely to be valid, in this domain (i.e., one favorable study).

(++) There is strong evidence supporting the validity of this indicator in this domain (i.e., multiple studies with consistent results, or studies showing both high sensitivity and high predictive value).

b Coding: Sensitivity is the proportion of patients who suffered an adverse event, based on detailed chart review or prospective data collection, for whom that event was coded on a discharge abstract or Medicare claim. Predictive value is the proportion of patients with a coded adverse event who were confirmed as having suffered that event, based on detailed chart review or prospective data collection.

Construct, explicit process: Adherence to specific, evidence-based or expert-endorsed processes of care, such as appropriate use of diagnostic modalities and effective therapies. Our construct is that hospitals that provide better processes of care should experience fewer adverse events.

Construct, implicit process: Adherence to the “standard of care” for similar patients, based on global assessment of quality by physician chart reviewers. Our construct is that hospitals that provide better overall care should experience fewer adverse events.

Construct, staffing: Our construct is that hospitals that offer more nursing hours per patient day, better nursing skill mix, better physician skill mix, or more experienced physicians, should have fewer adverse events.

c Note that when content validity is exceptionally high, as for transfusion reaction or iatrogenic pneumothorax, construct validity becomes less important.

Table 10 Summary of Strength of Evidence in Literature for Experimental Indicators^a^

Indicator | Coding | Construct Explicit Process | Construct Implicit Process | Construct Staffing
Postoperative aspiration pneumonia | + | ± | + | +
CABG following PTCA | + | 0 | 0 | ++
Decubitus ulcer in high-risk patients | - | 0 | 0 | 0
Postoperative fractures potentially related to falls | + | 0 | 0 | 0
Intraoperative nerve compression injuries | 0 | 0 | 0 | 0
Malignant hyperthermia | 0 | 0 | 0 | 0
Postoperative acute myocardial infarction | ++ | - | + | -
Postoperative iatrogenic complications - cardiac | ± | 0 | + | 0
Postoperative iatrogenic complications - nervous system | 0 | 0 | 0 | 0
Postoperative reopening of surgical site | + | - | + | 0
Postoperative suture of laceration | + | 0 | + | +
Obstetric wound complications - cesarean | ± | 0 | 0 | 0
Obstetric wound complications - vaginal | ± | 0 | 0 | 0
Other obstetric complications of delivery | ± | 0 | 0 | 0
Third or fourth degree obstetric lacerations | + | 0 | 0 | 0
Uterine rupture | + | 0 | 0 | 0
Postpartum urinary tract infection | - | 0 | 0 | 0

a See footnotes to Table 9

### Accepted Indicators

#### Complications of Anesthesia

Source. A subset of this indicator was originally proposed by Iezzoni et al.10 as part of the CSP (CSP 21, “Complications relating to anesthetic agents and other CNS depressants”). Their definition also includes poisoning due to centrally acting muscle relaxants (968.0) and accidental poisoning by nitrogen oxides (E869.0), which were omitted from this PSI. Their definition excludes other codes included in this PSI, namely, poisoning by other and unspecified general anesthetics and external cause of injury codes for “endotracheal tube wrongly placed during anesthetic procedure” (E876.3) and adverse effects of anesthetics in therapeutic use (E938.1–E938.9).

##### Evidence

We were unable to find evidence on validity from prior studies.

#### Death in Low Mortality DRGs

Source. This indicator was originally proposed by Hannan et al. as a criterion for targeting “cases that would have a higher percentage of quality of care problems than cases without the criterion, as judged by medical record review.” ^139^ An alternative form of this indicator focused on “primary surgical procedures,” rather than DRGs, with less than 0.5% inpatient mortality.

##### Evidence

Construct validity. Based on two-stage implicit review of 8,109 randomly selected deaths from 104 New York hospitals in 1985-86, Hannan et al. found that patients in low-mortality DRGs (<0.5%) were 5.2 times more likely than all other patients who died (9.8% versus 1.7%) to have received “care that departed from professionally recognized standards,” after adjusting for patient demographic, geographic, and hospital characteristics. In 15 of these 26 cases (58%) of substandard care, the patient's death was attributed at least partially to that care. The association with substandard care was stronger for the DRG-based definition of this indicator than for the procedure-based definition (5.7% versus 1.7%, OR=3.2). We were unable to find other evidence on the validity of this indicator.

#### Decubitus Ulcer

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 6, “cellulitis or decubitus ulcer”). Their definition also includes cellulitis of the upper extremity (682.3–682.4), which was omitted from this PSI. Needleman and Buerhaus ^137^ identified decubitus ulcer as an “Outcome Potentially Sensitive to Nursing,” but unlike this PSI their definition includes cellulitis of any site (682). The American Nurses Association, its state associations, and the California Nursing Outcomes Coalition have identified the total prevalence of inpatients with Stage I, II, III, or IV pressure ulcers (based on clinical data collection) as a “nursing-sensitive quality indicator for acute care settings.” ^140^

##### Evidence

Coding validity. No evidence on validity is available from CSP studies. Geraci et al. ^141^ confirmed only 2 of 9 episodes of pressure ulcers (707.0) reported on discharge abstracts of Veterans Affairs (VA) patients hospitalized in 1987-89 for congestive heart failure (CHF), chronic obstructive pulmonary disease (COPD), or diabetes; the sensitivity for a nosocomial ulcer was 40% (2/5). Among Medicare hip fracture patients from 297 hospitals in 1985-86, Keeler et al. ^51^ confirmed 6 of 9 (67%) reported pressure ulcers, but failed to ascertain 89 additional cases (6% sensitivity) using ICD-9-CM codes. In the largest study to date, Berlowitz et al. ^142^ found that the sensitivity of a discharge diagnosis of pressure ulcer among all patients transferred from VA hospitals to VA nursing homes in 1996 was 31% overall, or 54% for stage IV (deep) ulcers. The overall sensitivity increased modestly since 1992 (26.0%), and was slightly but statistically significantly better among medical patients than among surgical patients (33% versus 26%).

Construct validity. Needleman and Buerhaus ^137^ found that nurse staffing was inconsistently associated with the occurrence of pressure ulcers among medical patients from 799 hospitals in 11 states in 1997, and was independent of pressure ulcers among major surgery patients. Nursing skill mix (RN hours/licensed nurse hours) was significantly associated (in the expected direction) with the pressure ulcer rate among 352 and 295 California hospitals in 1992 and 1994, respectively, and also among 126 and 131 New York hospitals in the same years. ^138^ Total licensed nurse hours per acuity-adjusted patient day were inconsistently associated with the rate of pressure ulcers.

#### Failure To Rescue

Source. This indicator was originally proposed by Silber et al. ^31^ as a more powerful tool than the risk adjusted mortality rate to detect true differences in patient outcomes across hospitals. The underlying premise was that better hospitals are distinguished not by having fewer adverse occurrences but by more successfully averting death among (i.e., rescuing) patients who experience such complications. Silber et al's original definition was based on key clinical findings abstracted from the medical records of 2,831 cholecystectomy patients and 3,141 transurethral prostatectomy patients admitted to 531 hospitals in 1985. The key postoperative diagnoses that defined the denominator at risk of “ failure to rescue” included cardiac arrhythmias, congestive heart failure, cardiac arrest, pneumonia, pulmonary embolus, pneumothorax, renal dysfunction, stroke, wound infection, and unplanned return to surgery.

More recently, Needleman and Buerhaus ^137^ adapted failure to rescue to administrative data sets, hypothesizing that this outcome might be sensitive to nurse staffing. Their denominator definition included the ICD-9-CM codes for sepsis, pneumonia (including aspiration), acute upper gastrointestinal bleeding, shock, cardiac/respiratory arrest, deep vein thrombosis (DVT), and pulmonary embolus (PE).

##### Evidence

Construct validity. Silber and colleagues have published a series of studies establishing the construct validity of failure to rescue rates through their associations with hospital characteristics and other measures of hospital performance. Among patients admitted for cholecystectomy and transurethral prostatectomy, failure to rescue was independent of severity of illness at admission, but was significantly associated with the presence of surgical housestaff and a lower percentage of board-certified anesthesiologists. ^31^ The adverse occurrence rate was independent of this hospital characteristic. In a larger sample of 74,647 patients who underwent general surgical procedures in 1991-92, lower failure to rescue rates were found at hospitals with high ratios of registered nurses to beds. ^68^ Failure rates were strongly associated with risk adjusted mortality rates, as expected, but not with complication rates. ^143^ Finally, among 16,673 patients admitted for coronary artery bypass surgery, failure rates were lower (whereas complication rates were higher) at hospitals with magnetic resonance imaging facilities, bone marrow transplantation units, or approved residency training programs. ^32^

More recently, Needleman and Buerhaus ^137^ confirmed that higher registered nurse staffing (RN hours/adjusted patient day) and better nursing skill mix (RN hours/licensed nurse hours) were consistently associated with lower failure to rescue rates among major surgery patients from 799 hospitals in 11 states in 1997, even using administrative data to define complications. An increase from the 25^th^ to the 75^th^ percentile on these two measures of staffing was associated with 5.9% (95% CI, 1.5% to 10.2%) and 3.9% (95% CI, -1.1% to 8.8%) decreases, respectively, in the rate of failure-to-rescue among major surgery patients. ^138^ These associations were inconsistent among medical patients, in that nursing skill mix was associated with the failure-to-rescue rate (rate ratio 0.81, 95% CI 0.66–1.00) but aggregate registered nurse staffing was not (rate ratio 1.00, 95% CI 0.99–1.01). An increase from the 25^th^ to the 75^th^ percentile on nursing skill mix was associated with a 2.5% (95% CI, 0.0% to 5.0%) decrease in the failure-to-rescue rate among medical patients.

#### Foreign Body Left in During Procedure

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the Complications Screening Program (CSP “sentinel events”), along with gas gangrene, CNS abscess, anoxic brain injury, accidental puncture or laceration, wound dehiscence, and ABO/Rh transfusion reactions (all of which were omitted from this PSI). It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ It was proposed by Miller et al. ^17^ in the “Patient Safety Indicator Algorithms and Groupings.” Based on expert consensus panels, McKesson Health Solutions included this indicator in its CareEnhance Resource Management Systems, Quality Profiler Complications Measures Module.

##### Evidence

We were unable to find evidence on validity from prior studies, which is likely due to the rarity of this diagnosis.

#### Iatrogenic Pneumothorax

Source. This diagnosis code was proposed by Miller et al. ^17^ as one component of a broader indicator (“iatrogenic conditions”) in the “Patient Safety Indicator Algorithms and Groupings.” It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's Version 1.3 HCUP Quality Indicators.

##### Evidence

We were unable to find evidence on validity from prior studies, which is probably because this diagnosis code was introduced in 1994.

#### Infection Due to Medical Care

Source. This indicator was originally proposed by Iezzoni et al. as part of the Complications Screening Program (CSP 11, “miscellaneous complications”). Their definition also includes other specified and unspecified complications of procedures or medical care, air embolism, persistent postoperative fistula, minor transfusion reactions, and an array of external cause of injury codes representing various “misadventures” and “abnormal reaction of patient” during medical care, including aspiration (which were omitted from this PSI). ^10^ The University HealthSystem Consortium adopted the CSP indicator for major (#2933) and minor (#2961) surgery patients. A much narrower definition, including only 999.3 (“other infection after infusion, injection, transfusion, vaccination”) was proposed by Miller et al. ^17^ in the “Patient Safety Indicator Algorithms and Groupings.” The American Nurses Association and its state associations have identified the number of laboratory-confirmed bacteremic episodes associated with central lines per critical care patient day as a “nursing-sensitive quality indicator for acute care settings.” ^140^

##### Evidence

No evidence on validity is available from CSP studies, because this code was grouped with “miscellaneous complications.” Geraci et al. ^141^ grouped this code with sepsis (see below). Keeler et al. ^51^ grouped this code with pneumonia and hip joint infection. We were unable to find other evidence on the validity of this indicator.

#### Postoperative Hemorrhage or Hematoma

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the Complications Screening Program (CSP 24, “post-procedural hemorrhage or hematoma”), although their definition allowed either procedure (i.e., control of hemorrhage) or diagnosis (i.e., hemorrhage, hematoma, or seroma) codes. By contrast, the current definition requires either a hemorrhage diagnosis with an associated procedure to control that hemorrhage, or a hematoma diagnosis with an associated procedure to drain that hematoma. The University HealthSystem Consortium adopted the CSP indicator for medical (#2804), cardiac procedure (#2912), and major surgery (#2947) patients. It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^

##### Evidence

Coding validity. The original CSP definition had a relatively high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (83% by coders' review, 57% by physicians' review, 52% by nurse-abstracted clinical documentation, and 76% if nurses also accepted physicians' notes as adequate documentation). ^13^ – ^15^ Its confirmation rate was moderate among medical cases (49% by coders' review, 55% by physicians' review, 29% by nurse-abstracted clinical documentation, and 65% if nurses also accepted physicians' notes), partially because some cases were present at admission. An earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York in FY1993 revealed poorer confirmation rates of 34% (35/104) among major surgical cases (of whom 17 or 49% lacked laboratory or clinical evidence of significant blood loss) and 28% (24/85) among medical cases (of whom 10 or 42% lacked laboratory or clinical evidence of significant blood loss). ^145^

Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of hemorrhage codes (definition not given) were 57% (8/14) and 80% (8/10), respectively. Faciszewski et al. ^147^ aggregated postoperative hemorrhage or hematoma (998.1) with wound dehiscence (998.3), and reported a pooled confirmation rate of 17% (1/6) with 3% (1/34) sensitivity of coding among 310 patients who underwent spinal fusion at the Marshfield Clinic in 1991-92 (given an unusually broad clinical definition of these wound complications). Romano et al. ^93^ identified 6 of 16 episodes of hemorrhage or hematoma (998.1) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91; there were no false positives.

At least two studies have estimated the validity of hemorrhage codes using a gold standard based on transfusion “requirement.” Hartz and Kuhn identified only 146 of 568 (26%) episodes of bleeding (defined as requiring return to surgery or transfusion of at least 6 units of blood products) by applying this indicator (998.1) to Medicare patients who underwent coronary artery bypass surgery in Wisconsin in 1990-91; the predictive value was 75% (146/195). ^66^ In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, in which hemorrhage is defined by transfusion of at least four units of blood products within 30 days after surgery, the ICD-9-CM diagnosis (998.1) had a sensitivity of 13% and a predictive value of 10%. ^148^

Construct validity. Explicit process of care failures in the CSP validation study were relatively frequent among major surgical cases with CSP 24, but not among medical cases (66% and 13%, respectively), after excluding patients who had hemorrhage or hematoma at admission. ^16^ Cases flagged on this indicator and unflagged controls did not differ significantly on a composite of 17 generic process criteria. Similarly, cases flagged on this indicator and unflagged controls did not differ significantly on a composite of 4 specific process criteria for major surgical cases and 2 specific process criteria for medical cases in the earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York. ^145^ Physician reviewers identified potential quality problems in 37% of major surgery patients and 31% of medical patients with CSP 24 (versus 2% of unflagged controls for each risk group). ^15^

#### Postoperative Hip Fracture

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 25, “in-hospital hip fracture or fall”). Their definition also includes any documented fall, based on external cause of injury codes, which was omitted from this PSI. Needleman and Buerhaus ^137^ considered in-hospital hip fracture as an “Outcome Potentially Sensitive to Nursing,” based on input from their Technical Expert Panel, but discarded it because the “event rate was too low to be useful.” The American Nurses Association, its state associations, and the California Nursing Outcomes Coalition have identified the number of patient falls leading to injury per 1,000 patient days (based on clinical data collection) as a “nursing-sensitive quality indicator for acute care settings.” ^140^

##### Evidence

Coding validity. The original CSP definition had an adequate confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (57% by coders' review, 71% by physicians' review), but a very poor confirmation rate among medical cases (11% by both coders' and physicians' review). ^13,^ ^15^ This problem was attributable to the fact that most hip fractures among medical inpatients were actually comorbid diagnoses present at admission rather than complications of hospital care. Nurse reviews were not performed.

Construct validity. Explicit process of care failures in the CSP validation study were relatively frequent among cases with CSP 25 (76% of major surgery patients, 54% of medical patients), after excluding patients who had hip fractures at admission, but unflagged controls were not evaluated on the same criteria. ^16^ Physician reviewers identified potential quality problems in 24% of major surgery patients and 5% of medical patients with CSP 25 (versus 2% of unflagged controls for each risk group). ^15^

#### Postoperative Physiologic and Metabolic Derangements

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 20, “postoperative physiologic and metabolic derangements”). Their definition also includes (non-diabetic) hypoglycemic coma (251.0), postoperative shock (998.0), and oliguria/anuria (788.5), which were omitted from this PSI, but it excludes several codes that were included in this PSI, namely, diabetes with hyperosmolarity, diabetes with other (hypoglycemic) coma, and acute renal failure. The University HealthSystem Consortium adopted the CSP indicator for major surgery patients (#2945). Needleman and Buerhaus ^137^ identified postoperative physiologic/metabolic derangement as an “Outcome Potentially Sensitive to Nursing,” but they added fluid and electrolyte disorders (276) to the original CSP 20. Hannan et al. had earlier focused an analogous indicator exclusively on those fluid and electrolyte disorders. ^139^

##### Evidence

Coding validity. No evidence on validity is available from CSP studies. Geraci et al. ^141^ confirmed (by serum chemistry) only 5 of 15 (33%) episodes of acute renal failure (584, 586) and 12 of 34 (35%) episodes of hypoglycemia (E932.3, 251.0, 251.2, 962.3) reported on discharge abstracts of VA patients hospitalized in 1987-89 for CHF, COPD, or diabetes. The sensitivity for a 2.0 mg/dL or greater increase in serum creatinine was 28% (5/18), while the sensitivity for symptomatic diabetic hypoglycemia less than 70 mg/dL was 16% (12/76). Romano et al. ^93^ identified 2 of 2 episodes of acute renal failure or hypoglycemia (251.0, 251.2, E932.3, 584.x) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91; there were no false positives. In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, in which acute renal failure is defined as requiring dialysis within 30 days after surgery, ICD-9-CM diagnoses (585 or 788.5) had a sensitivity of 8% and a predictive value of 4%. ^148^

Construct validity. Based on two-stage review of 8,109 randomly selected deaths from 104 New York hospitals in 1985-86, Hannan et al. ^139^ reported that cases with a secondary diagnosis of fluid and electrolyte disorders were no more likely to have received care that departed from professionally recognized standards than cases without that code (2.2% versus 1.7%, OR=1.13), after adjusting for patient demographic, geographic, and hospital characteristics. However, these ICD-9-CM codes were omitted from the accepted AHRQ PSI. Needleman and Buerhaus ^137^ found that nurse staffing was independent of the occurrence of metabolic derangement among major surgery patients from 799 hospitals in 11 states in 1997.

#### Postoperative Pulmonary Embolism or Deep Vein Thrombosis

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 22, “venous thrombosis and pulmonary embolism”), although their definition was slightly narrower. It was one of AHRQ's original HCUP Quality Indicators ^144^ for major surgery and invasive vascular procedure patients. Needleman and Buerhaus ^137^ identified DVT/PE as an “Outcome Potentially Sensitive to Nursing,” using the same CSP definition. The Health Care Financing Administration (now CMS) selected “venous thrombosis or pulmonary embolism following selected inpatient surgical procedures” as one of its surveillance measures of Medicare quality of care. ^149^ A code introduced in 1995 (415.11) that maps to this indicator in the final AHRQ PSI was proposed by Miller et al. ^17^ as one component of a broader indicator (“iatrogenic conditions”) in the “Patient Safety Indicator Algorithms and Groupings.”

##### Evidence

Coding validity. CSP 22 had a moderately high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (59% by coders' review, 70% by physicians' review, 60% by nurse-abstracted clinical documentation, and 68% if nurses also accepted physicians' notes as adequate documentation). Its confirmation rate among medical cases was poor (32% by coders' review, 28% by physicians' review, 32% by nurse-abstracted clinical documentation, and 39% if nurses also accepted physicians' notes as adequate documentation) because many cases were present at admission. ^13^ – ^15^

Geraci et al. ^34^ confirmed only 1 of 6 episodes of DVT (451.1x) or PE (415.1) reported on discharge abstracts of Veterans Affairs (VA) patients hospitalized in 1987-89 for CHF, COPD, or diabetes; the sensitivity was 100% (1/1). Among Medicare hip fracture patients from 297 hospitals in 1985-86, by contrast, Keeler et al. ^51^ confirmed 11 of 20 (88%) reported PE cases, and failed to ascertain just 6 cases (65% sensitivity) using ICD-9-CM codes. For DVT (451.x, 453.x, 997.2), they found just 1 of 6 cases using ICD-9-CM codes (but no false positive codes). Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of DVT codes (definition not given) were 50% (4/8) and 100%, respectively. Romano et al. ^93^ identified 5 of 6 episodes of thromboembolic disease (415.1x, 451.1x, 451.2, 451.8x, 451.9, 453.2, 453.8, 453.9) using discharge abstracts of diskectomy patients at 30 California hospitals; there was one false positive. In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, the ICD-9-CM diagnosis of PE (415.1) had a sensitivity of 49% and a predictive value of 48% for PE within 30 days after surgery. ^148^ Although Best et al. also reported on the ability to use administrative data to find cases of DVT, their results cannot be interpreted due to misapplication of ICD-9-CM.

Other studies using the California patient discharge data set have demonstrated that ICD-9-CM codes for DVT and PE have high predictive value when listed as the principal diagnosis for readmissions after major orthopedic surgery (i.e., 17/17 or 100%) or after inferior vena cava filter placement (i.e., 64/65 or 98%). ^150^ However, these findings do not directly address the validity of DVT/PE as a secondary diagnosis among patients treated by anticoagulation.

Construct validity. Explicit process of care failures in the CSP validation study were relatively frequent among both major surgical and medical cases with CSP 22 (72% and 69%, respectively), after disqualifying cases in which DVT/PE was actually present at admission. ^16^ Major surgical cases flagged on this indicator and unflagged controls differed marginally (11% versus 4%, p=0.09) on a composite of 17 generic process criteria; medical cases and controls were not evaluated on the same criteria. Physician reviewers identified potential quality problems in 50% of major surgery patients and 20% of medical patients with CSP 22 (versus 2% of unflagged controls for each risk group). ^15^

Needleman and Buerhaus ^137^ found that nurse staffing was independent of the occurrence of DVT/PE among both major surgical or medical patients from 799 hospitals in 11 states in 1997. However, Kovner and Gergen reported that among 506 community hospitals in the 1993 NIS, having more registered nurse hours and non-RN hours per adjusted patient day were both associated with a lower rate of DVT/PE after major surgery. ^126^ Nurse staffing was not associated with the rate of DVT/PE after invasive vascular procedures.

#### Postoperative Respiratory Failure

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 3, “postoperative pulmonary compromise”). Their broader definition also includes not just respiratory failure, but also pulmonary congestion, other (or postoperative) pulmonary insufficiency, and acute pulmonary edema, which were omitted from this PSI. The University HealthSystem Consortium (#2927) and AHRQ's original HCUP Quality Indicators ^144^ adopted the CSP indicator for major surgery patients. Needleman and Buerhaus ^137^ identified postoperative pulmonary failure as an “Outcome Potentially Sensitive to Nursing,” using the original CSP definition.

##### Evidence

Coding validity. CSP 3 had a relatively high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (72% by coders' review, 75% by physicians' review). ^13,^ ^15^ Nurse reviews were not performed. An earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York in FY1993 revealed a similarly high confirmation rate of 72% (66/92) among major surgical cases, although 27% of those patients (18/66) had inadequate clinical documentation of the diagnosis. ^145^

Geraci et al. ^34^ confirmed 1 of 2 episodes of respiratory failure (518.81, 518.82) reported on discharge abstracts of VA patients hospitalized in 1987-89 for CHF or diabetes; the sensitivity for respiratory decompensation requiring mechanical ventilation was 25% (1/4). Best et al. ^148^ reported on the ability to use administrative data to find cases of “unplanned intubation,” but their results cannot be interpreted due to misapplication of ICD-9-CM.

Construct validity. Explicit process of care failures in the CSP validation study were slightly but not significantly more frequent among major surgical cases with CSP 3 than among unflagged controls (52% versus 46%). ^16^ Indeed, cases flagged on this indicator were significantly less likely than unflagged controls (24% versus 64%) to have at least one of four specific process-of-care problems in the earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York. ^145^ Physician reviewers identified potential quality problems in 20% of major surgery patients with CSP 3 (versus 2% of unflagged controls). ^15^

Needleman and Buerhaus ^137^ found that nurse staffing was independent of the occurrence of pulmonary failure among major surgery patients from 799 hospitals in 11 states in 1997. However, Kovner and Gergen reported that among 506 community hospitals in the 1993 NIS, having more registered nurse hours per adjusted patient day was associated with a lower rate of “pulmonary compromise” after major surgery. ^126^

#### Postoperative Sepsis

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the Complications Screening Program (CSP 7, “septicemia”), although their definition also includes unspecified bacteremia, which was omitted from this PSI. Needleman and Buerhaus ^137^ identified sepsis as an “Outcome Potentially Sensitive to Nursing,” using the same CSP definition.

##### Evidence

Coding validity. No evidence on validity is available from CSP studies. Barbour ^151^ reported that only 38% (53/141) of discharge abstracts from 5 VA medical centers in 1990 with a diagnosis of sepsis (038.x) actually had hospital-acquired sepsis. However, this review was not limited to cases with a secondary diagnosis of sepsis, and sensitivity could not be evaluated. Massanari et al. ^152^ identified 79% of cases of “nosocomial bacteremia” using 1984 hospital discharge data from the University of Iowa, but no definitions were provided. Geraci et al. ^34^ confirmed (by blood culture) only 2 of 15 episodes of sepsis or “other infection” (038.x, 999.3) reported on discharge abstracts of VA patients hospitalized in 1987-89 for CHF, COPD, or diabetes; the sensitivity for a positive blood culture was 50% (2/4). Romano et al. ^93^ identified 2 of 3 episodes of sepsis or bacteremia (038.x, 707.0) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91; there were no false positives. Belio-Blasco et al. ^153^ reported that “discharge forms” had a sensitivity of 18% (7/39) and a specificity of 100% for identifying nosocomial bacteremia among surgical patients in a Spanish teaching hospital. In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, in which “systemic sepsis” is defined by a positive blood culture and systemic manifestations of sepsis within 30 days after surgery, the ICD-9-CM diagnosis (038.x) had a sensitivity of 37% and a predictive value of 30%. ^148^

Construct validity. Needleman and Buerhaus ^137^ found that nurse staffing was independent of the occurrence of sepsis among both major surgical or medical patients from 799 hospitals in 11 states in 1997.

#### Postoperative Wound Dehiscence

Source. An indicator on this topic (998.3) was originally proposed by Hannan et al. to target “cases that would have a higher percentage of quality of care problems than cases without the criterion, as judged by medical record review.” ^139^ The same code was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ Iezzoni et al. ^10^ identified an associated procedure code for reclosure of an abdominal wall dehiscence (54.61), and included both codes in the CSP (CSP “sentinel events” and CSP 9, “reopening of surgical site,” respectively). Miller et al. ^17^ suggested the use of both codes (as “wound disruption”) in the original “AHRQ PSI Algorithms and Groupings.”

##### Evidence

Coding validity. No evidence on validity is available from CSP studies. Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of 998.3 were both 100% (4/4). Faciszewski et al. ^147^ aggregated wound dehiscence (998.3) with postoperative hemorrhage or hematoma (998.1), and reported a pooled confirmation rate of 17% (1/6) with 3% (1/34) sensitivity of coding among 310 patients who underwent spinal fusion at the Marshfield Clinic in 1991-92 (given an unusually broad clinical definition of these wound complications). In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, in which dehiscence is defined as fascial disruption within 30 days after surgery, the ICD-9-CM diagnosis of wound dehiscence (998.3) had a sensitivity of 25% and a predictive value of 23%. ^148^ This code (998.3) was ultimately removed from the accepted PSI because our clinical panel was concerned that the ICD-9-CM definition was too broad and failed to distinguish skin from fascial separation.

Construct validity. Based on two-stage review of 8,109 randomly selected deaths from 104 New York hospitals in 1985-86, Hannan et al. ^139^ reported that cases with a secondary diagnosis of 998.3 (wound disruption) were 3.0 times more likely to have received care that departed from professionally recognized standards than cases without that code (4.3% versus 1.7%), after adjusting for patient demographic, geographic, and hospital characteristics. In 3 of these 7 cases (44%) of substandard care, the patient's death was attributed at least partially to that care. However, this code was removed from the accepted PSI after discussions with our clinical panel.

#### Technical Difficulty With Procedure

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP, although unlike the final PSI, its codes were split between two CSP indicators (CSP 27, “technical difficulty with medical care,” and “sentinel events”). The latter indicator also includes gas gangrene, CNS abscess, anoxic brain injury, foreign body left in, wound dehiscence, and ABO/Rh transfusion reactions, all of which were omitted from this PSI. The former indicator also includes failure of sterile precautions, mechanical failure of instrument or apparatus, and “contaminated or infected blood, other fluid, drug,” etc, although these codes were not included in the final definition of this PSI. It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ The University HealthSystem Consortium adopted CSP 27 as an indicator for medical (#2806) and major surgery (#2956) patients. Miller et al. ^17^ also split this set of ICD-9-CM codes into two broader indicators (“miscellaneous misadventures” and “E codes”) in the original “AHRQ PSI Algorithms and Groupings.” Based on expert consensus panels, McKesson Health Solutions included one component of this PSI (998.2, “Accidental Puncture or Laceration”) in its CareEnhance Resource Management Systems, Quality Profiler Complications Measures Module.

##### Evidence

Coding validity. No evidence on validity is available from CSP studies. A study of laparoscopic cholecystectomy in 18 Ontario hospitals in 1991-95 ^154^ found that 95% (99/104) of patients with an ICD-9 code of 998.2 or E870.0 had a confirmed injury to the bile duct or gallbladder. However, only 27% had a clinically significant injury that required any intervention; sensitivity of reporting was not evaluated. A similar study of all cholecystectomies performed in Western Australia between 1988 and 1994 reported that these two ICD-9 codes had a sensitivity of 40% (19/48) and a predictive value of 23% (19/84) in identifying bile duct injuries. ^155^ Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of codes describing “miscellaneous mishaps during or as a direct result of surgery” (definition not given) were 86% (6/7) and 55% (6/11), respectively. Romano et al. ^93^ identified 19 of 45 episodes of accidental puncture or laceration (998.2, E870.0, or related procedure) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91; there was one false positive.

#### Transfusion Reaction

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the Complications Screening Program (CSP “sentinel events”), along with gas gangrene, CNS abscess, anoxic brain injury, accidental puncture or laceration, wound dehiscence, and foreign body left in (all of which were omitted from this PSI). It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ It was proposed by Miller et al. ^17^ in the original “AHRQ PSI Algorithms and Groupings,” although their definition also includes minor transfusion reactions (999.8), which was omitted from this PSI.

##### Evidence

We were unable to find evidence on validity from prior studies, most likely because this complication is quite rare.

### Accepted Obstetric Indicators

#### Birth Trauma - Injury to Neonate

Source. This indicator has been widely used in the obstetric community, although it is most commonly based on chart review rather than administrative data. It was proposed by Miller et al. ^17^ in the original “AHRQ PSI Algorithms and Groupings,” although their definition also includes injury to the brachial plexus (767.6), which was excluded from this PSI. Based on expert consensus panels, McKesson Health Solutions included a broader version of this indicator (767.xx) in its CareEnhance Resource Management Systems, Quality Profiler Complications Measures Module.

##### Evidence

Coding validity. A study of 669 newborns at Georgetown University Hospital who had a discharge diagnosis of birth trauma (codes not specified) found that only 25% (164/669) had sustained a significant injury to the head, neck, or shoulder. ^156^ The remaining patients either had superficial injuries or injuries inferior to the neck. We were unable to find other evidence on the validity of this indicator. Towner et al. linked California maternal and infant discharge abstracts from 1992 through 1994, but they used only infant discharge abstracts to describe the incidence of neonatal intracranial injury, and they did not report the extent of agreement between the two data sets. ^157^

#### Obstetric Trauma (All Delivery Types)

Source. An overlapping subset of this indicator (third or fourth-degree perineal laceration [664.2x–664.3x]) has been adopted by the Joint Commission for the Accreditation of Healthcare Organizations (JCAHO) as a core performance measure for “pregnancy and related conditions” (PR-25). (The JCAHO indicator was less preferred by the clinical panelists than a definition restricted to fourth degree lacerations, so the JCAHO definition was retained for exploration as an Experimental indicator.) Based on expert consensus panels, McKesson Health Solutions included the JCAHO indicator in its CareEnhance Resource Management Systems, Quality Profiler Complications Measures Module. Fourth degree laceration (664.3x), one of the codes mapped to this PSI, was included as one component of a broader indicator (“obstetrical complications”) in AHRQ's original HCUP Quality Indicators. ^144^

##### Evidence

Coding validity. In a stratified probability sample of 1,611 vaginal and cesarean deliveries from 51 California hospitals in 1992-93, the weighted sensitivity and predictive value of coding for third and fourth degree lacerations and vulvar/perineal hematomas (based on either diagnosis or procedure codes) were 89% (311/340) and 90% (311/337), respectively. ^158^ The authors did not report coding validity for third and fourth degree lacerations separately. We were unable to find other evidence on validity from prior studies.

### Experimental Indicators

#### Aspiration Pneumonia

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 2, “aspiration pneumonia”). Needleman and Buerhaus ^137^ identified postoperative pneumonia as an “Outcome Potentially Sensitive to Nursing,” but their definition aggregated bacterial, aspiration (507.0), and “hypostatic” (514) pneumonia. The University HealthSystem Consortium adopted the CSP indicator for major surgery patients (#2924).

##### Evidence

Coding validity. CSP 2 had a moderate confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (77% by coders' review, 59% by physicians' review, 50% by nurse-abstracted clinical documentation, and 85% if nurses also accepted physicians' notes as adequate documentation). ^13^ – ^15^ Geraci et al. ^34^ confirmed (by chest radiography) 0 of 7 episodes of aspiration pneumonia (482.9, 507.0) reported on discharge abstracts of VA patients hospitalized in 1987-89 for CHF, COPD, or diabetes; the sensitivity for a new alveolar infiltrate was 0% (0/5).

Construct validity. Explicit process of care failures in the CSP validation study were relatively frequent among major surgical cases with CSP 2 (69%), after excluding two patients who had aspiration pneumonia at admission. ^16^ Cases flagged on this indicator and unflagged controls did not differ significantly on a composite of 17 generic process criteria. Physician reviewers identified potential quality problems in 21% of major surgery patients with CSP 2 (versus 2% of unflagged controls). ^15^

Needleman and Buerhaus ^137^ found that higher registered nurse staffing (RN hours/adjusted patient day) and better nursing skill mix (RN hours/licensed nurse hours) were consistently associated with the occurrence of pneumonia (including aspiration and “hypostatic” pneumonia) among medical patients from 799 hospitals in 11 states in 1997. An increase from the 25^th^ to the 75^th^ percentile on these two measures of staffing was associated with 2.7% (95% CI, -0.4% to 5.8%) and 6.4% (95% CI, 2.8% to 10.0%) decreases, respectively, in the rate of pneumonia. ^159^ Skill mix was “weakly” associated with the rate of pneumonia among major surgical patients. Nursing skill mix was significantly associated (in the expected direction) with the pneumonia rate among 352 and 295 California hospitals in 1992 and 1994, respectively, but not among 126 and 131 New York hospitals in the same years. ^138^ Total licensed nurse hours per acuity-adjusted patient day were not associated with the pneumonia rate, except in California in 1994, where the association was actually positive.

#### CABG Following PTCA

Source. This indicator was developed by the University HealthSystem Consortium (#2906) to identify patients who experienced a complication of PTCA that required urgent surgical repair. This indicator has been used in several studies of PTCA outcomes and the relationship between volume and outcome. ^127^ – ^135^

##### Evidence

We were unable to find evidence on validity from prior studies, except insofar as higher hospital angioplasty volume has consistently been associated with lower risk of CABG following PTCA. ^127^ – ^135^ Physician volume generally has an independent effect on the risk of CABG following PTCA, confirming that this measure is sensitive to operator experience and skill, ^132^ – ^135^ although some recent data suggest that this effect may disappear at high-volume hospitals. ^160^ One study involving Medicare inpatient claims from 1987 through 1990 also showed that CABG following PTCA was slightly less frequent at hospitals with “major” medical school affiliations than at other hospitals. ^131^

#### Decubitus Ulcer in High-Risk Patients

Source. This variation of Accepted PSI “Decubitus ulcer” was designed in response to concerns that the accepted indicator excludes the subset of patients at highest risk of developing pressure ulcers if they receive inadequate care in the hospital. It differs from Accepted PSI “Decubitus Ulcer” in that the denominator population is limited to patients with hemiplegia, paraplegia, or quadriplegia, and patients admitted from long term care facilities. The American Nurses Association, its state associations, and the California Nursing Outcomes Coalition have identified the total prevalence of inpatients with Stage I, II, III, or IV pressure ulcers (based on clinical data collection) as a “nursing-sensitive quality indicator for acute care settings.” ^140^

##### Evidence

We were unable to find evidence on validity from prior studies, but this is simply a modified version of an indicator on the accepted list. Validity may be lower in this setting, if a substantial proportion of pressure sores are pre-existing, but may be higher if these patients are especially sensitive to the effects of suboptimal nursing care.

#### In-Hospital Fractures Possibly Related to Falls

Source. This indicator was developed by our clinical panels, based on Accepted indicator “Postoperative hip fracture.” Needleman and Buerhaus ^137^ considered in-hospital fall or fracture as an “Outcome Potentially Sensitive to Nursing,” based on input from their Technical Expert Panel, but discarded it because the “event rate was too low to be useful.” The American Nurses Association, its state associations, and the California Nursing Outcomes Coalition have identified the number of patient falls leading to injury per 1,000 patient days (based on clinical data collection) as a “nursing-sensitive quality indicator for acute care settings.” ^140^

##### Evidence

Coding validity. Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of “fall and fracture” codes (definition not given) were 80% (4/5) and 100%, respectively. We were unable to find other evidence for this indicator.

#### Intraoperative Nerve Compression Injuries

Source. A subset of this indicator (brachial plexus lesions [353.0]) was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 13, “postoperative complications relating to central or peripheral nervous system”). The University HealthSystem Consortium adopted this CSP indicator for major surgery patients (#2934). However, this indicator was extensively revised after discussions with our clinical panels.

##### Evidence

We were unable to find evidence on validity from prior studies, because this complication is quite rare. Best et al. ^148^ reported on the ability to use administrative data to find cases of “other neurologic” (including peripheral nerve) deficits, but their results cannot be interpreted due to misapplication of ICD-9-CM.

#### Malignant Hyperthermia

Source. This indicator was created after review of ICD-9-CM codes, and discussions with our clinical panel.

##### Evidence

We were unable to find evidence on validity from prior studies, because this diagnosis code was introduced in 1998.

#### Postoperative Acute Myocardial Infarction

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 14, “postoperative acute myocardial infarction”). The University HealthSystem Consortium (#2935) and AHRQ's original HCUP Quality Indicators ^144^ adopted this CSP indicator for major surgery patients.

##### Evidence

Coding validity. CSP 14 had a high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (84% by coders' review, 95% by physicians' review, 81% by nurse-abstracted clinical documentation, and 89% if nurses also accepted physicians' notes as adequate documentation). ^13^ – ^15^ An earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York in FY1993 revealed a similarly high confirmation rate of 84% (69/82) among major surgical cases, although 39% of those patients (27/69) had neither electrocardio­graphic nor enzyme evidence supporting the diagnosis. ^145^

Geraci et al. ^141^ identified 0 of 3 AMI episodes (410.x1) using the discharge abstracts of VA patients hospitalized in 1987-89 for CHF, COPD, or diabetes. In comparison with the VA's National Surgical Quality Improvement Program database from 123 hospitals in 1994-95, the ICD-9-CM diagnosis of AMI (410.xx) had a sensitivity of 58% and a predictive value of 47% for Q-wave infarctions within 30 days after surgery. ^148^ By contrast, the 1985 National DRG Validation Study suggested that the sensitivity of ICD-9-CM 410.xx exceeds 75%, even when it is coded as a secondary diagnosis (n=67) rather than as the reason for admission. ^161^

Construct validity. Explicit process of care failures in the CSP validation study were only moderately frequent among major surgical cases with CSP 14 (46%). ^16^ Cases flagged by this indicator and unflagged controls differed significantly (p<0.02) on a composite of 17 generic process criteria, but the latter group actually demonstrated worse performance. Similarly, cases flagged on this indicator were significantly less likely than unflagged controls (29% versus 57%) to have at least one of seven specific process-of-care problems in the earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York. ^145^ Physician reviewers identified potential quality problems in 22% of major surgery patients with CSP 14 (versus 2% of unflagged controls). ^15^ Kovner and Gergen reported that among 506 community hospitals in the 1993 NIS, having more registered nurses per adjusted patient day was not associated with lower rates of AMI after major surgery. ^126^

#### Postoperative Iatrogenic Complications - Cardiac System

Source. This indicator was originally proposed by Hannan et al. as a criterion for targeting “cases that would have a higher percentage of quality of care problems than cases without the criterion, as judged by medical record review.” ^139^ It was endorsed by Iezzoni et al. ^10^ as one component of a much broader indicator (CSP 26, “iatrogenic complications”) in the CSP. The definition of that indicator includes central nervous system, cardiac, peripheral vascular, respiratory, gastrointestinal, urinary, and unspecified amputation stump complications, as well as complications affecting other body systems. It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ The University HealthSystem Consortium adopted this CSP indicator for cardiac procedure patients (#2913).

##### Evidence

Coding validity. CSP 26 had a very high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (92% by coders' review) and a borderline confirmation rate among medical cases (59% by coders' review). ^13^ Physician reviews were not performed. Faciszewski et al. ^147^ confirmed only 20% (2/10) of reported cases of cardiac complications (997.1) among 310 patients who underwent spinal fusion at the Marshfield Clinic in 1991-92. The sensitivity of coding for this complication was 40% (2/5). Among 185 total knee replacement patients from 5 Ontario hospitals in 1984-90, Hawker et al. ^146^ found that the sensitivity and predictive value of cardiac complication codes (definition not given) were 67% (6/9) and 86% (6/7), respectively. Romano et al. ^93^ identified 2 of 5 episodes of cardiac complications (with 2 false positives) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91.

Construct validity. Explicit process of care failures in the CSP validation study were slightly but not significantly more frequent among cases with CSP 26 (58% surgical, 9% medical) than among unflagged controls (46% surgical, 5% medical). Based on two-stage review of 8,109 randomly selected deaths from 104 New York hospitals in 1985-86, Hannan et al. ^139^ reported that cases with a secondary diagnosis of 997.1 (cardiac) were 3.4 times more likely to have received care that departed from professionally recognized standards than cases without that code (7.1% versus 1.7%), after adjusting for patient demographic, geographic, and hospital characteristics. In 25 of these 33 cases (76%) of substandard care, the patient's death was attributed at least partially to that care.

#### Postoperative Iatrogenic Complications - Nervous System

Source. This diagnosis code was originally proposed by Iezzoni et al. ^10^ as one component of a much broader indicator (CSP 26, “iatrogenic complications”), which was part of the CSP. Their definition includes central nervous system, cardiac, peripheral vascular, respiratory, gastrointestinal, urinary, and unspecified amputation stump complications, as well as complications affecting other body systems. It was also included as one component of a broader indicator (“adverse events and iatrogenic complications”) in AHRQ's original HCUP Quality Indicators. ^144^ The University HealthSystem Consortium adopted this CSP indicator for cardiac procedure patients (#2913).

##### Evidence

Coding validity. CSP 26 had a very high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (92% by coders' review) and a borderline confirmation rate among medical cases (59% by coders' review). ^13^ Physician reviews were not performed. Romano et al. ^93^ identified 1 of 2 episodes of CNS complications (with 4 false positives) using discharge abstracts of diskectomy patients at 30 California hospitals in 1990-91.

Construct validity. Explicit process of care failures in the CSP validation study were slightly but not significantly more frequent among cases with CSP 26 (58% surgical, 9% medical) than among unflagged controls (46% surgical, 5% medical).

#### Reopening of Surgical Site

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 9, “reopening of surgical site”), although their definition was slightly broader than the proposed PSI (i.e., it includes revision of corrective procedure on heart (35.95) and reclosure of postoperative disruption of the abdominal wall (54.61)). The University HealthSystem Consortium adopted this CSP indicator for major surgery patients (#2930).

##### Evidence

Coding validity. CSP 9 had a relatively high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (97% by coders' review, 61% by physicians' review, 84% by nurse-abstracted clinical documentation). ^13^ – ^15^

Construct validity. Explicit process of care failures in the CSP validation study were only moderately frequent among major surgical cases with CSP 9 (43%), after excluding one patient who had this complication at admission, ^16^ but unflagged controls were not evaluated on the same criteria. Physician reviewers identified potential quality problems in 48% of major surgery patients with CSP 9 (versus 2% of unflagged controls). ^15^

#### Suture of Laceration

Source. This indicator was originally proposed by Iezzoni et al. ^10^ as part of the CSP (CSP 17, “procedure-related perforation or laceration”). Their definition includes diagnosis codes (not included in this PSI) for spontaneous perforation of the esophagus (530.4), intestine (569.83), gallbladder (575.4), or bile duct (576.3), as well as procedure codes for repair of various organ lacerations. It was utilized by Miller et al. ^17^ in the original “AHRQ PSI Algorithms and Groupings,” although their definition added suture of laceration of diaphragm (34.82), small intestine (46.73), and anus (49.71). These additional codes were included in this PSI, along with a few more codes (e.g. laceration of nerve). The University HealthSystem Consortium adopted this CSP indicator for major surgery patients (#2941).

##### Evidence

Coding validity. This cluster is very similar to CSP 17, which had a relatively high confirmation rate among major surgical cases in the FY1994 Medicare inpatient claims files from California and Connecticut (71% by coders' review, 58% by physicians' review, 69% by nurse-abstracted clinical documentation, and 75% if nurses also accepted physicians' notes as adequate documentation). ^13^ – ^15^ The CSP criteria were not fully successful in excluding pre-admission trauma, but it is not clear which code(s) accounted for this problem. An earlier study of elderly Medicare beneficiaries from Massachusetts, Alabama, Iowa, and New York in FY1993 revealed a similar confirmation rate of 70% (65/93) among major surgical cases, although 18% of those patients (12/65) lacked clear physical examination evidence of the diagnosis. ^145^

Construct validity. Physician reviewers identified potential quality problems in 36% of major surgery patients with CSP 17 (versus 2% of unflagged controls). ^15^ In the New York SID from 1997, nursing expertise (full-time and part-time RNs as a proportion of all licensed nurses) below the statewide median level was associated with a higher unadjusted rate of this indicator (24 versus 15 events per 10,000 discharges). ^17^

### Experimental Obstetric Indicators

#### Obstetric Wound Complications - Cesarean Delivery

Source. Disruption of a cesarean wound (674.1x) was proposed by Miller et al. ^17^ as part of a broader indicator (“obstetrical misadventures”) in the original “AHRQ PSI Algorithms and Groupings.” It was also included as one component of a broader indicator (“obstetrical complications”) in AHRQ's original HCUP Quality Indicators. ^144^

##### Evidence

Coding validity. Weiss et al. ^162^ reviewed 636 deliveries in Massachusetts hospitals in 1990-97 reported to have had cesarean wound disruption (674.1x), and found that 29% (179/636) were actually uterine ruptures before or during labor. Therefore, the maximum possible predictive value of this diagnosis was 71%. In a stratified probability sample of 1,611 vaginal and cesarean deliveries from 51 California hospitals in 1992-93, the sensitivity and predictive value of wound disruption, hematoma, or infection (based on either diagnosis or procedure codes) were 27% and 91%, respectively. ^163^ We were unable to find other evidence on validity from prior studies.

#### Obstetric Wound Complications - Vaginal Delivery

Source. This variation of the above PSI was designed as a “sister” measure for vaginal deliveries, based on review of ICD-9-CM codes and discussions with the clinical panel. Perineal wound disruption (674.2x), one of the codes mapped to this PSI, was also included as one component of a broader indicator (“obstetrical complications”) in AHRQ's original HCUP Quality Indicators.

##### Evidence

Coding validity. In a stratified probability sample of 1,611 vaginal and cesarean deliveries from 51 California hospitals in 1992-93, the weighted sensitivity and predictive value of wound disruption, hematoma, or infection (based on either diagnosis or procedure codes) were 27% (18/37) and 91% (18/21), respectively. ^163^ We were unable to find other evidence on validity from prior studies.

#### Other Obstetric Complications

Source. These diagnosis codes were proposed by Miller et al. ^17^ as part of a broader indicator (“obstetrical misadventures”) in the original “AHRQ PSI Algorithms and Groupings.” They include codes 668.x and 669.x (pulmonary, cardiac, and central nervous system complications, other specified and unspecified complications of anesthesia or sedation, shock and other major complications of obstetric procedures, acute postpartum renal failure). All of the codes mapped to this PSI were included as part of a broader indicator (“obstetrical complications”) in AHRQ's original HCUP Quality Indicators. ^144^

##### Evidence

Coding validity. In a stratified probability sample of 1,611 vaginal and cesarean deliveries from 51 California hospitals in 1992-93, the weighted sensitivity and predictive value of coding for cardiac (668.1x, 995.4) and pulmonary (668.2x) complications of obstetric anesthesia or analgesia were 24% (8/16) and 97% (8/9), respectively. ^163^ The authors did not report coding validity for the other components of this PSI. We were unable to find other evidence on validity from prior studies.

#### Postpartum Urinary Tract Infection

Source. This indicator was created after review of ICD-9-CM codes and discussions with the clinical panel. The definition is specific to “infections of the genitourinary tract” that are labeled as postpartum complications, although some of these infections may have originated in the antepartum period.

##### Evidence

Coding validity. In a stratified probability sample of 1,611 vaginal and cesarean deliveries from 51 California hospitals in 1992-93, the weighted sensitivity and predictive value of postpartum urinary tract infection were 20% (5/13) and 41% (5/8), respectively. ^163^ We were unable to find other evidence on validity from prior studies, because this indicator has not previously been used as a measure of quality.

#### Third or Fourth Degree Obstetric Lacerations

Source. This indicator has been adopted by the JCAHO as a core performance measure for “pregnancy and related conditions” (PR-25). A revised version of this indicator, based on input from our clinical panel, qualified as Accepted indicators, “Obstetric trauma.”

##### Evidence

Coding validity. In a stratified probability sample of 1,611 deliveries from 51 California hospitals in 1992-93, the weighted sensitivity and predictive value of coding for third and fourth degree lacerations and vulvar/perineal hematomas (based on either diagnosis or procedure codes) were 89% (311/340) and 90% (311/337), respectively. ^158^ The authors did not report coding validity for third and fourth degree lacerations separately. We were unable to find other evidence on validity from prior studies.

#### Uterine Rupture

Source. This indicator has been widely used for monitoring the impact of vaginal birth after cesarean delivery, which is associated with an increased incidence of uterine rupture. ^164,^ ^165^

##### Evidence

Coding validity. Weiss et al. ^162^ reviewed 615 deliveries in Massachusetts hospitals in 1990-97 reported to have had uterine rupture before or during labor (665.0x, 665.10, 665.11), and confirmed 51% (306/615). The maximum possible sensitivity was 64% (306/480), because some uterine ruptures were miscoded as cesarean wound disruption (674.1x). We describe this estimate as the “maximum possible sensitivity” because false negatives were only captured if they were miscoded with 674.1.

Construct validity. Although we found no data on how often quality-of-care problems are associated with uterine rupture, Gregory et al. showed that women in California who delivered at hospitals with high attempted VBAC (vaginal birth after cesarean) rates in 1995 were more likely to have successful VBAC, but also more likely to experience uterine rupture, than women who delivered at hospitals with lower VBAC rates. This finding is consistent with the construct that high uterine rupture rates reflect an overly aggressive approach to VBAC. Induction of labor with prostaglandins has been associated with a major increase in the risk of uterine rupture (RR=15.6). ^164,^ ^165^

## Section 3B. Indicator Selection

Indicator selection consisted of a multi-stage process, shown in Flow Diagram 1. Promising indicators identified from the literature or other sources were assessed for face validity by clinicians through a structured process. The first round specifications of indicators were usually modified to varying extents based on clinical and coding input. Then for each indicator, the revised specification was rated by panelists on a number of dimensions, but most importantly the likely usefulness of the indicator as a screen for potentially preventable complications of care. The usefulness rating provided the primary filter by which indicators were grouped into three categories representing the more promising to less useful indicators — a.) Accepted, b.) Experimental, or c.) Rejected. Table 11 provides a summary of Accepted PSIs and the panel ratings show that these indicators were rated as fairly useful by either practically all of the panelists (Acceptable) or most with minimal dissent from those rating it lower (Acceptable (-)). Table 12 lists the Experimental PSIs, those measures which panelists were less sanguine about than those in the Accepted indicator set or that were more problematic to specify according to the intent of the panel discussion. Each indicator in the Experimental indicator set has some positive characteristics, along with some relatively important potential limitations. Table 13 lists Rejected indicators, indicators that received low ratings by the panelists, and did not merit further exploration. The footnotes to these tables summarize idiosyncratic reasons for the categorization rationale.

Table 12 Experimental Indicators

Indicator Name | Multi-specialty Panel Evaluation^a^ | | Surgical Panel Evaluation^a^ | | Definition Used
Aspiration pneumonia | S2 | Unclear | 2 | Unclear | Same
CABG after PTCA^b^ | P1 | Acceptable
Decubitus ulcer in high risk patients^c^
In-hospital fractures possibly related to falls^d^ | M1 | Acceptable
Intraoperative nerve compression injuries^e^ | S3 | Acceptable | 3 | Acceptable | Surgical
Malignant hyperthermia^f^ | S3 | Acceptable | 1 | Acceptable (-) | Same
Postoperative acute myocardial infarction^g^ | S1 | Unclear (-) | 3 | Acceptable (-) | Surgical
Postoperative iatrogenic complications - cardiac system^h^ | P1 | Not rated separately
Postoperative iatrogenic complications - nervous system^h,i^ | P1 | Not rated separately
Reopening of surgical site^j^ | S2 | Unclear | 3 | Acceptable (-) | Surgical
Suture of laceration^k^ | S2 | Acceptable | 2 | Unclear (-) | Surgical
Obstetric wound complications-cesarean section | O2 | Acceptable
Obstetric wound complications-vaginal delivery | O2 | Unclear
Other obstetric complications | O2 | Unclear
Post-partum urinary tract infection | O2 | Acceptable (-)
Third or fourth degree obstetric laceration (JCAHO)^l^
Uterine rupture^m^

a M, P, O, S refer to Medical, Procedure, Obstetric or Surgery Multi-specialty Panels and their identifying number (see Appendix B for further detail). 1,2,3 refers to the Surgical Panel, if reviewed by Surgical Panel (see Appendix B). “Acceptable” indicates that the indicator was rated as useful by almost all panelists. “Acceptable (-)” indicates that the indicator was rated as useful by most panelists, although a few rated it as less useful (but not as poor). “Unclear” indicates that almost all panelists rated the usefulness of the indicator as moderate. “Unclear (-)” indicates that most of the panelists rated the usefulness as moderate, although a few rated it as less useful. Panel overall ratings are described in detail Clinician Panel Review Methods (Section 2D) under Tabulation of Results subsection.

b Accepted by panel, but lack of review by physicians performing PTCA led to demoting indicator.

c Indicator suggested by panel, with concerns, and by AHRQ.

d This indicator was defined as closely to the panel suggestion as possible, but empirical analysis showed higher fracture rates in non-elderly men. Further analysis led to exclusions and a more limited list of fractures to reduce the likelihood of capturing fractures unrelated to falls. However, the problem still persists to some degree. We therefore demoted the indicator to the experimental list and retained a CSP based version of the hip fracture indicator on the accepted list.

e This indicator is extremely rare, leading to questions regarding coding and operationalization. This indicator requires the code 997.09 which was not added until October 1995. This indicator is invalid before that date.

f This code (995.86) was added in October 1998 and thus this indicator is invalid before this date. Although accepted by panels, with one dissent, we cannot evaluate because data sources date only to 1997.

g This indicator was rejected by the multi-specialty panel (median=4), but accepted by the surgical panel.

h These indicators, although accepted by panel were demoted due to concern that panel discussions were not comprehensive enough to justify acceptance for each of the split indicators.

i Codes for iatrogenic nervous system complications were expanded to include 5th digits in October 1995, and therefore this indicator is invalid before that date.

j Accepted by surgical panel only, but concerns about operationalization remain and cannot be easily resolved.

k This indicator was rejected by surgical panel (median = 5), accepted by multi-specialty.

l This indicator is a core JCAHO indicator, not reviewed by panel, although 4th degree lacerations are part of the Obstetric Trauma indicator on the Accepted Listing.

m This indicator was split off from other Obstetric complications, due to questions on operationalization of panel requests and strong arguments for splitting.

The degree to which panelists perceived indicators as preventable (e.g., “Foreign body left in during procedure,” “Decubitus ulcer,” “Obstetric trauma-cesarean section”) tended to relate to the usefulness rating. In other words, the higher the rating for usefulness, the higher the rating for preventability. All indicators in the Accepted indicator set received a median rating of at least 6 by one or more panels (on a scale from 1 to 9 where higher scores represent the opinion that a complication is preventable). However, some rejected indicators that panelists thought would surely be preventable (e.g., dosage complications received a median score of 8) were rated poorly overall because of problems with the indicator (e.g., that it would be inconsistently documented). The adapted UCLA/RAND method may be applied to the preventability ratings to identify complications felt by panelists to be more or less preventable, although this rating does not take into account other potential pitfalls of indicators, such as bias or charting practices. Table 14 shows the results of this categorization for the preventability ratings for the Accepted indicators.

Table 14 Groupings Based on Preventability

Acceptable | Acceptable (-) | Unclear | Unclear (-)
Decubitus ulcer | Comp. of anesthesia | Death in low mortality DRG | Failure to rescue
Foreign body | Infection due to med. care | PO hemmorhage/ hematoma | PO physio. or metab. derangement
Iatrogenic pneumothorax^a^ | PO PE or DVT^b^ | PO pulmonary compromise
In-hosp. fracture^a^ | Transfusion reaction | PO wound dehiscence
Tech. diff. with procedure | Birth trauma | Postoperative sepsis
OB trauma (all delivery types) | Post-partum UTI | OB wound comp. - c-sect

a Panel ratings based on definitions different than final definitions. For “Iatrogenic pneumothorax,” the rated denominator was restricted to patients receiving thorocentesis or central lines; the final definition expands the denominator to all patients (with same exclusions). For “In-hospital fracture” panelists rated the broader Experimental indicator, which was replaced in the Accepted set by “Postoperative hip fracture” due to operationalization concerns.

b Vascular complications rated as Unclear (-) by surgical panel.

For most indicators, panelists rated the medical error scale lower than the preventability scale. However, several indicators had relatively high scores (median, 7 –8) equivalent for both of these scales - “Foreign body left in during procedure,” “Decubitus ulcer,” “Iatrogenic pneumothorax,” “Dosage complications,” “In-hospital fracture,” and “Transfusion reaction.” Again, the UCLA/RAND method may be applied to the medical error ratings. Table 15 demonstrates the wider dispersion in Accepted indicators when medical error ratings are used.

Table 15 Grouping Based on Medical Error

Acceptable | Acceptable (-) | Unclear | Unclear (-)
Decubitus ulcer^g^ | Comp. of anesthesia^g^ | Death in low mort. DRG | Failure to rescue
Foreign body^c, g^ | In-hosp. fracture^a, g^ | Infection due to med. care | PO hemmorhage/ hematoma
Iatrogenic pneumothorax^a, g^ | Transfusion reaction^d, g^ | PO PE or DVT^b^ | PO pulmonary compromise
| | PO wound dehiscence^e^ | Birth trauma
| | Postoperative sepsis | OB trauma
| | Tech. diff. with procedure
| | PO physio. or meta. Derangement^f^

a Panel ratings based on definitions different than final definitions. (See Table 14 footnote)

b Vascular complications rated as Unacceptable by surgical panel.

c Foreign body rated as Acceptable (-) by surgical panel.

d Transfusion reaction rated as Unclear (-) by surgical panel.

e PO wound dehiscence rated as Unclear (-) by surgical panel.

f PO physiologic and metabolic derangement rated as Unclear (-) by surgical panel.

g Rated highly on both preventability and medical error questions.

Although the Accepted indicators did have relatively high ratings regarding the overall usefulness of the indicator, the panel review only addressed the face validity of the indicators. Additional research will be required to establish the validity of all indicators. In general, Accepted indicators have more compelling validity based on the current findings than do Experimental indicators. Each of the Experimental indicators is subject to one or more major concerns that tend to group into three categories. First, panelists rated some of the Experimental indicators lower than the Accepted indicators because they had concerns regarding the construct validity of the indicator (the ability of the indicator to measure potentially preventable complications). Additional research utilizing other sources of data, such as medical charts, will help to determine the construct validity of these indicators. Although all indicators have no or little current evidence regarding their construct validity, panelists felt particularly concerned about those indicators designated as Experimental. Second, a few indicators either did not have adequate panel review, or were not evaluated by panels (since they were added after the panel review). These indicators should be reviewed by clinical panels with appropriate composition (e.g., inclusion of cardiac surgeons and interventional cardiologists for “CABG after PTCA”). Finally, a few indicators were of interest to the panels, but could not be operationalized adequately within the project timeframe and resources, and will therefore require investigation into whether available codes capture the complication of interest and risk pool adequately. Table 16 identifies the suggested research for each of the Experimental indicators.

Table 16 Suggested Initial Further Research for Experimental Indicators

Indicator | Construct Validity | Clinician Panel Review | Operationalization Review
Aspiration pneumonia | X
CABG after PTCA | | X
Decubitus ulcer in high risk patients | X | X
In-hospital Fractures possibly related to falls | | | X
Intraoperative nerve compression injuries | X | | X
Malignant hyperthermia | X | | X
Postoperative acute myocardial infarction | X | X^a^
Postoperative iatrogenic complications - cardiac system | | X
Postoperative iatrogenic complications - nervous system | | X
Reopening of surgical site | | | X
Suture of laceration | X | X^a^
Obstetric wound complications - cesarean section | X
Obstetric wound complications - vaginal delivery | X
Other obstetric complications | X
Post-partum urinary tract infection | X
Third or fourth degree obstetric laceration (JCAHO) | X
Uterine rupture | X | X

a Indicators were accepted by one panel, but rejected by another. Additional review may aid in interpreting these differences of opinion.

Most of the indicators were specified to include pediatric patients. To assess the applicability of the indicators to the pediatric population, rates were also calculated for the following age strata: less than one year, 1 – 14 years, 15 – 24 years and 25 years and older (see Appendix G, Supplemental Tables 3 and 4). Many indicators appear to have similar rates across all pediatric patients as adults. However, the mechanisms of complication development may differ in the pediatric population. For instance, DVTs in a pediatric population may be more reflective of catheter care and use than perioperative prevention strategies. Where mechanisms or risk factors may differ from the adult population, they are noted in Section 3D.

The remaining portions of the report focus on reporting more details about these indicators. Section 3C. Overall Clinician Review Results provides general themes related to these indicators and highlighted by the panel discussions. Section 3D. Detailed Panel Results by Indicator, provides details on the definition choices made for each indicator, and the concerns raised specific to each indicator. Section 3E. Comparative Empirical Results, relates the findings of the empirical analyses for indicators in the Accepted and Experimental indicator sets. Appendix E provides the detailed specification for the final definitions used for each indicator, and Section 3D. Detailed Panel Results by Indicator also includes the basic definition and rationale for each indicator. As previously noted, all of the results for and brief descriptions of the Rejected indicators are presented in Appendix F.

## Flow Diagram 1. Process for the Selection of Indicators

[image]

## Section 3C. Overall Clinician Panel Review Results

During the course of the clinician review, panelists discussed and offered both specific suggestions regarding a specific indicator, as well as general themes about quality indicator use. These “themes” provided important insights into how quality improvement and indicators are viewed by clinicians, how such indicators are likely to be used and interpreted, and the validity of such indicators from a clinical perspective. While our sample of clinicians was diverse, it is not a nationally representative sample, as these individuals were nominated and volunteered to participate. Nevertheless, the themes that consistently arose in the process are important to address in the development and use of quality indicators. While many of these themes reflect areas covered in previous studies, the novel, though not surprising, finding is that clinician panelists considered these areas vital to discuss as they provided input about the development of patient safety and complications indicators.

### Application of Quality Indicators

Panelists repeatedly discussed that the validity of quality indicators is dependent on the intended use (e.g., public reporting of provider rates versus internal quality improvement). For example, an indicator designed to be more specific increases the surety that the indicator will most certainly flag only cases where a medical error or process failure has occurred. The tradeoff, as with any diagnostic test, is that the indicator will then be less sensitive, missing true instances of error. For internal quality improvement, it may be more useful to identify changes in rates of complications that may signal a potential process flaw. While this approach is less precise in terms of yielding only cases of high concern, it would likely identify a broader range of potential quality concerns. For public reporting of provider rates, however, a choice to emphasize sensitivity over specificity in designing indicators may lead to misinterpretation about a particular providers' performance, as some that may use such data may be unfamiliar with the extensive list of caveats that must be considered when interpreting results for each quality indicator. The primary goal of the AHRQ quality indicators is to implement screening tools, meaning that further investigation is expected to certify that an abnormal rate is indeed due to a quality problem. Nonetheless, panelists remained concerned that if these indicators were used to report rates publicly, such limitations would be obscured.

### Purpose of Quality Indicators

Indicators may be designed for a variety of uses. There is a distinction between the use of QIs as “case finding tools” and as “quality improvement” tools. Case finding tools are primarily used to identify a specific case or patient in which a quality problem may have led to the outcome in question. In some cases, this may be used for case investigation, mortality and morbidity discussions, or negligence attributions. Another way to use the indicators is as quality improvement tools, in which the rate of a complication provides the most useful information. Unlike case finding tools, this approach focusing on complication rates admits that not each case will reflect negligence or medical error. However, hospitals with extremely high rates compared to similar institutions may have cause for concern. Interventions may be able to reduce the rate of a complication, but not always prevent a complication from occurring in a particular patient. Panelists were told that this indicator set is designed as a quality improvement tool. Like indicators used for public reporting of provider rates, indicators used for case finding must be much more specific than quality improvement tools, since imprecision from a more sensitive measure may cause problems. Panelists expressed concern that some of the indicators under development may be construed as case finding tools, despite being designed and validated as quality improvement tools. In this event, physicians or other clinicians may be unfairly accused of negligence in a particular case, when, in fact, the clinician could not have prevented the outcome for that particular patient.

### Importance of Risk Adjustment or Stratification

Panelists noted that for many indicators, case mix, screening and charting practices, and other factors vary systematically between providers. Panelists discussed alternatives to address such bias, as outlined below.

For many indicators, the exclusion of certain high risk populations, such as trauma patients, may increase the homogeneity of the population at risk. Such restrictions would decrease bias that could result from inconsistent distribution among hospitals of high risk populations. In some cases, panelists favored such exclusions when the population was at such a high risk, that most of the complications would not be preventable. Panelists noted that this approach has the undesired effect of obscuring outstanding quality care, where some providers may be better at preventing complications in high risk patients. This difference would be very important to illuminate, leading some panelists to suggest stratification rather than exclusions.

Stratification has the advantage of allowing providers to view rates of complications in patients with varying risks of developing that complication. Such stratification would remove bias caused by high risk patients. For instance, deep vein thromboses (DVT) and pulmonary embolism (PE) are more common after some orthopedic surgeries. Providers specializing in orthopedic surgery may appear to have an abnormally high rate of DVT/PE, although the rate is due primarily to case mix. Stratified rates would allow the provider to view the orthopedic surgical complications rates separately from other lower risk procedures, allowing exploration of whether the high rate was indeed due to the provider's orthopedic surgery case-mix. Panelists suggested stratifying some indicators by primary procedure type, trauma, elective and urgent admission, and specified comorbidities. In addition to singling out potentially high risk strata, stratification may aid in illuminating the source of a particularly high rate, beyond case mix differences. For demonstration, panelists noted that DVT and PE are identified differently by different providers. Some providers specifically screen for DVT after surgery, while others do not. Thus, providers that screen will appear to have a higher rate, simply because they detect more DVTs. Stratification by DVT rate versus PE rate would allow providers to identify whether a high rate is driven by a higher rate of DVTs, which may be due to screening, or whether the more serious and less ambiguous PE rate is also high. The review of each specific indicator notes suggestions that panelists made regarding stratification.

In some cases, stratification may not be the best or only approach. Panelists noted that case mix adjustment is desirable for many indicators, especially when a variety of factors, such as age, sex, principal procedure or diagnosis, and comorbidities, may influence the likelihood of complications occurring, and when many of these factors vary systematically by providers. Under these circumstances, case-mix adjustment may be easier to interpret than stratification or other approaches. However, case-mix adjustment has many caveats, especially when limited to administrative data. Panelists noted that for many of these indicators, risk adjustment using administrative data is a blunt tool. Additional clinical data would provide much better risk adjustment information. Such data are likely to differ by indicator, and often would require chart review. However, even some risk adjustment may indicate whether or not there is a possibility that a high rate could be due to differences in case mix. While many panelists expressed concern that without risk adjustment indicator results would be misconstrued as due to poor quality of care, some panelists also expressed that blaming high rates on case mix differences may not be appropriate. Their point of view was that adequate risk adjustment could reveal under what circumstances high complication rates appear attributable to case mix differences.

### Understanding of Data

Throughout the structured review process, it was clear that some panelists had sophisticated knowledge of administrative data and ICD-9-CM coding, while many panelists were unclear about the limitations of administrative data. To remedy this problem, we provided panelists with information on coding and administrative data. Throughout the conference call we clarified any misconceptions regarding the available data. Through these interventions, panelists' understanding appeared sufficient regarding the limited nature of administrative data. However, we did note that before this education, panelists often assumed that administrative data were clinically rich, containing information on physiological data or very specified diagnoses or procedures. Most panelists were unaware of how ICD-9-CM codes were assigned; unaware that such codes are based on the physician notes and are therefore subject to differences in physicians' diagnosis and charting practices. Panelists were also often unaware that the precise timing of a diagnosis or procedure was impossible to ascertain with most administrative data. The variety of baseline knowledge regarding administrative data from which indicators are constructed suggests potential future problems in interpretation. Physicians and other clinicians, as well as the public and other end users may assume that the data from which indicators are created are detailed, and therefore that indicators or risk adjustment procedures are more clinically valid than is true. A lack of understanding of administrative data may promote inappropriate use of indicators. Without understanding data elements captured in an indicator specification, users of indicators may have difficulties determining what additional data collection efforts might help explain varying rates observed by providers. It should be noted that while some panelists appeared to believe that administrative data were more detailed, others had great skepticism about its use (see below).

### Charting, Coding and Reporting

Panelists expressed skepticism about the quality of coding for some of the indicators, stemming from a variety of problems ranging from incentives to chart events to possible inexperience of coders assigning ICD-9-CM codes. Panelists noted that there are many reasons why a physician may not chart a diagnosis or procedure. First, some of the reviewed complications, such as “failure of sterile procedures” or “suture of laceration” when the laceration is minor, may not be coded by some physicians because they may not seem to be clinically significant. In these cases the “rate” of a complication is related mostly to the detail of the physician notes, and thus may be biased. In some cases, there may be disincentive to specifically chart a complication of questionable clinical importance. The culture of a hospital may discourage reporting of errors, if a physician feels that they will be punished for reporting the error. Thus, hospitals with good reporting programs for medical error may appear to have poorer quality of care than hospitals that do not encourage error reporting.

In some cases, the clinical significance of a complication may be very clear, and will usually be charted. However, panelists noted that there still may be variation in charting these complications. Since ICD-9-CM codes are assigned based on physicians' written notes, the exact term a physician uses to describe a condition effects the code assigned. For instance, pneumonia and atelectasis may be used by different physicians to describe the same clinical findings, resulting in different ICD-9-CM codes. In addition, physicians may have differing clinical thresholds and diagnostic practices when identifying a condition. In the pneumonia example, some physicians may diagnose pneumonia using chest x-ray findings, while others may require positive results from a broncoscopy before documenting the diagnosis. Again, these variations result in varying “rates” without true variation in the rate of the actual complication. Even when the complication is clearly defined, some indicators require that the complication be labeled as the direct result of a procedure or medical care, or “iatrogenic”. Panelists reported that such a link is often not included in the chart. If another code is available, such as is the case for hypotension, for instance, that code is likely to be assigned. Coders, by direction, and because they are not physicians, do not make inferences during coding to correct some of these variations. In fact, panelists repeatedly expressed skepticism about the accuracy of coding from physician notes, although specific observations of inaccuracy were not reported.

### Summary

Throughout our clinical panel review process, we identified recurring themes relating to the usefulness of indicators in a clinical setting. Panelists noted that many problems associated with indicators might not be accurately noted when interpreting indicators in a clinical setting, and generally expressed concern regarding the use of these indicators as definitive quality measures or for public reporting. However, panelists did express interest and indicated a need for such quality indicators, especially for non-punitive internal quality monitoring and improvement.

## Section 3D. Detailed Panel Results by Indicator

This section reports the results of the clinician panel's ratings and discussion of each indicator. Medical, procedure and obstetric related indicators were reviewed by multi-specialty panels. A subset of indicators was then reviewed by surgical panels. The table (Table 17) below summarizes the genealogy or history of panel reviews for each indicator; letters in parentheses after an indicator show the final disposition of the indicator based on panel and other findings. Rejected means that the indicator was not retained for further evaluations, usually due to low ratings by the panelists. These rejected indicators are in addition to ones that were not even evaluated by clinical panels. Experimental indicates that the indicator was of some potential use as a patient safety indicator, but had generated some reasonable concerns that would need to be explored through chart reviews or other methods that were outside of the scope of this project. These indicators were evaluated as an Experimental indicator set in the empirical analysis. The final disposition, Accepted means that an indicator as specified after panel input was thought to be useful as a screen for potentially preventable complications of care. These Accepted indicators were evaluated empirically in detail. In this section, Accepted indicators are presented first, in alphabetical order; non-obstetric indicators are followed by obstetric indicators. Next Experimental indicators are presented, also in alphabetical order; again, non-obstetric indicators are followed by obstetric indicators. For explanation of the isolation of obstetric indicators see the introduction to this chapter. The results for each Rejected indicator are found in Appendix F.

Table 17 Indicators Reviewed by Panel Type

Indicator^a^ | Multi-specialty Panel^b^ | | Surgical Panel^b^ | | Final Designation^c^
| Pre Conf. Call | Post Conf. Call | Pre Conf. Call | Post Conf. Call
Aspiration pneumonia | XXX | XXX | XXX | XXX | Experimental
Birth trauma - injury to neonate | XXX | XXX | | | Accepted
CABG following PTCA | XXX | XXX | | | Experimental
Complications of anesthesia^d^ | XXX | XXX | XXX | XXX | Accepted
Death in low mortality DRGs | XXX | XXX | | | Accepted
Decubitus ulcer | XXX | XXX | | | Accepted
Decubitus ulcer in high-risk patient^e^ | | | | | Experimental
Dosage complications | XXX | XXX | | | Rejected
Failure to rescue^f^ | XXX | XXX | | | Accepted
Foreign body left in during procedure | XXX | XXX | XXX | XXX | Accepted
Iatrogenic hypotension | XXX | XXX | | | Rejected
Iatrogenic pneumothorax | XXX | XXX | | | Accepted
Infection due to medical care | XXX | XXX | | | Accepted
In-hospital fractures possibly related to falls^g^ | | XXX | | | Experimental
Intestinal infection due to Clostridium difficile | XXX | XXX | | | Rejected
Intraoperative nerve compression injuries^i^ | | XXX | XXX | XXX | Experimental
Malignant hyperthermia^j^ | | XXX | XXX | XXX | Experimental
Obstetric thrombosis or embolism | XXX | XXX | | | Rejected
Obstetric trauma-cesarean section | Obstetric trauma^k^ | Obstetric trauma^k^ | | | Accepted
Obstetric trauma-vaginal with instrument | | | | | Accepted
Obstetric trauma-vaginal without instrument | | | | | Accepted
Obstetric wound complications-cesarean section delivery | Obstetric Wound Complications^l^ | XXX | | | Experimental
Obstetric wound complications-vaginal delivery | | XXX | | | Experimental
Other obstetric complications | XXX | XXX | | | Experimental
Postoperative acute myocardial infarction | XXX | XXX | XXX | XXX | Experimental
Postoperative hemorrhage or hematoma | XXX | XXX | XXX | XXX | Accepted
Postoperative iatrogenic complications-cardiac system | Postoperative iatrogenic complications^m^ | Postoperative iatrogenic complications | | | Experimental
Postoperative iatrogenic complications-digestive | | | | | Rejected
Postoperative iatrogenic complications-nervous | | | | | Experimental
Postoperative iatrogenic complications-respiratory | | | | | Rejected
Postoperative iatrogenic complications-urinary | | | | | Rejected
Postoperative iatrogenic complications-vascular | | | | | Rejected
Postoperative hip fracture^h^ | XXX | | | | Accepted
Postoperative physiologic and metabolic derangements | XXX | XXX | XXX | XXX | Accepted
Postoperative pneumonia | XXX | XXX | XXX | XXX | Rejected
Postoperative respiratory failure | XXX | XXX | XXX | XXX | Accepted
Postoperative pulmonary embolism or deep venous thrombosis | XXX | XXX | XXX | XXX | Accepted
Postoperative sepsis | XXX | XXX | | | Accepted
Postoperative wound dehiscence | XXX | XXX | XXX | XXX | Accepted
Post-partum UTI | | XXX | | | Experimental
Puerperal infection | XXX | XXX | | | Rejected
Reopening of surgical site | XXX | XXX | XXX | XXX | Experimental
Suture of laceration | XXX | XXX | XXX | XXX | Experimental
Technical difficulty with procedure | XXX | XXX | | | Accepted
Transfusion reaction | XXX | XXX | XXX | XXX | Accepted
Unexpected LOS/ Conditional LOS^n^ | XXX | XXX | | | Rejected
Uterine Rupture^o^ | | | | | Experimental

a Obstetric and non-obstetric indicators are included in this table for ease of finding indicators on table.

b XXX denotes indicator was reviewed.

c Accepted and experimental indicators were empirically evaluated; rejected indicators were not.

d Multi-specialty panel suggested that this indicator be dropped and suggested two indicators (minor peri-operative physical injuries and malignant hyperthermia) in lieu of indicator. Surgical panel reviewed and revised original indicator.

e Indicator was created after clinical panel reviews based on panel suggestion, underwent empirical evaluation only.

f Clinicians on multi-specialty panel evaluated 2 failure to rescue indicators with different definitions. Both definitions were combined into the single “Failure to rescue” indicator following the conference call.

g Original indicator was titled “Postoperative hip fracture and fall” prior to conference call; the new indicator reflects suggested change of panel.

h Indicator was accepted in lieu of the suggested indicator due to difficulty operationalizing the suggested indicator “in-hospital fractures, possibly due to falls”

i Original indicator was titled “Minor-perioperative physical injury.” Indicator name changed to “Intraoperative nerve compression injury” when corneal abrasion and lip laceration were eliminated from the definition.

j Indicator was created based on panel suggestion following discussion of “Complications of Anesthesia” indicator.

k Indicator was stratified according to delivery type following final rating due to panelist suggestions.

l Indicator was stratified according to delivery type following initial rating due to panelist suggestions.

m Indicator was split into 5 indicators, reflecting the individual complication codes included in the indicator. For the final rating, panelists were informed of the intention to split the indicator, but panelists provided only one rating.

n Multi-specialty panel reviewed 2 definitions, selecting “Unexpected LOS” for further consideration.

o Indicator was created after clinical panels reviewed the “Other obstetric complications” Indicator

Each indicator review follows the same pattern. First, a brief description of the indicator rationale is given followed by the final definition of the indicator. The definition shown reflects the suggested changes made by the panel. The original definitions presented to the panel may be found in Appendix I. The final definition is followed by the final post-conference call ratings for each indicator. These ratings are usually based on the definition provided. In cases where changes were made after the panel's final rating, an explanation is included in the narrative. Finally, two sections describe the input of the panel. The first section, “Changes to the indicator” documents suggested and implemented changes to the definition and the rationale for each. Definitional changes included changes to both the complication of interest and the population at risk. The second section, “Concerns not addressable by changes” documents any concerns raised during the conference call and subsequent ratings about the indicator.

The review of each indicator includes the indicator name, description with rationale, definition, panel ratings and a summary of panel comments. More detailed specifications of indicators are documented in Appendix E. The six questions about aspects of the indicator (e.g., how preventable the complication is) were rated by panelists on a scale from 1 to 9, with the higher numbers relating to better patient safety measures, with one exception. In the case of the question related to how subject an indicator might be to bias (e.g., effects of case mix), a lower rating corresponds to a better patient safety indicator. Each rating table shows the panel median score, as well as the level of agreement, where “agreement” corresponds to little dispersion of opinion, “indeterminate” means that the opinion ranged but did not reach the point of clear “disagreement”, the final category where there were panelists with diametrically different opinions. Section 2D. Clinician Panel Review Methods provides details on agreement categorization. The indicators are organized according to final designation as accepted or experimental, with non-obstetric indicators preceding obstetric indicators. Indicators that were reviewed, but ultimately rejected can be found in Appendix F.

### Accepted Indicators

#### Complications of Anesthesia

This indicator is intended to flag cases of specific complications due to anesthesia that can be clearly identified using administrative data. Specifically, the final definition captures cases flagged by External Cause-of-Injury Codes (E-Codes) and complications codes for adverse effects from the administration of therapeutic drugs, and the overdose of anesthetic agents used primarily in therapeutic settings.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM diagnosis codes for [anesthesia complications] in any secondary diagnosis field per 100 discharges.
Denominator | All [surgical] discharges.
| Exclude patients with codes for poisoning due to anesthetics [E855.1, 968.1–4, 968.7] AND any diagnosis code for [active drug dependence], [active nondependent abuse of drugs], or [self-inflicted injury].

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | Not Rated | | 7 | Indeterminate
Not present on admission | Not Rated | | 5.3 | Indeterminate
Preventability | Not Rated | | 7.5 | Indeterminate
Due to medical error | Not Rated | | 7.3 | Indeterminate
Charting by physicians | Not Rated | | 5.3 | Indeterminate
Bias (lower rating favorable) | Not Rated | | 6.8 | Disagreement

a Multi-specialty Panel - Surgical Complications 3

Surgical Panel - Surgical Complications 3

##### Multi-specialty Panel Results

This panel agreed that this indicator should be dropped as originally defined. They suggested the creation of two alternate indicators related to complications of anesthesia: “Malignant hyperthermia” and “Minor perioperative injuries”. Thus, this indicator was not rated after discussion by this panel.

Concerns not addressable by changes. This panel felt strongly that shock due to anesthesia was too nebulous of a diagnosis. This diagnosis varies widely depending on the charting and judgment, and this diagnosis may represent many varied physiological states. In addition, there was concern that shock was expected in certain situations, such as major abscesses. Finally, in many instances shock may not be clearly attributable to anesthesia, as it may have arisen from a variety of causes. The panel suggested this code be omitted.

The panel also expressed concern regarding the code for incorrect placement of endotrachial tube. Panelists were unsure what events would be assigned this code. They noted that in surgery, misplacement would be corrected immediately, and likely would not be charted. If the tube could not be placed correctly, the patient would be awakened. They noted that these few cases do not represent medical error. Indeed, they noted that true misplacement that resulted in harm to the patient does represent medical error, but they expressed skepticism over whether or not this code would be limited to those situations.

Panelists suggested several additional situations that could be monitored. A few situations, such as anoxic brain damage, did not have specific ICD-9-CM codes. Air embolism was included in another indicator. Suggestions for monitoring malignant hyperthermia and lip lacerations were included in new indicators.

##### Surgical Panel Results

Changes to the indicator. The surgical panel also expressed concern about the code for shock due to anesthesia. In addition to the concerns expressed by the multi-specialty panel, this panel specifically noted that shock may be labeled as hypotension instead of shock. They also noted that shock due to anesthesia is not always preventable. For these reasons, they suggested removing the code.

The panel suggested instead adding a variety of additional codes that may be used for reactions to and overdose of anesthetics. These codes include so-called “E-codes” for adverse effects of the administration of therapeutic drugs. Panelists did express concern that E-codes are not consistently coded, but agreed that they should be tracked nonetheless. Other codes included a series of codes representing accidental poisoning by anesthetics, limited to anesthetics that are not commonly used as recreational drugs, with specific exclusions to reduce the chance that poisoning was present on admission.

Concerns not addressable by changes. No other concerns were added.

##### Summary Across Panels

The two panels suggested different, almost entirely new, indicators, rejecting the original definition for this indicator. As a result all ratings were considered separately. The multi-specialty panel created two indicators that were rated separately. The surgical panels revised the definition of this indicator, and rated its overall usefulness as relatively favorable. As such, this indicator was retained in the Accepted provider level indicator set.

Panelists had concerns about the frequency of coding of these complications, especially since the use of E-codes is considered voluntary and appears to vary widely between providers. Plausibly a “reaction” may be described without attributing it to anesthetic. Another concern is that some of these cases would be present on admission (e.g., due to recreational drug use). Ideally, this indicator would be used with a coding designation that distinguishes conditions present on admission from those that develop in-hospital. However, this is not available in the administrative data used to define this indicator, and so this concern was addressed by eliminating codes for drugs that are commonly used as recreational drugs. While this does not eliminate the chance that these codes represent intentional or accidental overdose on the part of the patient, it should eliminate many of these cases.

#### Death in Low Mortality Drgs

This indicator is intended to identify in-hospital deaths in patients unlikely to die during hospitalization. The underlying assumption is that when patients admitted for an extremely low-mortality condition or procedure die, a health care error is more likely to be responsible. Patients experiencing trauma, or having an immunocompromised state or cancer are excluded, as these patients have higher non-preventable mortality.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | All discharges with disposition of “deceased” per 100 population at risk.
Denominator | Patients in DRGs with less than 0.5% mortality rate, based on NIS 1997 [low mortality DRG]. If a DRG is divided into “without/with complications” both DRGs must have mortality rates below 0.5% to qualify for inclusion.
| Exclude patients with any code for [trauma], [immunocompromised] state, or [cancer].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7.5 | Agreement
Not present on admission | Not applicable | Not applicable
Preventability | 6 | Indeterminate agreement
Due to medical error | 6 | Indeterminate agreement
Charting by physicians | 9 | Agreement
Bias (lower rating is favorable) | 4.5 | Indeterminate agreement

a Medical Complications 2 Multi-specialty Panel

Changes to the indicator. Panelists suggested no changes to this indicator.

Concerns not addressable through changes. Panelists expressed some concern regarding bias inherent in this indicator. Specifically, panelists noted that hospital case-mix may affect the rate of death in low mortality DRGs. Patients referred from skilled nursing facilities, those with certain comorbidities and older patients may be at higher risk of dying. Risk adjustment for comorbidities and age was highly advocated. Panelists also suggested that social factors play a role, with socio-economic status being correlated with many other risk factors that may affect the health and healing of the patient. Some panelists advocated for stratification by insurance status. Finally, panelists noted that some hospitals accept transfers from other hospitals. At times, these transfers are very appropriate, but sometimes the transfer occurs too late for the receiving hospital to prevent death. If these scenarios occur systematically, this indicator could be biased against referral centers. Panelists also expressed that hospital size may be a factor. Since deaths in these DRGs are rare, hospitals that have very few patients may be more affected by random variation.

Despite the concerns expressed regarding bias in the low mortality DRG indicator, panelists noted that this indicator was of great interest. Panelists noted that although many deaths in these DRGs are likely to be non-preventable and not due to medical error, that all deaths in low mortality DRGs should be subject to internal review, and that high rates may indicate a quality problem. However, panelists were quick to emphasize use of this indicator as a screening tool for internal quality improvement efforts. Given potential bias and questions about the extent of preventability, panelists advocated that this indicator not be subject to public reporting.

##### Summary

The overall usefulness of this indicator was rated as favorable by panelists, and as such it was retained in the Accepted provider level indicator set. To standardize the indicator, since the denominator of this indicator includes many heterogeneous patients cared for by different services, this indicator should be stratified by DRG type (i.e., medical, surgical, psychiatric, obstetric, pediatric) when used as an indicator of quality.

#### Decubitus Ulcer

This indicator is intended to flag cases of in-hospital decubitus ulcers. It is related to a complications indicator developed as part of the Complications Screening Program, ^7^ although it omits several of the original codes for cellulitis. In order to better screen out cases of decubitus ulcer that are present on admission, this indicator limits its definition of decubitus ulcer to secondary diagnoses (meaning decubitus ulcer was not labeled as the principal diagnosis). In addition, this indicator excludes patients that have a length of stay less than 4 days, as it is unlikely that a decubitus ulcer would develop within this period of time. Finally, this indicator excludes patients who are particularly susceptible to decubitus ulcer, namely patients with major skin disorders (MDC 9) and paralysis.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code of 707.0 in any secondary diagnosis field per 100 discharges.
Denominator | All [medical] and [surgical] discharges.
| Include only patients with a length of stay of more than 4 days.
| Exclude patients in MDC 9 or patients with any diagnosis of [hemiplegia, paraplegia, or quadriplegia].
| Exclude patients admitted from a [long term care facility].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 8 | Agreement
Not present on admission | 8 | Agreement
Preventability | 8 | Agreement
Due to medical error | 8 | Agreement
Charting by physicians | 7 | Indeterminate agreement
Bias (lower rating is favorable) | 3 | Indeterminate agreement

a Medical Complications 1 Multi-specialty Panel

Changes to the indicator. The original definition of this indicator was based on the Complications Screening Program. ^7^ This included an exclusion for patients older than 80 years of age, since these patients may be more likely to have pre-existing decubiti. Panelists felt that this exclusion was undesirable, as it eliminates patients who should be monitored. Panelists instead suggested that patients admitted from a long-term care facility be excluded, as these patients may have an increased risk of having decubiti present on admission.

The original definition included only patients with a length of stay of 10 days or more, to better ensure that the decubiti developed within the admission in question. Panelists agreed that this length of stay was too long, limiting the indicator to only the most ill patients. Instead, panelists agreed to limit the indicator to patients with length of stay to 4 days or more, a limitation utilized for this indicator in a study by Needleman et al. ^137^

Concerns not addressable through changes. Most panelists had few concerns regarding this indicator. In general panelists felt that this complication was preventable, and in many cases reflects medical error, although a small number of cases may not be preventable. One panelist suggested that little published evidence exists regarding practices that providers may adopt to reduce decubitus ulcer rates.

Some panelists had minimal concern that reporting of decubiti may vary by providers. Specifically, staging of decubitus ulcers affects the charting of the complication, with earlier stage ulcers reported more variably than later stage ulcers. Nurses were noted to be more vigilant than physicians in reporting ulcers; however, nursing notes are not considered when assigning ICD-9-CM diagnosis codes. In addition, some facilities routinely screen for decubitus ulcers as part of quality improvement programs, while other facilities do not. Hospitals that screen would have an artificially high rate of ulcers as compared to other hospitals. If this concern is demonstrated in reality, than this indicator may be somewhat biased.

A final source of potential bias is case mix. Panelists noted that very ill patients may be at higher risk for developing decubiti, and therefore hospitals that care for sicker patients may have higher rates of this complication. In addition, one panelist noted that since patients admitted from long-term care facilities are excluded, that hospitals admitting more patients from these facilities may appear better than other facilities.

Although panelists chose to retain the exclusion of high risk patients, many panelists expressed interest in tracking decubiti in a higher risk population. It was felt that bias may result from adding these patients to the population at risk. On the other hand, the high risk population is one for which vigilance of the treatment team should be high and may have a substantial effect. They suggested, that if possible in the future, that high risk patients also be tracked separately. An indicator for this purpose was added to the experimental set because of its face validity, but need for further testing.

##### Summary

The overall usefulness indicator was rated as very favorable by panelists. Although panelists felt that this complication most often reflected medical error, concerns regarding the systematic screening for ulcers and reliability of coding, especially for early stage ulcers brought into question that assertion. Thus, this indicator appears to be best used as a rate based indicator, despite its high rating on the medical error question. This indicator was retained in the Accepted provider level indicator set.

This indicator includes pediatric patients. Pressure sores are very unusual in children, except among the most critically ill children (who may be paralyzed to improve ventilator management) and children with chronic neurologic problems.

#### Failure To Rescue

This indicator is intended to identify patients that die following the development of a complication. The underlying assumption is that good hospitals may not be able to prevent complications, but they identify these complications quickly and treat them aggressively to prevent adverse sequelae, such as death. The original definition of this indicator was developed by Silber et al. ^31^ and was based on clinical data, focusing on complications of cardiac surgery that were serious and often non-preventable. Jack Needleman and colleagues, in a recent study, operationalized failure to rescue using administrative data only, across a wide range of surgical and medical patients. ^137^ Needleman's list of complications was closely related to the complications defined in the Complications Screening Program. ^7^ These complications include exclusions designed to avoid counting patients with the complication present on admission. In this definition, Needleman used patients identified under his modified definition as having a serious iatrogenic complication as the population at risk. Patients that transferred to or from another hospital are excluded. Patients admitted from a long-term facility are also excluded.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | All discharges with disposition of “deceased” per 100 population at risk.
Denominator | Discharges with potential complications of care listed in [failure to rescue] definition (i.e., pneumonia, DVT/PE, sepsis, acute renal failure, shock/cardiac arrest, or GI hemorrhage/acute ulcer). Exclusion criteria specific to each diagnosis.
| Exclude patients [transferred to acute care facility].
| Exclude patients [transferred from acute care facility]
| Exclude patients admitted from a [long-term care facility].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7 | Agreement
Not present on admission | 7 | Indeterminate agreement
Preventability | 5 | Agreement
Due to medical error | 5 | Indeterminate agreement
Charting by physicians | 8 | Agreement
Bias (lower rating is favorable) | 4 | Disagreement

a Medical Complications 2 Multi-specialty Panel

Changes to the indicator. Panelists were asked for additional suggestions of complications to be included in the denominator of this indicator. Panelists unanimously suggested that acute renal failure be added.

Panelists expressed concern regarding patients with “do not resuscitate” (DNR) status. In cases where this DNR status is not a direct result of poor quality of care, it would be contrary to patient desire and poor quality of care to rescue a patient. In addition, very old patients, or patients with advanced cancer or human immunodeficiency virus (HIV) may not desire or may be particularly difficult to rescue from these complications. As a result, several changes were suggested for this indicator. These changes include the stratification of this indicator by age, such that patients over 75 years may be examined separately from younger patients. In addition, panelists suggested the exclusion of patients admitted from long term care facilities. Although these changes do not directly nor completely address panelist concerns, they may improve ability to interpret results.

Panelists also noted that transfer practices may play a role in this indicator. As patients that develop some complications may be transferred to more specialized hospitals, referral centers may not always be able to rescue that patient, particularly if the transfer occurs too late. In this case the referral care center would appear to have poorer quality than the hospital in which the complication arose in the first place. Thus, patients who have been transferred to or from another acute care facility are also excluded from this indicator.

Concerns not addressable through changes. Panelists expressed some concern over the validity of this indicator, although it was eventually accepted by panelists for inclusion. Some panelists wanted to see additional validity work on the concept that failure to rescue is a valid marker of quality of care. Others were concerned that although the concept may be valid, that it would be very difficult to operationalize this indicator well, with varied definitions of complications, difficulty ascertaining whether the complication occurred in-hospital, and the lack of adjustment for the many factors that influence the ability and appropriateness of the hospital to rescue a patient from these complications.

Panelists noted that several adverse incentives may be introduced by implementing this indicator. In particular, since some type of adjustment may be desirable, this indicator may encourage the upcoding of complications and comorbidities to inflate the denominator or manipulate risk adjustment. Others noted that this indicator could encourage irresponsible resource use and allocation, although this is likely to be a controversial idea. Finally, panelists emphasized that this indicator should be used internally by hospitals, as it is not validated for public reporting.

##### Summary

The overall usefulness of this indicator was rated favorably and as such it is included in the Accepted provider level indicator set. However, this indicator may be fundamentally different than other indicators reviewed in this report, as it may reflect different aspects of quality of care (effectiveness in rescuing a patient from a complication versus preventing a complication). For this reason, this indicator has been considered separately from other indicators in this report.

This indicator includes children. It is important to note that children beyond the neonatal period inherently recover better from physiological stress and thus may have a higher rescue rate.

#### Foreign Body Left in During Procedure

This indicator is intended to flag cases of a foreign body accidentally left in body during a procedure. It is based on an indicator developed as part of the Complications Screening Program, ^7^ although all codes are considered sentinel events in that system. The indicator is defined both on the area level by including all cases, and on the hospital level by restricting cases to those flagged by a secondary diagnosis or procedure code.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [foreign body left in during procedure] in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [medical] and [surgical] discharges.

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 8 | Agreement | 7 | Indeterminate
Not present on admission | 8 | Agreement | 7 | Agreement
Preventability | 8 | Agreement | 7.5 | Agreement
Due to medical error | 8 | Agreement | 7 | Indeterminate
Charting by physicians | 7 | Agreement | 8 | Indeterminate
Bias (lower rating favorable) | 3.5 | Indeterminate | 4 | Indeterminate

a Multi-specialty Panel - Surgical Complications 2

Surgical Panel - Surgical Complications 2

##### Multi-specialty Panel Results

Changes to the indicator. Panelists were queried regarding the addition of the code for the removal of foreign body from the peritoneal cavity. This code may include some foreign bodies accidentally left in during abdominal surgery when the physician has not specified that the foreign body was not accidentally left in, or the coder chooses to use this code instead of the 998 code. This procedure code was included in Iezonni's CSP. ^7^ Panelists agreed that this code would also pick up some important events, although this code does not specify that the foreign body must be left in accidentally.

Concerns not addressable by changes. Panelists noted that each case of foreign body left in during procedure needed examination. Some automated systems do report this complication when a foreign body is actually left in intentionally. In addition, other cases may require a foreign body to remain. As some codes do not specify that the foreign body must accidentally be left in the body during procedure, some of these foreign bodies may be left in the patient intentionally. This code can be used when a granuloma occurs from a suture accidentally left in the body. Panelists agreed that such granulomas are substantially different in terms of morbidity from other foreign bodies accidentally left in during a procedure. They recommended that the percentage of suture granulomas be ascertained when using this indicator.

Some patients seem to be more likely to have foreign bodies left in during a procedure. Although panelists agreed that these patients (e.g., trauma) should not be excluded, except in the case of removal of foreign body from the abdominal cavity (e.g., possible gun shots). Panelists suggested that users of this indicator examine these cases closely. Panelists suggested that this indicator be adjusted for emergency surgery or type of procedure.

##### Surgical Panel Results

Changes to the indicator. Panelists suggested no changes to this indicator.

Concerns not addressable by changes. Panelists, especially orthopedic surgeons, noted that some foreign bodies are left in on purpose. This occurs frequently, such as when a k-wire or a drill bit breaks off during a procedure. To remove the foreign body may cause more damage than to leave it in. In this case, surgeons felt that the foreign body did not reflect a medical error. The panelists felt that this indicator should be stratified or risk adjusted for the type of procedure. Panelists were concerned about the coding of this indicator. Specifically, this coding requires the physician to note that the foreign body was accidentally left in. There was concern that this additional information would not always be reported. Because of this situation, some physicians have a higher rate than others. Therefore, physicians who do not specify that a foreign body was left in accidentally would not be flagged by this indicator. Panelists also noted that some foreign bodies left in do not cause substantial morbidity, although the foreign body may be removed, resulting in a diagnosis code or an E-code. Some foreign bodies do not represent a clinically significant complication.

Panelists noted that the population at risk included both medical and surgical patients, but not all of these patients are at risk. The panelists felt that limiting to surgical patients would decrease the sensitivity of this indicator substantially. However, it should be made clear that not all patients in the denominator are actually at risk. Therefore, some hospitals may appear to have a lower rate if they have less medical patients who have undergone invasive procedures.

The surgical panel was also queried about removing the code related to removal of foreign body from peritoneal cavity. However, this panel felt that the category was too broad, and could easily include a number of cases where no foreign body was left in. For this reason, they suggested that this code not be included.

##### Summary Across Panels

Both panels believed that this indicator was useful in identifying cases of a foreign body left in during a procedure. They suggested that since this indicator was likely to yield few cases, that each case identified be examined carefully by the hospital. Since both panels did not agree to add the code for removal of foreign bodies in the peritoneal cavity, this code was not included. Given the favorable rating of the overall usefulness of this indicator, it is included in the Accepted provider level indicator set. An area level analog of this indicator was included in the Accepted area level indicator set.

#### Iatrogenic Pneumothorax

This indicator is intended to flag cases of pneumothorax caused by medical care. The area level indicator is intended to capture all cases of iatrogenic pneumothorax, not only those occurring in-hospital. The provider level indicator is restricted to secondary diagnosis of iatrogenic pneumothorax, and is intended to flag cases occurring during the hospitalization. To exclude patients that may be more susceptible to non-preventable iatrogenic pneumothorax, or patients with miscoded traumatic pneumothorax, this indicator excludes all trauma patients.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code of 512.1 in any diagnosis field per 100 discharges.
Denominator | All discharges.
| Exclude patients with any diagnosis of [trauma].
| Exclude patients with any code indicating [thoracic surgery] or [lung or pleural biopsy] or assigned to [cardiac surgery].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7.5 | Agreement
Not present on admission | 8 | Agreement
Preventability | 8 | Agreement
Due to medical error | 8 | Agreement
Charting by physicians | 7 | Indeterminate agreement
Bias (lower rating is favorable) | 3 | Indeterminate agreement

a Procedural Complications 1 Multi-specialty Panel

Changes to the indicator. The original definition of this indicator included all patients, surgical and medical. Panelists noted that pneumothorax can arise from different causes, primarily as a result of a procedure, or from barotrauma in ventilated patients. They noted that although ventilator management matters, pneumothorax arising from barotrauma is much less straightforward than that arising from procedures such as central line placement. Thus, panelists suggested that the indicator would better reflect quality of care, if it were restricted to patients receiving a central line, Swan-Ganz catheter, or thorocentesis (see summary paragraph below, as this change was ultimately removed).

Pneumothorax is an expected complication of some procedures, namely thoracic surgery and pleural or lung biopsy. Panelists felt that these patients should be excluded, since pneumothorax may not be preventable in those patients.

Concerns not addressable through changes. Panelists noted that pneumothorax is a good marker of operator skill. In particular, panelists postulated a clear “July effect” of increased rates when new residents begin performing such procedures.

A few panelists noted that it would be helpful to know the exact procedure associated with the pneumothorax, specifically the approach of the central line placement (e.g., subclavian, jugular). Panelists did express concern that some patients with a recorded central line placement may also be ventilated. In this case it would be impossible to tell from administrative data whether the complication arose from the central line placement procedure or from barotrauma.

Finally, it should be noted that this indicator includes Peripherally Inserted Central Catheter (PICC) line placement as well as central line placement, due to coding constraints. Panelists felt that this was not of concern. They noted that an appropriate replacement of use of central line access with PICC lines might occur to some degree as a result of implementing this indicator.

##### Summary

Panelists rated the overall usefulness of this indicator favorably, although the definition rated included the suggested denominator, limited to patients receiving a central line, Swan-Ganz catheter or thorocentesis. However, exploratory empirical analyses found that this denominator was not reliably defined using administrative data, as these procedures appeared to be under-reported. Thus, the ratings reported reflect a definition that could not be operationalized, and must be considered in that context. Although the panelists noted that this complication, given the definition rated, reflected medical error, the actual final definition of this indicator includes cases which may be less reflective of medical error. Specifically, this indicator includes patients in whom a pneumothorax resulted from barotrauma, including patients with acute respiratory distress syndrome. Thus, this indicator may not as clearly detect medical error as suggested by the panel ratings.

Panelists expressed concern that some approaches of placing a central line (e.g., subclavian) may be more likely to result in pneumothorax than other approaches (e.g., internal jugular). However, other complications, such as complications of the carotid artery would be more common with internal jugular approaches. Thus, if providers simply change approach they may have a decrease in pneumothorax, but an increase in other unmeasured complications.

This indicator includes children, which was not discussed by panelists. It should be noted that the smaller anatomy of children may increase the technical complexity of these procedures in this population (especially among neonates). However, these procedures are less likely to be performed in this population in unmonitored settings.

Given the high overall rating of the indicator, and the great interest in identifying this complication, this indicator was included in the Accepted provider level indicator set. An area level analog of this indicator was included in the Accepted area level indicator set.

#### Infection Due to Medical Care

This indicator is intended to flag cases of infection due to medical care, specifically those related to IV lines and catheters. As an area indicator, it is intended to capture all cases of such infection, not only those that occur in-hospital. Defined as a hospital level indicator, it captures cases based on secondary diagnosis, and is therefore limited to those infections associated with the same hospitalization. This indicator excludes patients with potential immunocompromised states (e.g., AIDS, cancer, transplant), as they may be more susceptible to such infection.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code of 999.3 or 996.62 in any diagnosis field per 100 discharges.
Denominator | All [medical] and [surgical] discharges.
| Excludes patients with any diagnosis code for [immunocompromised] state or [cancer].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 8 | Indeterminate agreement
Not present on admission | 7 | Indeterminate agreement
Preventability | 7 | Indeterminate agreement
Due to medical error | 6 | Indeterminate agreement
Charting by physicians | 7 | Agreement
Bias (lower rating is favorable) | 3.5 | Indeterminate agreement

a Medical Complications 1 Multi-specialty Panel

Changes to the indicator. The original definition of this indicator included several ICD-9-CM codes representing infections that may arise as a result of medical care, including intravenous (IV) and catheter infections and infection due to contaminated or infected blood or other substance. Panelists felt that these two codes identified two very different complications and should not be combined. They felt that the former code, which focused on IV and catheter infections, was most useful for quality improvement, while the latter code is likely to be very rare and poorly reported. For this reason, panelists agreed that this indicator should only include the code for “other infection due to medical care,” focusing on IV and catheter infections. A second code was added after consultation with a coding specialist, as this code also is used to denote catheter infections.

Panelists expressed that the existing exclusion criteria for this indicator needed revision. The original definition excluded trauma patients, as these patients may be at a higher risk for these types of infection. The panel agreed unanimously that these patients should be tracked and therefore included in the population at risk. Panelists did feel that immunocompromised patients were at a higher risk of developing these complications, and that these infections may be less preventable in this population. Therefore, the panel agreed to exclude immunocompromised patients from the population at risk.

Concerns not addressable through changes. Panelists noted that while many of these infections are preventable, even with the best of care, there is a normal underlying rate of these infections. Panelists also expressed concern over the charting of this indicator. Panelists noted that charting of these infections is likely to be varied, and reflect differences in documenting clinically less significant infections, or the aggressiveness of treating such infections. Despite the potential of bias due to charting or under-reporting, panelists for the most part felt that these complications were important to track. Finally, as with other indicators tracking infections, concern regarding the potential overuse of prophylactic antibiotics remains.

##### Summary

Panelists rated the overall usefulness of this indicator favorably, and they expressed particular interest in tracking IV and catheter related infections. This indicator was retained as in the Accepted provider level indicator set. An area level analog of this indicator was included in the Accepted area level indicator set.

This indicator includes children and neonates, which was not specifically discussed by panelists. It should be noted that high-risk neonates are at particularly high risk for catheter-related infections.

#### Postoperative Hemorrhage and Hematoma

This indicator is intended to flag cases of hemorrhage or hematoma following a surgical procedure. It is based on an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits hemorrhage and hematoma codes to secondary procedure and diagnosis codes in order to isolate those hemorrhages that can truly be linked to a surgical procedure. For the same reason, this indicator eliminates all procedures to control hemorrhages that take place before the principal procedure. To ensure that the reported hematoma or hemorrhage is a clinically significant complication, such diagnoses must be accompanied by a procedure code, indicating clinical intervention.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [postoperative hemorrhage] or postoperative hematoma] in any secondary diagnosis field AND code for postoperative [control of hemorrhage] or [drainage of hematoma] (respectively) in any secondary procedure code field per 100 surgical discharges.
| Procedure code for postoperative control of hemorrhage or hematoma must occur on the same day or after the principal procedure.
Denominator | All [surgical] discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 7 | Indeterminate | 7 | Agreement
Not present on admission | 8 | Agreement | 8 | Agreement
Preventability | 8 | Agreement | 6 | Indeterminate
Due to medical error | 4.5 | Indeterminate | 5 | Agreement
Charting by physicians | 7 | Agreement | 8 | Agreement
Bias (lower rating favorable) | 5 | Disagreement | 3 | Disagreement

a Multi-specialty Panel - Surgical Complications 1

Surgical Panel - Surgical Complications 1

##### Multi-specialty Panel Results

Changes to the indicator. Panelists did not suggest any changes to this indicator to address concerns.

Concerns not addressable through changes. Panelists noted that risk of developing postoperative hemorrhage or hematoma differs in complicated and uncomplicated cases. They suggested that an exclusion be added for patients with coagulopathies or for those on anticoagulant medication. However, this exclusion cannot be adequately implemented using administrative data. They suggested that this indicator be risk adjusted, rather than using exclusions of complicated cases. This panel felt that examining the overall rate followed by further investigations would be more useful than creating a homogenous denominator of uncomplicated cases. This panel noted that postoperative hemorrhage and severe hematoma are captured frequently because they require a return to the operating room. However, some panelists expressed that during the re-operative procedure, it is often difficult to find the source of the hemorrhage. They questioned whether or not surgical technique influenced the rate of postoperative hemorrhage or hematoma. Overall, this panel deferred to the surgical specialists in reviewing this indicator.

##### Surgical Panel Results

Changes to the indicator. The panelists noted that seromas are often clinically insignificant complications. They expressed that this complication is not of interest and should be removed from the indicator. The panel also noted that some hematomas may be insignificant, but that those requiring a procedure are highly significant and should be tracked. The panelists expressed the desire to have any diagnosis code linked to a procedure for drainage of hematoma. The procedure for drainage of hematoma is not specific to hematoma but may also include draining of other fluids, including abscesses or seromas. Because of this non-specificity of procedure codes, all procedure codes must be paired with a diagnosis code for hemorrhage or hematoma in order to be included in this indicator. Panelists felt that this specification would limit the flagged complications to those reflecting higher morbidity of patients.

Concerns not addressable through changes. Surgical panelists noted that post-surgical hemorrhage or hematoma occurs in non-surgical patients undergoing invasive procedures such as those undergoing PTCA or cardiac catheterization. They noted that this is an important population that is not covered by this indicator. They also noted that additional patients would be missed if they were admitted for hematoma after an outpatient surgery or if they were discharged before the hemorrhage or hematoma occurred and then readmitted to the hospital. Panelists felt that these patients were particularly import to track. However, the administrative data used in this project do not allow for tracking readmissions, or admissions after outpatient surgery. Panelists noted that some patients may be at higher risk for developing a postoperative hemorrhage or hematoma. Specifically, like the multi-specialty panel, the surgical panel was concerned about patients with coagulopathies, and those on anticoagulants. They suggested that where possible, this indicator be stratified for patients with underlying clotting differences. They also noted that patients admitted for trauma may be at a higher risk for developing postoperative hemorrhage or may have a hemorrhage diagnosed that occurred during the trauma. They also suggest that this indicator be stratified for trauma and non-trauma patients.

##### Summary Across Panels

Because the multi-specialty panelists suggested further surgical input for this indicator, the changes to definitions suggested by the surgical panel were implemented. The ratings of the surgical panelists were considered more valid, and resulted in the indicator being included in the Accepted provider level indicator set.

#### Postoperative Hip Fracture

In-Hospital Fractures Possibly Related To Falls

(Initially reviewed: “In-hospital hip fracture and fall”; see Summary below)

This indicator is intended to flag cases of in-hospital fracture, specifically hip fractures for one version of the indicator, and a broader group of fractures possibly related to falls for another version of the indicator. It is related to an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits diagnosis codes to secondary diagnosis codes in order to eliminate fractures that were present on admission. It further excludes patients in MDC 8 (musculoskeletal disorders) and patients with indications for trauma or cancer, or principal diagnoses of seizure, syncope, stroke, coma, cardiac arrest, or poisoning, as these patients may have a fracture present on admission.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code for [fracture] in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude all patients with diseases and disorders of the musculoskeletal system and connective tissue (MDC 8).
| Excludes patients with principal diagnosis codes for [seizure], [syncope], [stroke], [coma], [cardiac arrest], [anoxic brain injury], [poisoning], [delirium or other psychoses], [trauma], [minor trauma and/or physical abuse], indication of [alcohol or drug abuse], or [self-inflicted injury].
| Exclude patients with any diagnosis of [metastatic cancer], [lymphoid malignancy] or [bone malignancy].
| Exclude patients 17 years of age or younger.

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 8 | Agreement
Not present on admission | 7 | Indeterminate agreement
Preventability | 8 | Agreement
Due to medical error | 7 | Indeterminate agreement
Charting by physicians | 8 | Agreement
Bias (lower rating is favorable) | 3 | Indeterminate agreement

a Medical Complications 1 Multi-specialty Panel

Changes to the indicator. Panelists noted the following:

In-hospital falls. Panelists expressed concern that physicians would variably report in-hospital falls. Therefore, providers who record falls less would appear to have higher quality, without actually having lower rates of falls. In addition, panelists were concerned that the definitions of “fall” may vary. Although coding conventions require that any recorded fall result in a medical intervention or injury, that intervention could be screening x-rays or other procedures. Panelists were concerned that some clinically insignificant falls would be variably reported. Overall, panelists agreed unanimously that falls should not be tracked in this indicator, and these codes were removed.

Expansion of tracked fractures. Panelists agreed that in-hospital hip fractures were severe complications that increase patient morbidity and resource consumption. Panelists also reported that many preventable falls and injuries in hospitals do not result in hip fractures, but other types of fractures, including other extremity fractures. Panelists agreed that all fractures occurring in the hospital setting were important to track. This indicator specification was expanded to include all types of fractures. (However, empirical testing of this specification revealed a disproportionate number of fractures in younger men, raising the concern that the administrative data exclusions were not adequately limiting the population at risk, as these fractures seemed more likely to occur as a result of trauma rather than in-hospital falls. Thus, it was felt that this change could not be implemented. As a result, the panel ratings, which were clearly based on the indicator measuring in-hospital fractures, would be more applicable to the “In-hospital fracture possibly related to falls” Experimental indicator which shows increasing prevalence with increasing patient age, as expected.)

Addition of exclusions. In response to the final questionnaire, panelists suggested that patients with delirium may be at higher risk for having fractures present on admission. In response, patients with a principal diagnosis of delirium were excluded from the population at risk. In addition, panelists noted that patients with lymphoma or bone cancer are at a higher risk for non-preventable fractures in-hospital. These patients were also excluded from the population at risk for both of the empirically tested indicator definitions (i.e., in-hospital hip fracture on the accepted indicator set, and in-hospital fractures possibly related to falls on the experimental indicator set).

Concerns not addressable through changes. After implementing the changes listed above, a few relatively minor concerns remained. Panelists rated this indicator very well, despite these concerns. Several panelists expressed a desire to expand the population at risk to medical patients in addition to surgical patients. This change was not implemented based on data reported by Iezzoni et al. ^15^ in relation to their “In-hospital hip fracture and fall” indicator. They reported that only 11% of “flagged” cases of in-hospital hip fracture in medical patients actually represented true cases of this complication, with most of the “false positives” representing fractures that were present on admission. On the other hand, 51%–71% of “flagged” cases in surgical patients represented true occurrences of in-hospital hip fractures and falls. To minimize the number of “false positive” cases, we chose to limit this indicator to surgical patients, who are less likely to have such a fracture present on admission (given our exclusions to the population at risk).

Panelists did express that given the occurrence of an in-hospital fracture, some of these fractures may not be preventable by good quality care. Fractures may be more likely in the aged and frail population, who have weaker bones, and are more vulnerable to falls. This may result in some slight bias for this indicator for hospitals that care for more of these patients. Finally, in the effort to prevent some falls, adverse effects may occur. One panelist expressed concern that deconditioning may be a particularly dangerous side effect of efforts to reduce fractures by decreasing the mobilization of elderly patients.

##### Summary

Although this indicator was initially presented as “In-hospital hip fracture and fall,” panelists unanimously suggested that falls should be eliminated from this indicator and that all in-hospital fractures should be included. The resulting indicator implemented both of these changes, and was termed “In-hospital fracture possibly related to falls.” The exclusion of children was added after empirical analysis revealed that children did not have a substantial number of cases in the numerator. Ratings are reported for this specification. However, the “In-hospital hip fracture” indicator was selected for inclusion in the Accepted provider level indicator set, as a subset of the preferred specification of a broader group of fractures related to in-hospital falls. The more inclusive fracture indicator was retained on the Experimental indicator set because of both its potential usefulness and its need for further validation to assure restriction to the intended group of patients who likely experience in-hospital fall.

#### Postoperative Physiologic and Metabolic Derangements

This indicator is intended to flag cases of selected postoperative metabolic or physiologic complications. It is based on an indicator developed as part of the Complications Screening Program. ^7^ The population at risk is limited to elective surgical patients, as patients undergoing non-elective surgery may develop less preventable derangements. In addition, each diagnosis has specific exclusions, designed to reduce the number of flagged cases in which the diagnosis was present on admission or was more likely to be non-preventable.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [physiologic and metabolic derangements] in any secondary diagnosis field per 100 surgical discharges.
| Discharges with acute renal failure (subgroup of physiologic and metabolic derangements) must be accompanied by a procedure code for dialysis (39.95, 54.98).
Denominator | All [elective][surgical] discharges.
| Exclude patients with both a diagnosis code of ketoacidosis, hyperosmolarity or other coma (subgroups of physiologic and metabolic derangements coding) AND a principal diagnosis of [diabetes].
| Exclude patients with both a secondary diagnosis code for acute renal failure (subgroup of physiologic and metabolic derangements coding) AND a principal diagnosis of [acute myocardial infarction], [cardiac arrhythmia], [cardiac arrest], [shock], [hemorrhage] or [gastrointestinal hemorrhage].
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 8 | Indeterminate | 6.8 | Indeterminate
Not present on admission | 7.5 | Indeterminate | 7 | Indeterminate
Preventability | 7 | Indeterminate | 6 | Disagreement
Due to medical error | 6 | Indeterminate | 5.3 | Disagreement
Charting by physicians | 7 | Indeterminate | 7 | Indeterminate
Bias (lower rating favorable) | 6 | Indeterminate | 3.5 | Indeterminate

a Multi-specialty panel - Surgical Complications 3

Surgical panel - Surgical Complications 3

##### Multi-specialty Panel Results

Changes to the indicator. The multi-specialty panel suggested several changes to this indicator. First, they agreed that diabetic comas be added in addition to diabetic ketoacidosis. They noted that hyperosmolar coma is less clearly medical error than hypoglycemic coma, but that both should be tracked. They also supported the addition of hyponatremia to the indicator, suggesting that appropriate fluid management should prevent this complication when it is clinically severe. They conceded that both minor and major hyponatremia would be caught by this indicator, and noted that further investigation would be needed to examine only the severe cases. Finally, this panel supported the removal of shock from this indicator, noting that this diagnosis is nebulous and subject to interpretation. Thus, it is impossible to know what physiological state exactly is represented by this code.

In addition to changes in the numerator, this panel supported the limitation of the population at risk to elective surgery patients. This panel felt that only these patients could be appropriately screened and managed preoperatively in an effort to prevent these complications. Patients admitted emergently or urgently may not have the same opportunity for assessment, and thus complications in these patients may be less preventable.

Concerns not addressable through changes. Panelists noted that the coding of some metabolic and physiologic complications may be lacking. Specifically they noted that if the episode is relatively transient, such as in some cases of diabetic ketoacidosis, then the physician may not code the episode. In other cases, some physicians may be quite vigilant in recording small physiologic disturbance, such as minor oliguria, resulting in the capture of non-clinically significant events in this indicator. Similarly, they noted that acute renal failure is a vague diagnosis, and that use of specific creatinine levels would be a better indicator of renal failure.

##### Surgical Panel Results

Changes to the indicator. The surgical panel suggested most of the same changes supported by the multi-specialty panel, for similar reasons, and some additional changes. Panelists supported the removal of shock and addition of diabetic comas, as well as the limitation of the population at risk to elective surgical patients. However, the panel did not support the addition of hyponatremia. They noted that most hyponatremia is clinically insignificant, and does not constitute a serious adverse event. They further argued that a diagnosis of hyponatremia represents a variety of severities and that it was impossible to distinguish easily which events were clinically significant.

Panelists expressed similar concerns about oliguria and anuria as they did about hyponatremia. They expressed that oliguria is difficult to define and in many patients difficult to prevent. The varied preventability and definitions introduce extreme bias to this indicator. For this reason, they argued that these codes be dropped from the indicator. Acute renal failure also suffers from the problem of varied definitions. What one doctor calls acute renal failure, another may not. In addition, the inclusion of this code may help to shift patients to a higher paying DRG, increasing its use artificially. To ensure that the only renal failure cases that are picked up are those that are clinically severe, this panel suggested that acute renal failure be included only when it is paired with a procedure code for dialysis.

Finally, panelists questioned the exclusion of MDC 8. This exclusion was included to exclude patients with hemodialysis who are at increased risk of developing acute renal failure which is not due to medical error. However, panelists felt that this exclusion was too broad and did not really identify patients who were at increased risk for acute renal failure after surgery which is not due to medical error.

Concerns not addressable through changes. No additional concerns were discussed during the conference call.

##### Summary Across Panels

The two indicators proposed by each panel differed substantially in their definitions. For this reason it was necessary to select a definition. The inclusion of hyponatremia could not adequately be specified, as it was difficult to exclude patients that are at a high risk of developing this complication. The multi-specialty panel also expressed similar concerns over oliguria and acute renal failure as the surgical panel, although they did not feel as strongly about these concerns. Because these concerns were expressed by both panels, we chose the most conservative indicator, that proposed by the surgical panel. This indicator is included in the Accepted provider level indicator set, given the high overall rating of the indicator.

This indicator includes children, which was not specifically discussed by the panel. It should be noted that the incidence of these complications is a function of the underlying prevalence of diabetes and renal impairment which are less common among children than among adults.

#### Postoperative Respiratory Failure

(formerly Postoperative pulmonary compromise)

This indicator is intended to flag cases of Postoperative respiratory failure, specifically respiratory failure. It is based on an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits the code for respiratory failure to secondary diagnosis codes in order to eliminate respiratory failure that was present on admission. It further excludes patients who have major respiratory or circulatory disorders, as these patients may have respiratory failure present on admission, or may be more likely to develop such compromise after surgical procedures. This indicator also limits the population at risk to elective surgery patients, as these patients were judged to be at a lower risk for non-preventable complications.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for acute respiratory failure (518.81) in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [elective][surgical] discharges.
| Exclude patients with respiratory or circulatory diseases (MDC 4 and MDC 5).
| Exclude all obstetric admissions (MDC 14 and 15)

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 6.5 | Indeterminate | 7 | Indeterminate
Not present on admission | 6.5 | Indeterminate | 8 | Agreement
Preventability | 6 | Indeterminate | 6 | Indeterminate
Due to medical error | 4.5 | Agreement | 4 | Agreement
Charting by physicians | 6 | Indeterminate | 8 | Agreement
Bias (lower rating favorable) | 6 | Indeterminate | 6 | Indeterminate

a Multi-specialty panel - Surgical Complications 2

Surgical panel - Surgical Complications 2

##### Multi-specialty Panel Results

Changes to the indicator. The panel suggested that only acute respiratory failure and acute edema of lung, unspecified be used. These complications were felt to be the only complications from the original definitions that are more likely to be preventable, and for which variations in rates might be meaningful in reference to the quality of care.

Panelists felt that the population at risk should be limited to patients undergoing elective surgical procedures, as complications in these patients were felt to be more preventable compared with non-elective surgery cases. In addition, panelists suggested that trauma patients should be excluded, as some pulmonary complications are expected in the course of treatment for trauma.

Concerns not addressable by changes. Panelists noted that this indicator is “messy,” in that even with the more conservative definition, preventability of these complications in some patients is dubious. Further, panelists expressed concern that the clinical definition of these complications may vary from provider to provider.

##### Surgical Panel Results

Changes to the indicator. Panelists felt that only acute respiratory failure should be retained in this indicator. They noted that this is a clinically significant event that is at least partially preventable. ICD-9-CM coding guidelines state “Respiratory failure is a life-threatening disorder that requires close patient monitoring and evaluation, with aggressive management usually requiring placement of the patient in a monitored bed, aggressive respiratory therapy, and/or mechanical ventilation.” ^166^

Panelists felt that mechanical ventilation is a hard clinical endpoint, and thus, there would be less variation in the severity of the conditions captured by this indicator. All other codes in the original indicator definition were considered to be either less preventable or nebulous as to their clinical significance, and thus were eliminated.

The surgical panel agreed that the population at risk should be limited to elective surgical patients for similar reasons as the multi-specialty panel.

Concerns not addressable by changes. Panelists expressed concern that acute respiratory failure is affected by case mix and type of surgery. For instance, patients undergoing hepatic resections or patients that are immunocompromised or malnourished may be more likely to develop these complications. As a result, this indicator may be subject to some bias.

##### Summary Across Panels

Both panels rated the overall usefulness of this indicator as relatively favorable. The surgical panel proposed a more conservative indicator than the multi-specialty panel. Since it was beyond the scope of our study to inquire of the multi-specialty panel regarding the more conservative definition, the more conservative definition was retained as an Accepted provider level indicator.

#### Postoperative Pulmonary Embolism or Deep Venous Thrombosis

This indicator is intended to flag cases of postoperative venous thromboses and embolism, specifically pulmonary embolism (PE) and deep venous thromobosis (DVT). It is closely related to an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits vascular complications codes to secondary diagnosis codes in order to eliminate complications that were present on admission. It further excludes patients who have principal diagnosis of DVT, as these patients are likely to have had PE/DVT present on admission.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [deep vein thrombosis] or [pulmonary embolism] in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude patients with a principal diagnosis of [deep vein thrombosis].
| Exclude all obstetric admissions (MDC 14 and 15).
| Exclude patients with secondary procedure code 38.7 when this procedure occurs on the day of or previous to the day of the principal procedure.

Panelists suggested that this indicator be reported for PE and DVT separately. Thus, this indicator would be reported by the software as three rates - the overall thromboembolism rate, the PE rate, and the DVT rate (all other codes). Panelists felt that the reporting of PE and DVT separately would allow users to distinguish rates which may be higher than expected due to routine postoperative screening for DVT, or other differences in diagnostic methods.

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 7 | Indeterminate | 7 | Agreement
Not present on admission | 7 | Indeterminate | 7 | Agreement
Preventability | 7 | Indeterminate | 6 | Disagreement
Due to medical error | 6 | Indeterminate | 3 | Indeterminate
Charting by physicians | 7 | Indeterminate | 7 | Indeterminate
Bias (lower rating favorable) | 5 | Indeterminate | 6.5 | Indeterminate

a Multi-specialty panel - Surgical Complications 1

Surgical Panel - Surgical Complications 1

##### Multi-specialty Panel Results

Changes to the indicator. Panelists expressed concern about the code for venous embolism, and thrombosis of the vena cava. Panelists felt that these complications were not preventable through the same mechanisms as the other diagnoses included in the definition (e.g., pulmonary embolism, phlebitis and thrombophlebitis, femoral vein or other deep vessels, etc.). Although some vena cava thromboses may result from intra vena cava (IVC) filters, the panel was concerned that the pathophysiology of thrombosis in this setting is quite different, and that the decision to place an IVC involves a difficult balancing of risks and benefits. For this reason the code for venous embolism of thrombosis of the vena cava was removed from the definition of this indicator.

Concerns not addressable through changes. There were no other additional concerns regarding this indicator expressed during the conference call.

##### Surgical Panel Results

Changes to the indicator. This panel expressed concerns regarding the code for phlebitis for venous embolism and thrombosis of the vena cava. They felt that the data on IVC filters were still inconclusive and that venous embolism and thrombosis of the vena cava represented a different type of complication than the other codes. They recommended that the code for venous embolism of thrombosis of the vena cava be deleted from the indicator definition.

Panelists were concerned that reporting pulmonary embolism and deep venous thrombosis together may be misleading. Panelists noted that, although in many cases pulmonary embolism and deep venous thrombosis are simply different manifestations of the same complication, deep vein thrombosis is reported more variably. Several panelists noted that some hospitals routinely screen patients for deep vein thrombosis, while others do not. In addition, deep vein thrombosis is diagnosed by various methods. While some providers require ultrasound verification, others require clinical symptoms in order to diagnose deep vein thrombosis. These differences in diagnosis may lead to bias for this indicator. For this reason, panelists suggested that this indicator include reporting of three rates: the overall thrombosis embolism and the pulmonary embolism rate together, the pulmonary embolism rate alone, and the deep vein thrombosis embolism rate alone. This suggestion will be incorporated into the final software for this indicator.

Concerns not addressable through changes. It is widely documented that the risk for DVT/PE varies greatly according to the type of procedure performed. As clotting is more common in peripheral orthopedic procedures, these surgeries have a higher postoperative vascular complication rate than other types of surgeries. Panelists noted, that because of this difference in underlying risk for deep vein thrombosis or pulmonary embolism, that this indicator should be adjusted or stratified according to surgical procedure types. Panelists also noted that despite varying causes for developing DVT/PE that preventative techniques currently exist and the proper use of these techniques should reduce the rate of venous thrombosis or pulmonary embolism. Panelists did note that the literature surrounding preventative techniques is limited to deep vein thrombosis and may or may not be generalized to pulmonary embolism.

##### Summary Across Panels

Both panels rated the overall usefulness of this indicator relatively highly as compared to other indicators. Panelists expressed interest in tracking for the DVT/PE in surgical patients. They noted that preventative techniques should decrease the rate of this indicator. Both recommended the same changes to the indicator. The surgical panel also suggested reporting of pulmonary embolism and deep vein thrombosis separately in the software. This indicator was retained in the Accepted provider level indicator set.

This indicator includes children, which was not specifically discussed by our panelists. It should be noted that in the absence of specific thrombophilic disorders, postoperative thromboembolic complications in children are most likely to be secondary to venous catheters rather than venous stasis in the lower extremities.

#### Postoperative Sepsis

This indicator is intended to flag cases of nosocomial Postoperative sepsis. It is closely related to a complications indicator developed as part of the Complications Screening Program. ^7^ In order to better screen out cases of sepsis that are present on admission this indicator limits its definition of sepsis to secondary diagnoses (meaning sepsis was not labeled as the principal diagnosis). In addition this indicator excludes patients that have principal diagnoses of infection, as it is likely that these patients may have developed sepsis due to these infections, and patients which had a length of stay less than 3 days, as it is unlikely that nosocomial sepsis may have developed in such a short time. This indicator limits the population at risk to patients only with certain medical conditions, as these patients are not at as high a risk for sepsis as other patients (e.g., patients that have undergone procedures of a contaminated structure). Finally, this indicator excludes patients who are particularly susceptible to non-preventable sepsis, namely patients with potential immunocompromised states (e.g., Acquired Immune Deficiency Syndrome (AIDS), cancer, transplant).

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code for [sepsis] in any secondary diagnosis field per 100 discharges in the population at risk.
Denominator | All [elective][surgical] discharges.
| Exclude patients with a principal diagnosis of [infection], or any code for [immunocompromised] state, or [cancer].
| Include only patients with a length of stay of more than three days.
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 8 | Indeterminate agreement
Not present on admission | 8 | Agreement
Preventability | 6.5 | Agreement
Due to medical error | 6 | Indeterminate agreement
Charting by physicians | 8 | Agreement
Bias (lower rating is favorable) | 3 | Indeterminate agreement

a Medical Complications 1 Multi-specialty Panel

Changes to the indicator. The original definition of this indicator, based on Iezzoni et al.'s CSP, ^7^ limited the population at risk to patients in certain MDCs and DRGs for which it was judged that sepsis would be a potentially preventable complication. Panelists felt that this population at risk was too broad, and may include patients that either had sepsis present on admission, or patients with conditions predisposing patients to sepsis. In addition, this definition excluded some patients for which sepsis would be preventable. Panelists agreed that limiting this indicator to all surgery patients undergoing elective surgery was a better way to capture patients for which sepsis is a potentially preventable complication, primarily through pre-surgical screening and appropriate prophylactic therapy.

Concerns not addressable through changes. Panelists expressed few additional concerns regarding this indicator during the conference call and the subsequent evaluation. Some concern was expressed over the varying clinical definitions of “sepsis.” Providers may have different thresholds and methods of diagnosing a patient as septic, leading to some bias for this indicator. Some panelists also expressed that this complication was less of a concern than other complications rated, and that it would be very rare in the population at risk. Finally, two panelists expressed concern about increased inappropriate antibiotic use resulting from the implementation of this indicator.

##### Summary

Panelists rated the overall usefulness of this indicator favorably, although they were less sure that this complication was reflective of medical error. Given the overall rating, this indicator was retained in the Accepted provider level indicator set.

This indicator includes children, which was not specifically discussed by the panel. It should be noted that high-risk neonates are at particularly high risk for catheter-related infections.

#### Postoperative Wound Dehiscence in Abdominopelvic Surgical Patients

This indicator is intended to flag cases of wound dehiscence in patients who have undergone abdominal and pelvic surgery. The area level indicator is intended to capture all cases of wound dehiscence, not only those occurring in-hospital. The hospital level indicator is restricted to secondary diagnoses, and is intended to capture cases occurring during the same hospitalization.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for reclosure of postoperative disruption of abdominal wall (54.61) in any secondary procedure field per 100 discharges.
Denominator | All [abdominopelvic] surgical discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 7.5 | Indeterminate | 7 | Indeterminate
Not present on admission | 7.5 | Indeterminate | 8 | Agreement
Preventability | 6 | Agreement | 7 | Indeterminate
Due to medical error | 6 | Agreement | 5 | Indeterminate
Charting by physicians | 7 | Agreement | 8 | Indeterminate
Bias (lower rating favorable) | 4 | Indeterminate | 7 | Indeterminate

a Multi-specialty panel - Surgical Complications 2

Surgical panel - Surgical Complications 2

##### Multi-specialty Panel Results

Changes to the indicator. Panelists felt that the diagnosis code for postoperative wound disruption would include both minor and severe wound dehiscence, without a means of distinguishing between the two. Panelists felt that a majority would be clinically insignificant minor dehiscences, and preferred to limit the indicator to cases in which a procedure was performed.

Panelists felt that cancer patients should not be excluded, as most of these patients are not at a significant increased risk for the development of non-preventable wound dehiscence.

Concerns not addressable by changes. Panelists reported that the risk of developing wound dehiscence varies with patient factors such as age and comorbidities. If these factors varied systematically by institution, this indicator could be subject to some bias.

##### Surgical Panel Results

Changes to the indicator. Panelists suggested the removal of the diagnosis code for postoperative wound disruption for similar reasons as the multi-specialty panel. As a result, the only code left was limited to abdominal and pelvic surgical patients, and the population at risk was modified to reflect this.

The surgical panel suggested that trauma, cancer, and immunocompromised patients be included as they were interested in tracking these patients, and felt that these patients would not add a sufficient amount of false positives to raise concern. These groups could be examined more closely on further evaluation of this indicator.

Concerns not addressable by changes. Like the multi-specialty panel, the surgical panel noted that patient health is an important factor underlying the risk of developing postoperative wound dehiscence. Patients with comorbidities and older patients may be at higher risk.

##### Summary Across Panels

Both panels suggested similar indicators, although the surgical panel suggested that the indicator include trauma, cancer, and immunocompromised patients. The surgical panel definition was retained in the Accepted provider level indicator set. An area level analog of this indicator was included in the Accepted area level indicator set.

#### Technical Difficulty With Procedure

This indicator is intended to flag cases of complications that arise due to technical difficulties in medical care, specifically those involving an accidental puncture or laceration. It is based on an indicator developed as part of the Complications Screening Program. ^7^

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code denoting [technical difficulty] (e.g., accidental cut, puncture, perforation or laceration during a procedure) in any secondary diagnosis field per 100 discharges.
Denominator | All [medical] and [surgical] discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7 | Agreement
Not present on admission | 8 | Agreement
Preventability | 7 | Agreement
Due to medical error | 6 | Indeterminate agreement
Charting by physicians | 6 | Indeterminate agreement
Bias (lower rating is favorable) | 5 | Indeterminate agreement

a Procedural Complications 1 Multi-specialty Panel

Changes to the indicator. The original definition of this indicator included several complications that could arise from difficulty in performing a procedure, including failure of sterile precautions, performance of an inappropriate operation, emphysema arising from a procedure, cataract fragments in the eye following cataract surgery, and air embolism. However, panelists felt that most of these codes were of questionable clinical significance, variably reported, and not of interest for inclusion in this indicator. As a result, panelists suggested retaining only the two codes for accidental puncture, cut, perforation or hemorrhage during a procedure.

Concerns not addressable through changes. Panelists noted that even with the retained codes, reporting is likely to be variable. Some panelists felt that only major situations are likely to be coded, and that this may be appropriate. However, it is unclear how the culture of quality improvement in a hospital would affect the coding of this complication. Some physicians may be reluctant to record the occurrence of this complication for fear of punishment. Panelists also noted that some of these occurrences are not preventable. However, panelists noted that a high rate may be indicative of poor quality of care.

##### Summary

Panelists rated the overall usefulness of this indicator favorably, although they were less sure that this complication was reflective of medical error. Given the overall rating, this indicator was retained in the Accepted provider level indicator set.

This indicator includes children, which was not specifically discussed by the panel. It should be noted that the smaller anatomy of children may increase the technical complexity of procedures.

#### Transfusion Reaction

This indicator is intended to flag cases of major reactions due to transfusions (ABO and Rh). The area level indicator is intended to capture all cases of transfusion reactions, not only those occurring in-hospital. The hospital level indicator is restricted to patients who have a secondary diagnosis of transfusion reaction, as is intended to flag cases occurring during hospitalization.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [transfusion reaction] in any secondary diagnosis field per 100 discharges.
Denominator | All [medical] and [surgical] discharges.

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 8 | Agreement | 7.8 | Agreement
Not present on admission | 7 | Agreement | 7.5 | Agreement
Preventability | 7 | Disagreement | 8 | Indeterminate
Due to medical error | 7 | Indeterminate | 5.3 | Disagreement
Charting by physicians | 8 | Indeterminate | 7.5 | Agreement
Bias (lower rating favorable) | 6 | Disagreement | 2.5 | Agreement

a Multi-specialty Panel - Surgical Complications 3

Surgical Panel - Surgical Complications 3

##### Multi-specialty Panel Results

Changes to the indicator. Panelists expressed concern that the code 999.8, “other transfusion reaction,” was nebulous and may include reactions caused by minor antigens in patients with complex hematologic histories who may have been sensitized by multiple prior transfusions. These complications were seen as less preventable than Rh or ABO incompatability reactions, and clinically different. For this reason this panel suggested that this code be removed from this indicator.

Panelists also noted that while trauma patients may be at higher risk for developing transfusion reactions, as it may be occasionally appropriate to use blood without cross-matching, reactions in these patients should be monitored and may be preventable. For this reason panelists suggested that trauma patients be added to the population at risk, but that this subgroup should be examined closely.

Concerns not addressable through changes. No other concerns were reported by this panel.

##### Surgical Panel Results

Changes to the indicator. The surgical panel suggested the same changes to this indicator as the multi-specialty panel for similar reasons.

Concerns not addressable through changes. No other concerns were reported by this panel.

##### Summary Across Panels

Both panels rated the overall usefulness of this indicator highly and suggested similar changes to the definition. The indicator is part of the Accepted provider level indicator set. An area level analog of this indicator was included in the Accepted area level indicator set.

This indicator only includes those events which actually result in additional medical care. Thus, near misses and errors in which no harm or little harm results are not included in this indicator. Some minor reactions may be missed, although the panel suggested that these minor reactions are less clearly due to medical error than the Rh or ABO reactions included in the indicator.

### Accepted Obstetric Indicators

#### Birth Trauma - Injury to Neonate

This indicator is intended to flag cases of birth trauma for infants born alive in a hospital. It excludes patients born pre-term, as birth trauma in these patients may be less preventable than for full-term infants.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [birth trauma] in any diagnosis field per 100 liveborn births.
Denominator | All [liveborn] infants.
| Exclude infants with a subdural or cerebral hemorrhage (subgroup of birth trauma coding) AND any diagnosis code of [pre-term infant] (denoting a birth weight of less than 2,500 g and less than 37 weeks gestation).
| Exclude infants with injury to skeleton (767.3, 767.4) AND any diagnosis code of osteogenesis imperfecta (756.51).

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 8 | Agreement
Not present on admission | 8 | Agreement
Preventability | 7 | Indeterminate agreement
Due to medical error | 6 | Disagreement
Charting by physicians | 7 | Indeterminate agreement
Bias (lower rating is favorable) | 4 | Indeterminate agreement

a Obstetric Complications of Delivery 1 Panel

Changes to the indicator. Panelists felt that injury to the brachial plexus often includes injuries that are transient and minor, and therefore may be reported variably. Thus, they suggested removing this code.

Panelists suggested two specific exclusions. First, they suggested that pre-term infants with low birth weight be excluded from the population at risk for intracranial hemorrhage, due to concern that some of these injuries would not be preventable in pre-term infants, who have very fragile bridging veins and may also be at risk for hypoxic injury. Second, they suggested that infants with osteogenesis imperfecta be excluded from the population at risk for injury to skeleton, as these complications are not preventable in these infants.

Concerns not addressable through changes. Panelists noted that some infants are prone to birth injuries, such as babies with shoulder dystocia or large babies. Panelists suggested that predicting these types of deliveries is difficult, and such complications in these babies are often not preventable. Panelists also felt that patients with no or little prenatal care should be treated differently than those with prenatal care. However, these patients cannot be accurately identified using administrative data.

##### Summary

Panelists felt that this indicator was very useful. Although it may not indicate medical error, it does capture potentially preventable complications. It should be noted that panelists were particularly conflicted about the ability of this indicator to detect medical error, with some panelists feeling that it clearly does and others that it clearly does not. Given the relatively high overall rating, this indicator was retained as part of the Accepted provider level indicator set.

#### Obstetric Trauma (All Delivery Types Reviewed in One Indicator)

This indicator is intended to flag cases of potentially preventable trauma during delivery in women delivering during the index hospitalization.

Final Definition: Obstetric Trauma - Vaginal With Instrument

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 instrument assisted vaginal deliveries.
Denominator | All [vaginal delivery] discharges with any procedure code for [instrument assisted delivery].

Final Definition: Obstetric Trauma - Vaginal Without Instrument

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 instrument assisted vaginal deliveries.
Denominator | All [vaginal delivery] discharges.
| Exclude [instrument assisted delivery].

Final Definition: Obstetric Trauma - Cesarean Section

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 cesarean deliveries.
Denominator | All [cesarean delivery] discharges.

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7 | Indeterminate agreement
Not present on admission | Not applicable | Not applicable
Preventability | 7 | Agreement
Due to medical error | 5 | Disagreement
Charting by physicians | 8 | Agreement
Bias (lower rating is favorable) | 4 | Indeterminate agreement

a Obstetric Complications of Delivery 1 Panel

Changes to the indicator. The original definition of this indicator included both 3^rd^ and 4^th^ degree lacerations. Panelists, citing some evidence, felt that 3^rd^ degree lacerations are variably reported, and thus rates would be more reflective of reporting than of the actual rate. If reporting were standardized, panelists were interested in retaining 3^rd^ degree lacerations, but as standardization cannot be guaranteed with administrative data, this indicator was limited to 4^th^ degree lacerations as well as other major lacerations.

Panelists noted that the risk of trauma varies substantially by delivery type, and that indications for different modes of delivery may vary systematically between hospitals. Thus, panelists suggested that this indicator be split into 3 different indicators - vaginal delivery without instrument, instrument assisted delivery, and cesarean section.

Concerns not addressable through changes. Panelists noted that while this indicator is of use (with one panelist dissenting), it is not a pure indicator of medical error. Many cases of trauma will not be preventable, but an unusually high rate would be worth investigating for potential quality problems. Specifically, panelists noted that overuse of episiotomy, may be associated with high rates of obstetrical trauma.

Panelists noted that the obstetrical trauma rate is best interpreted in the context of additional data. Notably, since providers may shift more patients to cesarean sections rather than perform instrument assisted deliveries, which may increase trauma rates, a provider's cesarean section rate should be monitored simultaneously. In addition, providers may want to interpret this indicator in the context of epidural anesthesia rate and perinatal mortality.

##### Summary

Panelists rated the overall usefulness of this indicator favorably, although they suggested that this indicator be stratified. Panelists rated this indicator as one entity, although it was eventually split into three indicators: vaginal delivery with instrument, vaginal delivery without instrument, and cesarean section. Given the high overall rating, all three indicators were retained as part of the Accepted provider level indicator set. Also, a JCAHO 3^rd^ and 4^th^ degree laceration indicator was tested in the empirical analyses as part of the Experimental indicator set.

### Experimental Indicators

#### Aspiration Pneumonia

This indicator is intended to flag cases of perioperative aspiration pneumonia. It is based on an indicator developed as part of the Complications Screening Program, ^7^ although this indicator adds two “E-codes”. This indicator limits aspiration pneumonia codes to secondary diagnosis codes in order to eliminate aspiration pneumonia that was present on admission. It further excludes patients with a primary diagnosis of seizure, trauma, drug overdose or poisoning, as these patients may have aspiration pneumonia or a precursor condition present on admission.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [aspiration pneumonia] in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [elective][surgical] discharges.
| Exclude patients with a principal diagnosis of [seizure], [trauma], [drug overdose], or [poisoning].
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 6 | Indeterminate | 6.5 | Indeterminate
Not present on admission | 7 | Agreement | 8 | Indeterminate
Preventability | 6 | Indeterminate | 6 | Indeterminate
Due to medical error | 6 | Disagreement | 5.3 | Indeterminate
Charting by physicians | 7 | Indeterminate | 5.3 | Agreement
Bias (lower rating favorable) | 5 | Indeterminate | 3 | Indeterminate

a Multi-specialty panel - Surgical Complications 3

Surgical panel - Surgical Complications 3

#### Multi-specialty Panel Results

Changes to the indicator. The panel suggested that the population at risk may be too broad, as patients undergoing emergent or urgent surgery may not have adequate time before surgery to screen patients for risk factors, including having food matter in the stomach. These patients are more susceptible to aspirating perioperatively. For this reason, this panel suggested the population at risk be limited to patients undergoing elective surgery only.

Concerns not addressable through changes. Panelists expressed concern about the diagnosis of this complication. Different physicians diagnose pneumonia differently, with some relying on clinical factors such as chest x-ray and sputum analysis, and others requiring broncoscopy to verify the diagnosis. In addition, some physicians may not label the pneumonia as due to “aspiration” but simply as pneumonia. Panelists noted that such differences may lead to bias for this indicator.

Panelists also noted that the preventability of aspiration pneumonia varies depending on the timing of the aspiration. Aspirations occurring during surgery and in the recovery room are often preventable using preoperative interventions. Pneumonia resulting from these aspirations may be further preventable through administration of medications peri-operatively. However, aspirations that occur later in a hospitalization, for instance in an intensive care unit while a patient is intubated, are less preventable. Because it is impossible to distinguish the timing of the complication using administrative data, this concern cannot be addressed through changes to the indicator definition.

##### Surgical Panel Results

Changes to the indicator. The surgical panel suggested limiting the population at risk to patients undergoing elective surgery for similar reasons as the multi-specialty panel. They also added that even with the exclusions of trauma, seizure, drug overdose and poisoning patients that it is impossible to tell whether patients admitted emergently or urgently aspirated before admission or perioperatively.

Concerns not addressable through changes. The surgical panel also expressed concern regarding the diagnosis of aspiration pneumonia for similar reasons as the multi-specialty panel. Also like the multi-specialty panel, the surgical panel expressed concern about the varied preventability of this complication. They suggested, in addition, that the timing of the aspiration be tracked carefully, if at all possible. They expanded that elderly and highly medicated patients are more likely to aspirate later in a hospitalization.

##### Summary Across Panels

Both panels expressed equivocation about this indicator. While the idea of tracking preventable aspiration pneumonia was of interest, the panels expressed skepticism about whether or not it can be done with administrative data. Both panels suggested the same revisions to this indicator, which are incorporated in the definition of this indicator. The overall rating of this indicator did not meet criteria for full acceptance, and thus this indicator was retained only in the Experimental indicator set.

#### CABG Following PTCA

This indicator is intended to flag cases where CABG follows a PTCA in the same hospitalization, presumably due to complications of that procedure. This indicator was adapted from several published studies, which used CABG after PTCA to examine operator proficiency in relation to procedure volume. ^127^ – ^134,^ ^160^

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [CABG] in any procedure field per 100 discharges with PTCA in any procedure field.
| CABG must occur on the same day or the day after the PTCA procedure.
Denominator | All discharges with ICD-9-CM code for [PTCA] in any procedure field.

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7 | Agreement
Not present on admission | Not reported | Not reported
Preventability | Not reported | Not reported
Due to medical error | Not reported | Not reported
Charting by physicians | Not reported | Not reported
Bias (lower rating is favorable) | Not reported | Not reported

a Procedural Complication 1 Multi-specialty Panel

##### Summary

Overall this indicator was rated as useful, although the panelists were interested in having more cardiologists consulted. The only cardiologist on the panel rated the indicator as very poor. As the other panelists do not perform or care for PTCA patients, and since we were unable to review this indicator with a panel of cardiologists, we assigned this indicator as to the Experimental indicator set, requiring further review. The remaining results from the multi-specialty panel are not reported due to panelists' concerns about rating this indicator.

The denominator for this indicator includes children that receive PTCA, however, this is rare, except in the setting of underlying coronary artery anomalies or cardiac transplantation.

#### Decubitus Ulcer in High Risk Patients

(See “Decubitus ulcer” in Accepted indicators section. This Experimental indicator was not rated by panelists.)

#### In-Hospital Fractures Possibly Related to Falls

(See “In-hospital hip fracture” in Accepted indicators section.)

#### Intraoperative Physical Injuries

(Re-named to: “Intraoperative nerve compression injuries,” after exclusion of corneal abrasions and lip lacerations)

This indicator is intended to flag cases of minor physical trauma caused by the handling of patients in the peri-operative period, particularly the unconscious and/or anesthetized patient. Trauma patients are excluded as these patients may have such complications on admission.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code for [nerve compression injuries] AND a diagnosis code of 997.09 in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude patients with a principal diagnosis of [trauma].
| Exclude patients with a principal diagnosis of [disorders of the peripheral nervous system] or [dorsopathies].

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 8 | Agreement | 8 | Agreement
Not present on admission | 7 | Agreement | 8 | Agreement
Preventability | 8 | Agreement | 8 | Agreement
Due to medical error | 7 | Agreement | 5 | Disagreement
Charting by physicians | 7 | Agreement | 5 | Indeterminate
Bias (lower rating favorable) | 5 | Disagreement | 4 | Indeterminate

a Multi-specialty panel - Surgical Complications 3

Surgical panel - Surgical Complications 1

##### Multi-specialty Panel Results

This indicator was suggested by the multi-specialty panel in lieu of the complications of anesthesia. It was not rated in the initial evaluation, and was briefly discussed for operationalization reasons during the conference call. The panelists suggested that lip lacerations, corneal abrasions and brachial plexopathy be used as complications of surgery.

##### Surgical Panel Results

Changes to the indicator. The surgical panel felt that superficial injuries to the cornea were not of interest to track, as they are temporary and clinically less significant injuries. In addition, this panel suggested that potentially minor lip lacerations be eliminated, leading to the elimination of the code for uncomplicated open wound to the lip.

The surgical panel suggested that additional nerve compression injuries, such as injuries to the ulnar nerve, as they felt that these injuries are important to track as well.

Concerns not addressable through changes. Panelists felt that if these injuries could be accurately detected, it would be of great interest to track. They noted that these injuries, while they often resolve, are distressing to patients, and rather preventable. Panelists did suggest however, that some of these injuries would not be reliably charted by the physician.

##### Summary Across Panels

Both panels agreed that the indicator captured complications that affected the patient, and that were likely to be preventable with careful patient handling. The indicator was slated for the Accepted indicator set, but further information about specification based on coding input raised concerns. For example, lip laceration could not be reliably detected through administrative data, leading to the renaming of this indicator to better reflect the remaining codes, nerve compression injuries. In addition, corneal abrasions were included in the specification rated by the panelists, but ophthalmology specialists would need to be consulted to assess the face validity of including this complication. Concerns about charting from the panelists, along with coding conventions related to a relatively new pertinent code used in the indicator (997.09) resulted in demoting the indicator to the Experimental indicator set.

Recent evidence has suggested that patient factors, such as previous subclinical nerve dysfunction, may play a large role in nerve compression injuries. ^167^ In exploring this indicator, attention should be paid to the potential preventability of these complications. In addition, these conditions are much less common among children than among adults.

#### Malignant Hyperthermia

This indicator is intended to flag cases of malignant hyperthermia. Cases of trauma are excluded, as these patients may be more susceptible to complications.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for malignant hyperthermia (995.86) in any diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 7 | Agreement | 7.5 | Indeterminate
Not present on admission | 8 | Agreement | 8.8 | Agreement
Preventability | 7 | Indeterminate | 5.5 | Indeterminate
Due to medical error | 6 | Disagreement | 3.3 | Indeterminate
Charting by physicians | 8 | Agreement | 8.5 | Agreement
Bias (lower rating favorable) | 2 | Agreement | 1.5 | Agreement

a Multi-specialty panel - Surgical Complications 3

Surgical panel - Surgical Complications 3

##### Multi-specialty Panel Results

Changes to the indicator. No changes were suggested for this indicator.

Concerns not addressable through changes. This indicator was created by the panel during the conference call. As a result panelists only commented on this indicator through written comments. Some panelists noted that this complication is only preventable if a family or personal history of malignant hyperthermia is detected preoperatively. If the question is not asked, or the history ignored, then the complication is undoubtedly due to medical error. However, when the family history is not known or reported by the patient when asked, then the complication is not preventable. Therefore, this rare complication would need to be examined on a case by case basis.

##### Surgical Panel Results

Changes to the indicator. No changes were suggested for this indicator.

Concerns not addressable through changes. Panelists expressed similar concern about two opposing aspects of this indicator, with the complication almost entirely preventable or impossible to prevent based on prior knowledge of family history. They also noted that this rare complication must be considered on a case by case basis.

Panelists also noted that a more appropriate denominator would be all procedures in which anesthesia is used. However, it is impossible to define the denominator as all procedures with anesthesia using administrative data. Thus some complications may be missed, as a result of limiting the population at risk to surgical cases.

##### Summary Across Panels

The overall usefulness of this indicator was rated relatively highly by both panels, with the caveat that some cases are not entirely preventable. Panelists appeared to have conflicting opinions about this indicator, although the final rating did not reflect disagreement. While most panelists agreed that when a family history is known and proper screening and/or preventative measures are not taken, that this is a clearly preventable complication. However, the frequency of this complication occurring under those circumstances is likely to be rare. More frequently, a family history is unknown or unclear, and in these cases there is no link to quality of care. It has been suggested that death due to malignant hyperthermia may be a better measure than malignant hyperthermia alone, however, this idea was not reviewed by the panels, nor empirically examined. This code was implemented in 1998, and thus this indicator could not be analyzed empirically using available data. For this reason this indicator was assigned to the Experimental indicator set.

#### Postoperative Acute Myocardial Infarction (AMI)

This indicator is intended to flag cases of postoperative AMI. It is similar to an indicator developed as part of the Complications Screening Program.7 Codes denoting a “subsequent episode of care” for AMI are not included. This indicator limits AMI codes to secondary diagnosis codes in order to eliminate AMIs that were present on admission. It includes only patients undergoing elective surgery, and excludes patients who are undergoing cardiac surgery, as these patients may be more likely to develop an AMI perioperatively.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [Acute Myocardial Infarction] in any secondary diagnosis field per 100 non-cardiac surgical discharges.
Denominator | [Elective], [surgical] discharges.
| Exclude patients undergoing [cardiac surgery].
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 4 | Indeterminate | 7 | Indeterminate
Not present on admission | 7 | Indeterminate | 8 | Agreement
Preventability | 5 | Indeterminate | 6 | Disagreement
Due to medical error | 4 | Indeterminate | 5 | Indeterminate
Charting by physicians | 7 | Indeterminate | 8 | Agreement
Bias (lower rating favorable) | 5 | Disagreement | 6 | Indeterminate

a Multi-specialty panel - Surgical Complications 1

Surgical panel - Surgical Complications 1

##### Multi-specialty Panel Results

Changes to the indicator. Panelists felt that the risk of acute myocardial infarction varies greatly depending on the comorbidities of the patient, the type of procedure, and the urgency of the procedure. While preventative interventions (e.g., use of beta-blockers in high risk patients) may decrease the postoperative AMI rate, these interventions may be impossible to implement for urgent cases, where there is not adequate time for appropriate screening and risk stratification. In addition, beta-blockers may be inappropriate for trauma patients. Due to these concerns, the panel felt it was best to limit the population at risk to elective surgical patients, who could be appropriately assessed before surgery.

Concerns not addressable through changes. Panelists expressed concerns over the preventability of this complication in some patients. Some patients may be appropriately screened, and assessed, but may have some risk factors. However, the benefits of surgery may outweigh the risk of AMI. Panelists advocated that some established algorithms of AMI risk, such as that adopted by the American Society of Anesthesiologists, may be helpful in appropriately risk adjusting this indicator. However, the clinical detail required for these algorithms is not available in administrative data. As a result, this panel strongly encouraged the use of this indicator only for internal reporting, noting the caveat that many AMIs may not have been preventable. Some panelists felt that examining the appropriate use of beta-blockers directly would be a more appropriate indicator.

In addition to the known risk factors in patients, unknown coronary artery disease may predispose a patient to having a non-preventable postoperative AMI.

##### Surgical Panel Results

Changes to the indicator. The surgical panel questioned the exclusion of MDC 5, as this MDC included vascular surgery patients. Unlike patients undergoing cardiac surgery, for whom it is difficult to establish whether or not an AMI actually occurred, AMI in vascular patients can be established. Panelists felt that vascular surgery patients were an important population at risk for this complication, and thus should not be excluded. The exclusion of MDC 5 was removed, and cardiac surgery patients were excluded using the existing exclusion criteria based on DRGs and ICD-9-CM codes.

The surgical panel advocated for the limitation of the population at risk to elective surgery for similar reasons as the multi-specialty panel. However, they noted that many of the AMIs in this risk group would not be preventable, since they would be unexpected.

Concerns not addressable through changes. The surgical panel also expressed concern over the variable preventability of this complication. They noted that the preventability of this complication depends on the risk factors of the patient. Interventions exist to reduce the chance of AMI in patients with known cardiac artery disease. However, some patients may have unknown disease, or other unknown risk factors. These patients could not receive preventative interventions. In addition, the panel noted that older patients are at higher risk, and advocated for stratification of older patients.

##### Summary Across Panels

The two panels reached different conclusions regarding the usefulness of this indicator (i.e., rejected by multi-specialty panel, accepted by surgical panel). Neither panel was considered to carry more weight because of their unique knowledge of the complication. As a result, the panel scoring was combined, which resulted in this indicator being assigned to the Experimental indicator set. In addition, the multi-specialty panel did not discuss the removal of the exclusion of MDC 5. However, the objection to the exclusion appeared clinically sound. For this reason it was retained in the final definition.

Many patients experiencing postoperative AMI have pre-existing subclinical or clinical coronary artery disease. These diseases are rare in children.

#### Postoperative Iatrogenic Complications

(All complications reviewed in one indicator)

This indicator is intended to flag cases of postoperative iatrogenic complications. It is closely related to an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits complication codes to secondary diagnosis codes in order to eliminate complications that were present on admission.

Final Definition: Postoperative Iatrogenic Complications - Nervous System Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes of [iatrogenic nervous system complications] in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Final Definition: Postoperative Iatrogenic Complications - Cardiac Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes of 997.1 in any secondary diagnosis field per 100 surgical discharges.
Denominator | All [surgical] discharges.
| Exclude all obstetric admissions (MDC 14 and 15).

Final Definition: Postoperative Iatrogenic Complications -Digestive System Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Secondary dx codes of iatrogenic complication of digestive system (997.4)
Denominator | [Surgical] patients

Final Definition: Postoperative Iatrogenic Complications - Respiratory Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Secondary dx code of iatrogenic complication of respiratory system (997.3)
Denominator | [Surgical] patients

Final Definition: Postoperative Iatrogenic Complications - Urinary Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Secondary dx code of iatrogenic complications of urinary system (997.5)
Denominator | [Surgical] patients

Final Definition: Postoperative Iatrogenic Complications - Vascular Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Secondary dx code of iatrogenic peripheral vascular complication (997.2)
Denominator | [Surgical] patients

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | Not reported | Not reported
Not present on admission | Not reported | Not reported
Preventability | Not reported | Not reported
Due to medical error | Not reported | Not reported
Charting by physicians | Not reported | Not reported
Bias (lower rating is favorable) | Not reported | Not reported

a Procedural Complications 1 Multi-specialty Panel

After the panelists rated this indicator, the project team received additional pertinent details about coding conventions for iatrogenic complications coded with 997.xx. These conventions would have been important to the discussion of the indicator, and would have likely influenced the ratings by panelists. As a result, the actual ratings are not reported. The indicator also included 6 distinct clinical areas that could be defined separately: urinary, digestive, respiratory, vascular, cardiac, and nervous system. Empirical analysis of patients who receive these codes was used to determine that four of the six were capturing clinically minor complications that may not be of interest to track. The remaining two areas, cardiac and nervous system, appeared to be identifying cases of potentially serious clinical complications. Thus, cardiac and nervous system iatrogenic complications were retained on the experimental indicator list for further empirical evaluation. However, it would have not been appropriate to include these two indicators in the Accepted indicator set since a clinical panel did not fully assess their face validity. Thus, these two indicators were assigned to the Experimental set, and all others were not considered further.

#### Reopening of Surgical Site

This indicator is intended to flag cases where a surgical site is reopened. It is closely related to an indicator developed as part of the Complications Screening Program. ^7^ This indicator limits reopening codes to secondary procedure codes in order to eliminate scheduled reopening of surgical sites. To further ensure that the reopening of a surgical site is associated with a principal procedure, the reopening must occur at least one day after the principal procedure.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [reopening of a surgical site] in any secondary procedure field per 100 surgical discharges.
| Reopening of surgical site must occur at least one day after the principal procedure.
| Revision of vascular procedure 39.49 must occur within 24 hours of principal procedure.
Denominator | All [surgical] discharges.

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 6 | Indeterminate | 7 | Indeterminate
Not present on admission | 7 | Agreement | 7 | Indeterminate
Preventability | 7 | Indeterminate | 7 | Indeterminate
Due to medical error | 6 | Indeterminate | 6 | Indeterminate
Charting by physicians | 7.5 | Agreement | | Agreement
Bias (lower rating favorable) | 3.5 | Agreement | 5 | Indeterminate

a Multi-specialty panel - Surgical Complications 2

Surgical panel - Surgical Complications 2

##### Multi-specialty Panel Results

Changes to the indicator. Panelists felt the codes for revision of the heart or a vascular procedure were inherently different from other reopening of surgical site codes. Therefore these codes were removed from the definition. Panelists also felt that trauma patients may undergo reopening of surgical sites as a planned procedure. For this reason they suggested that trauma patients be excluded from this indicator. Finally, this panel felt that immunocompromised patients may undergo reopening of surgical site that is not preventable due to wound infection or other complications. Therefore these patients were excluded.

Concerns not addressable by changes. Panelists felt that the preventability of this indicator depends on the reason for reopening. In addition, panelists felt that patient factors such as comorbidities or immunocompromised state may increase the likelihood that a patient would develop this complication.

##### Surgical Panel Results

Changes to the indicator. Panelists suggested the removal of the code for a correction procedure on the heart, for similar reasons as the multi-specialty panel. However, they rejected the removal of the code for revision of vascular procedure, instead opting for the limitation to procedures occurring within 24 hours of the principal procedure. It was felt that these early complications are most likely preventable, due to poor technique or poor patient selection.

Concerns not addressable by changes. Panelists noted that some procedures are purposely staged procedures, and that these procedures should be removed. However, it is impossible to remove all staged procedures using ICD-9-CM codes. In addition, some patients may be at higher risk of reopening, such as when a patient undergoes the removal of failed hardware after an orthopedic surgery.

##### Summary Across Panels

The definition of this indicator relies on ICD-9-CM codes which are defined as reopenings that cannot be defined using another ICD-9-CM code. Thus, reopenings that result in a more complicated procedure than simply a reopening of the surgical site would not be captured by this indicator. Panelists were not aware of this caveat when rating this indicator, and it was felt then that their ratings did not truly reflect the actual nature of this indicator. In addition, panelists requested that planned reopenings such as staged procedures be excluded. The operationalization of this suggestion was beyond the scope of this study, as it would have required a full review of ICD-9-CM procedure codes. Thus, this indicator was retained only in the Experimental indicator set.

#### Suture of Laceration

This indicator is intended to flag cases of lacerations during a surgical procedure, which result in a suturing procedure. It is closely related to a indicator developed as part of the Complications Screening Program, ^7^ although it does add codes for the suture of laceration of diaphragm, blood vessel, small intestine, and anus. This indicator limits suture of laceration codes to secondary procedure codes in order to isolate those lacerations that can truly be linked to a surgical procedure. For the same reason, this indicator eliminates all sutures of lacerations that take place before the principal procedure.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [suture of laceration] in any secondary procedure field per 100 surgical discharges.
| Suture of laceration must occur on the same day or after the principal procedure.
Denominator | All [surgical] discharges.
| Exclude patients with any diagnosis code for [foreign body] or [trauma].
| Exclude all obstetric admissions (MDC 14 and 15).

Post-Conference Call Panel Ratings^a^

Question | Median (MS) | Agreement status (MS) | Median (S) | Agreement status (S)
Overall rating | 8 | Agreement | 5 | Indeterminate
Not present on admission | 7 | Agreement | 7 | Agreement
Preventability | 8 | Agreement | 6 | Indeterminate
Due to medical error | 7 | Indeterminate | 6 | Indeterminate
Charting by physicians | 8 | Indeterminate | 6 | Indeterminate
Bias (lower rating favorable) | 4 | Indeterminate | 5 | Indeterminate

a Multi-specialty panel - Surgical Complications 2

Surgical panel - Surgical Complications 2

##### Multi-specialty Panel Results

Changes to the indicator. Panelists expressed concern that lacerations vary in morbidity. Some lacerations, minor in nature, would be considered routine during a procedure, and may not be reported, depending on the detail of the surgical notes. Some surgeons, however, may report these minor lacerations leading to bias in reporting of lacerations. Panelists agreed that some more serious lacerations are important complications to track. To ensure that lacerations are consistently reported and are of sufficient morbidity to cause concern, this panel suggested that the indicator be limited to lacerations that require a return to the operating room. Administrative data do not allow for tracking returns to the operating room that occur on the same day of the principal procedure. The only option to implement the suggestion would be to limit suture of laceration codes to those occurring the day following the procedure or later.

Concerns not addressable by changes. No additional concerns were raised during the conference call of surgical panels.

##### Surgical Panel Results

Changes to the indicator. Unlike the multi-specialty panel, the surgical panel disagreed with the exclusion requiring a return to the operating room, because this required that the suture of laceration occur one day after or following. They felt that this exclusion would limit the number of flagged complications to a very small number making the indicator less useful.

The panel noted that the listed lacerations do not include lacerations that may occur during all procedures. As a result, they suggested several types of lacerations that should be included in the indicator, including obstetric and gynecological lacerations. Obstetric lacerations are included in another indicator. For this reason these codes were not added. However gynecological lacerations were added as were urological and nerve suture of laceration codes.

Concerns not addressable by changes. The surgical panel also noted that many lacerations occurring during surgery are trivial in nature. They thought that these lacerations are less likely to be recorded by the physician, and are less important to track. Many panelists felt that the exclusion of the trivial lacerations from this indicator would be desirable, as this restriction would limit complications to those causing significant morbidity for the patient.

Panelists noted that patient characteristics and procedure type greatly affect risk of a laceration occurring. Lacerations may occur as an expected complication of the procedure, during complex procedures on complicated structures, such as some types of hand surgery. It was also noted that re-surgery or repeat surgery is the major risk factor for suture of laceration, due to a build up of scar tissue. They noted that this case-mix difference is not addressable by limiting the indicator to elective surgery. Since re-surgery cannot be adjusted for using administrative data, panelists recommended that re-surgery rates be examined when using this indicator.

##### Summary Across Panels

The two panels arrived at slightly different definitions. The first panel required a return to the operating room, which was rejected by the second all surgeon panel. Empirical analysis revealed that this restriction significantly lowers the number of cases. Since the second panel had more expertise, the surgical panel's definition was retained for further analysis. The surgical panel rated the overall usefulness of this indicator relatively low and the multi-specialty panel rated this definition very highly, so this indicator was assigned to the Experimental indicator set.

### Experimental Obstetric Indicators

#### Obstetric Wound Complications - Cesarean Section Delivery

This indicator is intended to flag cases of potentially preventable delivery wound complications in women delivering by cesarean section during the index hospitalization.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [cesarean wound complications] in any diagnosis field per 100 deliveries.
Denominator | All [cesarean delivery] discharges.

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7.5 | Agreement
Not present on admission | 8.5 | Agreement
Preventability | 6.5 | Indeterminate agreement
Due to medical error | 2.5 | Indeterminate agreement
Charting by physicians | 7 | Indeterminate agreement
Bias (lower rating is favorable) | 5 | Agreement

a Obstetric Complications 2 Panel

Changes to the indicator. This indicator was originally presented as a combined indicator of all obstetric wound complications (cesarean and vaginal). Panelists felt that wound complications of cesarean delivery differed substantially from those of vaginal delivery in both cause and preventability. For this reason they suggested that these complications be split into two separate indicators, and that the more useful indicator would be limited to cesarean deliveries.

Concerns not addressable through changes. Panelists expressed concern that the severity and layer of the wound dehiscence could not be determined using this indicator. Thus both superficial disruptions and deep fascial disruptions are combined into one indicator. If possible, panelists felt that the deeper wound disruptions should be tracked more closely than superficial disruptions. However, this is not possible with the current coding conventions.

Panelists noted that wound complications are less preventable in some subgroups, such as patients with overall poor tissue health, diabetics, and those having had a prior c-section, and that these risk factors are more common in patients with lower socioeconomic status. Thus, panelists expressed concern that some bias may be present for this indicator based on patient case mix.

Finally, some panelists felt that the use of this indicator could lead to the inappropriate overuse of antibiotics.

##### Summary

Panelists rated the overall usefulness of this indicator favorably. However, they rated the extent to which this indicator reflected medical error as very poor. Because these indicators are intended to identify potential patient safety problems, the lack of literature supporting this indicator and the panel's equivocality regarding the indicator, this indicator was assigned to the Experimental indicator set.

#### Obstetric Wound Complications - Vaginal Delivery

This indicator is intended to flag cases of potentially preventable delivery wound complications in women delivering during the index hospitalization.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [perineal wound complications] in any diagnosis field per 100 deliveries.
Denominator | All [vaginal delivery DRGs].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 6.5 | Indeterminate agreement
Not present on admission | 8 | Agreement
Preventability | 4 | Indeterminate agreement
Due to medical error | 3 | Indeterminate agreement
Charting by physicians | 6 | Indeterminate agreement
Bias (lower rating is favorable) | 5 | Indeterminate agreement

a Obstetric Complications 2 Panel

Changes to the indicator. This indicator was originally presented as a combined indicator of all obstetric wound complications (cesarean and vaginal). Panelists felt that wound complications of cesarean delivery differed substantially from that of vaginal delivery in both cause and preventability. For this reason they suggested that these complications be split into two separate indicators. For patients who deliver vaginally, panelists agreed that diagnosis codes for vulval and perineal hematoma should be added as they felt that these complications may be preventable.

Concerns not addressable through changes. Panelists felt that some case mix bias may result from differing preventability of this complication. Patients having poor tissue health, poor nutrition, underlying conditions such as diabetes, or undergoing operative vaginal delivery would be more susceptible to this complication. Panelists also noted that many perineal wound disruptions are not apparent until after hospital discharge. Thus a large percentage of these wound disruptions would be missed using inpatient administrative data. Finally, panelists expressed concern that the use of this indicator may lead to a higher cesarean section rate, as physicians avoid operative delivery or episiotomies.

##### Summary

Panelists were uncertain about the usefulness of this indicator and they clearly noted that this complication is not reflective of medical error. Because of the ambiguity of this indicator, this indicator was retained in the Experimental indicator set for further investigation.

### Other Obstetric Complications

#### Uterine Rupture

This “other obstetric complications” indicator is intended to flag cases of potentially preventable delivery complications in women delivering during the index hospitalization. The “Uterine rupture” indicator became a separate indicator based on panel input, and is intended to flag cases of uterine rupture in women who have undergone a trial of labor.

Final Definition: Other Obstetric Complications

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [other obstetrical complications] in any diagnosis field per 100 deliveries.
Denominator | All [deliveries].

Final Definition: Uterine rupture

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM codes for [rupture of uterus during or after labor] in any diagnosis field per 100 deliveries with trial of labor.
Denominator | All deliveries with a [trial of labor].

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 6.5 | Indeterminate Agreement
Not present on admission | 8 | Agreement
Preventability | 5 | Indeterminate Agreement
Due to medical error | 5 | Indeterminate Agreement
Charting by physicians | 8 | Agreement
Bias (lower rating is favorable) | 5 | Indeterminate Agreement

a Obstetric Complications 2 Panel

Changes to the indicator. Panelists suggested that the rate of uterine rupture be adjusted for vaginal birth after cesarean section (VBAC) rate, as these patients are well documented to be at higher risk of uterine rupture. To address the intent of this suggestion, a separate indicator was specified to measure the rate of uterine rupture only for patients who have a trial of labor. Panelists rated the “Other obstetric complications” indicator, with uterine rupture included, but adjusted for VBAC rate. The implementation of the “Uterine rupture” indicator occurred after the panelists' final evaluation.

Concerns not addressable through changes. Panelists expressed concern that the preventability of these heterogeneous and relatively rare complications varies by the complication. They noted that a majority of these complications are not easily preventable, although some are minimized if a diagnosis is made and treatment promptly started. They noted that patient comorbidities and factors influence some of these complications, and that referral centers receive more of these patients than other centers.

Panelists were concerned that differences in coding may affect this indicator. For instance, some benign uterine ruptures, so called uterine windows, may be coded, when they are clinically insignificant. Panelists were not interested in tracking these minor complications, but the restrictions of administrative data make tracking only severe complications impossible.

##### Summary

Panelists were uncertain about the usefulness of this indicator and they clearly noted that this complication is not reflective of medical error. Because of the ambiguity of this indicator, this indicator was retained in the Experimental indicator for further investigation. Also stemming from this indicator was a separate uterine rupture indicator. Although panelists requested that uterine rupture be combined with other complications, such that this currently widely discussed complication would not be singled out, the requested risk adjustment for trial of labor after cesarean was not easily operationalized when uterine rupture was combined with other complications for which this risk adjustment was inappropriate. The uterine rupture indicator was also retained in the Experimental indicator set.

#### Post-partum Urinary Tract Infection (UTI)

This indicator is intended to flag cases of potentially preventable puerperal urinary tract infections in women delivering during the index hospitalization. This indicator excludes patients with infection of the amniotic cavity, as infection in these patients is more likely to be present on admission or non-preventable. This indicator was suggested by one of the obstetric complication panels.

Final Definition

Quality Measure | Number of events per 100 discharges of population at risk
Numerator | Discharges with ICD-9-CM code of 646.62 or 646.64 in any diagnosis per 100 deliveries.
Denominator | All [cesarean delivery] and [vaginal delivery] discharges

Post-Conference Call Panel Ratings^a^

Question | Median | Agreement status
Overall rating | 7 | Indeterminate agreement
Not present on admission | 5 | Indeterminate agreement
Preventability | 7 | Indeterminate agreement
Due to medical error | 3.5 | Indeterminate agreement
Charting by physicians | 7 | Indeterminate agreement
Bias (lower rating is favorable) | 3.5 | Indeterminate agreement

a Obstetric Complications 2 Panel

Changes to the indicator. This indicator was suggested and created by the panel, due to the interest in tracking post-partum urinary tract infections.

Concerns not addressable through changes. Several concerns about this indicator were raised, although most panelists remained interested in tracking this complication, since its use may decrease unnecessary catheterization. Panelists felt that some hospitals may have a higher rate of these complications due to patient case mix. Specifically, they noted that patients with other infections or overall poor health are more likely to develop these complications. These factors vary systematically with socioeconomic status. Also, patients that undergo operative delivery or regional anesthesia may be at higher risk of developing post-partum UTI. Further, they noted that many of these complications develop after discharge. Thus, there may be significant underreporting resulting from the exclusive use of inpatient data. Finally, panelists expressed concern that the use of this indicator would lead to the inappropriate overuse of antibiotics.

##### Summary

Panelists rated the overall usefulness of this indicator favorably. However, they rated the extent to which this indicator reflected medical error as very poor. Because these indicators are intended to identify potential patient safety problems, the lack of literature supporting this indicator and the panels equivocality regarding the indicator, this indicator was assigned to the Experimental indicator set.

Third or Fourth Degree Obstetric Laceration

(This indicator was not reviewed. See “Obstetric trauma” in Accepted indicators section for discussion.)

Uterine Rupture

(See “Other obstetric complications.”)

## Section 3E. Comparative Empirical Results

Extensive empirical analyses were conducted on indicators accepted by the clinical panels as having met minimum criteria for face validity (i.e., Accepted Hospital Level Indicators, Accepted Area Level Indicators). These analyses were intended to provide additional information about indicators, rather than as decision making tools regarding the validity of these indicators. Additional research exploring the validity of these indicators is discussed in Chapter 4. The analyses included in this report are intended to provide guidance for future research and use of these indicators, and include statistical measures of reliability, bias, relatedness of indicators and persistence over time, in addition to adjusting for demographics, DRG and comorbidities. MSX methods, correlation analysis and factor models investigated relationships among the set of accepted indicators in order to identify potential underlying constructs (e.g., processes of care or structural characteristics) common to some or all of the indicators. ^ 1 ^

1 The empirical analyses reported, except for raw rates, reflect a prior version of the indicator definitions (e.g., specified software) than specified in Appendices D and E. In this prior version of the software used in this report three differences were present. First, for the indicator “Postoperative hemorrhage or hematoma,” procedure codes for control of hemorrhage and hematoma were combined into a single category, applied to either diagnosis, resulting in a 20% increase in this indicator's rate compared to the final definition. Second, “Postoperative hip fracture” included pediatric patients, a group seldom experiencing this condition. Third, in the comorbidity software, when fifth digits specified the presence of more than one comorbidity, only one comorbidity was assigned (renal failure, if present, or congestive heart failure, if renal failure was not present). It is anticipated that these minor changes would not affect the overall results of these analyses.

Less extensive empirical analyses were conducted on the Experimental Hospital Level Indicators, including statistical measures of reliability and bias, with adjustments for demographics, DRG and comorbidities. Because there was no a priori reason to suspect an underlying construct common to these heterogeneous measures, no attempt was made to identify one. Therefore each of the experimental indicators are meant to be evaluated separately and subjected to further investigation and refinement. Although there are exceptions, in general the experimental indicators tend to have less systematic hospital level variation than the accepted indicators, but do not appear to be more or less biased.

All of the findings on bias reflect the level of information available for risk adjustment using HCUP SID data, and may therefore not apply to data sets that have more clinically detailed data elements. The presence of “high bias” mentioned in this section suggests that risk adjustment, using administrative data elements, is necessary to interpret hospital level differences in the rates of these indicators. However, for all indicators, the risk adjustment that is possible using HCUP data may or may not be adequate to correct potential bias.

The text in this section makes reference to numbered tables that can be found in Appendix G. The figures and tables contained in this section graphically or categorically summarize the numerical results in the Appendix G tables.

The empirical evidence presented here is intended to guide future use and development of these PSIs. As such, the relevance on any particular piece of empirical evidence will depend on the purpose of the analysis being conducted. However, among the accepted non-obstetric hospital level indicators, five of the measures that appear to perform well on several different dimensions, including reliability, bias, relatedness of indicators, and persistence over time, are the following: “Complications of anesthesia,” “Postoperative wound dehiscence,” “Postoperative hemorrhage or hematoma,” “Death in low mortality DRGs,” and “Postoperative hip fracture.” The other 11 non-obstetric accepted indicators often perform well, and provide useful information for their intended purpose. The obstetric indicators (“Birth trauma,” “Obstetric trauma - vaginal delivery with instrumentation,” “Obstetric trauma - vaginal delivery without instrumentation,” “Obstetric trauma - cesarean section,”) also tend to perform well, though partly because of the higher rates and consequently large amount of variation among providers in these indicators; and partly because only age and gender risk adjustment was applied, so that the indicators showed little apparent bias.

### Accepted Hospital Level Indicators

An analysis of the overall rates of PSIs in the National SID found that the least frequent PSI is Transfusion Reaction, with only 16 cases in Florida and 129 cases in the National SID in 1997. The most frequent PSIs are “Obstetric trauma - vaginal delivery without instrumentation” and “Failure to rescue,” with 120,858 and 135,085 cases in the National SID, respectively. The total number of adverse events (numerator), the total number of patients at risk (denominator), and the overall rate in Florida and the National SID for each accepted patient safety indicator can be found in Appendix G Table 1. The rates for the Florida SID used for initial testing, and the National SID were generally similar.

The mean hospital rates for each indicator in the National SID are depicted in Figure 1 below. A comparison of the National SID mean hospital rates and the Florida SID show that these rates are similar (see Appendix G Table 2), although the standard deviation and skew statistic (which is a measure of the symmetry of the hospital level distribution) are greater in the National SID than in Florida, especially for the relatively rare PSI. This is likely true for most individual states; the greater number of the hospitals in the National SID increases the detection of occurrence for infrequent events. Also noteworthy in this analysis is that some indicators have a substantial number of hospitals that do not have any discharges in the denominator. For the obstetric indicators in particular, about one-fourth of hospitals have no deliveries at risk.

Figure 1. Summary of Mean Hospital Level Rates

The rates vary considerably across measures, from a high of 20.3% for “Obstetric trauma - vaginal delivery with instrumentation” to a low of 0.001% for “Transfusion reaction” (which represents 129 cases in the National SID in 1997). “Obstetric trauma - vaginal delivery without instrumentation” and “Failure to rescue” also have much higher rates than the other PSI, which are generally 2% or less.

The apparent standard deviations, as shown in Figure 2, (unadjusted for risk or reliability) also vary considerably among the measures, from a high of 14.2 percentage points for “Obstetric trauma - vaginal delivery with instrumentation” (relative to a mean of 20.3 percentage points) to a low of less than 0.1 percentage points for “Iatrogenic pneumothorax,” “Transfusion reaction” and “Foreign body left during procedure.” The non-obstetric measures with the greatest amount of hospital level variation in absolute magnitude are “Failure to rescue,” “Postoperative sepsis” and “Decubitus ulcer.” Among the obstetric indicators, “Obstetric trauma (with and without instrumentation)” has the most variance. Relative to the mean hospital level rate, the measures with the greatest hospital level variation are “Postoperative physiological and metabolic derangement,” and “Death in low mortality DRGs.” In other words, some of these measures have low rates of occurrence, so the absolute magnitude of the variance is small, but the degree of spread in the rates is relatively large.

Figure 2. Summary of Standard Deviations in Hospital Level Rates

The hospital level variation tends to be skewed toward the right, meaning that there is a long right-hand tail of hospitals with higher rates (see Appendix G, Table 3). The most highly skewed measures are “Complications of anesthesia,” “Postoperative physiological and metabolic derangement,” and “Death in low mortality DRGs,” with a median skew statistic for all indicators of 10.0. Examples of the distributions may be found in Appendix G, Figures 1 and 2. These figures show the distribution of hospital level rates for “Decubitus ulcer” (with a median rate of 1.6%, a mean rate of 2.1% and skew statistic of 3.57) and “Birth trauma” (with a median rate of 0.25%, a mean rate of 0.94% and a skew statistic of 11.85). Hospitals with zero rates are excluded from the figures, which comprise 10% and 25% for “Decubitus ulcer” and “Birth trauma,” respectively.

Figure 1. Decubitus Ulcer

Distribution of non-zero hospital level Decubitus Ulcer rates in 1997 National SID (10% of the hospitals have a zero rate). Y-Axis is the percent of hospitals. X-axis is the hospital's Decubitus Ulcer rate, unadjusted. The blue line is the normal distribution superimposed on the actual distribution. Median rate is 1.6%, mean rate is 2.1% and skew statistic is 3.62.

Figure 2. Birth Trauma

Distribution of non-zero hospital level Birth Trauma rates in 1997 National SID (25% of the hospitals have a zero rate). Y-Axis is the percent of hospitals. X-axis is the hospital's Birth Trauma rate, unadjusted. The blue line is the normal distribution superimposed on the actual distribution. Median rate is 0.25%, mean rate is 0.88% and skew statistic is 13.00.

#### Risk Adjustment

Three levels of risk adjustment were applied to the measures using a logistic model. First, the hospital level measures were adjusted for age, gender and age-gender interactions. The age groups are the standard age categories used by the National Center for Health Statistics (NCHS) in their descriptive statistics, namely 0, 1–4, 5–14, 15–24, 25–34, 35–44, 45–54, 55–64, 65–74, 75–84 and 85+. Next, the measures were adjusted for age, gender, and modified DRG category. The categories were modified to combine separate DRGs with and without complications, and to exclude the super-MDC DRGs (e.g., Tracheostomies). Finally, the measures were adjusted for age, gender, DRG and comorbidity, using a modified version of the AHRQ comorbidity software. Details are provided in Section 2E Empirical Methods.

Overall, age-gender risk adjustment tended to increase the level of apparent hospital level variation by about 2% (see Appendix G, Table 3). Given the low rates of occurrence, “Transfusion reaction” and “Foreign body left in during procedure” were not risk adjusted for technical reasons, although there may be conceptual reasons to risk adjust these indicators. The impact was greatest on “Postoperative respiratory failure,” “Postoperative hemorrhage or hematoma,” “Postoperative wound dehiscence,” and “Death in low mortality DRGs,” and minimal on most other indicators. The rates tend to be slightly more skewed, meaning that differences in the age-gender mix were masking differences in rates, but several measures are slightly more skewed, meaning that some of the higher rates could be accounted for by differences in the age-gender mix of the population at-risk.

In addition to age-gender risk adjustment, DRG and comorbidity risk adjustment was performed (see Appendix G Table 4). The obstetric measures are not adjusted for DRG. The “Death in low mortality DRGs” indicator is also not adjusted for DRG. Rather, the indicator is stratified by DRG group, namely medical (adult and pediatric), surgical (adult and pediatric), neonatal, obstetric and psychiatric (See Appendix G, Table 1). Relative to age-gender adjustment, the overall impact of DRG adjustment was greater, decreasing hospital level variation by 4.1%. Comorbidity adjustment decreased variation by 1.6%. Most of the variation among hospitals explained by the risk adjustment was accounted for by DRG, with incremental amounts accounted for by the comorbidity categories, although comorbidity adjustment was relatively more important for some indicators. DRG risk adjustment had the biggest impact on “Technical difficulty with procedure,” “Failure to rescue,” “Infection due to medical care,” and Postoperative PE or DVT.” Comorbidity risk adjustment had the biggest impact on “Postoperative respiratory failure,” “Infection due to medical care,” “Decubitus ulcer,” and “Postoperative sepsis.” Variation in “Postoperative hemorrhage or hematoma” and “Death in low mortality DRGs” actually increased slightly.

#### Reliability Adjustment

The effect of the reliability adjustment was examined by the statistics on the signal standard deviation, signal share and signal ratio (see Appendix G, Table 5). Hospitals with fewer than three patients in the denominator were not included in the reliability adjustment. Multivariate methods (taking into account correlations among indicators in order to extract additional ‘signal’) were applied to most of the accepted indicators. The exceptions were “Death in low mortality DRGs” and “Failure to rescue.” Only univariate smoothing methods were applied to these two indicators. Overall, the reliability adjustment reduced the hospital level variation dramatically. On average, over one-half of the apparent hospital level variation, even after risk adjustment, was estimated to be attributable to noise. The measures that were affected the most by reliability adjustment in terms of reduction in the hospital level standard deviation were “Postoperative physiological and metabolic derangement,” “Postoperative sepsis,” and “Postoperative hemorrhage or hematoma.” The measures that were affected the least were “Birth trauma,” “Iatrogenic pneumothorax” and “Technical difficulty with procedure.” (For examples of the distribution of indicators see Appendix G, Figures 3 and 4.) These figures show the distribution of hospital rates for “Decubitus ulcer” and “Birth trauma” after risk and reliability adjustment.

Figure 3. Decubitus Ulcer

Distribution of non-zero hospital level Decubitus Ulcer rates in 1997 National SID (25% of the hospitals have a zero rate). Y-Axis is the percent of hospitals. X-axis is the hospital's Decubitus Ulcer rate, adjusted for risk and reliability. The blue line is the normal distribution superimposed on the actual distribution. Median rate is 1.4%, mean rate is 1.7% and skew statistic is 3.23.

Figure 4. Birth Trauma

Distribution of non-zero hospital level Birth Trauma rates in 1997 National SID (25% of the hospitals have a zero rate). Y-Axis is the percent of hospitals. X-axis is the hospital's Birth Trauma rate, adjusted for risk and reliability. The blue line is the normal distribution superimposed on the actual distribution. Median rate is 0.26%, mean rate is 0.91% and skew statistic is 13.01.

#### MSX Statistics

The MSX statistics give estimates of the degree of total hospital level variation accounted for by signal and noise, and the degree of total variation (hospital and patient) accounted for by signal. Signal standard deviation is an estimate of the systematic variation (‘signal’) among hospitals (See Figure 3). The higher the signal standard deviation, the greater the opportunity to identify hospital characteristics associated with higher (or lower) rates. The non-obstetric measures with the most signal are “Failure to rescue,” “Decubitus ulcer” and “Postoperative PE or DVT.” Among the obstetric measures, “Obstetric trauma - vaginal delivery (with and without instrumentation)” and “Birth trauma” have the most signal. For “Decubitus ulcer,” the signal variance represents a difference of 60 adverse events (20 to 80 with a mean of 50) per hospital between the bottom and top hospitals in the middle two-thirds of the distribution. The measures with the least signal are “Postoperative hemorrhage or hematoma,” “Infection due to medical care” and “Iatrogenic pneumothorax. The measures “Transfusion reaction” and “Foreign body left during procedure” have no signal, meaning no detectable systematic hospital level variation.

Figure 3. Summary of Signal Standard Deviation in Hospital Level Rates

The signal share (see Figure 4) is a measure of the share of total variation (hospital and patient) accounted for by the signal (hospital). The higher the share is, the relatively more important the hospital in accounting for the rate. The lower the share is, the less important the hospital, and the more important other potential factors (e.g., patient characteristics). The non-obstetric measures with the higher signal share are “Death in low mortality DRGs,” “Decubitus ulcer” and “Failure to rescue.” “Birth trauma” and “Obstetric trauma - vaginal delivery (with and without instrumentation)” have the highest share among the obstetric indicators. The overall low levels of the share of total variation accounted for by hospitals is an indication that there are many other factors that influence these rates besides the hospital.

Figure 4. Summary of Signal Share in Hospital Level Rates

Finally, signal ratio is a measure of how much of the observed variation is signal and how much is noise (see Figure 5). The ratio is affected both by the amount of signal and by the amount of noise. In other words, the signal ratio will be high even in the absence of much signal, if the amount of noise is also low. For the PSIs, the ratios tend to be high even with little signal because the hospital sample sizes are very large for most of the indicators, which makes the hospital estimates precise (i.e., low noise). The higher the signal ratio, the more likely that observed differences in risk adjusted rates reflect true differences in hospital performance. The lower the signal ratio, the more likely that observed differences in risk adjusted rates reflect a large degree of noise. Non-obstetric indicators with the highest signal ratio are “Death in low mortality DRGs,” “Decubitus ulcer” and “Iatrogenic pneumothorax.” Among the obstetric indicators, “Birth trauma - injury to neonate” and “Obstetric trauma - vaginal delivery without instrumentation” have the highest ratio. Indicators with the lowest signal ratio are “Postoperative hemorrhage or hematoma,” “Postoperative sepsis” and “Postoperative wound dehiscence.”

Figure 5. Summary of Signal Ratio in Hospital Level Rates

#### Minimum Bias

The effect of age, gender, DRG and comorbidity risk adjustment on the relative ranking of hospitals, compared to no risk adjustment, was assessed using five measures of impact. Both the unadjusted and risk adjusted measures were adjusted for reliability, in order to remove the impact of noise on the assessment of potential bias. Also, even if risk adjustment reduces the apparent level of hospital level variation, the relative rank may not be affected if the distribution of the adjusters does not vary systematically across hospitals. A large impact on the relative ranking means that the measures are biased based on the patient characteristics we observe from the administrative data. Minimal or no impact means that the measures are not biased based on the characteristics we observe (although there might be characteristics that we do not observe using administrative data that are related to the patient's risk of experiencing an adverse event).

The first measure is a relative rank correlation statistic (a measure of the impact of adjustment on the assessment of relative hospital performance). The second measure is the average absolute magnitude of the change in unadjusted - adjusted rate for each hospital (a measure of the relative importance of adjustment). The third and fourth measures are the percentage of hospitals that remain in the top (or bottom) 10% of the distribution after adjustment (measures of the impact on the highest and lowest hospitals). The last measure is the percentage of hospitals that change more than two deciles in the distribution after adjustment (a measure of the impact throughout the distribution). According to the rank correlation, the indicators most affected in terms of the relative ranking of hospitals are “Failure to rescue,” “Decubitus ulcer,” “Technical difficulty with procedure,” “Postoperative PE or DVT,” “Death in low mortality DRGs,” “Iatrogenic pneumothorax,” “Postoperative sepsis” and “Postoperative respiratory failure.” The least affected indicators are “Birth trauma - injury to neonate,” “Obstetric trauma - vaginal delivery without instrumentation” and “Complications of anesthesia.” DRG risk adjustment could not be applied to the obstetric indicators, because obstetric DRGs are divided only by the mode of delivery and the presence or absence of complications or comorbidities. Also, comorbidity adjustment may not be as applicable to the obstetric population, and in some specific instances (see Appendix D) could not be applied to obstetric indicators, as applicable ICD-9-CM codes were not available.

In terms of absolute magnitude of the change in adjusted rate, the impact is greatest for “Failure to rescue,” “Technical difficulty with procedure,” and “Death in low mortality DRGs.” Along with “Decubitus ulcer,” “Failure to rescue,” “Technical difficulty with procedure” and “Death in low mortality DRGs” also have the greatest impact at the upper tail of the distribution, meaning that accounting for these patient characteristics accounts for the very high rates of these indicators for some hospitals.

Overall, if one were to create a simple score based on the five measures of potential bias (e.g., ranking the indicators 1 to 20 for each bias measures, and summing the ranks), the most biased measures would be “Failure to rescue,” “Technical difficulty with procedure,” “Decubitus ulcer” and “Postoperative PE or DVT.” The least biased measures would be “Postoperative hemorrhage and hematoma” and “Complications of anesthesia.” This is summarized in Table 18. Obstetric measures in general also demonstrate little bias, although these indicators were subjected to less risk adjustment than the other indicators. However, these categories are not definitive. Each bias measure stands on its own as a measure of performance, depending on the purpose of the analysis. Also, as mentioned in the introduction, more clinically detailed information than is available in the HCUP SID may yield different conclusions. What is certain is that unadjusted rates for the ‘high’ bias measures are likely to be misleading.

Table 18 Summary of Minimum Bias in Hospital Level Rates

High Bias | Medium Bias | Low Bias
Failure to rescue | Postoperative hip fracture | Postoperative hemorrhage or hematoma
Technical difficulty with procedure | Iatrogenic pneumothorax | Complications of anesthesia
Decubitus ulcer | Postoperative physiological and metabolic derangement
Postoperative PE or DVT | Infection due to medical care
Death in low mortality DRGs | Postoperative wound dehiscence
Postoperative sepsis
Postoperative respiratory failure

#### Relatedness of Indicators

To investigate the relationship between indicators, we examine the hospital level Spearman correlations among the measures, and conduct a factor analysis using principal factor analysis based on the Spearman correlations (with a varimax rotation in order to maximize the loadings on each factor). The correlations between the measures can be found in Appendix G Table 7. If a measure is valid, it should be correlated with related measures that reflect similar aspects of hospital performance or hospital characteristics. For example, “Obstetric trauma - vaginal delivery without instrumentation” is correlated with “Obstetric trauma - vaginal delivery with instrumentation” (a correlation of 0.545, p<.0001). For the most part the measures are positively correlated (p<.05), with the exception of “Postoperative respiratory failure” and “Failure to rescue,” which are negatively correlated with several other indicators. “Technical difficulty with procedure” is positively correlated with several other measures, including “Infection due to medical care” (0.306, p<.0001) and “Iatrogenic pneumothorax” (0.318, p<.0001). It is not expected that all indicators would be strongly correlated with each other, as different aspects of quality may be reflected by each indicator.

Two factor analyses were conducted to examine the relationship and possible underlying “factors.” The first analyses combined obstetric and non-obstetric indicators. This factor analysis reflects the correlation results and suggests that there are two “factors” or underlying constructs common among all the PSI. Appendix G, Table 8 shows the factor loadings and share of variation explained for each factor and for each PSI. There are two factors that explain almost all of the systematic variation among the PSIs (the remaining, unexplained variation is unique to each PSI). The first factor tends to be associated with the obstetric indicators and the surgical indicators, while the second factor tends to be associated with medical indicators, although two post-operative PSIs are included. The indicators with the highest loadings on the first factor, which explains about 10–20% of the variation for those PSIs and over one-half of the systematic variation among all PSIs, include “Infection due to medical care,” “Technical difficulty with procedure,” and “Obstetric trauma - vaginal delivery (with and without instrumentation),” “Decubitus ulcer,” “Postoperative respiratory failure,” " and “Postoperative sepsis” indicators load most heavily on the second factor, which explains about one-third of the systematic variation. A second factor analysis was conducted, removing the obstetric indicators. The removal of the obstetric indicators did not result in an obvious change to the factor results.

Overall, there is significant hospital level variation common among the patient safety indicators, and that variation is concentrated into two independent dimensions. Some underlying construct is potentially identifiable. However, most of the variation is unique to each PSI, meaning that to a large degree the indicators each measure an independent dimension of performance.

#### Persistence of Rates Over Time

Persistence was examined using the Florida SID from 1995-1997 (See Appendix G, Table 8). Two important points emerged from this examination. First, the rates are consistent from year to year, suggesting that at least for the years considered no fundamental changes in coding or practice confound comparison across years. The exception is “Postoperative hemorrhage or hematoma” which relies on ICD-9-CM codes adopted in October, 1996. Second, hospital performance is consistent from year to year for many of the indicators. “Decubitus ulcer,” “Technical difficulty with procedure,” “Obstetric trauma - vaginal delivery without instrumentation,” and “Infection due to medical care,” all have year to year correlations in excess of 0.70 for 1995-96 and 1996-97. “Decubitus ulcer” and “Technical difficulty with procedure” have correlations across a two year time period in excess of 0.70. But most of the indicators are correlated from year to year, meaning that hospitals that are above average tend to remain above average, at least over a three year period.

### Experimental Hospital Level Indicators

Analyses of the experimental indicators show that the least frequent PSI is “Intra-operative nerve compression injury,” with only 7 cases in Florida and 102 cases in the National SID in 1997. The most frequent PSIs are “Postoperative iatrogenic complication - cardiac,” and “3^rd^ or 4^th^ degree obstetric laceration,” with 83,502 and 99,383 cases in the National SID, respectively. The total number of adverse events (numerator), the total number of patients at risk (denominator), and the overall rate in Florida and the National SID for each experimental PSI can be found in Appendix G Table 9. The rates vary considerably across measures, from a high of 6.1% for “Decubitus ulcer in high risk patients” to a low of 0.001% for “Intra-operative nerve compression injury” (which represents 7 cases in the National SID in 1997). Like the accepted PSIs, the rates between the Florida and National SID are similar.

The apparent standard deviations (unadjusted for reliability) also vary considerably among the measures, from a high of 6.5 percentage points for “Decubitus ulcer in high risk patients” (relative to a mean of 6.2 percentage points) to a low of less than 0.37 percentage points for “Uterine rupture” and “Intra-operative nerve compression injury.” “Malignant Hyperthermia,” which relies on an ICD-9-CM code that was not in use in 1997 was not assessed. The measures with the greatest amount of hospital level variation in absolute magnitude are “Decubitus ulcer in high risk patients,” “3rd or 4th degree obstetric laceration” and “In-hospital fractures related to falls.”

Also like the accepted PSIs, the hospital level variation tends to be skewed toward the right, meaning that most hospitals are slightly less than the mean, with a long right-hand tail of hospitals with higher rates. The most highly skewed measures are “In-hospital fractures possibly related to falls,” “Wound complication of vaginal delivery,” “Uterine rupture,” and “Aspiration pneumonia,” with a median skew statistic among all indicators of 9.2 which primarily reflects the low rates of occurrence, meaning that most providers have rates near zero, giving little latitude for a left-hand tail to the distribution.

#### Risk Adjustment

Overall, age-gender risk adjustment tended to reduce the level of apparent hospital level variation by about 0.4% (see Appendix G, Table 11). Given the low rate of occurrence, “Intra-operative nerve compression injury” was not included in the risk adjustment. The impact was greatest on “Postoperative iatrogenic complication - nervous system” and “Reopening of a surgical site,” and least on “Post-Operative AMI.” The rates tend to be slightly more skewed, meaning that differences in the age-gender mix of the population at-risk masked some of the difference in rates.

Relative to age-gender adjustment, the overall impact of DRG adjustment on the hospital level variation was much greater, reducing variation by about 3.8% (see Appendix G, Table 12). Comorbidity adjustment decreased the apparent variation among hospitals by 1.1%. DRG risk adjustment had the biggest impact on “Postoperative iatrogenic complications - cardiac,” “Decubitus ulcer in high risk patients” and “Reopening of a surgical site.” Comorbidity risk adjustment had the biggest impact on “Decubitus ulcer in high risk patients,” “Other obstetric complications” and “Reopening of a surgical site.”

#### Reliability Adjustment

The effect of the reliability adjustment, based only on univariate smoothing methods, was examined along with the statistics on the signal standard deviation, signal share and signal ratio (See Appendix G, Table 13). Hospitals with fewer than three patients in the denominator were not included in the reliability adjustment. Overall, the reliability adjustment reduced the hospital level variation dramatically. On average, one-half of the apparent hospital level variation, even after risk adjustment, was estimated to be attributable to noise. The measures that were affected the most by reliability adjustment were “Uterine rupture,” “In-hospital fractures possibly related to falls” and “Wound complication of vaginal delivery.” “Aspiration pneumonia,” “Postoperative AMI” and “Intra-operative nerve compression injury” had no signal, meaning no systematic hospital level variation. The measures that were impacted the least were “3rd or 4th degree obstetric laceration,” “Other obstetric complications” and “Postoperative iatrogenic complication - cardiac.”

#### Univariate Smoothing Statistics

Like the MSX statistics, the univariate smoothing statistics give estimates of the degree of total hospital level variation accounted for by signal and noise, and the degree of total variation (hospital and patient) accounted for by signal. Signal standard deviation is an estimate of the systematic variation (‘signal’) among hospitals. The measures with the most signal are “Decubitus ulcer in high risk patients,” “3rd or 4th degree obstetric laceration” and “Postoperative iatrogenic complications - cardiac.” The measures with the least signal are “Uterine rupture” and “Wound complication of vaginal delivery,” in addition to “Aspiration pneumonia,” “Postoperative AMI” and “Intra-operative nerve compression injury” which had no signal.

The signal share is a measure of the share of total variation (hospital and patient) accounted for by the signal. The measures with the higher signal share are “3rd or 4th degree obstetric laceration,” “Decubitus ulcer in high risk patients” and “Postoperative iatrogenic complications - cardiac.” The overall low level of the share of total variation accounted for by hospitals is an indication that there are many other factors that influence these rates besides the hospital.

Finally, signal ratio is a measure of how much of the observed variation is signal and how much is noise. The higher the signal ratio, the more likely that observed differences in risk adjusted rates reflect true differences in hospital performance. Indicators with the highest signal ratio are “3rd or 4th degree obstetric laceration,” “Postoperative iatrogenic complication - cardiac” and “Other obstetric complication.” Indicators with the lowest signal ratio are “Uterine rupture,” “Wound complication of vaginal delivery” and “CABG after PTCA.”

#### Minimum Bias

Bias was measured using the same techniques as were used in the analyses of the accepted indicators (See Appendix G, Table 14). The same caveats apply to the experimental indicators as the accepted indicators. According to the rank correlation, the indicators most affected in terms of relative rank are “Postoperative iatrogenic complications - cardiac,” “Decubitus ulcer in high risk patients” and “Reopening of a surgical site.” The least affected indicators are “CABG after PTCA” and “3rd or 4th degree obstetric laceration,” which was not included in the DRG risk adjustment, because obstetric DRGs are divided only by the mode of delivery and the presence or absence of complications or comorbidities. “CABG after PTCA” is similar.

Overall, if one were to create a simple score based on the five measures of potential bias (ranking each indicator 1 to 17, and summing the ranks), the most biased measures are “Postoperative iatrogenic complications - cardiac,” “Decubitus ulcer in high risk patients,” “Reopening of a surgical site” and “Postoperative iatrogenic complication - nervous system.” The least biased measures are “CABG after PTCA” and “3rd or 4th degree obstetric laceration.” Similar to the accepted indicators, caveats about interpretation of bias are necessary. In addition, the experimental indicators are not considered a related set, so comparisons across indicators are not as appropriate as in the case of accepted indicators where they are at least related based on their more likely detection of potentially preventable adverse events.

### Accepted Area Indicators

Unadjusted and adjusted area level rates were also calculated for the area level indicators (see Appendix G, Table 15). The unit of analysis is the MSA or county (in rural areas). These six indicators are accepted patient safety indicators that were modified into area indicators to assess the total incidence of the adverse event within geographic areas. The modification generally was to use principal rather than secondary diagnosis codes, and to use the area population as the denominator. The number of additional adverse events identified using the area definition is listed in Table 19.

Table 19 Additional Cases Identified by Area Level Indicators

Indicator | Number of adverse events | | % Increase
| Hospital Definition | Area Definition
Iatrogenic pneumothorax | 16,815 | 19,892 | 16.8%
Transfusion reaction | 131 | 142 | 8.1%
Infection due to medical care | 27,457 | 49,419 | 58.8%
Wound dehiscence | 2,401 | 2,609 | 8.3%
Foreign body left in during procedure | 1,631 | 1,943 | 17.5%
Technical difficulty with procedure | 46,707 | 50,659 | 8.1%

The rates vary considerably across measures, from a high a 23.5 per 100,000 population for “Infection due to medical care” to a low of 0.08 per 100,000 for “Transfusion reactions” (which represents 142 cases in the National SID in 1997) (See Appendix G, Table 15).

The apparent standard deviations (unadjusted for reliability) also vary considerably among the measures, from a high of 43.7 per 100,000 for “Technical difficulty with procedure” (relative to a mean of 23.5 per 100,000) to a low of less than 2.1 per 100,000 for “Foreign body left in during procedure” and “Transfusion reaction.” The measures with the greatest amount of area level variation in absolute magnitude are “Technical difficulty with procedure,” “Infection due to medical care,” and “Iatrogenic pneumothorax.”

#### Risk Adjustment

Only age and gender risk adjustment, with age-gender interactions, was applied to the area measures. The age groups are the standard age categories used by the Census Bureau in their descriptive statistics, namely 0–4, 5–9, 10–14, 15–19, 20–24, 25–29, 30–34, 35–39, 40–44, 45–49, 50–54, 55–59, 60–64, 65–69, 70–74, 75–79, 80–84, and 85+.

Overall, age-gender risk adjustment tended to increase the level of apparent hospital level variation by about 8% (See Appendix G, Table 15). A similar increase was noted for all six area level indicators. The rates tend to be slightly more skewed after adjustment for age and gender, meaning that the age and gender distribution among the counties was obscuring some of the true differences in rates.