# Methodology

## Section 2A. Conceptual Framework and Definitions

In approaching the task of evaluating patient safety indicators based on administrative data, we developed a conceptual framework and standardized definitions of commonly used terms. In the literature, the distinctions between medical error, adverse events, complications of care, and other terms pertinent to patient safety are not well established and are often used interchangeably. In this report, the terms medical error, adverse events or complications, and similar concepts are defined as follows:

- Quality: “Quality of care is the degree to which health services for individuals and populations increase the likelihood of desired health outcomes and are consistent with current professional knowledge.” In this definition, “the term health services refers to a wide array of services that affect health...(and) applies to many types of health care practitioners (physicians, nurses, and various other health professionals) and to all settings of care...” ^4^
- Quality indicators: Screening tools for the purpose of identifying potential areas of concern regarding the quality of clinical care. For the purpose of this report, we focus on indicators that reflect the quality of care inside hospitals. Quality indicators may assess any of the four system components of health care quality, including patient safety (see below), effectiveness (i.e., "providing services based on scientific knowledge to all who could benefit, and refraining from providing services to those not likely to benefit), patient centeredness, and timeliness (i.e., “minimizing unnecessary delays”). ^4^
- Patient safety: “Freedom from accidental injury,” or “avoiding injuries or harm to patients from care that is intended to help them.” Ensuring patient safety “involves the establishment of operational systems and processes that minimize the likelihood of errors and maximizes the likelihood of intercepting them when they occur.” ^5^
- Patient safety indicators: Specific quality indicators which also reflect the quality of care inside hospitals, but focus on aspects of patient safety. Specifically, PSIs screen for problems that patients experience as a result of exposure to the healthcare system, and that are likely amenable to prevention by changes at the system or provider level.
- Medical error: “The failure of a planned action to be completed as intended (i.e., error of execution) or the use of a wrong plan to achieve an aim (i.e., error of planning).” ^1^ The definition includes errors committed by any individual, or set of individuals, working in a health care organization.
- Complication or adverse event: “An injury caused by medical management rather than by the underlying disease or condition of the patient.” ^6^ In general, adverse events prolong the hospitalization, produce a disability at the time of discharge, or both. Used in this report, complication does not refer to the sequelae of diseases, such as neuropathy as a “complication” of diabetes. Throughout the report, “sequelae” is used to refer to these conditions.
- Preventable adverse event: An adverse event attributable to error is a “preventable adverse event.” ^6^ A condition for which reasonable steps may reduce (but not necessarily eliminate) the risk of that complication occurring.
- Case finding indicators: Indicators for which the primary purpose is to identify specific cases in which a medical error may have occurred, for further investigation.
- Rate based indicators: Indicators for which the primary purpose is to identify the rate of a complication rather than to identify specific cases.

While the definitions above are intended to distinguish between events that are less preventable, from those that are more preventable, the difference is best described as a spectrum. To conceptualize this spectrum we developed the following three categories of conditions:

1 Conditions which could be either a comorbidity or a complication. These conditions, inasmuch as they are present on admission, and not caused by medical management, but rather due to the patient's underlying disease, include conditions such as congestive heart failure. It is extremely difficult to distinguish complications from comorbidities for these conditions using administrative data. As a result, these conditions were not considered in this report.
2 Conditions which are likely to reflect medical error. These conditions, such as foreign body accidentally left during a procedure, are likely to have been caused by medical error. Most of these conditions appear infrequently in administrative data, and thus rates of events lack the precision to allow for comparisons between providers. However, these conditions may be the subject of case finding indicators.
3 Conditions which conceivably, but not definitively reflect medical error. These conditions represent a spectrum of preventability between the previous two categories from those which are mostly unpreventable to those which are mostly preventable (i.e., category 2 above). Because of the uncertainty regarding the preventability of these conditions and the likely heterogeneity of cases with the condition, indicators utilizing these conditions are less useful as case finding indicators. However, examining the rate of these conditions may highlight potential areas of concern.

## Evaluation Framework

To evaluate the soundness of each indicator we applied the same framework as was applied in the companion QI report. ^3^ This included six areas of evidence:

Framework for Evaluating the Quality Indicators

1 Face validity: Does the indicator capture an aspect of quality that is widely regarded as important and subject to provider or public health system control? Consensual validity expands face validity beyond one person to the opinion of a panel of experts.
2 Precision: Is there a substantial amount of provider or community level variation that is not attributable to random variation?
3 Minimum bias: Is there either little effect on the indicator of variations in patient disease severity and comorbidities, or is it possible to apply risk adjustment and statistical methods to remove most or all bias?
4 Construct validity: Does the indicator perform well in identifying true (or actual) quality of care problems?
5 Fosters real quality improvement: Is the indicator insulated from perverse incentives for providers to improve their reported performance by avoiding difficult or complex cases, or by other responses that do not improve quality of care?
6 Application: Has the measure been used effectively in practice? Does it have potential for working well with other indicators?

A full discussion of this framework is available in the companion QI report. ^3^ Since the literature surrounding PSIs is sparse, this report uses a variety of techniques to evaluate each indicator. Specifically, face validity (consensual validity) was evaluated using a structured panel review (Section 2D. Clinician Panel Review Methods), minimum bias was explored empirically (Section 3E. Comparative Empirical Results) and briefly during the panel review, and construct validity was evaluated using the limited literature available (Section 3A. Literature Review Results).

The relative importance of each of these evaluation areas may differ for the PSIs as compared to the QIs. For indicators which are primarily designed to screen only for medical error, precision and minimum bias may be less important, since these events are relatively rare, and in general are better utilized as case-finding indicators. For these indicators comparisons between rates are less relevant. However, for rate-based indicators, concerns of precision and minimum bias remain, if indicators are used in any comparison of rates (comparison to national averages, peer group, etc.).

## Section 2B. Literature Review Methods

The literature searches performed in connection with assessing potential HCUP QIs in previous work ^3^ identified many references relevant to potential PSIs. In addition, we performed the electronic searches outlined below for articles published before February 2002 followed by hand searching the bibliographies of identified references. Members of the project team were queried to supplement this list, based on their personal knowledge of recent work in the field. Because Iezzoni et al.'s Complications Screening Program (CSP) ^7^ included numerous candidate indicators, we also performed an author search using her name. Forthcoming articles and Federal reports in press, but not published, were also included when identified through personal contacts. The search strategy is shown in Table 1.

Table 1 Electronic Search Strategy for Articles Pertaining to Patient Safety Indicators

MEDLINE^®^ Search String | EMBASE^®^ Search String
1) medical error [mh] OR iatrogenic disease [mh] OR sentinel surveillance [mh] OR safety [mh] | 1) iatrogenic disease [em] OR health survey [em] OR danger, risk, safety & related phenomenon[em] OR drug safety [em] OR error[em]/all exploded
2) (adverse [ti] AND events [ti]) OR complications [ti] OR iatrogenesis [ti] OR iatrogenic [ti] | 2) (adverse AND events).ti OR complication$.ti OR iatrogen$.ti OR mistake$.ti OR error$.ti
3) epidemiologic studies [mh] OR quality of health care [mh] OR comparative study [mh] OR disease/classification [mh] | 3) health care quality[em] OR epidemiology[em]
4) (#1 OR #2) AND #3 | 4) (#1 OR #2) AND #3
5) health services research [mh] OR abstracting and indexing [mh] OR medical records [mh] OR medical audit [mh] OR hospitalization [mh] OR patient readmission [mh] OR patient discharge [mh] | 5) health services research[em] OR documentation[em] OR medical record[em] OR medical audit[em] OR hospitalization[em] OR child hospitalization[em] OR hospital admission[em]
6) reproducibility of results [mh] OR sensitivity and specificity [mh] | 6) reproducibility[em] OR reproducib$.kw OR (sensitive$ or specific$).kw
7) #4 AND #5 AND #6 | 7) #4 AND #5 AND #6
8) #7 BUTNOT (case report [mh] OR case* [ti] OR report [ti] OR editorial [pt] OR comment [pt] OR letter [pt]) Limits: English Language

® MEDLINE and EMBASE database search from January, 1990 to February, 2002.

Abbreviations: [mh] = [MeSH terms], [ti] = [Title word]

Three-hundred twenty six articles were identified from the MEDLINE^®^ search. Articles were screened using both the titles and abstracts. To qualify for abstraction, an article must have described, evaluated, or validated a potential indicator of medical errors, patient safety, or potentially preventable complications based on International Classification for Diseases -Ninth Revision-Clinical Modifications (ICD-9-CM) coded administrative (hospital discharge or claims) data. Some indicators were also considered if they appeared to be readily translated into ICD-9-CM, even if the original authors did not use ICD-9-CM codes.

This search was adapted slightly and repeated using the OVID interface with EMBASE^®^ ^8^ , limited to articles published from January 1990 through the end of first quarter 2002. Our EMBASE^®^ search identified 463 references. These articles were screened in the same manner, after elimination of articles that had already been identified using MEDLINE^®^ ^9^ and the other approaches described above. Only 9 additional articles met criteria for abstraction.

## Section 2C. Development of Initial Candidate List of Indicators

Indicators that measured rates of complications at both the hospital level and area level were considered. A flow diagram outlining the selection of indicators is included in Section 3B. Indicator Selection. Two types of indicators were considered: hospital level and area level. The intent of a hospital level indicator is to provide a measure of the potentially preventable complication for patients who received their initial care and the complication of care within the same hospitalization. On the other hand, the intent of an area level indicator is to capture all cases of the potentially preventable complication that occur in a given area (e.g., metropolitan service area or county). Thus, hospital level measures typically include only cases where a secondary diagnosis code flags a potentially preventable complication since the patient was being hospitalized for a different principal diagnosis. In contrast, area level measures would be specified to include principal diagnosis, as well as secondary diagnoses, for the complications of care, thereby adding cases where a patient's risk of the complication occurred in a separate hospitalization. The denominator specification for these two types of indicators is described in Section 2E. Empirical Methods.

The literature search located relatively few indicators amenable to identifying patient safety concerns (see Appendix A) that could be defined using unlinked administrative data. The majority of such indicators were from the Complications Screening Program (described below). ^7^ Several similar, but less comprehensive, measures of potentially preventable complications were identified from other sources in the literature.

### Identifying Potential Indicators

#### Complications Screening Program

The Complications Screening Program (CSP) was developed by Lisa Iezzoni et al. ^7^ for the purpose of identifying potentially preventable complications of adult medical and surgical hospital care, using commonly available administrative data. The algorithm utilizes discharge abstract data, specifically, ICD-9-CM diagnosis and procedure codes, patient age, sex, DRG, and date of procedure, to identify 28 complications “that raise concern about the quality of care based on the rate of such occurrence at individual hospitals.” ^7^ The CSP was initially developed using the clinical judgment of the developers, complemented by “detailed consideration of the ICD-9-CM codebook, and an extensive review” of the literature on health services research, quality assurance, and clinical indicators. ^7^ Each of the complications is applied to some or all of the following specified “risk pools” separately: major surgery, minor surgery, invasive cardiac procedure, endoscopy, medical patients, all patients. In addition, specified inclusion and exclusion criteria are applied to each complication. These criteria are aimed at ensuring that the complication developed in-hospital, as opposed to being present on admission, and that the complication was potentially preventable.

Iezzoni and colleagues published a series of four papers in the mid 1990s on the face validity and construct validity of the CSP. ^7,^ ^10^ – ^12^ First, they asked each of 29 physicians who were not involved in the development of the CSP to review 100 randomly selected hospital discharge abstracts, including 53 flagged and 47 not flagged by the algorithm. These physicians were asked whether “on the basis of your review, is there anything about this summary that would make you want to review the care rendered at hospitals with high rates of this type of case for potentially avoidable quality-of-care problems.” Of the 30 cases targeted by a majority of physicians, the CSP flagged 28 (sensitivity=93%); of the 70 cases not targeted by a majority of physicians, the CSP screens also did not flag 45 (specificity=64%). Second, they reported relationships between the CSP and hospital characteristics, patient characteristics, and utilization. Using California discharge abstract data, researchers found that patients with CSP-defined complications were more likely to be older, to die before discharge, to have longer lengths of stay, and to incur higher hospital charges, than cases with none of these complications. Having a chronic condition raised the probability of experiencing a complication (after adjusting for age), especially among major surgery patients, but the predictive power of models that used these chronic conditions to predict complications was relatively poor. More surprisingly, larger and major teaching hospitals, including hospitals equipped to perform open heart surgery, appeared to have higher complication rates than smaller and non-teaching hospitals. However, all findings appeared to be dependent on the risk pool being examined. ^7,^ ^10^ – ^12^ It was also notable that hospital ranks based on indirectly standardized CSP complication rates were not significantly correlated with hospital ranks based on indirectly standardized Medicare mortality rates (with the exception of medical cases, among whom the correlation was inverse). Intra-hospital correlations across the six risk pools were weak.

Four later studies were designed to test criterion and construct validity by validating the data used to construct CSP screens, validating the screens as a flag for actual quality problems, and validating the replicability of hospital-level results using different data sources. ^13^ – ^16^ First, Iezzoni et al. trained expert coders to re-abstract ICD-9-CM diagnosis and procedure codes on a random sample of hospital records from Connecticut and California, and then assessed how often CSP trigger codes were corroborated by re-review of the medical record. ^13^ The predictive value of medical complications was relatively poor, because 58% of the flagged complications in this risk pool were actually present at admission. Corroboration rates were often even lower when Iezzoni et al. used objective clinical criteria, abstracted by nurses, to diagnose complications. ^14^ The last two studies in this series utilized implicit physician review and explicit nurse review to identify potential quality-of-care problems and process-of-care failures, respectively, among CSP-flagged cases and unflagged controls. These studies also raised concerns about the validity of the CSP, as for most indicators flagged cases were no more likely than unflagged controls to have suffered explicit process

failures. ^15,^ ^16^ It should be noted that potential process failures were perhaps undetectable by this study, because of limitations in medical record documentation. Details of the performance of the individual complications are contained in Section 3A. Literature Review Results.

The Complications Screening Program has been purchased by HCIA-Sachs (now Solucient), although additional development and research completed by this company was not available to the researchers of this report.

#### Miller et al. PSIs

Researchers at AHRQ reviewed all ICD-9-CM codes implemented in or before 1999 identifying codes that possibly describe medical errors or reflect the consequences of such errors. ^17^ Examples of codes identified by AHRQ include iatrogenic pneumothorax, iatrogenic hypotension, and several “external cause-of-injury codes” (E-codes). In addition, AHRQ researchers reviewed all codes included in the CSP indicators. AHRQ investigators applied clinical and coding knowledge to identify those codes most likely to identify medical error. These codes included foreign body left in during a procedure, suture of laceration codes, and several other sentinel event codes. These efforts at AHRQ provided the foundation for the candidate list of potential PSIs for this report. This initial set of PSIs will be referred to in this report as the Miller et al. PSIs. ^17^

#### UCSF-Stanford EPC Development

The EPC team reviewed and updated the Miller et al. PSIs. Additions included relevant codes from the 2000 and 2001 revisions of ICD-9-CM, and selected codes from the CSP, such as those not clearly reflective of medical error, but representing a potentially preventable complication. This process was guided principally by conceptual considerations. For example, postoperative acute myocardial infarction was included since recent evidence suggests that it is a potentially preventable complication. ^2^ A few codes were also deleted from the initial list based on a review of ICD-9-CM coding guidelines, described in Coding Clinics for ICD-9-CM and the American Hospital Association's ICD-9-CM Coding Handbook. For example, the code 259.3 for hypoglycemic coma specifically excludes patients with diabetes mellitus, the population for which this complication is most preventable. This process of updating the Miller et al. PSIs resulted in a list of over 200 ICD-9-CM codes (valid in 2001) potentially related to medical error.

Codes were then grouped into indicators. Where feasible, codes were compiled as they were in the CSP, or in some cases the Miller et al. PSIs, ^17^ depending on which grouping yielded more clinically homogeneous groups. In most cases the resulting indicators were not identical to the CSP indicators, although they were closely related, as some of the specific codes included in the original CSP had been eliminated after our review of coding guidelines. Five indicators were identical to the CSP indicators. The remaining codes were then incorporated into the most appropriate CSP-based indicator, or were grouped into clinically meaningful concepts to define novel indicators. Exclusion criteria were added based on CSP methods and clinical judgment. As a result, over 40 patient safety indicators were defined that, while building on prior work, reflected significantly changed measures to focus more narrowly on the most preventable complications.

Indicators were defined with both a numerator (complication of interest) and a denominator (population at risk). Different patient subpopulations have inherently different risks for developing a complication, with some patients having almost no risk. Thus, for each indicator a specified population at risk was specified as a denominator. The intention was to restrict the complication (and consequently the rate) to a more homogeneous population who are actually at risk for that complication. The population at risk for the candidate indicators tended to be narrower than the combination of all risk pools available in the CSP definitions, and was intended to reflect the population for which the complication is more likely to reflect a potentially preventable complication. In general, the population at risk corresponded to one risk pool (e.g., major surgery) from the CSP, if applicable, or was defined more narrowly.

### Initial Selection of Indicators

After the development of this list of potential indicators, a subset of indicators was selected to undergo face validity testing by clinician panels (see Section 2D. Clinician Panel Review Methods). Two sources of information guided the selection process.

First, validation data from previous studies were reviewed and thresholds were set for indicator retention of CSP based indicators. Four studies were identified that evaluated the CSP indicators. Three of these studies, ^13^ – ^15^ examined the predictive value of each indicator in identifying a complication that occurred in-hospital, regardless of whether this complication was due to medical error or was preventable. Coder, physician and nurse reviewers examined medical charts and used specified criteria to judge whether or not the flagged complication had indeed occurred during the hospitalization (as opposed to being present on admission, or not having occurred at all). In a fourth study, ^16^ nurses identified specific process failures that may have contributed to complications. In order to be retained as a potential PSI, at least one of the first three studies corroborating the ICD-9-CM code with an actual in-hospital complication needed to demonstrate a positive predictive value of at least 75%, meaning that 3 out of 4 patients identified by the measure did indeed have the complication of interest. In addition, the positive predictive value of a “process failure” identified in the fourth study needed to reach or exceed 46%, which was the average rate for surgical cases that were not flagged by any of the CSP indicators. In other words, by this criterion, potential PSIs must have demonstrated that approximately half or more of the patients flagged received care where a process failure contributed to a complication, indicating a potentially preventable error. As a result, we only retained CSP-derived indicators that were at least somewhat predictive of objectively defined process failures, or medical errors.

Second, specific changes to previous definitions or constructs of indicators fell into the following general categories that were considered for the initial selection by the team of this candidate set for face validity testing, as well as discussed during the clinician panel review process (see Section 2D. Clinician Panel Review Methods):

1 Changes to the denominator definitions (inclusion or exclusion criteria), intended to reduce bias due to the inclusion of atypical patients or to improve generalizability to a broader set of patients at risk.
2 Elimination of selected ICD-9-CM codes from numerator definitions, intended to focus attention on more clinically significant complications, or complications more likely to result from medical errors.
3 Addition of selected ICD-9-CM codes to numerator definitions, intended to capture related complications that could result from the same or similar medical errors.
4 Division of a single indicator into two or more related indicators, intended to create more clinically meaningful and conceptually coherent indicators.
5 Stratification or adjustment by relevant patient characteristics, intended to reflect fundamental clinical differences among procedures (e.g., vaginal delivery with or without instrumentation) and the complications that result from them, or fundamental differences in patient risk (e.g., decubitus ulcer in lower-risk versus high-risk patients).

A total of 34 indicators, intended to be applied to all age groups, were retained for face validity testing by clinician panels (Appendix A). Because of the primary intent in the development of these indicators to detect potentially preventable complications related to health care exposure, the final definitions for this set of indicators represented mostly new measures that built upon previous work.

### Coding Review

Concurrent with clinician panel review, we contracted with a consultant from AHIMA to review each of the 34 indicators. The consultant, an expert in ICD-9-CM coding guidelines, reviewed each code for accuracy of capturing the questioned complication and population at risk, according to current coding guidelines. She consulted additional resources, including members of the central staff of ICD-9-CM, as appropriate. In some cases, additional codes or other refinements to the indicators were suggested, based on current coding guidelines. For example, clarification of the procedure codes included in the indicator “Reopening of a surgical site” revealed that the nature of these codes was substantially different than what the team and panels had assumed. This resulted in a change to the overall rating of this indicator.

## Section 2D. Clinician Panel Review Methods

A structured review of each indicator was undertaken to evaluate the face validity (from a clinical perspective) of the indicators. Specifically, the panels approach sought to establish consensual validity, which “extends face validity from one expert to a panel of experts who examine and rate the appropriateness of each item....” ^18^ The methodology for the structured review was adapted from the RAND/UCLA Appropriateness Method ^19^ and consisted of an initial independent assessment of each indicator by clinician panelists using an initial questionnaire, a conference call among all panelists, followed by a final independent assessment by clinician panelists using the same questionnaire. The panel process served to refine definitions of some indicators, add new measures, and dismiss indicators with major concerns from further consideration.

This standardized panel approach, although differing somewhat from the approach used in this report, was used to evaluate potential indicators of primary care quality ^20,^ ^21^ as well as ambulatory care sensitive conditions. ^22^

### Panel Selection

Twenty-one professional clinical organizations were invited to submit nominations. These organizations were selected based on the applicability of the specialty or subspecialty to our quality indicators. Organizations that represented general practitioners (e.g., general surgeons, internists, critical care physicians, perioperative nurses, and critical care nurses) were asked to nominate more panelists than those representing sub-specialties. Fifteen organizations submitted nominations: American Association of Critical-Care Nurses; American Academy of Family Physicians; American College of Cardiology; American College of Nurse-Midwives; American College of Obstetricians and Gynecologists; American College of Physicians/American Society of Internal Medicine; American College of Radiology; American College of Surgeons; American Geriatric Society; Association of Perioperative Nurses; American Society of Anesthesiologists; American Society of Health-system Pharmacists; American Thoracic Society; Association of Women's Health Obstetric and Neonatal Nurses; and National Association of Inpatient Physicians.

These professional organizations nominated a total of 162 clinicians. Each nominee was invited to participate in the evaluation. In order to be eligible to participate, nominees were required to spend at least 30% of their work time on patient care, including hospitalized patients. Ninety-two nominees accepted this invitation. Five nominees were ineligible to participate. Nominees were asked to provide information regarding their practice characteristics, including specialty and subspecialty and setting (i.e., urban vs. rural location, region of country, and service to underserved populations), information regarding primary hospital of practice (i.e., funding source) and personal information (i.e., clinical education history, academic affiliation).

For assignments to each panel, a list of applicable specialties was identified for the indicators to be evaluated by a given panel. Panelists were selected so that each panel had diverse membership in terms of practice characteristics and setting. Thus, when a specific area was over-represented by the pool of eligible nominees, randomly drawn members from that specific sub-group were contacted first to fill the panels. In addition, conference call scheduling logistics influenced assignments. Fifty-seven of the eligible panelists accepted the invitation to participate on specific panels. Four did not participate in the conference call, and thus were removed from the panels. All other panelists (53) completed the evaluation in full.

### Panel Composition

Eight panels were formed. Complications of medical care indicators were examined by two panels. Surgical complications indicators were reviewed by three panels. Another panel assessed indicators related to procedural complications. Finally, two panels examined obstetric complications indicators. Participants in the panels are listed in Appendix B. All panels had diversity in the geographic location of panelists, and the type of practice (see Table 2).

Table 2 Multi-specialty Panel Composition

Characteristic | % (N)
Gender
Female | 38% (20)
Academic Affiliation^a^
Yes | 64% (34)
No | 26% (14)
Not reported | 9% (5)
Geographic Region
East | 26% (14)
West | 21% (11)
South | 21% (11)
Midwest | 32% (17)
Community
Urban | 49% (26)
Suburban | 19% (10)
Rural | 16% (9)
Not reported | 15% (8)
Funding of Primary Hospital
Private | 42% (22)
Public | 32% (17)
Both | 6% (3)
Not Reported | 21% (11)
Patient Population Served
Underserved | 47% (25)
General | 28% (15)
Not reported | 25% (13)

1 Clinical and/or research affiliation

### Initial Evaluation

After agreeing to evaluate each indicator, panelists were sent information (see Appendix C) regarding administrative data, ICD-9-CM coding, assignment of Diagnostic Related Groups (DRGs) and Major Diagnostic Categories (MDCs), and specific definitions for “adverse events or complications,” “preventability,” and “medical error.” The definitions of these terms, including distinctions are available in Appendix C and in Section 2A. Framework and Definitions. Panelists were presented with four to five indicators. The standardized text used to describe each ICD-9-CM code was presented along with the specific numeric code. Exclusion and inclusion criteria were also given, as well as the clinical rationale for the indicator and the specification criteria. Panelists were provided potential questions regarding the indicator definition that the study team planned to explore during the conference call.

Each of the 5 to 9 panelists from a given panel provided input for a given indicator by completing a 10-item questionnaire (see Appendix C). This questionnaire asked panelists to consider the ability of this indicator to screen out conditions present on admission, the potential preventability of the complication and the ability of the indicator to identify medical error. In addition, the questionnaire asked panelists to consider the potential bias, reporting or charting problems, potential for gaming the indicator, and adverse effects of implementing the indicator. Finally, panelists were invited to suggest changes to the indicator.

### Conference Call

Following the submission of the initial evaluation questionnaires, all panelists participated in a 90-minute conference call for their panel to discuss the indicators. The purpose of each conference call was to allow panelists to discuss their opinions regarding each indicator. Following the instructions in the RAND/UCLA method where the primary goal of interaction between panelists is to allow room for varied opinions about the appropriateness of an indicator, panelists were explicitly told that consensus was not the goal of discussion. In some cases, panelists agreed on proposed changes to the indicator definitions, and such consensus was noted and the definition was modified accordingly before the final round of rating. Each call was moderated by a team member (KM), who directed the structure of the call, and ensured that all panelists had a chance to share their opinions. Also present was a technical expert, who answered questions regarding administrative data and coding (PR), and a silent observer, who maintained comprehensive notes of the call (SD). All team members refrained from offering opinion regarding indicators during the call. Each indicator was discussed for approximately 15 minutes. Agenda items were set based on the feedback received from the initial evaluation, and in general focused on points of disagreement among panelists. Panelists were prompted throughout the process to consider the appropriate population at risk for each indicator (specifically inclusion and exclusion criteria) in addition to the complication of interest. However, if panelists wished to discuss other aspects of the indicator, this discussion was allowed within the time allotted for that indicator. If time remained at the end of a call, topics that were not fully addressed previously were revisited.

### Final Evaluation

Following each conference call, changes to each indicator were made where suggested by panelists. In each case, near consensus of the panelists must have been reached during the conference call for the change to be implemented. The indicators were then redistributed to panelists along with questionnaires used in the initial evaluation. Each indicator description included explication of any definition changes made and the reason. Panelists were asked to re-rate each indicator based on their current opinion. They were asked to keep in mind the discussion during the conference call.

### Tabulation of Results

To examine the results of the panels, we applied a modified version of the “appropriateness” criteria outlined in the RAND/UCLA Appropriateness Method. Results from the final evaluation questionnaire were used to calculate median scores from the 9 point scale for each question and to categorize the degree of agreement among panelists (see Table 3). Median scores determined the level of acceptability of the indicator, and dispersion of ratings across the panel for each applicable question determined the agreement status. Therefore the median and agreement status were independent measurements for each question. The following six criteria covered in the questionnaire were used to identify the panel opinions (i.e., median, agreement status category) on the following aspects of the indicator:

1 Overall usefulness of the indicator,
2 Likelihood that indicator measures a complication and not a comorbidity (specifically, present on admission),
3 Preventability of complication,
4 Extent to which complication is due to medical error,
5 Likelihood that complication is charted given that it occurs; and
6 Extent that indicator is subject to bias (systematic differences, such as case mix that could affect the indicator, in a way not related to quality of care).

Table 3 Criteria for Agreement Status

Category | Panel size | Criteria
Agreement | 8–10 panelists | Two or fewer members rated indicator outside specific three-point range (1–3.9, 4–6.9, 7–9) in which the median falls.
| 5–7 panelists | One or fewer panelists rated indicator outside specific three-point range (1–3.9, 4–6.9, 7–9) in which the median falls.
Disagreement | 8–10 panelists | Three or more panelists rated indicator in each of the extreme three-point ranges (1–3.9, 7–9).
| 5–7 panelists | Two or more panelists rated indicator in each of the extreme three point ranges (1–3.9, 7–9).
Indeterminate Agreement | All panel sizes | Any panel rating not qualifying as either “agreement” or “disagreement” by above criteria.

These evaluations are included in the summary of results for each indicator (Section 3D. Detailed Panel Results by Indicator).

We used the ratings regarding the overall appropriateness of the indicator (i.e., criterion number 1 above based on question #8 on questionnaire in Appendix C) to assess the overall usefulness as a screen for potential patient safety problems (see Table 4). The median score and agreement category for this usefulness question were combined into modified RAND groupings. Akin to the RAND “Appropriate” level, we created two categories, “Acceptable” and “Acceptable (-).” “Acceptable (-)” refers to indicators which were considered acceptable, but this distinction was not as clear as for those receiving a pure “Acceptable” rating. The RAND “Uncertain” level was likewise divided into two parts, “Unclear,” and the slightly worse category, “Unclear (-).” The RAND “Inappropriate” level was defined identically but named “Unacceptable.” These designations, along with some initial administrative data testing and subsequent coding clarifications, were used to triage indicators into three sets: Accepted Indicators, Experimental Indicators, and Rejected Indicators (see Tables 11–13 in Section 3B. Indicator Selection).

Table 4 Definitions for Overall Appropriateness of Indicator

Acceptable | Median falls between 7 and 9 (inclusive of both), agreement
Acceptable (-): | Median falls between 7 and 9 (inclusive of both), indeterminate agreement
Unclear: | Median falls between 7 and 9 (inclusive of both), disagreement, OR
| Median falls between 5 and 7 (inclusive of neither), agreement or indeterminate agreement
Unclear (-): | Median between 4 and 5 (inclusive of both), agreement, indeterminate agreement or disagreement, OR
| Median falls between 1 and 3.9 with disagreement.
Unacceptable: | Median falls between 1 and 3.9, agreement or indeterminate agreement.

Table 11 Accepted Indicators (provider and area level)

Indicator Name | Multi-specialty Panel Evaluation^a^ | | Surgical Panel Evaluation^a^ | | Definition Used
Complications of anesthesia | | | 3 | Acceptable (-) | Surgical
Death in low mortality DRGs | M2 | Acceptable
Decubitus ulcer | M1 | Acceptable
Failure to rescue | M2 | Acceptable
Foreign body left in during procedure^b^ | S2 | Acceptable | 2 | Acceptable (-) | Same
Iatrogenic pneumothorax^b^ | P1 | Acceptable
Infection due to medical care^b^ | M1 | Acceptable (-)
Postoperative hemorrhage or hematoma^d^ | S1 | Acceptable (-) | 3 | Acceptable | Surgical
Postoperative hip fracture^c^ | M1 | Acceptable
Postoperative physiologic and metabolic derangements | S3 | Acceptable (-) | 3 | Unclear | Surgical
Postoperative respiratory failure | S2 | Unclear | 2 | Acceptable (-) | Surgical
Postoperative pulmonary embolism or deep venous thrombosis | S1 | Acceptable (-) | 1 | Acceptable | Same
Postoperative sepsis | M1 | Acceptable (-)
Postoperative wound dehiscence^b^ | S2 | Acceptable (-) | 2 | Acceptable (-) | Surgical
Technical difficulty with procedure^b^ | P1 | Acceptable
Transfusion reaction^b^ | S3 | Acceptable | 3 | Acceptable | Same
Birth trauma-injury to neonate | O1 | Acceptable
Obstetric trauma - cesarean section^e^ | O1 | Acceptable (-)
Obstetric trauma - vaginal with instrument^e^ | O1 | Acceptable (-)
Obstetric trauma - vaginal without instrument^e^ | O1 | Acceptable (-)

a M, P, O, S refer to Medical, Procedure, Obstetric or Surgery Multi-specialty Panels and their identifying number (see Appendix B for further detail). 1,2,3 refers to the Surgical Panel, if reviewed by Surgical Panel (see Appendix B). “Acceptable” indicates that the indicator was rated as useful by almost all panelists. “Acceptable (-)” indicates that the indicator was rated as useful by most panelists, although a few rated it as less useful (but not as poor). “Unclear” indicates that panelists rated the usefulness of the indicator as moderate. Panel overall ratings are described in detail Clinician Panel Review Methods (Section 2D) under Tabulation of Results subsection.

b Provider and area level indicators specified for this indicator.

c Panel requested other fractures in addition to hip fracture, but empirical analyses indicated concerns about ability to operationalize well enough for accepted list.

d Codes for post-op hemorrhage or hematoma were expanded to include 5th digits in October 1996, and therefore this indicator is invalid before that date.

e Obstetric trauma indicators were not rated separately, though panelists were informed that the indicator would be split into three types of delivery.

Table 13 Rejected Indicators

Indicator Name | Multi-specialty Panel Evaluation^a^ | | Surgical Panel Evaluation^a^ | | Definition Used
Dosage complications | M2 | Unclear (-)
Iatrogenic hypotension | P1 | Unclear (-)
Intestinal infection due to C. difficile | M1 | Unclear (-)
PO Iatrogenic complications - digestive complications^b^ | P1 | Not rated separately
PO Iatrogenic complications - respiratory complications^b^ | P1 | Not rated separately
PO Iatrogenic complications - urinary complications^b^ | P1 | Not rated separately
PO Iatrogenic complications - vascular complications^c^ | P1 | Not rated separately
Postoperative pneumonia | S1 | Unclear (-) | 3 | Unclear | Same
Unexpected LOS/Conditional LOS | M2 | Unclear | | | Unable to specify panel suggestions
Obstetric thrombosis or embolism | O2 | Unclear (-)
Puerperal infection | O2 | Unclear (-)

a M, P, O, S refer to Medical, Procedure, Obstetric or Surgery Multi-specialty Panels and their identifying number (see Appendix B for further detail). “Unclear” indicates that almost all panelists rated the usefulness of the indicator as moderate. “Unclear (-)” indicates that most of the panelists rated the usefulness as moderate, although a few rated it as less useful. Panel overall ratings are described in detail Clinician Panel Review Methods (Section 2D) under Tabulation of Results subsection.

b Panel accepted the concept of capturing a set of iatrogenic complications, but empirical analyses suggests that most complications in this category are clinically insignificant.

c Panel accepted, but covers same complications as vascular complications indicator, which is more complete measure.

### Surgical Panels

The multi-specialty panels had limited surgeon participation because of the need to include a variety of specialties without expanding the panel. No surgical subspecialties were represented, and each panel had at most two participating surgeons. As a result of panelists frequently requesting more surgical input for some of the indicators, we convened three additional panels consisting of only surgeons from various subspecialties to complete a second round of review. The method of review was identical to the previous panels. The surgeons reviewed the same indicators as were reviewed by the initial multi-specialty panels. Each panel received the same combinations of indicators, in their originally proposed form, with two exceptions. One panel received “Minor Perioperative Physical Injuries” and another “Malignant Hypertension” in addition to the group of four indicators originally reviewed as a packet by a multi-specialty panel. These two additional surgical indicators were created based on suggestions by the multi-specialty panels during the discussion of an indicator called “Complications of Anesthesia.”

Sixteen organizations representing surgical subspecialties were invited to nominate ten panelists. Nine organizations submitted at least one nomination, including: American Association of Hip and Knee Surgeons; American Association of Hand Surgeons; American Association of Neurological Surgeons; American Academy of Orthopedic Surgeons; American Society of Colon and Rectal Surgeons; American Urologic Association; North American Spine Society; Society of Thoracic Surgeons; and American Society of Transplant Surgeons. In addition to recruiting subspecialists, we contacted state chapters of the American College of Surgeons from the five most populous states, to obtain one or two nominations of general surgeons. Four of the 22 contacted chapters sent nominations: San Diego, Southern California, Metropolitan Chicago, and Central Pennsylvania. We received names of 79 nominees, forty-two of whom accepted our invitation to participate. Twenty-five were assigned to panels, based on their availability to participate and their subspecialty. Three panels were constructed with a variety of specialties represented (see Appendix B). Two panelists did not complete the entire review.

The demographic composition of the surgical panel (see Table 5) differed significantly from that of the multi-specialty panels only by gender (p<.05), with more males on the surgical panels than on the multi-specialty panels. No other differences were significant.

Table 5 Surgical Panel Composition

Characteristic | % (N)
Gender
Female | 9% (2)
Academic Affiliation
Yes | 87% (20)
No | 13% (3)
Geographic Region
East | 26% (6)
West | 17% (4)
South | 30% (7)
Midwest | 26% (6)
Community
Urban | 39% (9)
Suburban | 17% (4)
Rural | 17% (4)
Not reported | 26% (6)
Hospital Affiliation
Private | 52% (12)
Public | 22% (5)
Both | 9% (2)
Not Reported | 17% (4)
Population
Underserved | 43% (10)
General | 22% (5)
Not reported | 35% (8)

Surgical panelists followed the same procedure as the multi-specialty panels in rating each indicator. In order to ensure that similar topics were discussed in the conference calls of both the multi-specialty and surgical panels, and to obtain surgeon feedback on changes suggested by the multi-specialty panels, agendas for the conference calls included those topics discussed by the multi-specialty panels (though the source of these topics was not noted). As with the multi-specialty panels, the agenda also included concerns and areas of disagreement based on panelists' responses to the first round questionnaire. Panelists then re-rated each indicator based on the suggestions of their own panel. In some cases the final definitions suggested by consensus in the surgical panel calls, and therefore proposed in the second-round questionnaire differed substantially from those rated by the multi-specialty panels. For these cases, the study team reviewed the reasons for differences in definitions proposed, and defined the indicator based on input from both panels if possible. Panel results for each indicator note any differences between panels, and explain final decisions regarding indicator definitions and acceptability.

## Section 2E. Empirical Methods

### Purpose of Analyses

Empirical analyses were conducted to provide additional information about the indicators. These analyses were intended not as decision making tools, but rather explorations into the characteristics of the indicators. Specifically, these analyses explore the frequency and variation of the indicators, the potential bias, based on limited risk adjustment, and the relationship between indicators.

### Analysis Approach

#### Data Sources

The data sources used in the empirical analyses were the 1997 Florida State Inpatient Database (SID) (for initial testing and development; 1995-1997 used for persistence analysis) and the 1997 State Inpatient Databases (SID) for 19 HCUP participating states, referred to in this report as the National SID, (for the final empirical analysis). The Florida SID consists of about 2,000,000 discharges from over 200 hospitals, and was chosen because it is a large diverse state. The National SID consists of about 19,000,000 discharges from over 2,300 hospitals. The National SID contains all-payer data on hospital inpatient stays from participating states (Arizona, California, Colorado, Connecticut, Florida, Illinois, Iowa, Kansas, Maryland, Massachusetts, Missouri, New Jersey, New York, Oregon, Pennsylvania, South Carolina, Tennessee, Washington, Wisconsin). All discharges from participating States' community hospitals are included in the SID database, which defines community hospitals as nonfederal, short-term, general, and other specialty hospitals, excluding long-term hospitals and hospital units of long-term care institutions, psychiatric hospitals, and alcoholism/chemical dependency treatment facilities. A complete description of the content of the SID, including details of the participating States' discharge abstracts, can be found on the Agency for Healthcare Research and Quality web site (www.ahrq.gov/data/hcup/hcupsid.htm). Because the Florida SID was used only for initial testing and development, the empirical results reported are from the National SID. Descriptive results from the Florida SID are reported for comparison to ensure that the hospital level results were similar in both data sources. Differences between Florida and national results are pointed out in the text. The National SID data were also used for the construction of area measures, with data from the U.S. Census Bureau used to construct the denominator of these rates.

#### Reported Patient Safety Indicators

Three sets of patient safety indicators were examined. First, the Accepted patient safety indicators met the face validity criteria established through the literature review and clinician panel review. Second, the Experimental patient safety indicators did not meet those criteria, but appeared to warrant further testing and evaluation. Third, several Accepted patient safety indicators were modified into area indicators, which were designed to assess the total incidence of the adverse event within geographic areas. For example, we constructed an indicator for “Transfusion reaction” at both the hospital and area level. Transfusion reactions that occur after discharge from a hospitalization would result in a readmission. The area level indicator includes these cases, while the hospital level restricts the number of transfusion reactions to only those that occur during the same hospitalization that exposed the patient to this risk.

All potential indicators were examined empirically by developing and conducting statistical tests for precision, bias, and relatedness of indicators. For each indicator, we calculated five different estimates of hospital performance. First, we calculated the raw indicator rate using the number of adverse events in the numerator divided by the number of discharges in the population at risk by hospital. For the area indicators, the denominator is the population of the Metropolitan Statistical Area (MSA), New England County Metropolitan Area (for the New England states) or county (for non-MSA areas) of the hospital. Second, we adjusted the raw indicator using a logistic regression to account for differences among hospitals (and areas) in demographics (specifically, age and gender). Age was modeled using a set of dummy variables to represent 10-year categories except for young children whose age categories are narrower (i.e., less than 1, 1–4, 5–14, 15–24, 25–34, 35–44, 45–54, 55–64, 65–74, 75–84, and 85 or more years), along with a parallel set of age-gender interactions. Because of sparse cells, certain age categories were combined or omitted for selected indicators, such as the obstetric indicators. Third, we adjusted the raw indicator to account for differences among hospitals in age, gender and modified DRG category (as described below). Fourth, we adjusted the raw indicator to account for differences among hospitals in age, gender, modified DRG and comorbidities (defined using an adaptation of the AHRQ comorbidity software) of patients. Finally, we applied mutlivariate signal extraction (MSX) methods to adjust for reliability by estimating the amount of “noise” (i.e., variation due to random error) relative to the amount of “signal” (i.e., systematic variation in hospital performance or the ‘reliability’) for each indicator. This or similar “reliability adjustment” has been used in the literature for similar purposes. ^23,^ ^24^ Mutlivariate methods (taking into account correlations among indicators in order to extract additional ‘signal’) were applied to most of the accepted indicators. The exceptions were Death in Low Mortality DRGs and Failure to Rescue. Only univariate signal extraction methods (smoothing) were applied to these two indicators and to the experimental indicators, because these indicators possibly cover broader clinical concepts. Correlations between these indicators and other indicators may not reflect correlations due to quality of care, and thus inclusion of these indicators may adversely affect the MSX approximations. For additional details on the empirical methods, refer to the companion EPC HCUP Quality Indicator Report, published by AHRQ (http://www.ahrq.gov/data/hcup/qirefine.htm). Additional details on the modifications made to the DRG and comorbidity categories are described below.

#### Hospital Fixed Effects

In our risk-adjustment models, we calculated hospital fixed effects using the standard method with logistic models of first estimating the predicted value for each discharge, then subtracting the actual outcome from the predicted, and averaging the difference for each hospital to get the hospital fixed effect estimate. In the companion Quality Indicator Report, ^3^ we used linear regression models with hospital fixed effects included, arguing that the logistic approach yielded biased estimates due to the omission of a variable (the hospital) correlated with both the dependent (e.g., in-hospital mortality) and the independent (e.g., age, gender, APR-DRG) variables in the model. Given the rare occurrence of many of the PSI, however, the logistic approach may be more appropriate for this application. Linear methods assume that the distribution of the error term is normally distributed. This assumption is violated when the outcome is dichotomous. The QI means were generally an order of magnitude higher than the PSI means, so the assumption was not as problematic. However, the most appropriate method depends on the particular characteristics of each indicator, whether QI or PSI. To the extent that bias is a concern, accounting for the clustering of patients by using a hospital fixed effect is advantageous. To the extent that extreme values are a concern, then imposing structure on the error term with logistic methods is advantageous. In the end, the two approaches can be compared in terms of how much difference it makes in the relative assessment of provider performance. This is an issue that warrants further analysis, in order to better understand the trade-offs and limitations of each approach, and under what conditions and for what indicators each approach might best apply.

Specifically, the risk-adjusted “raw” estimate of a hospital's performance is constructed in two steps. In the first step, if we denote whether or not the event associated with a particular indicator Y^k^ (k=1,...,K) was observed for a particular patient i in year t (t=1,...,T), then the regression to construct a risk-adjusted “raw” estimate of a particular patient's performance on each indicator can be written as:

(1) Y^k^ _it_ = Z_it_ Π^k^ _t_ + ξ^k^ _it_, where

Y^k^ _it_ is the k^th^ PSI for patient i in year t (i.e., whether or not the event associated with the indicator occurred on that discharge);

Z_it_ is a vector of patient covariates for patient i in year t (i.e., the patient-level measures used as risk adjusters);

Π^k^ _t_ is a vector of parameters in each year t, giving the effect of each patient risk adjuster on indicator k (i.e., the magnitude of the risk adjustment associated with each patient measure); and

ε^k^ _it_ is the unexplained residual in this patient-level model.

In the second step, we estimated the hospital effect by subtracting the resulting predictions from this patient-level regression from the actual observed patient-level outcomes, and taking the mean of this difference for each hospital. That is, for each hospital j (j=1,...,J),

(2) M^k^ _jt_ = Y^k^ _ijt_ - (Z_it_ Π^k^ _t_ + ξ^k^ _it_), where

M^k^ _jt_ is the “raw” adjusted measure for indicator k for hospital j in year t (i.e., the hospital “fixed effect” in the patient-level regression); and

Z_it_ is the vector of patient covariates for patient i in year t estimated in Step 1.

In addition to age, sex, and age*sex interactions as adjusters in our model, we also included a modified DRG and comorbidity category for the admission.

#### Modified DRG Categories

We made two modifications to the Centers for Medicare and Medicaid Services (CMS, formerly Health Care Financing Administration) Diagnosis-Related Groups (DRGs). First, we collapsed adjacent DRG categories that were separated by the presence or absence of comorbidities or complications. For example, DRGs 076 (OTHER RESP SYSTEM OPERATING ROOM PROCEDURES W CC) and 077 (OTHER RESP SYSTEM OPERATING ROOM PROCEDURES W/O CC) were grouped into one category. The purpose was to avoid adjusting for the complication we were trying to measure. Appendix D Section 1 lists the categories that were grouped. Second, we excluded from the logistic models most of the super-MDC DRG categories. Excluding these categories also avoids adjusting for the complications we were trying to measure. For example, tracheostomies (DRG 482–483) often result from potentially preventable respiratory complications that require long-term mechanical ventilation. Similarly, operating room procedures unrelated to the principal diagnosis (DRG 468, 477) often result from potentially preventable complications that require surgical repair (i.e., fractures, lacerations). Appendix D Section 2 lists the super-MDC categories that were excluded and other DRGs that were excluded because they were no longer valid.

In the companion technical report on quality indicators, the risk adjustment method implemented All Patient Refined (APR)-DRGs, a refinement of DRGs to capture different levels of complications. However, patient safety indicators, designed to detect potentially preventable complications, require a risk adjustment approach that does not inherently remove the differences between patients based on their complications. The APR-DRGs could be modified to remove applicable complications, on an indicator by indicator basis, but implementation of such an approach was beyond the scope of the current project. In this report, APR-DRG risk adjustment was not implemented.

#### Modified Comorbidity Software

To adjust for comorbidities, we used an updated adaptation of AHRQ Comorbidity Software (http://www.ahrq.gov/data/hcup/comorbid.htm). The ICD-9-CM codes used to define the comorbidity categories were modified to address four main issues. First, we excluded comorbidity categories in the current software that include conditions likely to represent potentially preventable complications in certain settings, such as after elective surgery. Specifically, three DRG categories (cardiac arrhythmia, coagulopathy, and fluid/electrolyte disorders) were removed from the comorbidity adjustment. Second, most adaptations were designed to capture acute sequelae of chronic comorbidities, where both conditions are represented by a single ICD-9-CM code. For example, the definition of hypertension was broadened to include malignant hypertension, which usually arises in the setting of chronic hypertension. Unless these “acute on chronic” comorbidities are captured, some patients with especially severe comorbidities would be mislabeled as not having conditions of interest. Third, the comorbidity definitions did not include obstetric comorbidity codes, which are relevant for our obstetric indicators. Codes, when available, for these comorbidities in obstetric patients were added. Fourth, slight updating was necessary based on recent ICD-9-CM code changes. Modifications made to the AHRQ comorbidity software are explained in detail in Appendix D, Section 3.

#### Low Mortality DRGs

In order to be included in the “Low Mortality DRG” indicator, the DRG had to have an overall in-hospital mortality rate (based on the National SID sample) of less than 0.5%. In addition, if a DRG category was split based on the presence of comorbidities or complications, then we only included the category if both DRGs (with and without comorbidities or complications) met the mortality threshold. Otherwise the category was not included in the “Low mortality DRG” PSI. The indicator is reported as a single measure and stratified into medical (adult and pediatric), surgical (adult and pediatric), neonatal, obstetric and psychiatric DRGs. The 126 DRGs included in the measure are listed in Appendix D, Section 4 by stratification category.

### Empirical Analysis Statistics

Using these methods we constructed a set of statistical tests to examine precision, bias, and relatedness of indicators for all accepted hospital level indicators, and precision and bias for all accepted area level and experimental indicators. Each of the key statistical test results was summarized and explained in the overview section of the companion HCUP Quality Indicator report. ^3^ Tables 6–8 provide a summary of the statistical analyses and their interpretation.

Table 6 Precision Tests

Measure | Statistic/ Adjustments | | Interpretation
Precision. Is most of the variation in an indicator at the level of the hospital? Do smoothed estimates of quality lead to more precise measures?
a. Observed variation in indicator | - Hospital Level Standard Deviation; - Hospital Level Skew Statistic | - Unadjusted; - Age-gender adjusted; - Modified DRG adjusted; - Modified AHRQ Comorbidity adjusted | Risk adjustment can either increase or decrease observed variation. If increase, then differences in patient characteristics mask provider differences. If decrease, then differences in patient characteristics account for provider differences.
b. MSX methods | - Signal Standard Deviation; - Signal Share; - Signal Ratio | - Reliability adjusted | Estimates what percentage of the observed variation between hospitals reflects systematic differences versus random noise. Signal share is a measure of how much of the total variation (patient and provider) is potentially subject to hospital control.

Table 7 Bias Tests

Measure | Statistic | Interpretation
Bias. Does risk adjustment change our assessment of relative hospital performance, after accounting for reliability? Is the impact greatest among the best or worst performers, or overall? What is the magnitude of the change in performance?
MSX methods: unadjusted vs. age, sex, Modified DRG, Comorbidity risk adjustment | Spearman Rank Correlation Coefficient (Before and After Risk Adjustment) | Risk adjustment matters to the extent that it alters the assessment of relative hospital performance. This test determines the impact overall.
| Average Absolute Value Of Change Relative To Mean (After Risk Adjustment) | This test determines whether the absolute change in performance was large or small relative to the overall mean.
| Percentage of The Top 10% Of Hospitals That Remains The Same (After Risk Adjustment) | This test measures the impact at the highest rates (in general, the worse performers).
| Percentage of The Bottom 10% Of Hospitals That Remains The Same (After Risk Adjustment) | This test measures the impact at the lowest rates (in general, the better performers).
| Percentage of hospitals that move more than two deciles in rank (up or down) (After Risk Adjustment) | This test determines the magnitude of the relative changes.

Table 8 Relatedness Tests

Measure | Statistic | Interpretation
3. Relatedness of indicators. Is the indicator related to other indicators in a way that makes clinical sense? Do methods that remove noise and bias make the relationship clearer?
a. Correlation of indicator with other indicators | Spearman correlation coefficient | Are indicators correlated with other indicators in the direction one might expect?
b. Factor loadings of indicator | Factor loadings, based on Spearman correlation, Principal Component Analysis | Do indicators load on factors with other indicators that one might expect?