# Introduction

The often cited Institute of Medicine Report, To Err is Human: Building a Safer Health System ^1^ crystallized widespread public concern about the need to take action to reduce the occurrence of apparently common, serious medical errors. Achieving this goal involves identifying errors in practice, and undertaking initiatives to avoid and prevent them. It also requires national and regional attention to monitor and report to the public about patient safety. Widespread consensus exists that health care organizations can reduce patient injuries by learning from successful safety-improvement initiatives in other industries. Such initiatives have focused on systematically reducing opportunities for errors to occur, by improving the environment for safety. These diverse steps range from technical changes, such as implementing electronic medical record systems, to cultural ones, such as improving staff awareness of patient safety risks. Clinical process interventions also have strong evidence for reducing the risk of adverse events related to a patient's exposure to hospital care. ^2^ However, local and national initiatives may be better prioritized and evaluated through the use of adequate data on patient safety problems. This report reviews previous studies and presents new empirical evidence on one potentially important source of such data: computerized hospital discharge abstracts from the Agency for Healthcare Research and Quality (AHRQ) Healthcare Cost and Utilization Project (HCUP). Analyses of these and similar inexpensive, readily available administrative data sets may provide a screen for potential medical errors, and a method for monitoring trends over time.

## Using Administrative Data

Although prior studies of the utility of routinely available administrative data sets, like the HCUP Nationwide Inpatient Sample (NIS), leave many questions unanswered and raise some important concerns, the careful use of these sources of information holds promise for screening in order to target further data collection and analysis. The ability to assess all patients at risk for a particular patient safety problem, along with the relative low cost, are particular strengths of these data sets. However, two broad areas of concern also hold true for these data sets. First, questions about the clinical accuracy of discharge-based diagnosis coding lead to concerns about the interpretation of reported diagnoses that may represent safety problems. Specifically, administrative data are unlikely to capture all cases of a complication, regardless of the preventability, without false positives and false negatives (sensitivity and specificity). Further, when the codes are accurate in defining an event, the clinical vagueness inherent in the description of the code itself (e.g., “hypotension”), may lead to a highly heterogeneous pool of clinical states represented by that code. A final issue in accuracy of any data source used for identifying patient safety problems is the possibility of incomplete reporting, as medical providers might fear adverse consequences to reputation, disciplinary action, and lawsuits as a result of “full disclosure” in potentially public records such as discharge abstracts.

A second area of concern relates to the limited information about the ability of these data to distinguish adverse events in which no error occurred from true medical errors. A number of factors, such as the heterogeneity of clinical conditions included in some codes, lack of information about event timing available in these data sets, and limited clinical detail for risk adjustment, contribute to the difficulty in identifying complications that represent medical error or may be at least in some part preventable. These factors may exist for other sources of patient safety data as well. For example, they have been raised in the context of the Joint Commission on Accreditation of Healthcare Organizations (JCAHO) implementation of a “sentinel event” program geared at identifying serious adverse events that may be related to underlying safety problems.

Given the importance of patient safety, it is perhaps surprising that only a relatively limited literature exists related to the potential use of discharge data and other widely-used data sources in documenting patient safety problems and improving patient safety. While these limited studies have identified some discharge-based measures applicable to addressing patient safety problems that seem highly predictive of true errors, many discharge-based measures appear to have relatively low sensitivity and specificity for identifying potentially preventable complications or true errors.

However, virtually all of these studies failed to account for many potentially avoidable limitations of discharge data, including measurement error (“noise”) and bias. Moreover, most of these studies have been conducted at the patient level, and have focused on answering the question: does the discharge information identify a patient safety problem in this particular case? Despite the fact that most initiatives to improve patient safety focus on organizational or process change, almost no studies have addressed the question: can discharge data be used to identify systematic patient safety problems, and thereby target areas for opportunity at the level of groups of patients?

## Patient Safety Indicators Evidence Project

The Evidence-based Practice Center (EPC) at the University of California San Francisco and Stanford University (UCSF-Stanford), with collaboration from the University of California Davis, contracted with the AHRQ to review and improve the evidence base related to potential patient safety indicators (PSIs) that can be developed from administrative data. The term “patient safety indicator,” for the purposes of this report, refers to measures that screen for potential problems that patients experience resulting from exposure to the health care system, and that are likely amenable to prevention by changes at the level of the system. The key intent of the PSIs are thus as a “screening tool” or “starting point” for further analysis to reduce “potentially preventable errors” through system or process changes.

In addition to the need for data to guide quality improvement initiatives, there is a public mandate to monitor patient safety as part of quality in general. Measures are needed for aggregate statistical reporting, as planned for the National Quality Report. The PSIs developed and evaluated by the EPC will be shared with the AHRQ directed task force charged to develop this national report regarding national, regional (e.g., Northeast, South, Midwest,West) and state statistics about health care quality and patient safety.

This report follows the approach of a previous quality indicator development and evaluation project described in a companion technical report from the EPC, and published by AHRQ (available at: http://www.achq.gov/data/hcup/qirefine.htm). ^3^ Similarly, this report takes a multifaceted approach to evaluating the validity of potential indicators, applying the same validation framework. This report documents the background literature review and empirical analyses performed to develop recommendations for and provide information about AHRQ PSIs. In addition, the project included consultation with expert coders from the American Health Information Management Association (AHIMA), and clinical panel reviews based on a process adapted from RAND and the University of California Los Angeles (RAND/UCLA) Appropriateness Method. We present new evidence on the ability of a broad range of discharge-based PSIs to identify systematic differences across hospitals, and potentially to monitor trends on a national or regional basis. The research reported here reflects an examination of the face validity of these indicators, and as such is subject to limitations. Primarily, due to the paucity of evidence available in the literature, this review relied on the expert opinion of clinician panels. The limitations are fully discussed in the final chapter of this report. Further research will be needed to establish the validity of these indicators in identifying potential patient safety concerns.

The PSIs developed here follow some of the same goals as the refined quality indicators (QIs) reviewed in the companion report. AHRQ QIs (referred to as HCUP II Quality Indicators in the companion report) ^3^ were developed as a screening tool to provide an accessible and low-cost approach to identifying potential problems in quality of care for organizations that lack the resources to develop their own quality assessment program. The initial version of the QI software was based mostly on quality measures already reported in the literature. The principal requirement was that the measures could be derived from common denominator discharge data sets comprised of variables that are available from most state-level hospital administrative data. Data elements in these sets include, but may not be limited to, International Classification of Disease, Clinical Modification (ICD-9-CM) discharge diagnosis and procedure codes; dates of admission, discharge and major procedures; age; gender; and diagnostic related group (DRG). In addition, the measures could not require linkages outside the hospital stay (e.g., post-hospital mortality or readmissions) because most state databases do not accommodate such linkages. The HCUP State Inpatient Databases (SID) is an example of such a common denominator discharge data set, and was used for the development of the AHRQ PSIs, reported here. While similar goals for the development of the previous AHRQ QIs apply to the PSIs reported here, the relevant literature is considerably less extensive. Consequently, we review the literature in a more general way for indicators as a whole, and for specific indicators we only review those studies validating the indicator use, rather than the clinical soundness of the concept of the indicator. As a result, we devote more attention to the development and validation of the most promising PSIs.

The report reviews the methods applied in our survey of discharge-based patient safety indicators, further development and selection of indicators, detailed clinician panel review, and empirical analysis of the most promising indicators. The bulk of the report then presents the results of these activities. We conclude with recommendations about how the most promising discharge-based PSIs can be applied and improved.

## Anticipated Uses of Evidence Report

The approach to identification and evaluation of PSIs presented in this report serves as the basis for development of Version 1.0 of AHRQ PSI software. The primary goal of the report is to document the evidence, both from the literature, clinician review and data analysis, on suitable PSIs that can be derived from hospital discharge abstract data. By transparently inventorying and evaluating potential indicators and risk adjustment strategies, we anticipate that this report will provide detailed context for users who apply these measures to facilitate identifying promising areas for researching and improving patient safety in a number of settings. The clear message throughout this report is that these indicators are developed for use as an initial screen that can target promising areas for in-depth review.

The discharge-based PSIs may be useful screens for organizations, purchasers, and policymakers to identify problems at the hospital level, as well as to document systematic area level differences in potentially preventable adverse events or patient safety problems. Additionally, PSI rates would be amenable to monitoring over time by region (e.g., geographical area, nation), setting (e.g., urban vs. rural) or specific hospital type (e.g., teaching vs. community, large vs. small). The PSI rates calculated at the state or national level would also be useful to individual hospitals seeking to compare their own performance to a benchmark. However, these measures are not designed, nor are they suitable for public reporting for the purpose of comparing providers because of the limitations of discharge-based data sources, although public reporting at the aggregate level (e.g., state or national) may be appropriate. Further discussion of the appropriate uses of these indicators is included in Chapter 4, Conclusions.

Finally, this report may also serve as a reference for background material on patient safety measurement using routinely collected administrative data, and as a summary for the current state of discharge-based patient safety indicators and risk adjustment methods. In addition to the companion technical report on quality indicators, it documents a novel integration of evidence-based methods with other approaches to develop and evaluate health care measures related to patient safety.