# Definitions of Indicators Presented to Panelists

This appendix presents the definitions of each indicator as presented to panelists during the first round of ratings. Panelists then discussed these definitions during the conference call and suggested changes to the indicator. Short descriptions of the indicators are presented first followed by the ICD-9-CM level details for each indicator.

Indicator | Numerator | Denominator
Aspiration pneumonia | Discharges with ICD-9-CM codes of 507.0, E911, or E912 in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
| | Exclude patients with a principal diagnosis of seizure, trauma, drug overdose, or poisoning.
CABG following PTCA | Discharges with ICD-9-CM codes for CABG (see below) in any procedure field per 100 discharges with PTCA (see below) in any procedure field. | All discharges with ICD-9-CM code for PTCA (see below) in any procedure code.
| CABG must occur on the same day or after the PTCA.
Complications of anesthesia | Discharges with ICD-9-CM codes of 995.4 (Shock due to anesthesia) or E876.3 (ETT misplacement) in any diagnosis field per 100 discharges. | Medical and surgical discharges.
| | Exclude patients with any diagnosis of trauma.
Death in low mortality DRGs | All discharges with disposition of “deceased” per 100 population at risk. | Patients in DRGs with less than 0.5% mortality rate.
| | Exclude patients with any diagnosis code of trauma, immunocompromised state, or cancer.
Decubitus ulcer | Discharges with ICD-9-CM code of 707.0 in any secondary diagnosis field per 100 discharges. | Medical and surgical discharges.
| | Exclude patients greater than or equal to 80 years of age.
| | Include only patients with a length of stay of more than 10 days.
| | Exclude patients in MDC 9 or patients with any diagnosis of hemiplegia, paraplegia, quadriplegia, or IV drug abuse.
Dosage complications | Discharges with ICD-9-CM code denoting a dosage complication (see below) in any diagnosis field per 100 discharges. | Medical and surgical discharges.
Foreign body left in during procedure | Discharges with ICD-9-CM codes of 998.4, 998.7, E871.x in any secondary diagnosis field per 100 surgical discharges. | Medical and surgical discharges.
Iatrogenic hypotension | Discharges with ICD-9-CM code of 458.2 in any diagnosis field per 100 discharges. | Medical and surgical patients.
| | Exclude patients with any diagnosis of trauma.
Iatrogenic pneumothorax | Discharges with ICD-9-CM code of 512.1 in any diagnosis field per 100 discharges. | Medical and surgical patients.
| | Exclude patients with any diagnosis of trauma.
Infection due to medical care | Discharges with ICD-9-CM code of 999.3 or E875.x in any diagnosis field per 100 discharges. | Medical or surgical patients.
| | Excludes patients with any diagnosis code for trauma.
In-hospital hip fracture and fall | Discharges with ICD-9-CM code for hip fracture or fall (see below) in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
(Renamed Postoperative hip fracture) | | Excludes patients in MDC 8.
| | Excludes patients with principal diagnosis codes for seizure, syncope, stroke, coma, cardiac arrest anoxic brain injury or poisoning or any diagnosis code of trauma or metastatic cancer.
Intestinal infection due to C. difficile | Discharges with ICD-9-CM code of 008.45 in any secondary diagnosis field per 100 discharges. | Medical and surgical patients.
Postoperative acute myocardial infarction | Discharges with ICD-9-CM codes for AMI (see below) in any secondary diagnosis field per 100 non-cardiac surgical discharges. | Non-cardiac surgical discharges.
| | Exclude patients undergoing cardiac surgery (see below).
| | Exclude patients in MDC 5.
Postoperative hemorrhage or hematoma | Discharges with ICD-9-CM codes for hemorrhage or hematoma (see below) in any secondary diagnosis or procedure code field per 100 surgical discharges. | All surgical discharges.
| Procedure code for control of hemorrhage must occur on the same day or after the principal procedure.
Postoperative iatrogenic complications | Discharges with ICD-9-CM code for iatrogenic complications (see below) in any secondary procedure fields per 100 surgical discharges. | All surgical discharges.
Postoperative physiologic and metabolic derangements | Discharges with ICD-9-CM codes for physiologic and metabolic derangements (see below) in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
| | Exclude patients with a principal diagnosis of trauma.
| | Exclude patients with both a diagnosis code of ketoacidosis and a principal diagnosis of diabetes.
| | Exclude patients with both a secondary diagnosis code for oliguria or anuria or acute renal failure and a principal diagnosis of AMI, cardiac arrhythmia, cardiac arrest, or hemorrhage or in MDC 8.
Postoperative pneumonia | Discharges with ICD-9-CM codes for pneumonia (see below) in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
| | Exclude patients in MDC 4.
| | Exclude patients with any diagnosis of AIDs, immunocompromised state or cancer.
Postoperative pulmonary compromise | Discharges with ICD-9-CM codes for pulmonary compromise (see below) in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
(Renamed Postoperative respiratory failure) | | Exclude patients in MDC 4 and MDC 5.
Postoperative pulmonary embolism or deep vein thrombosis | Discharges with ICD-9-CM codes for pulmonary embolism or deep vein thrombosis (see below) in any secondary diagnosis field per 100 surgical discharges. | All surgical discharges.
| | Exclude patients with a principal diagnosis of deep vein thrombosis.
Postoperative septicemia | Discharges with ICD-9-CM code for septicemia (see below) in any secondary diagnosis field per 100 discharges in the population at risk. | Patients in DRG 5, 106, 107, 110, 111, 209 or MDC 11, 12, 13.
| | Exclude patients with a principal diagnosis of infection, or any diagnosis of AIDS, immunocompromised state, or cancer.
| | Include only patients with a length of stay of more than three days.
Postoperative wound dehiscence | Discharges with ICD-9-CM codes of 998.3 (postoperative wound disruption) in any diagnosis or 54.61or 11.52 in any procedure field per 100 discharges. | Medical or surgical discharges.
| | Exclude patients with any diagnosis code for trauma, cancer, AIDs, transplant or immunocompromised state.
Reopening of a surgical site | Discharges with ICD-9-CM codes for reopening of a surgical site (see below) in any secondary procedure field per 100 surgical discharges. | All surgical discharges.
| Reopening of surgical site must occur at least one day after the principal procedure.
Suture of laceration | Discharges with ICD-9-CM codes for suture of laceration (see below) in any secondary procedure field per 100 surgical discharges. | All surgical discharges.
| Suture of laceration must occur on the same day or after the principal procedure. | Exclude patients with any diagnosis code for foreign body or trauma.
Technical difficulty with procedure | Discharges with ICD-9-CM code denoting a condition arising from technical difficulty (see below) in any diagnosis field per 100 discharges. | Medical and surgical patients.
Transfusion reaction | Discharges with ICD-9-CM codes for transfusion reaction (see below) in any diagnosis field per 100 discharges. | Medical and surgical patients.
| | Exclude patients with any diagnosis of trauma.
Obstetric indicators
Birth trauma | Discharges with ICD-9-CM codes for birth trauma (see below) in any diagnosis field per 100 liveborn births. | All liveborn infants.
Obstetric complication of delivery - trauma | Discharges with ICD-9-CM codes for obstetric trauma (see below) in any diagnosis or procedure field per 100 deliveries. | All deliveries.
Obstetric thrombosis or embolism. | Discharges with ICD-9-CM codes for obstetric thrombosis or embolism (see below) in any diagnosis field per 100 deliveries. | All deliveries.
Obstetric complication of delivery - wound complications | Discharges with ICD-9-CM codes for obstetric wound complications (see below) in any diagnosis field per 100 deliveries. | All deliveries.
Obstetric complication of delivery - other | Discharges with ICD-9-CM codes for other obstetrical complications (see below) in any diagnosis field per 100 deliveries. | All deliveries.
Puerperal infection | Discharges with ICD-9-CM codes for major puerperal infection (see below) in any diagnosis field per 100 deliveries. | All deliveries.
| | Exclude patients with a diagnosis code of antepartum infection of amniotic cavity [65840, 1, 3]

Acute myocardial infarction | 363
Birth trauma | 364
CABG | 364
Cardiac surgery | 364
Deep vein thrombosis | 364
Dosage Complications | 364
Hemorrhage or hematoma | 364
Hip fracture or fall | 365
Iatrogenic complications | 365
Obstetric thrombosis or embolism | 365
Obstetric trauma | 365
Obstetric wound complications | 365
Other obstetrical complications | 365
Physiologic and metabolic derangements | 365
Pneumonia | 366
Puerperal infection | 366
PTCA | 366
Pulmonary Compromise | 366
Pulmonary embolism | 366
Reopening of a surgical site | 366
Septicemia | 366
Suture of laceration | 367
Technical difficulty with medical care (procedure) | 367
Transfusion reaction | 367

Acute myocardial infarction
ICD-9-CM diagnosis codes:
41000 | AMI OF ANTEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
41001 | AMI OF ANTEROLATERAL WALL - INITIAL EPISODE OF CARE
41010 | AMI OF OTHER ANTERIOR WALL - EPISODE OF CARE UNSPECIFIED
41011 | AMI OF OTHER ANTERIOR WALL - INITIAL EPISODE OF CARE
41020 | AMI OF INFEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
41021 | AMI OF INFEROLATERAL WALL - INITIAL EPISODE OF CARE
41030 | AMI OF INFEROPOSTERIOR WALL - EPISODE OF CARE UNSPECIFIED
41031 | AMI OF INFEROPOSTERIOR WALL — INITIAL EPISODE OF CARE
41040 | AMI OF INFERIOR WALL - EPISODE OF CARE UNSPECIFIED
41041 | AMI OF INFERIOR WALL - INITIAL EPISODE OF CARE
41050 | AMI OF OTHER LATERAL WALL - EPISODE OF CARE UNSPECIFIED
41051 | AMI OF OTHER LATERAL WALL - INITIAL EPISODE OF CARE
41060 | AMI TRUE POSTERIOR WALL INFARCTION - EPISODE OF CARE UNSPECIFIED
41061 | AMI TRUE POSTERIOR WALL INFARCTION - INITIAL EPISODE OF CARE
41070 | AMI SUBENDOCARDIAL INFARCTION - EPISODE OF CARE UNSPECIFIED
41071 | AMI SUBENDOCARDIAL INFARCTION - INITIAL EPISODE OF CARE
41080 | AMI OF OTHER SPECIFIED SITES - EPISODE OF CARE UNSPECIFIED
41081 | AMI OF OTHER SPECIFIED SITES - - INITIAL EPISODE OF CARE
41090 | AMI UNSPECIFIED SITE - EPISODE OF CARE UNSPECIFIED
41091 | AMI UNSPECIFIED SITE - INITIAL EPISODE OF CARE
Birth trauma
ICD-9-CM diagnosis codes:
7670 | SUBDURAL AND CEREBRAL HEMORRHAGE (DUE TO TRAUMA OR TO INTRAPARTUM ANOXIA OR HYPOXIA)
7673 | INJURIES TO SKELETON
7674 | INJURY TO SPINE AND SPINAL CORD
7676 | INJURY TO BRACHIAL PLEXUS
7677 | OTHER CRANIAL AND PERIPHERAL NERVE INJURIES
7678 | OTHER SPECIFIED BIRTH TRAUMA
7679 | BIRTH TRAUMA, UNSPECIFIED
CABG
ICD-9-CM procedure code:s
3610 | BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION
3611 | OPEN HEART VALVULOPLASTY WITHOUT REPLACEMENT
3612 | AORTOCORONARY BYPASS OF TWO CORONARY ARTERIES
3613 | AORTOCORONARY BYPASS OF THREE CORONARY ARTERIES
3614 | AORTOCORONARY BYPASS OF FOUR OR MORE CORONARY ARTERIES
3615 | SINGLE INTERNAL MAMMARY-CORONARY ARTERY BYPASS
3616 | BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION, DOUBLE INTERNAL MAMMARY-CORONARY ARTERY BYPASS
3617 | ABDOMINAL-CORONARY ARTERY BYPASS
3619 | OTHER BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION
Cardiac surgery
Diagnostic Related Groups (DRGs):
103 | HEART TRANSPLANT
104 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITH CARDIAC CATHETERIZATION
105 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITHOUT CARDIAC CATHETERIZATION
106 | CORONARY BYPASS WITH PTCA
107 | CORONARY BYPASS WITH CARDIAC CATHETERIZATION
108 | OTHER CARDIOTHORACIC PROCEDURES
110 | MAJOR CARDIOVASCULAR PROCEDURES WITH CC
111 | MAJOR CARDIOVASCULAR PROCEDURES WITHOUT CC
112 | PERCUTANEOUS CARDIOVASCULAR PROCEDURES
Deep vein thrombosis
ICD-9-CM diagnosis codes:
45111 | PHLEBITIS AND THROMBOSIS OF FEMORAL VEIN (DEEP) (SUPERFICIAL)
45119 | PHLEBITIS AND THROMBOPHLEBITIS - OF DEEP VESSEL OF LOWER EXTREMITIES - OTHER
4512 | PHLEBITIS AND THROMBOPHLEBITIS OF LOWER EXTREMITIES UNSPECIFIED
45181 | PHLEBITIS AND THROMBOPHLEBITIS OF ILIAC VEIN
4519 | PHLEBITIS AND THROMBOPHLEBITIS OF OTHER SITES - OF UNSPECIFIED SITE
4532 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF VENA CAVA
4538 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF OTHER SPECIFIED VEINS
4539 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF UNSPECIFIED SITE
Dosage Complications
ICD-9-CM diagnosis codes:
E8730 | EXCESSIVE AMOUNT OF BLOOD OR OTHER FLUID DURING TRANSFUSION OR INFUSION.
E8731 | INCORRECT DILUTION OF FLUID DURING INFUSION.
E8732 | OVERDOSE OF RADIATION IN THERAPY
E8733 | INADVERTENT EXPOSURE OF PATIENT TO RADIATION DURING MEDICAL CARE.
E8734 | FAILURE IN DOSAGE IN ELECTROSHOCK OR INSULIN-SHOCK THERAPY.
E8735 | INAPPROPRIATE (TOO HOT OR TOO COLD) TEMPERATURE IN LOCAL APPLICATION AND PACKING.
E8736 | NON-ADMINSTRATION OF NECESSARY DRUG OR MEDICINAL SUBSTANCE.
E8738 | OTHER SPECIFIED FAILURE IN DOSAGE
E8739 | UNSPECIFIED FAILURE IN DOSAGE.
E8761 | WRONG FLUID IN INFUSION
Hemorrhage or hematoma
ICD-9-CM diagnosis codes:
99811 | HEMORRHAGE COMPLICATING A PROCEDURE
99812 | HEMATOMA COMPLICATING A PROCEDURE
99813 | SEROMA COMPLICATING A PROCEDURE
ICD-9-CM procedure codes:
287 | CONTROL OF HEMORRHAGE AFTER TONSILLECTOMY AND ADENOIDECTOMY
3941 | CONTROL OF HEMORRHAGE AFTER TONSILLECTOMY AND ADENOIDECTOMY
3998 | CONTROL OF HEMORRHAGE NOS
4995 | CONTROL OF (POSTOPERATIVE) HEMORRHAGE OF ANUS
5793 | CONTROL OF (POSTOPERATIVE) HEMORRHAGE OF BLADDER
Hip fracture or fall
ICD-9-CM diagnosis codes: (includes all 5^th^ digits)
8200 | FRACTURE OF NECK OF FEMUR-TRANSCERVICAL FRACTURE, CLOSED
8201 | FRACTURE OF NECK OF FEMUR-TRANSCERVICAL FRACTURE, OPEN
8202 | FRACTURE OF NECK OF FEMUR-PERTROCHANTERIC FRACTURE, CLOSED
8203 | FRACTURE OF NECK OF FEMUR-PERTROCHANTERIC FRACTURE, OPEN
8208 | UNSPECIFIED PART OF NECK OF FEMUR, CLOSED
8209 | UNSPECIFIED PART OF NECK OF FEMUR, OPEN
E8842 | FALL FROM CHAIR OR BED
E8849 | FALL FROM ONE LEVEL TO ANOTHER
E885 | FALL ON SAME LEVEL FROM SLIPPING, TRIPPING OR STUMBLING
E887 | FRACTURE, CAUSE UNSPECIFIED
E888 | OTHER AND UNSPECIFIED FALL
Iatrogenic complications
ICD-9-CM diagnosis codes:
9970X | NERVOUS SYSTEM COMPLICATIONS
9971 | CARDIAC COMPLICATIONS
9972 | PERIPHERAL VASCULAR COMPLICATIONS
9973 | RESPIRATORY COMPLICATIONS
9974 | DIGESTIVE SYSTEM COMPLICATIONS
9975 | URINARY COMPLICATIONS
Obstetric thrombosis or embolism
ICD-9-CM diagnosis codes:
671.40 | DEEP VEIN THROMBOSIS - POSTPARTUM UNSPECIFIED
671.42 | DEEP VEIN THROMBOSIS - DELIVERED WITH MENTION OF POSTPARTUM COMPLICATION
671.44 | DEEP VEIN THROMBOSIS - POSTPARTUM CONDITION OR COMPLICATION
673.20–4 | OBSTETRIC PULMONARY EMBOLISM
Obstetric trauma
ICD-9-CM diagnosis codes:
66420, 1,4 | THRID-DEGREE PERINEAL LACERATION
66430, 1,4 | FOURTH-DEGREE PERINEAL LACERATION
66530, 1, 4 | LACERATION OF CERVIX
66540, 1, 4 | HIGH VAGINAL LACERATIONS
66550, 1, 4 | OTHER INJURY TO PELVIC ORGANS
ICD-9-CM procedure codes:
7550 | REPAIR OF CURRENT OBSTETRIC LACERATIONS UTERUS
7551 | REPAIR OF CURRENT OBSTETRIC LACERATIONS OF CERVIX
7552 | REPAIR OF CURRENT OBSTETRIC LACERATIONS OF CORPUS UTERI
7561 | REPAIR OF CURRENT OBSTETRIC LACERATION OF BLADDER AND URETHRA
7562 | REPAIR OF CURRENT OBSTETRIC LACERATION OF RECTUM AND SPHINCTER ANI
Obstetric wound complications
ICD-9-CM diagnosis codes:
67410,2,4 | DISRUPTION OF CESAREAN WOUND
67420,2,4 | DISRUPTION OF PERINEAL WOUND
67430 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS
Other obstetrical complications
ICD-9-CM diagnosis codes:
(includes 5th digits):
6651 | RUPTURE OF UTERUS DURING OR AFTER LABOR
6680 | PULMONARY COMPLICATIONS
6681 | CARDIAC COMPLICATIONS
6682 | CENTRAL NERVOUS SYSTEM COMPLICATIONS
6688 | OTHER COMPLICATIONS OF ANESTHESIA OR OTHER SEDATION IN LABOR AND DELIVERY
6689 | UNSPECIFIED COMPLICATION OF ANESTHESIA AND OTHER SEDATION
6691 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY
6694 | OTHER COMPLICATIONS OF OBSTETRICAL SURGERY AND PROCEDURES
66930, 2, 4 | ACUTE RENAL FAILURE FOLLOWING LABOR AND DELIVERY
Physiologic and metabolic derangements
ICD-9-CM diagnosis codes:
DIABETES WITH KETOACIDOSIS:
25010 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
25011 | TYPE 1 NOT STATED AS UNCONTROLLED
25012 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
25013 | TYPE 1 UNCONTROLLED
ACUTE RENAL FAILURE:
5845 | WITH LESION OF TUBULAR NECROSIS
5846 | WITH LESION OF RENAL CORTICAL NECROSIS
5847 | WITH LESION OF RENAL MEDULLARY [PAPILLARY] NECROSIS
5848 | WITH OTHER SPECIFIED PATHOLOGICAL LESION IN KIDNEY
5849 | ACUTE RENAL FAILURE, UNSPECIFIED
DIABETES WITH HYPEROSMOLARITY:
25020 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
25021 | TYPE 1 NOT STATED AS UNCONTROLLED
25022 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
25023 | TYPE 1 UNCONTROLLED
DIABETES WITH OTHER COMA:
25030 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
25031 | TYPE 1 NOT STATED AS UNCONTROLLED
25032 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
25033 | TYPE 1 UNCONTROLLED
Pneumonia
ICD-9-CM diagnosis codes:
481 | PNEUMOCOCCAL PNEUMONIA
4821 | KLEBSIELLA PNEUMONIAE
4822 | PNEUMONIA DUE TO PSEUDOMONAS
4823 | HEMOPHILIS PNEUMONIAE
4824 | PNEUMONIA DUE TO STREPTOCOCCUS
4825 | PNEUMONIA DUE TO STAPHYLOCOCCUS
4826 | PNEUMONIA DUE TO ANAEROBES
4827 | PNEUMONIA DUE TO E. COLI
4828 | PNEUMONIA DUE TO OTHER GRAM NEGATIVE
4829 | PNEUMONIA DUE TO LEGIONNAIRES DISEASE
4830–8 | PNEUMONIA DUE TO OTHER SPECIFIED ORGANISM (MYCOPLASMA PNEUMONIA, CHLAMYDIA, OTHER SPECIFIED)
485 | BRONCHOPNEUMONIA, ORGANISM UNSPECIFIED
486 | PNEUMONIA, ORGANISM UNSPECIFIED (EXCLUDES HYPOSTATIC OR PASSIVE PNUEMONIA, ASPIRATION PNEUMONIA)
Puerperal infection
ICD-9-CM diagnosis code:
67000 | MAJOR PUERPERAL INFECTION, UNSPECIFIED AS TO EPISODE OF CARE
67002 | MAJOR PUERPERAL INFECTION, DELIVERED WITH MENTION OF POST-PARTUM COMPLICATION
67004 | MAJOR PUERPERAL INFECTION, POST-PARTUM CONDITION OR COMPLICATION
PTCA
ICD-9-CM procedure codes:
3601 | SINGLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLASTY [PTCA] OR CORONARY ATHERECTOMY WITHOUT MENTION OF THROMBOLYTIC AGENT
3602 | SINGLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLASTY [PTCA] OR CORONARY ATHERECTOMY WITH MENTION OF THROMBOLYTIC AGENT
3605 | MULTIPLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLSTY [PTCA] OR CORONARY ATHERECTOMY PERFORMED DURING THE SAME OPERATION, WITH OR WITHOUT MENTION OF THROMBOLYTIC AGENT
3606 | INSERTION OF CORONARY ARTERY STENTS
Pulmonary compromise
ICD-9-CM diagnosis codes:
51881 | ACUTE RESPIRATORY FAILURE
51882 | OTHER PULMONARY INSUFFICIENCY NOT ELSEWHERE CLASSIFIED
514 | PULMONARY CONGESTION AND HYPOSTASIS
518.5 | PULMONARY INSUFFICIENCY FOLLOWING TRAUMA AND SURGERY
518.4 | ACUTE EDEMA OF LUNG, UNSPECIFIED
Pulmonary embolism
ICD-9-CM diagnosis codes:
41511 | IAGTROGENIC PULMONARY EMBOLISM AND INFARCTION
41519 | OTHER
Reopening of a surgical site
ICD-9-CM procedure codes:
123 | REOPENING OF CRANIOTOMY SITE
302 | REOPENING OF LAMINECTOMY SITE
602 | REOPENING OF WOUND OF THYROID FIELD
3403 | REOPENING OF RECENT THORACOTOMY SITE
3595 | REVISION OF CORRECTIVE PROCEDURE ON HEART
3949 | OTHER REVISION OF VASCULAR PROCEDURE
5412 | REOPENING OF RECENT LAPAROTOMY SITE
Septicemia
ICD-9-CM diagnosis codes:
0380 | STREPTOCOCCAL SEPTICEMIA
03810 | STAPHYLOCOCCAL SEPTICEMIA, UNSPECIFIED
03811 | STAPHYLOCOCCUS AUREUS SEPTICEMIA
03819 | OTHER STAPHYLOCOCCAL SEPTICEMIA
0382 | PNEUMOCOCCAL SEPTICEMIA (STREPTOCOCCUS PNEUMONIAE SEPTICEMIA)
0383 | SEPTICEMIA DUE TO ANAEROBES
SEPTICEMIA DUE TO
03840 | GRAM-NEGATIVE ORGANISM, UNSPECIFIED
03841 | HEMOPHILUS INFLUENZAE
03842 | ESCHERICHIA COLI
03843 | PSEUDOMONAS
03844 | SERRATIA
03849 | SEPTICEMIA DUE TO OTHER GRAM-NEGATIVE ORGANISMS
0388 | OTHER SPECIFIED SEPTICEMIAS
0389 | UNSPECIFIED SEPTICEMIA
Suture of laceration
ICD-9-CM procedure codes:
2951 | SUTURE OF LACERATION OF PHARYNX
3161 | SUTURE OF LACERATION OF LARYNX
3341 | SUTURE OF LACERATION OF BRONCHUS
3343 | CLOSURE OF LACERATION OF LUNG
3482 | SUTURE OF LACERATION OF DIAPHRAGM
3930 | SUTURE OF UNSPECIFIED BLOOD VESSEL
3931 | SUTURE OF ARTERY
3932 | SUTURE OF VEIN
4282 | SUTURE OF LACERATION OF ESOPHAGUS
4461 | SUTURE OF LACERATION OF STOMACH
4671 | SUTURE OF LACERATION OF DUODENUM
4673 | SUTURE OF LACERATION OF SMALL INTESTINE, EXCEPT DUODENUM
4675 | SUTURE OF LACERATION OF LARGE INTESTINE
4871 | SUTURE OF LACERATION OF RECTUM
4971 | SUTURE OF LACERATION OF ANUS
5581 | SUTURE OF LACERATION OF KIDNEY
5682 | SUTURE OF LACERATION OF URETER
5781 | SUTURE OF LACERATION OF BLADDER
5841 | SUTURE OF LACERATION OF URETHRA
5061 | CLOSURE OF LACERATION OF LIVER
5191 | REPAIR OF LACERATION OF GALLBLADDER
6941 | SUTURE OF LACERATION OF UTERUS
Technical difficulty with medical care (procedure)
ICD-9-CM Diagnosis Codes
E870X | ACCIDENTAL CUT, PUNCTURE, PERFORATION, OR HEMORRHAGE DURING MEDICAL CARE
E872X | FAILURE OF STERILE PRECAUTIONS DURING PROCEDURE
E8765 | PERFORMANCE OF INAPPROPRIATE OPERATION
9982 | ACCIDENTAL PUNCTURE OR LACERATION DURING A PROCEDURE
99881 | EMPHYSEMA (SUBCUTANEOUS) (SURGICAL) RESULTING FROM A PROCEDURE
99882 | CATARACT FRAGMENTS IN EYE FOLLOWING CATARACT SURGERY
99889 | OTHER SPECIFIED COMPLICATIONS OF PROCEDURES, NOT ELSEWHERE CLASSIFIED
9991 | AIR EMBOLISM
Transfusion reaction
ICD-9-CM diagnosis codes:
9996 | ABO INCOMPATIBILITY REACTION
9997 | RH INCOMPATIBILITY REACTION
9998 | OTHER TRANSFUSION REACTION
E8760 | MISMATCHED BLOOD IN TRANSFUSION