# Comparison of PSIs with CSP Indicators and Miller et al. PSIs

This appendix lists the differences between the final PSIs and the Complications Screening Program indicators and Miller et al. PSIs. These two sets of indicators were used as a starting point for this report. Also listed is the acceptance status of each indicator.

Table 1 Comparison of Miller et al. PSIs to PSIs evaluated in this report

Miller et al. PSIs | Relationship to PSI indicators
Procedure for suture of laceration | Experimental indicator (“Suture of laceration”). PSI adds 043, “suture of cranial and peripheral nerve,” 3930 “suture of unspecified blood vessel,” 3931, “suture of artery,” 3932, “suture of vein,” and 6761, “suture of laceration of cervix.” PSI excludes obstetric admissions, and does not limit to elective surgery.
| PSI includes timing restriction of same day or after procedure.
Perforation diagnosis | Rejected pre-panels due to coding input.
Postoperative infection | Rejected pre-panel.
Transfusion reaction | Accepted indicator (“Transfusion reaction”). PSI does not include 999.8, “other transfusion reaction.”
| PSI does not exclude trauma.
Foreign body left during procedure | Accepted indicator (“Foreign body left in during procedure”). PSI includes E871x, “foreign body left in body during procedure.” PSI does not exclude trauma.
Infection due to procedure | Accepted indicator (“Infection due to medical care”). PSI adds 996.62.
Iatrogenic conditions | Indicator split prior to panel. “Iatrogenic hypotension” rejected by panel. “Iatrogenic PE/infarction” combined in “Postoperative PE or DVT.” “Iatrogenic pneumothorax” retained as accepted indicator, with specified exclusions.
Wound disruption | Accepted indicator (“Wound dehiscence in abdominopelvic surgical patients”). PSI does not include 998.3, “Postoperative wound disruption.” PSI limited to abdominoplevic surgical patients and excludes obstetric admissions.
Miscellaneous misadventure | Indicator split prior to panel. Shock due to anesthesia included in “Complications of anesthesia,” rejected by panel. Postoperative shock due to procedure was rejected. Accidental puncture or laceration included in “Technical difficulty with procedure,” accepted by panel. Air embolism was rejected by panel as part of “Technical difficulty with procedure.”
Obstetric misadventure | Indicator split prior to panel. Most codes assigned to experimental indicator, “Other obstetric complications.” “Wound complication - cesarean section” was accepted.
Birth trauma | Accepted indicator (“Birth trauma - injury to neonate”). PSI does not include 767.6 “Injury to brachial plexus.” PSI excludes preterm infants with subdural or cerebral hemorrhage, and infants with osteogenic imperfecta.
E codes | E codes split prior to panels and assigned to indicators.

Table 2 Comparison of CSP Indicators to PSIs evaluated in this report

CSP Indicator | Relationship to PSI indicators
1. Post-operative cerebral infarction | Rejected pre-panel.
2. Aspiration pneumonia | Experimental (“Aspiration pneumonia”). PSI definition adds two E codes to numerator. PSI denominator is limited to elective surgery patients.
3. Post-operative pulmonary compromise | Accepted (“Postoperative pulmonary compromise”). PSI retains only acute respiratory failure (518.81), and limits to elective surgery. PSI excludes obstetric patients.
4. Post-operative gastrointestinal hemmorhage or ulceration following non-GI surgery | Rejected pre-panel
5. Post-operative complications relating to urinary tract anatomy | Rejected pre-panel
6. Cellulitis or decubitus ulcer | Accepted (“Decubitus ulcer”). PSI omits two cellulitis codes. PSI does not exclude IV drug users and patients 80 yrs and older. PSI does not limit to dxs after #5. PSI LOS is 4 days as opposed to 10. PSI definition excludes patients admitted from long term care facility.
7. Septicemia | Accepted (“Septicemia”). PSI doesn't include bacteraemia. PSI limits denominator to elective surgery patients, and does not limit to specified DRGs. PSI excludes obstetric admissions.
8. Post-or intra-operative shock due to anesthesia. | Code rejected as part of “Complications of anesthesia” indicator by panel.
9. Reopening of a Surgical Site | Experimental (“Reopening of surgical site”). PSI removed two codes, 5461 (moved to wound dehiscence) and 3595 (corrective procedure on heart). Other revision of vascular procedure (39.49) must occur withing 24 hours of principle procedure.
10. Mechanical complication due to device, implant or graft, except organ transplant. | Rejected pre-panel.
11. Miscellaneous complications | Rejected pre-panel, most codes reassigned to toher indicators. 999.1 “air embolism” rejected as part of “Technical difficulty with procedure.” 999.3, “other infection” accepted as part of “Infection due to medical care.” 999.8, “other transfusion reaction” rejected as part of “Transfusion reaction.” E911 abd E912, “inhalation and ingestion of food causing obstruction of respiratory tract or suffocation” assigned to experimental set as part of “Aspiration pneumonia.”
12. Shock or cardiopulmonary arrest in-hospital | Rejected pre-panel
13. Post-operative complications relating to central or peripheral nervous system. | Rejected pre-panel. Bracial plexus lesions (353.0) included as part of experimental indicator “Intaoperative nerve compression injuries.”
14. Post-operative acute myocardial infarction | Experimental (“Postoperative AMI”). PSI definition limits denominator to elective non-cardiac surgery.
| PSI does not exclude MDC 5.
15. Post-operative cardiac abnormalities except AMI | Rejected pre-panel
16. Post-operative infections except pneumonia and wound | Rejected pre-panel, infection due to c. difficile included in own indicator.
17. Procedure related perforation or laceration | Experimental (“Suture of laceration”). PSI definition does not include perforation codes. PSI adds 043, “suture of cranial and peripheral nerve,” 3782, “suture of laceration of diaphragm,” 3930 “suture of unspecified blood vessel,” 3931, “suture of artery,” 3932, “suture of vein,” 4673, “suture of laceration of small intestine,” and 6761, “suture of laceration of cervix.” PSI excludes obstetric admissions, and does not limit to elective surgery.
18. Post-operative coma or stupor | Rejected pre-panel
19. Post-operative pneumonia | Rejected by panel
20. Post-operative physiologic, metabolic derangements | Accepted (“Postoperative physiologic and metabolic derangements”). PSI omits oliguria and anuria, adds dialysis dependent acute renal failure, and other diabetic comas. PSI limits denominator to elective surgical patients, and excludes obstetric admissions.
21. Complications relating to anesthetic agents and other CNS depressents | Similar indicator proposed by panel (“Complications of anesthesia,” Accepted indicator).
22. Venous thrombosis and pulmonary embolism | Accepted indicator (“Postoperative PE or DVT”). PSI definition adds 453.9 and 451.9 (unspecified sight), and procedure code 38.7. PSI excludes obstetric patients.
23. Wound infection | Rejected pre-panel
24. Post-procedural hemorrhage or hematoma | Accepted indicator (“Postoperative hemorrhage or hematoma”). PSI requires both a dx and procedure code, adds hematoma codes, and 38.8x. PSI eliminates seroma code.
25. In-hospital hip fracture | Accepted (“In-hospital hip fracture”). PSI ecludes patients with lymphoma or bone cancer, or self-inflicted injury and principal dx of delirium and other psychoses and anoxic brain injury. PSI only excludes patients with principal dx of trauma. PSI limits to surgical patients.
26. Iatrogenic complications | Experimental (nervous system and cardiac). Rejected (all others). PSI definition splits into 5 separate indicators.
27. Technical difficulty with medical care | Accepted (“Technical difficulty with procedure”). PSI only includes E8700-9 and adds 998.2. PSI excludes obstetric admissions.
28. Complications relating to drugs | Rejected pre-panel.
Sentinel events | 999.6 and 999.7 are included in accepted indicator, transfusion reaction. E8710-9 and 998.4 accepted as part of “Foreign body left in during procedure.” 998.2 accepted as part of “Technical difficulty with procedure.” 54.92, "removal of foreign body from peritoneal cavity was rejected by panel, as was 998.3, “disruption of operation wound.”