# Detailed Empirical Results

This appendix presents the full empirical results for the analyses referenced in Section 3E.

## Accepted Indicators

Table 1 Discharge Level Accepted Patient Safety Indicators, Florida and National SID, 1997

| Florida | | | National
PSI Label | Num. | Den. | Rate | Num. | Den. | Rate
COMPLICATIONS OF ANESTHESIA | 408 | 533,234 | 0.00077 | 3,046 | 4,906,380 | 0.00062
DEATH IN LOW MORTALITY DRGS | 280 | 619,725 | 0.00045 | 3,002 | 6,866,745 | 0.00044
DECUBITUS ULCER | 12,243 | 587,557 | 0.02084 | 108,042 | 5,318,472 | 0.02031
FAILURE TO RESCUE | 17,101 | 93,216 | 0.18346 | 135,085 | 753,174 | 0.17935
FOREIGN BODY LEFT IN DURING PROC | 176 | 1,747,773 | 0.00010 | 1,608 | 16,575,205 | 0.00010
IATROGENIC PNEUMOTHORAX | 1,551 | 1,556,307 | 0.00100 | 16,574 | 14,699,703 | 0.00113
INFECTION DUE TO MEDICAL CARE | 3,276 | 1,504,601 | 0.00218 | 27,060 | 14,411,539 | 0.00188
POSTOP HEMORRHAGE OR HEMATOMA | 981 | 478,323 | 0.00205 | 9,387 | 4,358,493 | 0.00215
POSTOP HIP FRACTURE | 487 | 369,503 | 0.00132 | 2,918 | 3,307,360 | 0.00088
POSTOP PHYSIO METABOL DERANGMNT | 366 | 228,106 | 0.00160 | 2,110 | 2,310,718 | 0.00091
POSTOP PE OR DVT | 3,639 | 476,243 | 0.00764 | 34,167 | 4,340,545 | 0.00787
POSTOP RESPIRATORY FAILURE | 762 | 179,162 | 0.00425 | 5,349 | 1,883,955 | 0.00284
POSTOP SEPSIS | 882 | 72,485 | 0.01217 | 6,635 | 688,606 | 0.00964
POSTOP WOUND DEHISCENCE | 238 | 115,323 | 0.00206 | 2,207 | 1,066,800 | 0.00207
TECH DIFFICULTY W PROCEDURE | 4,943 | 1,545,259 | 0.00320 | 46,126 | 14,231,084 | 0.00324
TRANSFUSION REACTION | 16 | 1,747,773 | 0.00001 | 129 | 16,575,205 | 0.00001
BIRTH TRAUMA | 1,936 | 180,393 | 0.01073 | 27,880 | 2,052,545 | 0.01358
OB TRAUMA - C-SECTION | 185 | 41,642 | 0.00444 | 2,604 | 427,558 | 0.00609
OB TRAUMA - VAGINAL W INSTRUMENT | 2,149 | 10,593 | 0.20287 | 36,906 | 162,662 | 0.22689
OB TRAUMA - VAGINAL WO INSTRUMENT | 9,678 | 126,782 | 0.07634 | 120,858 | 1,470,327 | 0.08220

Table 1 shows the total number of adverse events (numerator), the total number of patients at risk (denominator), and the overall rate in Florida and the National SID for each accepted patient safety indicator. Florida was the state used for initial testing and development. The rates are shown to compare with the National SID rates, which are similar.

Table 2 Hospital Level Accepted Patient Safety Indicators, Florida and National SID, 1997

| Florida | | | | National
PSI Label | N | Rate | SD | Skew | N | Rate | SD | Skew
COMPLICATIONS OF ANESTHESIA | 191 | 0.00067 | 0.00100 | 2.40109 | 2,275 | 0.00080 | 0.00715 | 44.36257
DEATH IN LOW MORTALITY DRGS | 195 | 0.00124 | 0.00608 | 11.62252 | 2,344 | 0.00114 | 0.01194 | 34.01637
DECUBITUS ULCER | 195 | 0.02417 | 0.01850 | 3.61063 | 2,342 | 0.02052 | 0.02069 | 3.57004
FAILURE TO RESCUE | 194 | 0.18541 | 0.05659 | -0.11446 | 2,327 | 0.17031 | 0.08092 | 2.13958
FOREIGN BODY LEFT IN DURING PROC | 195 | 0.00008 | 0.00015 | 3.49444 | 2,349 | 0.00008 | 0.00018 | 5.38260
IATROGENIC PNEUMOTHORAX | 195 | 0.00089 | 0.00080 | 2.04115 | 2,349 | 0.00086 | 0.00135 | 5.40259
INFECTION DUE TO MEDICAL CARE | 195 | 0.00204 | 0.00223 | 3.65896 | 2,349 | 0.00137 | 0.00175 | 7.14722
POSTOP HEMORRHAGE OR HEMATOMA | 191 | 0.00198 | 0.00231 | 2.98257 | 2,272 | 0.00183 | 0.00314 | 8.03155
POSTOP HIP FRACTURE | 191 | 0.00191 | 0.00560 | 7.73000 | 2,269 | 0.00124 | 0.00594 | 21.90674
POSTOP PHYSIO METABOL DERANGT | 179 | 0.00149 | 0.00341 | 7.94790 | 2,122 | 0.00092 | 0.01112 | 42.82075
POSTOP PE OR DVT | 191 | 0.00769 | 0.00510 | 1.24004 | 2,272 | 0.00695 | 0.01225 | 16.20401
POSTOP RESPIRATORY FAILURE | 179 | 0.00530 | 0.00893 | 4.96602 | 2,121 | 0.00268 | 0.00501 | 6.15831
POSTOP SEPSIS | 177 | 0.01197 | 0.01674 | 5.25552 | 2,050 | 0.01000 | 0.02962 | 20.53298
POSTOP WOUND DEHISCENCE | 190 | 0.00212 | 0.00341 | 2.92101 | 2,227 | 0.00243 | 0.00877 | 25.50940
TECH DIFFICULTY W PROCEDURE | 195 | 0.00231 | 0.00225 | 2.02898 | 2,348 | 0.00242 | 0.00264 | 2.64406
TRANSFUSION REACTION | 195 | 0.00001 | 0.00010 | 10.39826 | 2,349 | 0.00001 | 0.00006 | 19.53736
BIRTH TRAUMA | 122 | 0.00965 | 0.01998 | 5.40175 | 1,784 | 0.00936 | 0.03144 | 11.85275
OB TRAUMA - C-SECTION | 121 | 0.00433 | 0.00597 | 1.78278 | 1,756 | 0.00613 | 0.01612 | 19.02428
OB TRAUMA - VAGINAL W INSTRUMENT | 121 | 0.17314 | 0.10291 | 0.31238 | 1,697 | 0.20359 | 0.14236 | 1.02616
OB TRAUMA - VAGINAL WO INSTRUMENT | 126 | 0.06878 | 0.03665 | 0.48016 | 1,805 | 0.07558 | 0.05789 | 3.50258

Table 2 shows the hospital level rates for Florida and the National SID, for comparison. The columns labeled ‘N’ show the number of hospitals with at least one patient in the at-risk denominator.

Table 3 Hospital Level Unadjusted and Age-Gender Adjusted Accepted Patient Safety Indicators, National SID, 1997

| | Unadjusted Rate | | | Age-Gender Adjusted
PSI Label | N | Rate | SD | Skew | Rate | SD | Skew
COMPLICATIONS OF ANESTHESIA | 2,275 | 0.00080 | 0.00715 | 44.36257 | 0.00082 | 0.00713 | 44.63764
DEATH IN LOW MORTALITY DRGS | 2,344 | 0.00114 | 0.01194 | 34.01637 | 0.00114 | 0.01284 | 30.11021
DECUBITUS ULCER | 2,342 | 0.02052 | 0.02069 | 3.57004 | 0.01777 | 0.02035 | 3.82908
FAILURE TO RESCUE | 2,327 | 0.17031 | 0.08092 | 2.13958 | 0.12169 | 0.07747 | 2.24665
FOREIGN BODY LEFT IN DURING PROC | 2,349 | 0.00008 | 0.00018 | 5.38260
IATROGENIC PNEUMOTHORAX | 2,349 | 0.00086 | 0.00135 | 5.40259 | 0.00083 | 0.00130 | 5.64325
INFECTION DUE TO MEDICAL CARE | 2,349 | 0.00137 | 0.00175 | 7.14722 | 0.00136 | 0.00172 | 7.20834
POSTOP HEMORRHAGE OR HEMATOMA | 2,272 | 0.00183 | 0.00314 | 8.03155 | 0.00189 | 0.00366 | 15.43509
POSTOP HIP FRACTURE | 2,269 | 0.00124 | 0.00594 | 21.90674 | 0.00126 | 0.00609 | 23.09444
POSTOP PHYSIO METABOL DERANGT | 2,122 | 0.00092 | 0.01112 | 42.82075 | 0.00103 | 0.01112 | 41.90483
POSTOP PE OR DVT | 2,272 | 0.00695 | 0.01225 | 16.20401 | 0.00696 | 0.01192 | 15.64592
POSTOP RESPIRATORY FAILURE | 2,121 | 0.00268 | 0.00501 | 6.15831 | 0.00293 | 0.00627 | 9.27298
POSTOP SEPSIS | 2,050 | 0.01000 | 0.02962 | 20.53298 | 0.01013 | 0.02882 | 21.75989
POSTOP WOUND DEHISCENCE | 2,227 | 0.00243 | 0.00877 | 25.50940 | 0.00270 | 0.00945 | 22.07093
TECH DIFFICULTY W PROCEDURE | 2,348 | 0.00242 | 0.00264 | 2.64406 | 0.00243 | 0.00258 | 2.65313
TRANSFUSION REACTION | 2,349 | 0.00001 | 0.00006 | 19.53736
BIRTH TRAUMA | 1,784 | 0.00936 | 0.03144 | 11.85275 | 0.00922 | 0.03150 | 11.73605
OB TRAUMA - C-SECTION | 1,756 | 0.00613 | 0.01612 | 19.02428 | 0.00628 | 0.01633 | 18.46638
OB TRAUMA - VAGINAL W INSTRUMENT | 1,697 | 0.20359 | 0.14236 | 1.02616 | 0.14700 | 0.13526 | 1.46571
OB TRAUMA - VAGINAL WO INSTRUMENT | 1,805 | 0.07558 | 0.05789 | 3.50258 | 0.06789 | 0.05818 | 3.64282

Table 3 shows the unadjusted and age-gender adjusted rates for the accepted indicators in the National SID in 1997. The second column shows the mean hospital level unadjusted rate, defined as the number of adverse events divided by the number of discharges in the population at risk. The third column shows the standard deviation in the hospital level rates, and the fourth column shows the skew statistic, which is defined as the third moment (where the variance is the second moment). The skew statistic is a measure of how symmetric the hospital level rates are relative to the mean hospital level rate. The more positive the skew statistic is, the longer the right-hand tail of the distribution. The closer to zero it is, the more symmetrical the distribution. Negative skew statistics indicate a longer the left-hand tail.

Table 4 Hospital Level Risk Adjusted Accepted Patient Safety Indicators, National SID, 1997

| | DRG Adjusted* | | | Co-morbidity Adjusted**
PSI Label | N | Rate | SD | Skew | Rate | SD | Skew
COMPLICATIONS OF ANESTHESIA | 2,275 | 0.00087 | 0.00712 | 44.62686 | 0.00088 | 0.00711 | 44.61020
DEATH IN LOW MORTALITY DRGS | 2,344 | 0.00114 | 0.01284 | 30.11021 | 0.00115 | 0.01287 | 30.10817
DECUBITUS ULCER | 2,342 | 0.01668 | 0.01903 | 3.88522 | 0.01603 | 0.01802 | 3.92876
FAILURE TO RESCUE | 2,327 | 0.09768 | 0.06615 | 2.17070 | 0.08461 | 0.06581 | 2.09463
FOREIGN BODY LEFT IN DURING PROC | 2,349
IATROGENIC PNEUMOTHORAX | 2,349 | 0.00091 | 0.00127 | 5.76631 | 0.00090 | 0.00127 | 5.72549
INFECTION DUE TO MEDICAL CARE | 2,349 | 0.00146 | 0.00152 | 6.63907 | 0.00150 | 0.00142 | 5.72947
POSTOP HEMORRHAGE OR HEMATOMA | 2,272 | 0.00200 | 0.00363 | 15.71185 | 0.00201 | 0.00363 | 15.64393
POSTOP HIP FRACTURE | 2,269 | 0.00129 | 0.00591 | 22.90517 | 0.00131 | 0.00590 | 23.06666
POSTOP PHYSIO METABOL DERANGT | 2,122 | 0.00117 | 0.01103 | 41.81183 | 0.00122 | 0.01093 | 41.69619
POSTOP PE OR DVT | 2,272 | 0.00681 | 0.01093 | 17.15800 | 0.00679 | 0.01082 | 17.17289
POSTOP RESPIRATORY FAILURE | 2,121 | 0.00314 | 0.00583 | 9.04823 | 0.00301 | 0.00515 | 8.64106
POSTOP SEPSIS | 2,050 | 0.01002 | 0.02759 | 23.83976 | 0.01004 | 0.02691 | 24.36537
POSTOP WOUND DEHISCENCE | 2,227 | 0.00277 | 0.00943 | 22.05895 | 0.00286 | 0.00942 | 22.02311
TECH DIFFICULTY W PROCEDURE | 2,348 | 0.00294 | 0.00207 | 2.87175 | 0.00293 | 0.00207 | 2.85770
TRANSFUSION REACTION | 2,349
BIRTH TRAUMA | 1,784 | 0.00920 | 0.03150 | 11.67889 | 0.00922 | 0.03150 | 11.61115
OB TRAUMA - C-SECTION | 1,756 | 0.00628 | 0.01633 | 18.46636 | 0.00668 | 0.01630 | 18.63379
OB TRAUMA - VAGINAL W INSTRUMENT | 1,697 | 0.14700 | 0.13526 | 1.46571 | 0.14463 | 0.13378 | 1.49142
OB TRAUMA - VAGINAL WO INSTRUMENT | 1,805 | 0.06786 | 0.05818 | 3.64127 | 0.06786 | 0.05764 | 3.70580

* Age, gender, DRG (except PSI 22, 24, 26, 27, 28, 29, 30);

** Age, gender, DRG, co-morbidity

Table 4 shows the mean hospital level risk-adjusted rates, standard deviations and skew statistic for the DRG and co-morbidity adjusted rates. The Obstetric measures are not adjusted for DRG. The Death in Low Mortality DRGs indicator is also not adjusted for DRG. Rather, the indicator is stratified by DRG group, namely medical (adult and pediatric), surgical (adult and pediatric), neonatal, obstetric and psychiatric [See supplemental Table 1].

Table 5 Hospital Level Reliability Adjusted Accepted Patient Safety Indicators, National SID, 1997

| | Reliability* Adjusted | | | MSX Statistics
PSI Label | N | Rate | SD | Skew | Signal SD | Share | Signal Ratio
COMPLICATIONS OF ANESTHESIA | 2,248 | 0.00069 | 0.00147 | 13.36595 | 0.00187 | 0.00563 | 0.75680
DEATH IN LOW MORTALITY DRGS | 2,338 | 0.00089 | 0.00531 | 24.87662 | 0.00439 | 0.04237 | 0.94157
DECUBITUS ULCER | 2,338 | 0.02063 | 0.01802 | 3.37971 | 0.01457 | 0.01067 | 0.85568
FAILURE TO RESCUE | 2,301 | 0.17498 | 0.04803 | 0.72576 | 0.04617 | 0.01450 | 0.66607
FOREIGN BODY LEFT IN DURING PROC
IATROGENIC PNEUMOTHORAX | 2,349 | 0.00093 | 0.00122 | 5.96158 | 0.00143 | 0.00183 | 0.79928
INFECTION DUE TO MEDICAL CARE | 2,349 | 0.00154 | 0.00119 | 2.76077 | 0.00134 | 0.00095 | 0.70798
POSTOP HEMORRHAGE OR HEMATOMA | 2,243 | 0.00264 | 0.00052 | 1.88841 | 0.00039 | 0.00006 | 0.08587
POSTOP HIP FRACTURE | 2,241 | 0.00107 | 0.00211 | 11.61516 | 0.00184 | 0.00403 | 0.67135
POSTOP PHYSIO METABOL DERANGT | 2,054 | 0.00084 | 0.00060 | 4.58555 | 0.00054 | 0.00033 | 0.20899
POSTOP PE OR DVT | 2,243 | 0.00722 | 0.00521 | 5.60448 | 0.00633 | 0.00511 | 0.72594
POSTOP RESPIRATORY FAILURE | 2,047 | 0.00301 | 0.00241 | 2.82516 | 0.00230 | 0.00187 | 0.46639
POSTOP WOUND DEHISCENCE | 2,193 | 0.00217 | 0.00194 | 3.37005 | 0.00188 | 0.00171 | 0.35599
POSTOP SEPSIS | 1,961 | 0.00976 | 0.00840 | 2.90175 | 0.00869 | 0.00790 | 0.53877
TECH DIFFICULTY W PROCEDURE | 2,348 | 0.00259 | 0.00236 | 2.81472 | 0.00279 | 0.00241 | 0.82937
TRANSFUSION REACTION
BIRTH TRAUMA | 1,752 | 0.00967 | 0.03157 | 11.83738 | 0.04128 | 0.13603 | 0.97040
OB TRAUMA - C-SECTION | 1,739 | 0.00618 | 0.00536 | 3.82585 | 0.00590 | 0.00576 | 0.45902
OB TRAUMA - VAGINAL W INSTRUMENT | 1,625 | 0.21119 | 0.09963 | 0.58224 | 0.09794 | 0.05539 | 0.69985
OB TRAUMA - VAGINAL WO INSTRUMENT | 1,758 | 0.07788 | 0.04634 | 1.50907 | 0.04314 | 0.02470 | 0.86416

* Age, gender, DRG, co-morbidity and reliability

Table 5 shows the effect of reliability adjustment, and provides statistics on the signal standard deviation, signal share and signal ratio. Hospitals with fewer than three patients in the denominator were not included in the reliability adjustment. Multi-variate methods (taking into account correlations among indicators in order to extract additional ‘signal’) were applied to most of the accepted indicators. The exceptions were Death in Low Mortality DRGs and Failure to Rescue. Only univariate smoothing methods were applied to these two indicators.

Table 6 Bias Measures*, Accepted Patient Safety Indicators, National SID, 1997

PSI Label | N | Rank Corr. | Abs. Value | Top 10% | Bot 10% | Two Declines
COMPLICATIONS OF ANESTHESIA | 2,275 | 0.987 | 0.154 | 0.649 | 0.951 | 0.004
DEATH IN LOW MORTALITY DRGS | 2,344 | 0.845 | 0.289 | 0.239 | 0.850 | 0.128
DECUBITUS ULCER | 2,342 | 0.741 | 0.280 | 0.376 | 0.829 | 0.262
FAILURE TO RESCUE | 2,327 | 0.417 | 0.508 | 0.192 | 0.419 | 0.437
FOREIGN BODY LEFT IN DURING PROC | 2,349
IATROGENIC PNEUMOTHORAX | 2,349 | 0.873 | 0.173 | 0.528 | 0.885 | 0.138
INFECTION DUE TO MEDICAL CARE | 2,349 | 0.900 | 0.170 | 0.579 | 0.847 | 0.103
POSTOP HIP FRACTURE | 2,270 | 0.921 | 0.219 | 0.493 | 0.844 | 0.079
POSTOP HEMORRHAGE OR HEMATOMA | 2,272 | 0.965 | 0.043 | 0.787 | 0.907 | 0.038
POSTOP PHYSIO METABOL DERANGT | 2,122 | 0.934 | 0.249 | 0.619 | 0.839 | 0.054
POSTOP PE OR DVT | 2,272 | 0.837 | 0.164 | 0.520 | 0.747 | 0.140
POSTOP RESPIRATORY FAILURE | 2,121 | 0.888 | 0.198 | 0.635 | 0.826 | 0.112
POSTOP SEPSIS | 2,050 | 0.879 | 0.228 | 0.648 | 0.774 | 0.114
POSTOP WOUND DEHISCENCE | 2,227 | 0.963 | 0.174 | 0.768 | 0.855 | 0.035
TECH DIFFICULTY W PROCEDURE | 2,348 | 0.796 | 0.307 | 0.379 | 0.826 | 0.237
TRANSFUSION REACTION | 2,349
BIRTH TRAUMA | 1,784 | 0.998 | 0.032 | 0.979 | 0.958 | 0.000
OB TRAUMA - C-SECTION | 1,756 | 0.972 | 0.107 | 0.828 | 0.828 | 0.024
OB TRAUMA - VAGINAL W INSTRUMENT | 1,697 | 0.951 | 0.302 | 0.761 | 0.840 | 0.049
OB TRAUMA - VAGINAL WO INSTRUMENT | 1,805 | 0.987 | 0.106 | 0.830 | 0.909 | 0.006

* Reliability adjusted to age, gender, DRG, co-morbidity and reliability adjusted

Table 6 shows the effect of age, gender, DRG and co-morbidity risk-adjustment on the relative ranking of hospitals, compared to no risk-adjustment, using five measures of impact. Both the unadjusted and risk-adjusted measures have been adjusted for reliability, in order to remove the impact of noise on the assessment of potential bias. Also, even if risk-adjustment reduces the apparent level of hospital level variation, the relative rank may not be affected if the distribution of the adjusters does not vary systematically across hospitals. A large impact on the relative ranking means that the measures are biased based on the patient characteristics we observe on the administrative data. A small or no impact means that the measures are not biased based on the characteristics we observe (although there might be characteristics that we do not observe that are related to the patient's risk of experiencing an adverse event).

The first measure is a relative rank correlation statistic (a measure of the impact of adjustment on the assessment of relative hospital performance). The second measure is the average absolute magnitude of the change in unadjusted - adjusted rate for each hospital (a measure of the relative importance of adjustment). The third and forth measures are the percentage of hospitals that remain in the top (or bottom) 10% of the distribution after adjustment (measures of the impact on the highest and lowest hospitals). The last measure is the percentage of hospitals that change more than two deciles in the distribution after adjustment (a measure of the impact throughout the distribution).

Table 7 Spearman Correlations, Accepted Patient Safety Indicators, National SID, 1997

PSI Label | 1 | 2 | 3 | 4 | 6 | 7 | 8 | 9 | 10 | 11
COMPLICATIONS OF ANESTHESIA | 1.000 | 0.033 | 0.061* | -0.024 | 0.063* | 0.147* | 0.054* | 0.096* | -0.008 | -0.011
DEATH IN LOW MORTALITY DRGS | | 1.000 | 0.013 | 0.151* | 0.118* | 0.126* | 0.049* | 0.002 | 0.011 | 0.039
DECUBITUS ULCER | | | 1.000 | 0.240* | 0.024 | 0.163* | 0.153* | 0.023 | 0.116* | 0.224*
FAILURE TO RESCUE | | | | 1.000 | 0.099* | 0.091* | 0.129* | -0.026 | -0.031 | 0.096*
IATROGENIC PNEUMOTHORAX | | | | | 1.000 | 0.369* | 0.074* | 0.142* | -0.015 | 0.036
INFECTION DUE TO MEDICAL CARE | | | | | | 1.000 | 0.048* | 0.182* | 0.102* | 0.130*
POSTOP HIP FRACTURE | | | | | | | 1.000 | 0.044* | -0.006 | 0.088*
POSTOP HEMORRHAGE OR HEMATOMA | | | | | | | | 1.000 | 0.036 | 0.000
POSTOP PHYSIO METABOL DERANGT | | | | | | | | | 1.000 | 0.239*
POSTOP RESPIRATORY FAILURE | | | | | | | | | | 1.000
POSTOP PE OR DVT
POSTOP SEPSIS
TECH DIFFICULTY W PROCEDURE
WOUND DEHISCENCE
BIRTH TRAUMA
OB TRAUMA - VAGINAL W INSTRUMENT
OB TRAUMA - VAGINAL WO INSTRUMENT
OB TRAUMA - C-SECTION
COMPLICATIONS OF ANESTHESIA | 0.107* | 0.043 | 0.157* | 0.025 | 0.124* | 0.111* | 0.085* | 0.065* | 0.114* | 0.064*
DEATH IN LOW MORTALITY DRGS | 0.133* | 0.004 | 0.019 | 0.024 | 0.006 | 0.009 | 0.038 | 0.020 | 0.032 | 0.054*
DECUBITUS ULCER | 0.229* | 0.219* | -0.104* | -0.028 | 0.093* | -0.090* | -0.039 | -0.075* | -0.066* | 0.043
FAILURE TO RESCUE | 0.072* | 0.057* | -0.047* | 0.000 | -0.012 | -0.086* | -0.11* | -0.104* | -0.115* | 0.028
IATROGENIC PNEUMOTHORAX | 0.206* | -0.007 | 0.318* | 0.026 | 0.205* | 0.093* | 0.115* | 0.108* | 0.131* | 0.045
INFECTION DUE TO MEDICAL CARE | 0.294* | 0.167* | 0.306* | 0.018 | 0.290* | 0.132* | 0.158* | 0.101* | 0.189* | 0.128*
POSTOP HIP FRACTURE | 0.166* | 0.020 | -0.093* | 0.016 | -0.004 | 0.006 | 0.032 | 0.011 | -0.018 | 0.010
POSTOP HEMORRHAGE OR HEMATOMA | 0.102* | 0.052* | 0.176* | 0.149* | 0.092* | 0.052* | 0.045 | 0.123* | 0.158* | 0.129*
POSTOP PHYSIO METABOL DERANGT | 0.065* | 0.281* | -0.058* | 0.025 | -0.004 | -0.039 | -0.008 | -0.022 | 0.014 | 0.002
POSTOP RESPIRATORY FAILURE | 0.138* | 0.322* | -0.134* | -0.003 | 0.023 | -0.130* | -0.048 | -0.045 | -0.111* | -0.037
POSTOP PE OR DVT | 1.000 | 0.122* | -0.003 | 0.056* | 0.122* | 0.045 | 0.114* | 0.029 | 0.084* | 0.064*
POSTOP SEPSIS | | 1.000 | -0.066* | 0.000 | 0.029 | -0.094* | 0.017 | -0.053* | -0.057* | -0.003
TECH DIFFICULTY W PROCEDURE | | | 1.000 | -0.016 | 0.218* | 0.289* | 0.229* | 0.175* | 0.250* | -0.013
WOUND DEHISCENCE | | | | 1.000 | -0.019 | -0.03 | -0.023 | 0.029 | 0.021 | 0.090*
BIRTH TRAUMA | | | | | 1.000 | 0.113* | 0.125* | 0.116* | 0.149* | 0.139*
OB TRAUMA - VAGINAL W INSTRUMENT | | | | | | 1.000 | 0.545* | 0.233* | 0.221* | 0.057*
OB TRAUMA - VAGINAL WO INSTRUMENT | | | | | | | 1.000 | 0.217* | 0.185* | 0.071*
OB TRAUMA - C-SECTION | | | | | | | | 1.000 | 0.267* | 0.129*

* Significant at p < 0.05

Table 8A Factor Loadings, Accepted Patient Safety Indicators, National SID, 1997

| | Factor 1 | | | | Factor 2
PSI | PSI Label | Loading | Var. Exp. | PSI | PSI Label | Loading | Var. Exp.
7 | INFECTION DUE TO MEDICAL CARE | 0.6009 | 0.236 | 11 | POSTOP RESPIRATORY FAILURE | 0.4641 | 0.085
15 | TECH DIFFICULTY W PROCEDURE | 0.5194 | 0.195 | 3 | DECUBITUS ULCER | 0.4634 | 0.088
6 | IATROGENIC PNEUMOTHORAX | 0.4834 | 0.136 | 14 | POSTOPERATIVE SEPSIS | 0.4221 | 0.072
19 | OB TRAUMA - VAGINAL WO INSTRUMENT | 0.4552 | 0.161 | 12 | POSTOPERATIVE PE OR DVT | 0.3179 | 0.087
18 | OB TRAUMA - VAGINAL W INSTRUMENT | 0.4363 | 0.195 | 4 | FAILURE TO RESCUE | 0.3120 | 0.039
17 | BIRTH TRAUMA | 0.4045 | 0.093 | 10 | POSTOP PHYSIO METABOL DERANGMNT | 0.2765 | 0.030
12 | POSTOPERATIVE PE OR DVT | 0.3501 | 0.127 | 7 | INFECTION DUE TO MEDICAL CARE | 0.2351 | 0.163
20 | OB TRAUMA - C-SECTION | 0.2651 | 0.066 | 8 | POSTOPERATIVE HIP FRACTURE | 0.1886 | 0.016
9 | POSTOP HEMORRHAGE OR HEMATOMA | 0.2356 | 0.032 | 2 | DEATH IN LOW MORTALITY DRGS | 0.1210 | 0.016
1 | COMPLICATIONS OF ANESTHESIA | 0.2350 | 0.031 | 6 | IATROGENIC PNEUMOTHORAX | 0.0727 | 0.093
2 | DEATH IN LOW MORTALITY DRGS | 0.1592 | 0.023 | 17 | BIRTH TRAUMA | 0.0345 | 0.064
5 | FOREIGN BODY LEFT IN DURING PROC | 0.1206 | 0.012 | 13 | POSTOPERATIVE WOUND DEHISCENCE | 0.0248 | 0.000
3 | DECUBITUS ULCER | 0.1033 | 0.128 | 9 | POSTOP HEMORRHAGE OR HEMATOMA | 0.0236 | 0.022
14 | POSTOPERATIVE SEPSIS | 0.0858 | 0.105 | 1 | COMPLICATIONS OF ANESTHESIA | -0.0021 | 0.022
8 | POSTOPERATIVE HIP FRACTURE | 0.0743 | 0.023 | 5 | FOREIGN BODY LEFT IN DURING PROC | -0.0785 | 0.008
4 | FAILURE TO RESCUE | 0.0472 | 0.056 | 16 | TRANSFUSION REACTION | -0.0982 | 0.074
11 | POSTOP RESPIRATORY FAILURE | 0.0417 | 0.123 | 20 | OB TRAUMA - C-SECTION | -0.2158 | 0.046
13 | POSTOPERATIVE WOUND DEHISCENCE | 0.0176 | 0.001 | 15 | TECH DIFFICULTY W PROCEDURE | -0.2706 | 0.134
10 | POSTOP PHYSIO METABOL DERANGMNT | 0.0121 | 0.043 | 19 | OB TRAUMA - VAGINAL WO INSTRUMENT | -0.2764 | 0.111
16 | TRANSFUSION REACTION | -0.4253 | 0.108 | 18 | OB TRAUMA - VAGINAL W INSTRUMENT | -0.3914 | 0.134
| Share of Variance Explained | 0.567 | | | Share of Variance Explained | 0.391

Black - Highest loading on factor 1; Bold - Highest loading on factor 2

Table 8B Factor Loadings, Non-OB Accepted Patient Safety Indicators, National SID, 1997

| | Factor 1 | | | | Factor 2
PSI | PSI Label | Loading | Var. Exp. | PSI | PSI Label | Loading | Var. Exp.
7 | INFECTION DUE TO MEDICAL CARE | 0.63096 | 0.272 | 11 | POSTOP RESPIRATORY FAILURE | 0.4256 | 0.108
6 | IATROGENIC PNEUMOTHORAX | 0.47137 | 0.193 | 14 | POSTOPERATIVE SEPSIS | 0.3911 | 0.099
12 | POSTOPERATIVE PE OR DVT | 0.46335 | 0.149 | 3 | DECUBITUS ULCER | 0.3632 | 0.099
3 | DECUBITUS ULCER | 0.31242 | 0.152 | 10 | POSTOP PHYSIO METABOL DERANGMNT | 0.3308 | 0.056
15 | TECH DIFFICULTY W PROCEDURE | 0.30459 | 0.225 | 16 | TRANSFUSION REACTION | 0.2037 | 0.090
14 | POSTOPERATIVE SEPSIS | 0.27547 | 0.151 | 8 | POSTOPERATIVE HIP FRACTURE | 0.1498 | 0.021
11 | POSTOP RESPIRATORY FAILURE | 0.26393 | 0.166 | 4 | FAILURE TO RESCUE | 0.1439 | 0.031
4 | FAILURE TO RESCUE | 0.22556 | 0.047 | 12 | POSTOPERATIVE PE OR DVT | 0.1069 | 0.098
9 | POSTOP HEMORRHAGE OR HEMATOMA | 0.22346 | 0.040 | 13 | POSTOPERATIVE WOUND DEHISCENCE | -0.0071 | 0.001
2 | DEATH IN LOW MORTALITY DRGS | 0.21816 | 0.032 | 2 | DEATH IN LOW MORTALITY DRGS | -0.0193 | 0.021
1 | COMPLICATIONS OF ANESTHESIA | 0.1923 | 0.030 | 1 | COMPLICATIONS OF ANESTHESIA | -0.0887 | 0.019
8 | POSTOPERATIVE HIP FRACTURE | 0.15945 | 0.032 | 5 | FOREIGN BODY LEFT IN DURING PROC | -0.0894 | 0.005
10 | POSTOP PHYSIO METABOL DERANGMNT | 0.13815 | 0.085 | 9 | POSTOP HEMORRHAGE OR HEMATOMA | -0.1050 | 0.026
5 | FOREIGN BODY LEFT IN DURING PROC | 0.06324 | 0.008 | 7 | INFECTION DUE TO MEDICAL CARE | -0.1187 | 0.178
13 | POSTOPERATIVE WOUND DEHISCENCE | 0.04133 | 0.001 | 6 | IATROGENIC PNEUMOTHORAX | -0.2649 | 0.126
16 | TRANSFUSION REACTION | -0.40846 | 0.138 | 15 | TECH DIFFICULTY W PROCEDURE | -0.4972 | 0.147
| Share of Variance Explained | 0.661 | | | Share of Variance Explained | 0.433

Black - Highest loading on factor 1; Bold - Highest loading on factor 2

## Experimental Indicators

Table 9 Discharge Level Experimental Patient Safety Indicators, Florida and National SID, 1997

| Florida | | | National
PSI Label | Num. | Den. | Rate | Num. | Den. | Rate
ASPIRATION PNEUMONIA | 683 | 170,643 | 0.00400 | 3,864 | 1,331,866 | 0.00290
CABG POST PTCA | 792 | 38,480 | 0.02058 | 6,267 | 281,771 | 0.02224
DECUBITUS ULCER IN HIGH RISK PATIENT | 2,190 | 33,283 | 0.06580 | 28,753 | 421,801 | 0.06817
IN-HOSPITAL FRACTURES RELATED TO FALLS | 967 | 398,488 | 0.00243 | 6,310 | 3,617,435 | 0.00174
INTRA-OPER NERVE COMP INJURY | 7 | 461,526 | 0.00002 | 102 | 4,254,914 | 0.00002
MALIGNANT HYPERTHERMIA | 0 | 478,400 | 0.00000 | 0 | 4,359,259 | 0.00000
POSTOPERATIVE AMI | 643 | 223,770 | 0.00287 | 4,264 | 1,833,269 | 0.00233
POSTOP IATROGENIC COMPL - CARDIAC | 9,109 | 478,400 | 0.01904 | 83,502 | 4,359,259 | 0.01916
POSTOP IATROGENIC COMPL - NERVOUS | 1,965 | 478,400 | 0.00411 | 18,121 | 4,359,259 | 0.00416
REOPENING OF A SURGICAL SITE | 3,244 | 533,311 | 0.00608 | 28,850 | 4,907,182 | 0.00588
SUTURE OF LACERATION | 2,344 | 422,227 | 0.00555 | 22,097 | 3,801,214 | 0.00581
OTHER OBSTERIC COMPLICATION | 703 | 179,018 | 0.00393 | 8,213 | 2,060,609 | 0.00399
OB WOUND COMP - C-SECTION DELIVERY | 482 | 41,642 | 0.01157 | 5,517 | 427,558 | 0.01290
OB WOUND COMPLICATION OF VAGINAL DEL | 124 | 137,376 | 0.00090 | 1,506 | 1,633,038 | 0.00092
POST-PARTUM UTI INFECTION | 497 | 179,017 | 0.00278 | 5,296 | 2,060,547 | 0.00257
3RD OR 4TH DEGREE OB LACERATION | 7,320 | 135,771 | 0.05391 | 99,383 | 1,620,823 | 0.06132
UTERINE RUPTURE | 127 | 160,424 | 0.00079 | 1,324 | 1,878,381 | 0.00070

Table 9 shows the total number of adverse events (numerator), the total number of patients at risk (denominator), and the overall rate in Florida and the National SID for each experimental PSI. Florida was the state used for initial testing and development. The rates are shown to compare with the National SID rates.

Table 10 Hospital Level Experimental Patient Safety Indicators, Florida and National SID, 1997

| Florida | | | | National
PSI Label | N | Rate | SD | Skew | N | Rate | SD | Skew
ASPIRATION PNEUMONIA | 178 | 0.00397 | 0.00514 | 4.36419 | 1,715 | 0.00256 | 0.00803 | 20.83495
CABG POST PTCA | 69 | 0.01727 | 0.01193 | 0.09464 | 612 | 0.02049 | 0.01683 | 1.04254
DECUBITUS ULCER IN HIGH RISK PATIENT | 194 | 0.07545 | 0.05976 | 2.28194 | 2,288 | 0.06173 | 0.06517 | 2.54328
IN-HOSPITAL FRAC RELATED TO FALLS | 191 | 0.00347 | 0.00790 | 7.74260 | 2,269 | 0.00284 | 0.02330 | 36.57401
INTRA-OPER NERVE COMP INJURY | 191 | 0.00001 | 0.00007 | 7.00068 | 2,274 | 0.00001 | 0.00011 | 10.74719
MALIGNANT HYPERTHERMIA
POSTOPERATIVE AMI | 179 | 0.00286 | 0.00300 | 2.15227 | 1,744 | 0.00199 | 0.00414 | 9.67318
POSTOP IATROGENIC COMPL - CARDIAC | 191 | 0.01273 | 0.01497 | 2.53648 | 2,272 | 0.01179 | 0.01333 | 2.07341
POSTOP IATROGENIC COMPL - NERVOUS | 191 | 0.00255 | 0.00308 | 2.02625 | 2,272 | 0.00239 | 0.00533 | 16.17496
REOPENING OF A SURGICAL SITE | 191 | 0.00490 | 0.00390 | 0.87565 | 2,275 | 0.00399 | 0.00551 | 8.65050
SUTURE OF LACERATION | 191 | 0.00543 | 0.00600 | 5.96016 | 2,267 | 0.00585 | 0.00840 | 7.40585
OB WOUND COMP - C-SECTION DELIVERY | 121 | 0.00987 | 0.01182 | 2.49694 | 1,756 | 0.01100 | 0.01677 | 3.92826
OB WOUND COMP OF VAGINAL DELIVERY | 126 | 0.00094 | 0.00160 | 2.72679 | 1,805 | 0.00097 | 0.00451 | 28.67962
OTHER OBSTERIC COMPLICATIONS | 126 | 0.00317 | 0.00367 | 1.90949 | 1,812 | 0.00347 | 0.00596 | 6.30315
POST-PARTUM UTI INFECTION | 126 | 0.00201 | 0.00247 | 1.46515 | 1,812 | 0.00349 | 0.03344 | 29.26669
3RD OR 4TH DEGREE OB LACERATION | 129 | 0.04825 | 0.02861 | 0.66478 | 1,813 | 0.05827 | 0.04083 | 2.26357
UTERINE RUPTURE | 126 | 0.00067 | 0.00104 | 2.56183 | 1,807 | 0.00071 | 0.00371 | 24.40042

Table 10 shows the hospital level rates for Florida and the National SID, for comparison.

Table 11 Hospital Level Unadjusted and Age-Gender Adjusted Experimental Patient Safety Indicators, National SID, 1997

| | Unadjusted Rate | | | Age-Gender Adjusted
PSI Label | N | Rate | SD | Skew | Rate | SD | Skew
ASPIRATION PNEUMONIA | 1,715 | 0.00256 | 0.00803 | 20.83495 | 0.00281 | 0.00766 | 21.80080
CABG POST PTCA | 612 | 0.02049 | 0.01683 | 1.04254 | 0.02054 | 0.01687 | 1.15669
DECUBITUS ULCER IN HIGH RISK PATIENT | 2,288 | 0.06173 | 0.06517 | 2.54328 | 0.05755 | 0.06584 | 2.84363
IN-HOSPITAL FRAC RELATED TO FALLS | 2,269 | 0.00284 | 0.02330 | 36.57401 | 0.00286 | 0.02313 | 36.66337
INTRA-OPER NERVE COMP INJURY | 2,274 | 0.00001 | 0.00011 | 10.74719
MALIGNANT HYPERTHERMIA
POSTOPERATIVE AMI | 1,744 | 0.00199 | 0.00414 | 9.67318 | 0.00214 | 0.00530 | 19.28620
POSTOP IATROGENIC COMPL - CARDIAC | 2,272 | 0.01179 | 0.01333 | 2.07341 | 0.01189 | 0.01288 | 2.30382
POSTOP IATROGENIC COMPL - NERVOUS | 2,272 | 0.00239 | 0.00533 | 16.17496 | 0.00248 | 0.00418 | 11.16202
REOPENING OF A SURGICAL SITE | 2,275 | 0.00399 | 0.00551 | 8.65050 | 0.00431 | 0.00467 | 4.81263
SUTURE OF LACERATION | 2,267 | 0.00585 | 0.00840 | 7.40585 | 0.00580 | 0.00879 | 9.51146
OB WOUND COMP - C-SECTION DELIVERY | 1,756 | 0.01100 | 0.01677 | 3.92826 | 0.01127 | 0.01795 | 4.37926
OB WOUND COMP OF VAGINAL DELIVERY | 1,805 | 0.00097 | 0.00451 | 28.67962 | 0.00100 | 0.00521 | 31.60748
OTHER OBSTERIC COMPLICATIONS | 1,812 | 0.00347 | 0.00596 | 6.30315 | 0.00359 | 0.00585 | 6.70887
POST-PARTUM UTI INFECTION | 1,812 | 0.00349 | 0.03344 | 29.26669 | 0.00351 | 0.03344 | 29.23084
3RD OR 4TH DEGREE OB LACERATION | 1,813 | 0.05827 | 0.04083 | 2.26357 | 0.05462 | 0.04070 | 2.68744
UTERINE RUPTURE | 1,807 | 0.00071 | 0.00371 | 24.40042 | 0.00074 | 0.00378 | 30.60857

Table 11 shows the unadjusted and age-gender adjusted rates for the experimental indicators in the National SID in 1997. The first column shows the number of hospitals with at least one patient in the at-risk denominator. The second column shows the mean hospital level unadjusted rate, defined as the number of adverse events divided by the number of discharges in the population at risk. The third column shows the standard deviation in the hospital level rates, and the fourth column shows the skew statistic, which is defined as the third moment (where the variance is the second moment). The skew statistic is a measure of how symmetric the hospital level rates are relative to the mean hospital level rate. The more positive the skew statistic is, the longer the right-hand tail of the distribution. The closer to zero it is, the more symmetrical the distribution. Negative skew statistics indicate a longer the left-hand tail.

Table 12 Hospital Level Risk Adjusted Experimental Patient Safety Indicators, National SID, 1997

| | DRG Adjusted* | | | Co-morbidity Adjusted**
PSI Label | N | Rate | SD | Skew | Rate | SD | Skew
ASPIRATION PNEUMONIA | 1,715 | 0.00302 | 0.00746 | 22.17259 | 0.00301 | 0.00739 | 23.14628
CABG POST PTCA | 612 | 0.02054 | 0.01687 | 1.15669 | 0.02112 | 0.01680 | 1.16310
DECUBITUS ULCER IN HIGH RISK PATIENT | 2,288 | 0.05368 | 0.05879 | 3.16838 | 0.05101 | 0.05633 | 3.11981
IN-HOSPITAL FRAC RELATED TO FALLS | 2,269 | 0.00288 | 0.02293 | 36.80870 | 0.00288 | 0.02266 | 36.73241
INTRA-OPER NERVE COMP INJURY
MALIGNANT HYPERTHERMIA
POSTOPERATIVE AMI | 1,744 | 0.00233 | 0.00525 | 19.35160 | 0.00240 | 0.00524 | 19.95945
POSTOP IATROGENIC COMPL - CARDIAC | 2,272 | 0.01607 | 0.01110 | 2.10968 | 0.01593 | 0.01100 | 2.12623
POSTOP IATROGENIC COMPL - NERVOUS | 2,272 | 0.00357 | 0.00390 | 14.02002 | 0.00352 | 0.00388 | 14.09111
REOPENING OF A SURGICAL SITE | 2,275 | 0.00511 | 0.00426 | 5.95044 | 0.00512 | 0.00419 | 6.09798
SUTURE OF LACERATION | 2,267 | 0.00554 | 0.00851 | 10.03914 | 0.00556 | 0.00849 | 10.02887
OB WOUND COMP - C-SECTION DELIVERY | 1,756 | 0.01127 | 0.01795 | 4.37917 | 0.01168 | 0.01763 | 4.42871
OB WOUND COMP OF VAGINAL DELIVERY | 1,805 | 0.00100 | 0.00521 | 31.60748 | 0.00110 | 0.00520 | 31.85472
OTHER OBSTERIC COMPLICATIONS | 1,812 | 0.00359 | 0.00585 | 6.70887 | 0.00369 | 0.00571 | 6.99412
POST-PARTUM UTI INFECTION | 1,812 | 0.00351 | 0.03344 | 29.23084 | 0.00358 | 0.03334 | 29.25606
3RD OR 4TH DEGREE OB LACERATION | 1,813 | 0.05462 | 0.04070 | 2.68744 | 0.05459 | 0.04006 | 2.79613
UTERINE RUPTURE | 1,807 | 0.00074 | 0.00378 | 30.60857 | 0.00081 | 0.00378 | 30.64062

* Age, gender, DRG (except PSI 3, 4, 5, 6, 11);

** Age, gender, DRG, co-morbidity

Table 12 shows the mean hospital level risk-adjusted rates, standard deviations and skew statistic for the DRG and co-morbidity adjusted rates.

Table 13 Hospital Level Reliability Adjusted Experimental Patient Safety Indicators, National SID, 1997

| | Reliability* Adjusted | | | MSX Statistics
PSI Label | N | Rate | SD | Skew | Signal SD | Share | Signal Ratio
ASPIRATION PNEUMONIA
CABG POST PTCA | 612 | 0.02319 | 0.00485 | 1.04367 | 0.00544 | 0.00137 | 0.34171
DECUBITUS ULCER IN HIGH RISK PATIENT | 2,288 | 0.05322 | 0.02164 | 1.73548 | 0.02696 | 0.01203 | 0.50482
IN-HOSPITAL FRAC RELATED TO FALLS | 2,269 | 0.00199 | 0.00151 | 16.45952 | 0.00182 | 0.00192 | 0.56207
INTRA-OPER NERVE COMP INJURY
MALIGNANT HYPERTHERMIA
POSTOPERATIVE AMI
POSTOP IATROGENIC COMPL - CARDIAC | 2,272 | 0.01691 | 0.00878 | 1.63677 | 0.01154 | 0.00752 | 0.77177
POSTOP IATROGENIC COMPL - NERVOUS | 2,272 | 0.00389 | 0.00130 | 2.62249 | 0.00193 | 0.00091 | 0.46311
REOPENING OF A SURGICAL SITE | 2,275 | 0.00560 | 0.00179 | 2.66912 | 0.00249 | 0.00108 | 0.51588
SUTURE OF LACERATION | 2,267 | 0.00570 | 0.00270 | 6.31452 | 0.00351 | 0.00215 | 0.57816
OB WOUND COMP - C-SECTION DELIVERY** | 1,739 | 0.01206 | 0.01094 | 3.19456 | 0.01158 | 0.01056 | 0.57486
OB WOUND COMP OF VAGINAL DELIVERY | 1,805 | 0.00104 | 0.00036 | 1.82693 | 0.00074 | 0.00060 | 0.29040
OTHER OBSTERIC COMPLICATIONS | 1,812 | 0.00389 | 0.00385 | 9.98124 | 0.00427 | 0.00462 | 0.69885
POST-PARTUM UTI INFECTION** | 1,761 | 0.00253 | 0.00326 | 3.92805 | 0.00328 | 0.00419 | 0.68333
3RD OR 4TH DEGREE OB LACERATION | 1,813 | 0.05637 | 0.02551 | 0.88812 | 0.02627 | 0.01206 | 0.79732
UTERINE RUPTURE | 1,807 | 0.00080 | 0.00015 | 2.28522 | 0.00038 | 0.00021 | 0.15962

* Age, gender, DRG, co-morbidity and reliability adjusted

** These two indicators were included in the Accepted indicator reliability adjustment, and then later demoted. The information reported here reflects that analysis.

Table 13 shows the effect of reliability adjustment, and provides statistics on the signal standard deviation, signal share and signal ratio. Hospitals with fewer than three patients in the denominator were not included in the reliability adjustment. Only univariate smoothing methods were applied to the experimental indicators, because there was less a priori reason to believe underlying processes or structural characteristics were common to these indicators.

Table 14 Bias Measures*, Experimental Patient Safety Indicators, National SID, 1997

PSI Label | N | Rank Corr. | Abs. Value | Top 10% | Bot 10% | Two Declines
ASPIRATION PNEUMONIA
CABG POST PTCA | 565 | 0.99201 | 0.02778 | 0.89474 | 0.89474 | 0.00000
DECUBITUS ULCER IN HIGH RISK PATIENT | 2194 | 0.76883 | 0.23354 | 0.47273 | 0.66818 | 0.22470
IN-HOSPITAL FRAC RELATED TO FALLS | 2240 | 0.89556 | 0.17110 | 0.62054 | 0.82143 | 0.10491
INTRA-OPER NERVE COMP INJURY
MALIGNANT HYPERTHERMIA
POSTOPERATIVE AMI
POSTOP IATROGENIC COMPL - CARDIAC | 2243 | 0.75712 | 0.42083 | 0.27111 | 0.73778 | 0.20285
POSTOP IATROGENIC COMPL - NERVOUS | 2243 | 0.84357 | 0.28434 | 0.47556 | 0.75556 | 0.15292
REOPENING OF A SURGICAL SITE | 2248 | 0.81376 | 0.20992 | 0.45333 | 0.76889 | 0.19440
SUTURE OF LACERATION | 2240 | 0.94803 | 0.08606 | 0.75446 | 0.86161 | 0.05625
OB WOUND COMP - C-SECTION DELIVERY | 1,756 | 0.972 | 0.090 | 0.828 | 0.868 | 0.025
OB WOUND COMP OF VAGINAL DELIVERY | 1758 | 0.97279 | 0.10114 | 0.85795 | 0.89205 | 0.02162
OTHER OBSTERIC COMPLICATIONS | 1761 | 0.96006 | 0.11163 | 0.68362 | 0.90960 | 0.03066
POST-PARTUM UTI INFECTION | 1,812 | 0.982 | 0.093 | 0.802 | 0.910 | 0.012
3RD OR 4TH DEGREE OB LACERATION | 1758 | 0.98284 | 0.07393 | 0.81818 | 0.89205 | 0.00967
UTERINE RUPTURE | 1760 | 0.95904 | 0.13337 | 0.81818 | 0.84659 | 0.03125

* Reliability adjusted to age, gender, DRG, co-morbidity and reliability adjusted

Table 14 shows the effect of age, gender, DRG and co-morbidity risk-adjustment on the relative ranking of hospitals, compared to no risk-adjustment, using five measures of impact. Even if risk-adjustment reduces the apparent level of hospital level variation, the relative rank may not be affected if the distribution of the adjusters does not vary systematically across hospitals. A large impact on the relative ranking means that the measures are biased based on the patient characteristics we observe on the administrative data. A small or no impact means that the measures are not biased based on the characteristics we observe (although there might be characteristics that we do not observe that are related to the patients risk of experiencing an adverse event). The first measure is a relative rank correlation statistic. The second measure is the average absolute magnitude of the change in actual - predicted rate for each hospital. The third and forth measures are the percentage of hospitals that remain in the top (or bottom) 10% of the distribution after adjustment. The last measure is the percentage of hospitals that change more than two deciles in the distribution after adjustment.

## Area Indicators

Table 15 Unadjusted and Risk-Adjusted Area Patient Safety Indicators, National SID, 1997

| | Unadjusted | | | Age-Gender Adjusted
PSI Label | N | Rate* | SD | Skew | Rate* | SD | Skew
FOREIGN BODY LEFT IN DURING PROCEDURE | 714 | 0.82 | 2.27 | 7.03015 | 0.83 | 2.41 | 9.62334
IATROGENIC PNEUMOTHORAX | 714 | 8.80 | 16.62 | 9.73506 | 8.07 | 15.43 | 9.76828
INFECTION DUE TO MEDICAL CARE | 714 | 12.98 | 25.24 | 10.40177 | 12.71 | 25.67 | 9.92958
TECHNICAL DIFFICULTY WITH PROCEDURE | 714 | 22.03 | 45.26 | 14.23158 | 21.45 | 44.14 | 13.08738
TRANSFUSION REACTION | 714 | 0.07 | 0.57 | 16.14953 | 0.07 | 0.51 | 14.95507
POSTOPERATIVE WOUND DEHISCENCE | 673 | 1.55 | 3.43 | 4.64596 | 1.90 | 7.20 | 12.43435

* Rate per 100,000 (except PSI31, which uses the number of abortions as the denominator)

Table 15 shows the unadjusted and age-gender adjusted rates for the area indicators in the National SID in 1997. The unit of analysis is the MSA or county (in rural areas), except for the Therapeutic Abortion indicator, where the denominator is the number of abortions in the state. The other six indicators are accepted patient safety indicators that were modified into area indicators to assess the total incidence of the adverse event within geographic areas. The modification generally was to use principal rather than secondary diagnosis codes, and to use the area population as the denominator.

## Supplemental Tables

Supplemental Table 1. Death in Low Mortality DRGs by Category, National SID, 1997

Category | Num. | Den. | Rate
Death in Low Mortality DRG – Adult Medical | 1,755 | 1,041,457 | 0.00169
Death in Low Mortality DRG – Pediatric Medical | 318 | 543,195 | 0.00059
Death in Low Mortality DRG - Adult Surgical | 375 | 685,286 | 0.00055
Death in Low Mortality DRG – Pediatric Surgical | 30 | 29,725 | 0.00101
Death in Low Mortality DRG – Obstetric | 201 | 2,310,440 | 0.00009
Death in Low Mortality DRG – Neonatal | 0 | 1,928,936 | 0.00000
Death in Low Mortality DRG – Psychiatric | 323 | 327,706 | 0.00099

Supplemental Table 2. Hospital Level Accepted Patient Safety Indicators, Florida, 1995-97

| | Risk-adjusted Rate | | | Spearman Correlation
PSI | PSI Label | 1995 | 1996 | 1997 | '95-'96 | '96-'97 | '95-'97
1 | COMPLICATIONS OF ANESTHESIA | 0.00069 | 0.00069 | 0.00081 | 0.379 | 0.410 | 0.320
2 | DEATH IN LOW MORTALITY DRGS | 0.00104 | 0.00111 | 0.00107 | 0.290 | 0.326 | 0.293
3 | DECUBITUS ULCER | 0.01639 | 0.01715 | 0.01782 | 0.702 | 0.728 | 0.636
4 | FAILURE TO RESCUE | 0.17851 | 0.17418 | 0.17144 | 0.480 | 0.497 | 0.463
5 | FOREIGN BODY LEFT IN DURING PROC | 0.00010 | 0.00009 | 0.00009 | 0.207 | 0.206 | 0.245
6 | IATROGENIC PNEUMOTHORAX | 0.00096 | 0.00099 | 0.00094 | 0.515 | 0.535 | 0.474
7 | INFECTION DUE TO MEDICAL CARE | 0.00147 | 0.00150 | 0.00155 | 0.613 | 0.614 | 0.519
8 | IN-HOSPITAL HIP FRACTURE | 0.00111 | 0.00122 | 0.00123 | 0.202 | 0.192 | 0.133
9 | POSTOP HEMORRHAGE OR HEMATOMA* | 0.00016 | 0.00068 | 0.00196 | 0.299 | 0.224 | -0.105
10 | POSTOP PHYSIO METABOL DERANGMNT | 0.00098 | 0.00085 | 0.00091 | 0.223 | 0.272 | 0.257
11 | POSTOP PULMONARY COMPROMISE | 0.00345 | 0.00293 | 0.00293 | 0.423 | 0.409 | 0.385
12 | POSTOPERATIVE PE OR DVT | 0.00610 | 0.00732 | 0.00718 | 0.407 | 0.414 | 0.358
13 | POSTOPERATIVE WOUND DEHISCENCE | 0.00262 | 0.00245 | 0.00257 | 0.236 | 0.226 | 0.202
14 | SEPTICEMIA | 0.00799 | 0.00896 | 0.01002 | 0.308 | 0.309 | 0.291
15 | TECH DIFFICULTY W PROCEDURE | 0.00293 | 0.00309 | 0.00313 | 0.587 | 0.596 | 0.510
16 | TRANSFUSION REACTION | . | . | .
17 | BIRTH TRAUMA | 0.00896 | 0.00945 | 0.00955 | 0.593 | 0.583 | 0.518
18 | OB TRAUMA - VAGINAL W INSTRUMENT | 0.20459 | 0.20691 | 0.20660 | 0.654 | 0.669 | 0.629
19 | OB TRAUMA - VAGINAL WO INSTRUMENT | 0.07452 | 0.07652 | 0.07639 | 0.753 | 0.756 | 0.692
20 | OB TRAUMA - C-SECTION | 0.00577 | 0.00623 | 0.00611 | 0.285 | 0.242 | 0.223

* ICD-9 codes 998.11 (Hemorrhage complicating a procedure) and 998.12 (Hematoma complicating a procedure) were added in October, 1996.

Supplemental Table 3. Accepted Indicator Discharge Level Rates by Age Strata

| Age < 1 | | | Age 1–14 | | | Age 15–24 | | | Age 25+
Label | Numer. | Denom. | Rate | Numer. | Denom. | Rate | Numer. | Denom. | Rate | Numer. | Denom. | Rate
COMPLICATIONS OF ANESTHESIA | 28 | 34,882 | 0.00080 | 100 | 141,690 | 0.000706 | 152 | 313,689 | 0.00048 | 2,766 | 4,416,119 | 0.00063
DEATH IN LOW MORTALITY DRGS | 144 | 2,136,175 | 0.00007 | 214 | 427,301 | 0.000501 | 126 | 961,976 | 0.00013 | 2,518 | 3,341,293 | 0.00075
DECUBITUS ULCER | 79 | 59,444 | 0.00133 | 308 | 132,028 | 0.002333 | 692 | 191,976 | 0.00360 | 106,963 | 4,935,024 | 0.02167
FAILURE TO RESCUE | 1,247 | 16,422 | 0.07593 | 657 | 11,994 | 0.054777 | 973 | 13,007 | 0.07481 | 132,208 | 711,751 | 0.18575
FOREIGN BODY LEFT IN DURING PROC | 11 | 275,937 | 0.00004 | 32 | 702,678 | 4.55E-05 | 95 | 1,394,663 | 0.00007 | 1,470 | 14,201,927 | 0.00010
IATROGENIC PNEUMOTHORAX | 105 | 259,393 | 0.00040 | 274 | 598,051 | 0.000458 | 385 | 1,245,587 | 0.00031 | 15,810 | 12,596,672 | 0.00126
INFECTION DUE TO MEDICAL CARE | 628 | 272,806 | 0.00230 | 662 | 654,920 | 0.001011 | 965 | 1,365,335 | 0.00071 | 24,805 | 12,118,478 | 0.00205
POSTOP HEMORRHAGE OR HEMATOMA | 150 | 34,588 | 0.00434 | 207 | 140,869 | 0.001469 | 275 | 178,186 | 0.00154 | 11,406 | 4,004,850 | 0.00285
POSTOP HIP FRACTURE | 0 | 31,190 | 0.00000 | 1 | 92,563 | 1.08E-05 | 14 | 236,426 | 0.00006 | 2,908 | 3,111,547 | 0.00093
POSTOP PHYSIO METABOL DERANGMNT | 8 | 16,432 | 0.00049 | 35 | 63,991 | 0.000547 | 63 | 65,469 | 0.00096 | 2,004 | 2,164,826 | 0.00093
POSTOP PE OR DVT | 63 | 34,572 | 0.00182 | 138 | 140,843 | 0.00098 | 528 | 177,749 | 0.00297 | 33,438 | 3,987,381 | 0.00839
POSTOP RESPIRATORY FAILURE | 45 | 12,762 | 0.00353 | 120 | 55,410 | 0.002166 | 86 | 61,653 | 0.00139 | 5,098 | 1,754,130 | 0.00291
POSTOP SEPSIS | 154 | 6,294 | 0.02447 | 150 | 17,519 | 0.008562 | 93 | 13,302 | 0.00699 | 6,238 | 651,491 | 0.00958
TECH DIFFICULTY W MED CARE | 285 | 275,640 | 0.00103 | 515 | 696,745 | 0.000739 | 841 | 590,352 | 0.00142 | 44,485 | 12,668,347 | 0.00351
TRANSFUSION REACTION | 2 | 275,937 | 0.00001 | 8 | 702,678 | 1.14E-05 | 8 | 1,394,663 | 0.00001 | 111 | 14,201,927 | 0.00001
WOUND DEHISCENCE | 21 | 15,564 | 0.00135 | 29 | 44,908 | 0.000646 | 38 | 50,406 | 0.00075 | 2,119 | 955,922 | 0.00222
BIRTH TRAUMA | 27,880 | 2,052,482 | 0.01358
OB TRAUMA - VAGINAL W INSTRUMENT | | | | 120 | 518 | 0.23166 | 11,563 | 55,072 | 0.20996 | 25,223 | 107,072 | 0.23557
OB TRAUMA - VAGINAL WO INSTRUMENT | | | | 403 | 3,762 | 0.107124 | 48,750 | 532,041 | 0.09163 | 71,705 | 934,521 | 0.07673
OB TRAUMA - C-SECTION | | | | 3 | 669 | 0.004484 | 439 | 108,850 | 0.00403 | 2,162 | 318,039 | 0.00680

Supplemental Table 3 reports the rate of each indicator by four age strata. This analysis is intended to provide information regarding the applicability of these indicators to the pediatric population.

Supplemental Table 4. Percentage of Indicator Numerator or Denominator Represented by Age Strata

| Age < 1 | | Age 1–14 | | Age 15–24 | | Age 25+
Label | Numer. | Denom. | Numer. | Denom. | Numer. | Denom. | Numer. | Denom.
COMPLICATIONS OF ANESTHESIA | 0.9% | 0.7% | 3.28% | 2.89% | 5.0% | 6.4% | 90.8% | 90.0%
DEATH IN LOW MORTALITY DRGS | 4.8% | 31.1% | 7.13% | 6.22% | 4.2% | 14.0% | 83.9% | 48.7%
DECUBITUS ULCER | 0.1% | 1.1% | 0.29% | 2.48% | 0.6% | 3.6% | 99.0% | 92.8%
FAILURE TO RESCUE | 0.9% | 2.2% | 0.49% | 1.59% | 0.7% | 1.7% | 97.9% | 94.5%
FOREIGN BODY LEFT IN DURING PROC | 0.7% | 1.7% | 1.99% | 4.24% | 5.9% | 8.4% | 91.4% | 85.7%
IATROGENIC PNEUMOTHORAX | 0.6% | 1.8% | 1.65% | 4.07% | 2.3% | 8.5% | 95.4% | 85.7%
INFECTION DUE TO MEDICAL CARE | 2.3% | 1.9% | 2.45% | 4.54% | 3.6% | 9.5% | 91.7% | 84.1%
POSTOP HEMORRHAGE OR HEMATOMA | 1.2% | 0.8% | 1.72% | 3.23% | 2.3% | 4.1% | 94.7% | 91.9%
POSTOP HIP FRACTURE | 0.0% | 0.9% | 0.03% | 2.67% | 0.5% | 6.8% | 99.5% | 89.6%
POSTOP PHYSIO METABOL DERANGMNT | 0.4% | 0.7% | 1.66% | 2.77% | 3.0% | 2.8% | 95.0% | 93.7%
POSTOP PE OR DVT | 0.2% | 0.8% | 0.40% | 3.24% | 1.5% | 4.1% | 97.9% | 91.9%
POSTOP RESPIRATORY FAILURE | 0.8% | 0.7% | 2.24% | 2.94% | 1.6% | 3.3% | 95.3% | 93.1%
POSTOP SEPSIS | 2.3% | 0.9% | 2.26% | 2.54% | 1.4% | 1.9% | 94.0% | 94.6%
POSTOP WOUND DEHISCENCE | 1.0% | 1.5% | 1.31% | 4.21% | 1.7% | 4.7% | 96.0% | 89.6%
TECH DIFFICULTY WITH PROCEDURE | 0.6% | 1.9% | 1.12% | 4.90% | 1.8% | 4.1% | 96.4% | 89.0%
TRANSFUSION REACTION | 1.6% | 1.7% | 6.20% | 4.24% | 6.2% | 8.4% | 86.0% | 85.7%
BIRTH TRAUMA | 100.0% | 100.0%
OB TRAUMA - VAGINAL W INSTRUMENT | | | 0.33% | 0.32% | 31.3% | 33.9% | 68.3% | 65.8%
OB TRAUMA - VAGINAL WO INSTRUMENT | | | 0.33% | 0.26% | 40.3% | 36.2% | 59.3% | 63.6%
OB TRAUMA - C-SECTION | | | 0.12% | 0.16% | 16.9% | 25.5% | 83.0% | 74.4%

Supplemental Table 4 reports the percentage of the numerator and denominator consisting of patients in four age strata. This analysis provides further information regarding the applicability of these indicators to the pediatric population.

## Supplemental Figures