# Details of Indicator Definitions

This appendix lists coding details for all indicators. It is divided into six sections (described below). For each indicator group (accepted, experimental, rejected) the definitions are provided in table form. In another section ICD-9-CM level details are presented for terms used in the tables (e.g. the codes used to define “hip fracture”). Terms are listed alphabetically and a table of contents is provided for ease of use.

ICD-9-CM codes are updated through 2001.

Section 1A contains the definition table for the Accepted hospital level indicators.

Section 1B contains the coding details for the Accepted hospital level indicators.

Section 2A contains the definition table for the Accepted area level indicators. Coding details are available in section 1B.

Section 3A contains the definition table for the Experimental indicators.

Section 3B contains the coding details for the Experimental indicators.

Section 4A contains the definition table for the Rejected indicators.

## Section 1A. Accepted Hospital-Level Indicator Definitions

Items in bold and brackets are fully specified in the ICD-9-CM and DRG listings after this table.

Indicator | Definition and Numerator | Denominator
• Complications of anesthesia | Discharges with ICD-9-CM diagnosis codes for [anesthesia complications] in any secondary diagnosis field per 100 discharges. | All [surgical] discharges.
| | Exclude patients with codes for poisoning due to anesthetics [E855.1, 968.1–4, 968.7] AND any diagnosis code for [active drug dependence], [active nondependent abuse of drugs], or [self-inflicted injury].
• Death in low mortality DRGs | All discharges with disposition of “deceased” per 100 population at risk. | All discharges in DRGs with less than 0.5% mortality rate, based on NIS 1997 [low mortality DRG]. If a DRG is divided into “without/with complications” both DRGs must have mortality rates below 0.5% to qualify for inclusion.
Indicator is stratified in 7 subgroup indicators:; 1 Adult surgical; 2 Adult medical; 3 Pediatric surgical; 4 Pediatric medical; 5 Psychiatric; 6 Obstetric; 7 Neonatal | | Exclude patients with any code for [trauma], [immunocompromised] state, or [cancer].
• Decubitus ulcer | Discharges with ICD-9-CM code of 707.0 in any secondary diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Include only patients with a length of stay of more than 4 days.
| | Exclude patients in MDC 9 or patients with any diagnosis of [hemiplegia, paraplegia, or quadriplegia].
| | Exclude patients admitted from a [long term care facility].
• Failure to rescue | All discharges with disposition of “deceased” per 100 population at risk. | Discharges with potential complications of care listed in [failure to rescue] definition (e.g., pneumonia, DVT/PE, sepsis, acute renal failure, shock/cardiac arrest, or GI hemorrhage/acute ulcer). Exclusion criteria specific to each diagnosis.
| | Exclude patients [transferred to acute care facility].
| | Exclude patients [transferred from acute care facility]
| | Exclude patients admitted from a [long-term care facility].
• Foreign body left in during procedure | Discharges with ICD-9-CM codes for [foreign body left in during procedure] in any secondary diagnosis field per 100 surgical discharges. | All [medical] and [surgical] discharges.
• Iatrogenic pneumothorax | Discharges with ICD-9-CM code of 512.1 in any secondary diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Exclude patients with any diagnosis of [trauma].
| | Exclude patients with any code indicating [thoracic surgery] or [lung or pleural biopsy] or [cardiac surgery].
• Infection due to medical care | Discharges with ICD-9-CM code of 999.3 or 996.62 in any secondary diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Exclude patients with any diagnosis code for [immunocompromised] state or [cancer].
• Postoperative hemorrhage or hematoma | Discharges with ICD-9-CM codes for [postoperative hemorrhage] or [postoperative hematoma] in any secondary diagnosis field AND code for postoperative [control of hemorrhage] or [drainage of hematoma] in any secondary procedure code field per 100 surgical discharges. | All [surgical] discharges.
| Procedure code for postoperative control of hemorrhage or hematoma must occur on the same day or after the principal procedure. | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative hip fracture | Discharges with ICD-9-CM code for [hip fracture] in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude patients who have musculoskeletal and connective tissue diseases (MDC 8).
| | Exclude patients with principal diagnosis codes for [seizure], [syncope], [stroke], [coma], [cardiac arrest], [poisoning], [trauma], [delirium and other psychoses], or [anoxic brain injury].
| | Exclude patients with any diagnosis of [metastatic cancer], [lymphoid malignancy] or [bone malignancy], [self-inflicted injury].
| | Exclude patients 17 years of age and younger.
• Postoperative physiologic and metabolic derangements | Discharges with ICD-9-CM codes for [physiologic and metabolic derangements] in any secondary diagnosis field per 100 surgical discharges. | All [elective][surgical] discharges.
| Discharges with acute renal failure (subgroup of physiologic and metabolic derangements) must be accompanied by a procedure code for dialysis (39.95, 54.98). | Exclude patients with both a diagnosis code of ketoacidosis, hyperosmolarity or other coma (subgroups of physiologic and metabolic derangements coding) AND a principal diagnosis of [diabetes].
| | Exclude patients with both a secondary diagnosis code for acute renal failure (subgroup of physiologic and metabolic derangements coding) AND a principal diagnosis of [acute myocardial infarction], [cardiac arrhythmia], [cardiac arrest], [shock], [hemorrhage] or [gastrointestinal hemorrhage].
| | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative pulmonary embolism or deep vein thrombosis | Discharges with ICD-9-CM codes for [deep vein thrombosis] or [pulmonary embolism] in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude patients with a principal diagnosis of [deep vein thrombosis].
| | Exclude all obstetric admissions (MDC 14 and 15).
| | Exclude patients with secondary procedure code 38.7 when this procedure occurs on the day of or previous to the day of the principal procedure.
• Postoperative respiratory failure | Discharges with ICD-9-CM codes for acute respiratory failure (518.81) in any secondary diagnosis field per 100 surgical discharges. | All [elective][surgical] discharges.
| (After 1999, include 518.84). | Exclude patients with respiratory or circulatory diseases (MDC 4 and MDC 5).
| | Exclude all obstetric admissions (MDC 14 and 15)
• Postoperative sepsis | Discharges with ICD-9-CM code for [sepsis] in any secondary diagnosis field per 100 discharges in the population at risk. | All [elective][surgical] discharges.
| | Exclude patients with a principal diagnosis of [infection], or any code for [immunocompromised] state, or [cancer].
| | Include only patients with a length of stay of more than three days.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Technical difficulty with procedure | Discharges with ICD-9-CM code denoting [technical difficulty] (e.g., accidental cut, puncture, perforation or laceration during a procedure) in any secondary diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Transfusion reaction | Discharges with ICD-9-CM codes for [transfusion reaction] in any secondary diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
• Postoperative wound dehiscence | Discharges with ICD-9-CM codes for reclosure of postoperative disruption of abdominal wall (54.61) in any secondary procedure field per 100 discharges. | All [abdominopelvic] surgical discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Birth trauma- injury to neonate | Discharges with ICD-9-CM codes for [birth trauma] in any diagnosis field per 100 liveborn births. | All [liveborn] infants.
| | Exclude infants with a subdural or cerebral hemorrhage (subgroup of birth trauma coding) AND any diagnosis code of [preterm infant] (denoting a birth weight of less than 2,500 g and less than 37 weeks gestation).
| | Exclude infants with injury to skeleton (767.3, 767.4) AND any diagnosis code of osteogenesis imperfecta (756.51).
• Obstetric trauma - vaginal with instrument | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 instrument assisted vaginal deliveries. | All [vaginal delivery] discharges with any procedure code for [instrument assisted delivery].
• Obstetric trauma - vaginal without instrument | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 instrument assisted vaginal deliveries. | All [vaginal delivery] discharges patients.
| | Exclude [instrument assisted delivery].
• Obstetric trauma - cesarean section | Discharges with ICD-9-CM codes for [obstetric trauma] in any diagnosis or procedure field per 100 cesarean deliveries. | All [cesarean delivery] discharges.

## Section 1B. Coding Details for Accepted Hospital-Level Indicators

Abdominopelvic | 233
Active drug dependence | 237
Active nondependent abuse of drugs | 237
Acute myocardial infarction | 237
Anesthesia complications | 238
Anoxic brain injury | 238
Birth trauma | 238
Bone malignancy | 238
Cancer | 238
Cardiac arrest | 240
Cardiac arrhythmia | 240
Cardiac surgery | 240
Cesarean delivery | 240
Coma | 240
Control of postoperative hemorrhage | 241
Deep vein thrombosis | 241
Delirium and other psychoses | 241
Diabetes | 241
Drainage of hematoma | 241
Elective | 242
Foreign body left in during procedure | 242
Gastrointestinal (GI) hemorrhage | 242
Hemiplegia, paraplegia, or quadriplegia | 243
Hemorrhage | 243
Hip fracture | 243
Immunocompromised | 243
Indications of current drug abuse | 244
Infection | 245
Instrument assisted delivery | 245
Liveborn | 245
Long term care facility | 246
Low mortality | 246
Lung or pleural biopsy | 248
Lymphoid malignancy | 248
Medical | 248
Metastatic cancer | 251
Obstetric trauma | 251
Physiologic and metabolic derangements | 251
Poisoning | 252
Postoperative hematoma | 253
Postoperative hemorrhage or hematoma | 253
Preterm infant | 253
Pulmonary embolism | 253
Seizure | 253
Self inflicted injury | 253
Sepsis | 254
Shock | 254
Stroke | 254
Surgical | 254
Syncope | 257
Technical difficulty | 257
Thoracic surgery | 258
Transferred to acute care facility | 259
Transferred from acute care facility | 259
Transfusion reaction | 259
Trauma | 259
Vaginal delivery | 262
FTR-FAILURE TO RESCUE | 262

Abdominopelvic
ICD-9-CM procedure codes:
38.04 | INCISION OF AORTA
38.06 | INCISION OF ABDOMINAL ARTERIES
38.07 | INCISION OF ABDOMINAL VEINS
38.14 | ENDARTERECTOMY OF AORTA
38.16 | ENDARTERECTOMY OF ABDOMINAL ARTERIES
38.34 | RESECTION OF AORTA WITH ANASTOMOSIS
38.36 | RESECTION OF ABDOMINAL ARTERIES WITH ANASTOMOSIS
38.37 | RESECTION OF ABDOMINAL VEINS WITH ANASTOMOSIS
38.44 | RESECTION OF AORTA, ABDOMINAL WITH REPLACEMENT
38.46 | RESECTION OF ABDOMINAL ARTERIES WITH REPLACEMENT
38.47 | RESECTION OF ABDOMINAL VEINS WITH REPLACEMENT
38.57 | LIGATION AND STRIPPING OF VARICOSE VEINS, ABDOMINAL VEINS
38.64 | OTHER EXCISION OF AORTA, ABDOMINAL
38.66 | OTHER EXCISION OF ABDOMINAL ARTERIES
38.67 | OTHER EXCISION OF ABDOMINAL VEINS
38.84 | OTHER SURGICAL OCCLUSION OF AORTA, ABDOMINAL
38.86 | OTHER SURGICAL OCCLUSION OF ABDOMINAL ARTERIES
38.87 | OTHER SURGICAL OCCLUSION OF ABDOMINAL VEINS
39.1 | INTRA-ABDOMINAL VENOUS SHUNT
39.24 | AORTA-RENAL BYPASS
39.25 | AORTA-ILIAC-FEMORAL BYPASS
39.26 | OTHER INTRA-ABDOMINAL VASCULAR SHUNT OR BYPASS
40.52 | RADICAL EXCISION OF PERIAORTIC LYMPH NODES
40.53 | RADICAL EXCISION OF ILIAC LYMPH NODES
41.2 | SPLENOTOMY
41.33 | OPEN BIOPSY OF SPLEEN
41.41 | MARSUPIALIZATION OF SPLENIC CYST
41.42 | EXCISION OF LESION OR TISSUE OF SPLEEN
41.43 | PARTIAL SPLENECTOMY
41.5 | TOTAL SPLENECTOMY
41.93 | EXCISION OF ACCESSORY SPLEEN
41.94 | TRANSPLANTATION OF SPLEEN
41.95 | REPAIR AND PLASTIC OPERATIONS ON SPLEEN
41.99 | OTHER OPERATIONS ON SPLEEN
42.40 | ESOPHAGECTOMY, NOS
42.41 | PARTIAL ESOPHAGECTOMY
42.42 | TOTAL ESOPHAGECTOMY
42.53 | INTRATHORACIC ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF SMALL BOWEL
42.54 | OTHER INTRATHORACIC ESOPHAGOENTEROSTOMY
42.55 | INTRATHORACIC ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF COLON
42.56 | OTHER INTRATHORACIC ESOPHAGOCOLOSTOMY
42.63 | ANTESTERNAL ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF SMALL BOWEL
42.64 | OTHER ANTESTERNAL ESOPHAGOENTEROSTOMY
42.65 | ANTESTERNAL ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF COLON
42.66 | OTHER ANTESTERNAL ESOPHAGOCOLOSTOMY
42.91 | LIGATION OF ESOPHAGEAL VARICES
43.0 | GASTROSTOMY
43.19 | OTHER GASTROSTOMY
43.3 | PYLOROMYOTOMY
43.42 | LOCAL EXCISION OF OTHER LESION OR TISSUE OF STOMACH
43.49 | OTHER DESTRUCTION OF LESION OR TISSUE OF STOMACH
43.5 | PARTIAL GASTRECTOMY WITH ANASTOMOSIS TO ESOPHAGUS
43.6 | PARTIAL GASTRECTOMY WITH ANASTOMOSIS TO DUODENUM
43.7 | PARTIAL GASTRECTOMY WITH ANASTOMOSIS TO JEJUNUM
43.81 | PARTIAL GASTRECTOMY WITH JEJUNA TRANSPOSITION
43.89 | OTHER PARTIAL GASTRECTOMY
43.91 | TOTAL GASTRECTOMY WITH INTESTINAL INTERPOSITION
43.99 | OTHER TOTAL GASTRECTOMY
44.00 | VAGOTOMY, NOS
44.01 | TRUNCAL VAGOTOMY
44.02 | HIGHLY SELECTIVE VAGOTOMY
44.03 | OTHER SELECTIVE VAGOTOMY
44.11 | TRANSABDOMINAL GASTROSCOPY
44.15 | OPEN BIOPSY OF STOMACH
44.21 | DILATION OF PYLORUS BY INCISION
44.29 | OTHER PYLOROPLASTY
44.31 | HIGH GASTRIC BYPASS
44.39 | OTHER GASTROENTEROSTOMY
44.40 | SUTURE OF PEPTIC ULCER, NOS
44.41 | SUTURE OF GASTRIC ULCER SITE
44.42 | SUTURE OF DUODENAL ULCER SITE
44.5 | REVISION OF GASTRIC ANASTOMOSIS
44.61 | SUTURE OF LACERATION OF STOMACH
44.63 | CLOSURE OF OTHER GASTRIC FISTULA
44.64 | GASTROPEXY
44.65 | ESOPHAGOGASTROPLASTY
44.66 | OTHER PROCEDURES FOR CREATION OF ESOPHAGOGASTRIC SPHINCTERIC COMPETENCE
44.69 | OTHER REPAIR OF STOMACH
44.91 | LIGATION OF GASTRIC VARICES
44.92 | INTRAOPERATIVE MANIPULATION OF STOMACH
45.00 | INCISION OF INTESTINE, NOS
45.01 | INCISION OF DUODENUM
45.02 | OTHER INCISION OF SMALL INTESTINE
45.03 | INCISION OF LARGE INTESTINE
45.31 | OTHER LOCAL EXCISION OF LESION OF DUODENUM
45.32 | OTHER DESTRUCTION OF LESION OF DUODENUM
45.33 | LOCAL EXCISION OF LESION OR TISSUE OF SMALL INTESTINE, EXCEPT DUODENUM
45.34 | OTHER DESTRUCTION OF LESION OF SMALL INTESTINE, EXCEPT DUODENUM
45.41 | EXCISION OF LESION OR TISSUE OF LARGE INTESTINE
45.49 | OTHER DESTRUCTION OF LESION OF LARGE INTESTINE
45.50 | ISOLATION OF INTESTINAL SEGMENT, NOS
45.51 | ISOLATION OF SEGMENT OF SMALL INTESTINE
45.52 | ISOLATION OF SEGMENT OF LARGE INTESTINE
45.61 | MULTIPLE SEGMENTAL RESECTION OF SMALL INTESTINE
45.62 | OTHER PARTIAL RESECTION OF SMALL INTESTINE
45.63 | TOTAL REMOVAL OF SMALL INTESTINE
45.71 | MULTIPLE SEGMENTAL RESECTION OF LARGE INTESTINE
45.72 | CESECTOMY
45.73 | RIGHT HEMICOLECTOMY
45.74 | RESECTION OF TRANSVERSE COLON
45.75 | LEFT HEMICOLECTOMY
45.76 | SIGMOIDECTOMY
45.79 | OTHER PARTIAL EXCISION OF LARGE INTESTINE
45.8 | TOTAL INTRA-ABDOMINAL COLECTOMY
45.90 | INTESTINAL ANASTOMOSIS, NOS
45.91 | SMALL-TO-SMALL INTESTINAL ANASTOMOSIS
45.92 | ANASTOMOSIS OF SMALL INTESTINE TO RECTAL STUMP
45.93 | OTHER SMALL-TO-LARGE INTESTINAL ANASTOMOSIS
45.94 | LARGE-TO-LARGE INTESTINAL ANASTOMOSIS
45.95 | ANASTOMOSIS TO ANUS
46.01 | EXTERIORIZATION OF SMALL INTESTINE
46.03 | EXTERIORIZATION OF LARGE INTESTINE
46.10 | COLOSTOMY, NOS
46.11 | TEMPORARY COLOSTOMY
46.13 | PERMANENT COLOSTOMY
46.20 | ILEOSTOMY, NOS
46.21 | TEMPORARY ILESOSTOMY
46.22 | CONTINENT ILEOSTOMY
46.23 | OTHER PERMANENT ILEOSTOMY
46.40 | REVISION OF INTESTINA STOMA, NOS
46.41 | REVISION OF STOMA OF SMALL INTESTINE
46.42 | REPAIR OF PERICOLOSTOMY HERNIA
46.43 | OTHER REVISION OF STOMA OF LARGE INTESTINE
46.50 | CLOSURE OF INTESTINAL STOMA, NOS
46.51 | CLOSURE OF STOMA OF SMALL INTESTINE
46.52 | CLOSURE OF STOMA OF LARGE INTESTINE
46.60 | FIXATION OF INTESTINE, NOS
46.61 | FIXATION OF SMALL INTESTINE TO ABDOMINAL WALL
46.62 | OTHER FIXATION OF SMALL INTESTINE
46.63 | FIXATION OF LARGE INTESTINE TO ABDOMINAL WALL
46.64 | OTHER FIXATION OF LARGE INTESTINE
46.72 | CLOSURE OF FISTULA OF DUODENUM
46.74 | CLOSURE OF FISTULA OF SMALL INTESTINE, EXCEPT DUODENUM
46.76 | CLOSURE OF FISTULA OF LARGE INTESTINE
46.80 | INTRA-ABDOMINAL MANIPULATION OF INTESTINE, NOS
46.81 | INTRA-ABDOMINAL MANIPULATION OF SMALL INTESTINE
46.82 | INTRA-ABDOMINAL MANIPULATION OF LARGE INTESTINE
46.91 | MYOTOMY OF SIGMOID COLON
46.92 | MYOTOMY OF OTHER PARTS OF COLON
46.93 | REVISION OF ANASTOMOSIS OF SMALL INTESTINE
46.94 | REVISION OF ANASTOMOSIS OF LARGE INTESTINE
46.99 | OTHER OPERATIONS ON INTESTINES
47.09 | OTHER APPENDECTOMY
47.19 | OTHER INCIDENTAL APPENDECTOMY
47.2 | DRAINAGE OF APPENDICEAL ABSCESS
47.91 | APPENDECTOMY
47.92 | CLOSURE OF APPENDICEAL FISTULA
47.99 | OTHER OPERATION APPENDIX
48.41 | SUBMUCOSAL RESECTION OF RECTUM
48.49 | OTHER PULL-THROUGH RESECTION OF RECTUM
48.5 | ABDOMINOPERINEAL RESECTION OF RECTUM
48.75 | ABDOMINAL PROCTOPEXY
50.0 | HEPATOTOMY
50.12 | OPEN BIOPSY OF LIVER
50.21 | MARSUPIALIZATION OF LESION OF LIVER
50.22 | PARTIAL HEPATECTOMY
50.29 | OTHER DESTRUCTION OF LESION OF LIVER
50.3 | LOBECTOMY OF LIVER
50.4 | TOTAL HEPATECTOMY
50.51 | AUXILIARY LIVER TRANSPLANT
50.59 | OTHER TRANSPLANT OF LIVER
50.69 | OTHER REPAIR OF LIVER
51.03 | OTHER CHOLECYSTOSTOMY
51.04 | OTHER CHOLECYSTOTOMY
51.13 | OPEN BIOPSY OF GALLBLADDER OR BILE DUCTS
51.21 | OTHER PARTIAL CHOLECYSTECTOMY
51.22 | CHOLECYSTECTOMY
51.31 | ANASTOMOSIS OF GALLBLADDER TO HEPATIC DUCTS
51.32 | ANASTOMOSIS OF GALLBLADDER TO INTESTINE
51.33 | ANASTOMOSIS OF GALLBLADDER TO PANCREAS
51.34 | ANASTOMOSIS OF GALLBLADDER TO STOMACH
51.35 | OTHER GALLBLADDER ANASTOMOSIS
51.36 | CHOLEDOCHOENTEROSTOMY
51.37 | ANASTOMOSIS OF HEPATIC DUCT TO GASTROINTESTINAL TRACT
51.39 | OTHER BILE DUCT ANASTOMOSIS
51.41 | COMMON DUCT EXPLORATION FOR REMOVAL OF CALCULUS
51.42 | COMMON DUCT EXPLORATION FOR RELIEF OF OTHER OBSTRUCTION
51.43 | INSERTION OF CHOLEDOCHOHEPATIC TUBE FOR DECOMPRESSION
51.49 | INCISION OF OTHER BILE DUCTS FOR RELIEF OF OBSTRUCTION
51.51 | EXPLORATION OF COMMON DUCT
51.59 | INCISION OF OTHER BILE DUCT
51.61 | EXCISION OF CYSTIC DUCT REMNANT
51.62 | EXCISION OF AMPULLA OF VATER WITH REIMPLANTATION OF COMMON DUCT
51.63 | OTHER EXCISION OF COMMON DUCT
51.69 | EXCISION OF OTHER BILE DUCT
51.71 | SIMPLE SUTURE OF COMMON BILE DUCT
51.72 | CHOLEDOCHOPLASTY
51.79 | REPAIR OF OTHER BILE DUCTS
51.81 | DILATION OF SPHINCTER OF ODDI
51.82 | PANCREATIC SPHINCTEROTOMY
51.83 | PANCREATIC SPHINCTEROPLASTY
51.89 | OTHER OPERATIONS ON SPHINCTER OF ODDI
51.92 | CLOSURE OF CHOLECYSTOSTOMY
51.93 | CLOSURE OF OTHER BILIARY FISTULA
51.94 | REVISION OF ANASTOMOSIS OF BILIARY TRACT
51.95 | REMOVAL OF PROSTHETIC DEVICE FROM BILE DUCT
51.99 | OTHER OPERATIONS ON BILIARY TRACT
52.01 | DRAINAGE OF PANCREATIC CYST BY CATHETER
52.09 | OTHER PANCREATOTOMY
52.12 | OPEN BIOPSY OF PANCREAS
52.22 | OTHER EXCISION OR DESTRUCTION OF LESION OR TISSUE OF PANCREAS OR PANCREATIC DUCT
52.3 | MARSUPIALIZATION OF PANCREATIC CYST
52.4 | INTERNAL DRAINAGE OF PANCREATIC CYST
52.51 | PROXIMAL PANCREATECTOMY
52.52 | DISTAL PANCREATECTOMY
52.53 | RADIAL SUBTOTAL PANCREATECTOMY
52.59 | OTHER PARTIAL PANCREATECTOMY
52.6 | TOTAL PANCREATECTOMY
52.7 | RADICAL PANCREATICODUODENECTOMY
52.80 | PANCREATIC TRANSPLANT, NOS
52.81 | REIMPLANTATION
52.82 | HOMOTRANSPLANT OF PANCREAS
52.83 | HETEROTRANSPLANT OF PANCREAS
52.92 | CANNULATION OF PANCREATIC DUCT
52.95 | OTHER REPAIR OF PANCREAS
52.96 | ANASTOMOSIS OF PANCREAS
52.99 | OTHER OPERATIONS ON PANCREAS
53.00 | UNILATERAL REPAIR OF INGUINAL HERNIA, NOS
53.01 | REPAIR OF DIRECT INGUINAL HERNIA
53.02 | REPAIR OF INDIRECT INGUINAL HERNIA
53.03 | AIR OF DIRECT INGUINAL HERNIA
53.04 | REPAIR OF INDIRECT INGUINAL HERNIA WITH GRAFT OR PROSTHESIS
53.05 | REPAIR OF INGUINAL HERNIA WITH GRAFT OR PROSTHESIS, NOS
53.10 | BILATERAL REPAIR OF INGUINAL HERNIA, NOS
53.11 | BILATERAL REPAIR OF DIRECT INGUINAL HERNIA
53.12 | BILATERAL REPAIR OF INDIRECT INGUINAL HERNIA
53.13 | BILATERAL REPAIR OF INGUINAL HERNIA, ONE DIRECT AND ONE INDIRECT
53.14 | BILATERAL REPAIR OF DIRECT INGUINAL HERNIA WITH GRAFT OR PROSTHESIS
53.15 | BILATERAL REPAIR OF INDIRECT INGUINAL HERNIA WITH GRAFT OR PROSTHESIS
53.16 | BILATERAL REPAIR OF INGUINAL HERNIA, ONE DIRECT AND ONE INDIRECT, WITH GRAFT OR PROSTHESIS
53.17 | BILATERAL INGUINAL HERNIA REPAIR WITH GRAFT OR PROSTHESIS, NOS
53.21 | UNILATERAL REPAIR OF FEMORAL HERNIA
53.29 | OTHER UNILATERAL FEMORAL HERNIORRHAPHY
53.31 | BILATERAL REPAIR OF FEMORAL HERNIA WITH GRAFT OR PROSTHESIS
53.39 | OTHER BILATERAL FEMORAL HERNIORRHAPHY
53.41 | REPAIR OF UMBILICAL HERNIA WITH PROSTHESIS
53.49 | OTHER UMBILICAL HERNIORRHAPHY
53.51 | INCISIONAL HERNIA REPAIR
53.59 | REPAIR OF OTHER HERNIA OF ANTERIOR ABDOMINAL WALL
53.61 | INCISIONAL HERNIA REPAIR WITH PROSTHESIS
53.69 | REPAIR OF OTHER HERNIA OF ANTERIOR ABDOMINAL WALL WITH PROSTHESIS
53.7 | REPAIR OF DIAPHRAGMATIC HERNIA, ABDOMINAL APPROACH
54.0 | INCISION OF ABDOMINAL WALL
54.11 | EXPLORATORY LAPAROTOMY
54.19 | OTHER LAPAROTOMY
54.22 | BIOPSY OF ABDOMINAL WALL OR UMBILICUS
54.23 | BIOPSY OF PERITONEUM
54.3 | EXCISION OR DESTRUCTION OF LESION OR TISSUE OF ABDOMINAL WALL OR UMBILICUS
54.4 | EXCISION OR DESTRUCTION OF PERITONEAL TISSUE
54.59 | OTHER LYSIS OF PERITONEAL ADHESIONS
54.63 | OTHER SUTURE OF ABDOMINAL WALL
54.64 | SUTURE OF PERITONEUM
54.71 | REPAIR OF GASTROSCHISIS
54.72 | OTHER REPAIR OF ABDOMINAL WALLS
54.73 | OTHER REPAIR OF PERITONEUM
54.74 | OTHER REPAIR OF OMENTUM
54.75 | OTHER REPAIR OF MESENTERY
54.92 | REMOVAL OF FOREIGN BODY FROM PERITONEAL CAVITY
54.93 | CREATION OF CUTANEOPERITONEAL FISTULA
54.94 | CREATION OF PERITONEOVASCULAR SHUNT
54.95 | INCISION OF PERITONEUM
55.51 | NEPHROURETERECTOMY
55.52 | NEPHRECTOMY OF REMAINING KIDNEY
55.53 | REMOVAL OF TRANSPLANTED OR REJECTED KIDNEY
55.54 | BILATERAL NEPHRECTOMY
55.61 | RENAL AUTOTRANSPLANTATION
55.69 | ULCERATIVE COLITIS, UNSPECIFIED
55.7 | NEPHROPEXY
55.83 | CLOSURE OF OTHER FISTULA OF KIDNEY
55.84 | REDUCTION OF TORSION OF RENAL
55.85 | SYMPHYSIOTOMY FOR HORESHOE KIDNEY
55.86 | ANASTOMOSIS OF KIDNEY
55.87 | CORRECTION OF URETEROPELVIC JUNCTION
55.91 | DECAPSULATION OF KIDNEY
55.97 | IMPLANTATION OR REPLACEMENT OF MECHANICAL KIDNEY
55.98 | REMOVAL OF MECHANICAL KIDNEY
56.51 | FORMATION OF CUTANEOUS URETERO-ILEOSTOMY
56.52 | REVISION OF CUTANEOUS URETERO-ILEOSTOMY
56.61 | FORMATION OF OTHER CUTANEOUS URETEROSTOMY
56.62 | REVISION OF OTHER CUTANEOUS URETEROSTOMY
56.71 | URINARY DIVERSION TO INTESTINE
56.72 | REVISION OF URETEROINTESTINAL ANASTOMOSIS
56.73 | NEPHROCYSTANASTOMOSIS, NOS
56.74 | URETERONEOXYSTOSTOMY
56.75 | TRANSURETEROURETEROSTOMY
56.83 | CLOSURE OF URETEROSTOMY
56.84 | CLOSURE OF OTHER FISTULA OF URETER
56.85 | URETEROPEXY
56.86 | REMOVAL OF LIGATURE FROM URETER
56.89 | OTHER REPAIR OF URETER
56.95 | LIGATION OF URETER
57.71 | RADICAL CYSTECTOMY
57.79 | OTHER TOTAL CYSTECTOMY
57.82 | CLOSURE OF CYSTOSTOMY
57.87 | RECONSTRUCTION OF URINARY BLADDER
59.00 | RETROPERITONEAL DISSECTION, NOS
59.02 | OTHER LYSIS OF PERIRENAL OR PERIURETERAL ADHESIONS
59.09 | OTHER INCISION OF PERIRENAL OR PERIURETERAL TISSUE
60.12 | OPEN BIOPSY OF PROSTATE
60.14 | OPEN BIOPSY OF SEMINAL VESICLES
60.15 | BIOPSY OF PERIPROSTATIC TISSUE
60.3 | SUPRAPUBIC PROSTATECTOMY
60.4 | RETROPUBIC PROSTATECTOMY
60.5 | RADICAL PROSTATECTOMY
60.61 | LOCAL EXCISION OF LESION OF PROSTATE
60.72 | INCISION OF SEMINAL VESICLE
60.73 | EXCISION OF SEMINAL VESICLE
60.79 | OTHER OPERATIONS ON SEMINAL VESICLES
60.93 | REPAIR OF PROSTATE
65.09 | OTHER OOPHORECTOMY
65.12 | OTHER BIOPSY OF OVARY
65.21 | MARSUPIALIZATION OF OVARIAN CYST
65.22 | WEDGE RESECTION OF OVARY
65.29 | OTHER LOCAL EXCISION OR DESTRUCTION OF OVARY
65.39 | OTHER UNLILATERAL OOPHORECTOMY
65.49 | OTHER UNILATERAL SALPINGOOPHORECTOMY
65.51 | OTHER REMOVAL OF BOTH OVARIES AT SAME OPERATIVE EPISODE
65.52 | OTHER REMOVAL OF REMAINING OVARY
65.61 | OTHER REMOVAL OF BOTH OVARIES AND TUBES AT SAME OPERATIVE EPISODE
65.62 | OTHER REMOVAL OF REMAINING OVARY AND TUBE
65.71 | OTHER SIMPLE SUTURE OF OVARY
65.72 | OTHER REIMPLANTATION OF OVARY
65.73 | OTHER SALPINGO OOPHOROPLASTY
65.79 | OTHER REPAIR OF OVARY
65.89 | OTHER LYSIS OF ADHESIONS OF OVARY AND FALLOPIAN TUBE
65.92 | TRANSPLANTATION OF OVARY
65.93 | MANUAL RUPTURE OF OVARIAN CYST
65.94 | OVARIAN DENERVATION
65.95 | RELEASE OF TORSION OF OVARY
65.99 | OTHER OPERATIONS ON OVARY
66.01 | SALPINGOTOMY
66.02 | SALPINGOSTOMY
66.31 | OTHER BILATERAL LIGATION AND CRUSHING OF FALLOPIAN TUBES
66.32 | OTHER BILATERAL LIGATION AND DIVISION OF FALLOPIAN TUBES
66.39 | OTHER BILATERAL DESTRUCTION OR OCCLUSION OF FALLOPIAN TUBES
66.4 | TOTAL UNILATERAL SALPINGECTOMY
66.51 | REMOVAL OF BOTH FALLOPIAN TUBES AT SAME OPERATIVE EPISODE
66.52 | REMOVAL OF REMAINING FALLOPIAN TUBE
66.61 | EXCISION OR DESTRUCTION OF LESION OF FALLOPIAN TUBE
66.62 | SALPINGECTOMY WITH REMOVAL OF TUBAL PREGNANCY
66.63 | BILATERAL PARTIAL SALPINGECTOMY, NOS
66.69 | OTHER PARTIAL SALPINGECTOMY
66.71 | SIMPLE SUTURE OF FALLOPIAN TUBE
66.72 | SALPINGO-OOPHOROSTOMY
66.73 | SALPINGO-SALPINGOSTOMY
66.74 | SALPINGO-UTEROSTOMY
66.79 | OTHER REPAIR OF FALLOPIAN TUBE
66.92 | UNILATERAL DESTRUCTION OR OCCLUSION OF FALLOPIAN TUBE
66.97 | BURYING OF FIMBRIAE IN UTERINE WALL
68.0 | OTHER INCISION AND EXCISION OF UTERUS
68.13 | OPEN BIOPSY OF UTERUS
68.14 | OPEN BIOPSY OF UTERINE LIGAMENTS
68.3 | SUBTOTAL ABDOMINAL HYSTERECTOMY
68.4 | TOTAL ABDOMINAL HYSTERECTOMY
68.6 | RADICAL ABDOMINAL HYSTERECTOMY
68.8 | PELVIC EVISCERATION
69.22 | OTHER UTERINE SUSPENSION
69.3 | PARACERVICAL UTERINE DENERVATION
69.41 | SUTURE OF LACERATION OF UTERUS
69.42 | CLOSURE OF FISTULA OF UTERUS
69.49 | OTHER REPAIR OF UTERUS
Active drug dependence
ICD-9-CM diagnosis codes:
304.00 | OPIOID TYPE DEPENDENCE-UNSPECIFIED
304.01 | OPIOID TYPE DEPENDENCE-CONTINUOUS
304.02 | OPIOID TYPE DEPENDENCE-EPISODIC
304.10 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC DEPENDENCE - UNSPECIFIED
304.11 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC DEPENDENCE - CONTINUOUS
304.12 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC DEPENDENCE, - EPISODIC
304.20 | COCAINE DEPENDENCE-UNSPECIFIED
304.21 | COCAINE DEPENDENCE-CONTINUOUS
304.22 | COCAINE DEPENDENCE-EPISODIC
304.30 | CANNABIS DEPENDENCE UNSPECIFIED
304.31 | CANNABIS DEPENDENCE CONTINUOUS
304.32 | CANNABIS DEPENDENCE EPISODIC
304.40 | AMPHETAMINE AND OTHER PSYCHO STIMULANT DEPENDENCE-UNSPECIFIED
304.41 | AMPHETAMINE AND OTHER PSYCHO STIMULANT DEPENDENCE-CONTINUOUS
304.42 | AMPHETAMINE AND OTHER PSYCHO STIMULANT DEPENDENCE-EPISODIC
304.50 | HALLUCINOGEN DEPENDENCE UNSPECIFIED
304.51 | HALLUCINOGEN DEPENDENCE-CONTINUOUS
304.52 | HALLUCINOGEN DEPENDENCE - EPISODIC
304.60 | OTHER SPECIFIED DRUG DEPENDENCE - UNSPECIFIED
304.61 | OTHER SPECIFIED DRUG DEPENDENCE - CONTINUOUS
304.62 | OTHER SPECIFIED DRUG DEPENDENCE - EPISODIC
304.70 | COMBINATIONS OF OPIOID TYPE DRUG WITH ANY OTHER - UNSPECIFIED
304.71 | COMBINATIONS OF OPIOID TYPE DRUG WITH ANY OTHER - CONTINUOUS
304.72 | COMBINATIONS OF OPIOID TYPE DRUG WITH ANY OTHER - EPISODIC
304.80 | COMBINATIONS OF DRUG EXCLUDING OPIOID TYPE DRUG - UNSPECIFIED
304.81 | COMBINATIONS OF DRUG EXCLUDING OPIOID TYPE DRUG - CONTINUOUS
304.82 | COMBINATIONS OF DRUG EXCLUDING OPIOID TYPE DRUG - EPISODIC
304.90 | UNSPECIFIED DRUG DEPENDENCE - UNSPECIFIED
304.91 | UNSPECIFIED DRUG DEPENDENCE - CONTINUOUS
304.92 | UNSPECIFIED DRUG DEPENDENCE - EPISODIC
Active nondependent abuse of drugs
ICD-9-CM diagnosis codes:
305.00 | ALCOHOL ABUSE-UNSPECIFIED
305.01 | ALCOHOL ABUSE-CONTINUOUS
305.02 | ALCOHOL ABUSE-EPISODIC
305.10 | TOBACCO USE DISORDER-UNSPECIFIED
305.11 | TOBACCO USE DISORDER - CONTINUOUS
305.12 | TOBACCO USE DISORDER -EPISODIC
305.20 | CANNABIS ABUSE-UNSPECIFIED
305.21 | CANNABIS ABUSE-CONTINUOUS
305.22 | CANNABIS ABUSE-EPISODIC
305.30 | HALLUCINOGEN ABUSE- UNSPECIFIED
305.31 | HALLUCINOGEN ABUSE-CONTINUOUS
305.32 | HALLUCINOGEN ABUSE- EPISODIC
305.40 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE-UNSPECIFIED
305.41 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE-CONTINUOUS
305.42 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE-EPISODIC
305.50 | OPIOID ABUSE-UNSPECIFIED
305.51 | OPIOD ABUSE-CONTINUOUS
305.52 | OPIOID ABUSE-EPISODIC
305.60 | COCAINE ABUSE-UNSPECIFIED
305.61 | COCAINE ABUSE-CONTINUOUS
305.62 | COCAINE ABUSE-EPISODIC
305.70 | AMPHETAMINE OR RELATED ACTING SYMPATHOMIMETIC ABUSE-UNSPECIFIED
305.71 | AMPHETAMINE OR RELATED ACTING SYMPATHOMIMETIC ABUSE-CONTINUOUS
305.72 | AMPHETAMINE OR RELATED ACTING SYMPATHOMIMETIC ABUSE - EPISODIC
305.80 | ANTIDEPRESSANT TYPE ABUSE-UNSPECIFIED
305.81 | ANTIDEPRESSANT TYPE ABUSE-CONTINUOUS
305.82 | ANTIDEPRESSANT TYPE ABUSE-EPISODIC
305.90 | OTHER, MIXED, OR UNSPECIFIED DRUG ABUSE-UNSPECIFIED
305.91 | OTHER, MIXED, OR UNSPECIFIED DRUG ABUSE- CONTINUOUS
305.92 | OTHER, MIXED, OR UNSPECIFIED DRUG ABUSE- EPISODIC
Acute myocardial infarction
ICD-9-CM diagnosis codes:
410.00 | AMI OF ANTEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.01 | AMI OF ANTEROLATERAL WALL - INITIAL EPISODE OF CARE
410.10 | AMI OF OTHER ANTERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.11 | AMI OF OTHER ANTERIOR WALL - INITIAL EPISODE OF CARE
410.20 | AMI OF INFEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.21 | AMI OF INFEROLATERAL WALL - INITIAL EPISODE OF CARE
410.30 | AMI OF INFEROPOSTERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.31 | AMI OF INFEROPOSTERIOR WALL - INITIAL EPISODE OF CARE
410.40 | AMI OF INFERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.41 | AMI OF INFERIOR WALL - INITIAL EPISODE OF CARE
410.50 | AMI OF OTHER LATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.51 | AMI OF OTHER LATERAL WALL - INITIAL EPISODE OF CARE
410.60 | AMI TRUE POSTERIOR WALL INFARCTION - EPISODE OF CARE UNSPECIFIED
410.61 | AMI TRUE POSTERIOR WALL INFARCTION - INITIAL EPISODE OF CARE
410.70 | AMI SUBENDOCARDIAL INFARCTION - EPISODE OF CARE UNSPECIFIED
410.71 | AMI SUBENDOCARDIAL INFARCTION - INITIAL EPISODE OF CARE
410.80 | AMI OF OTHER SPECIFIED SITES - EPISODE OF CARE UNSPECIFIED
410.81 | AMI OF OTHER SPECIFIED SITES - INITIAL EPISODE OF CARE
410.90 | AMI UNSPECIFIED SITE - EPISODE OF CARE UNSPECIFIED
410.91 | AMI UNSPECIFIED SITE - INITIAL EPISODE OF CARE
Anesthesia complications
ICD-9-CM diagnosis codes:
E876.3 | OTHER AND UNSPECIFIED MISADVENTURES DURING MEDICAL CARE, ENDOTRACHEAL TUBE WRONGLY PLACED DURING ANESTHETIC PROCEDURE
E855.1 | OTHER NERVOUS SYSTEM DEPRESSANTS
OTHER CENTRAL NERVOUS SYSTEM DEPRESSANTS AND ANESTHETICS:
E938.1 | HALOTHANE
E938.2 | OTHER GASEOUS ANESTHETICS
E938.3 | INTRAVENOUS ANESTHETICS
E938.4 | OTHER AND UNSPECIFIED GENERAL\ANESTHETICS
E938.5 | SURFACE AND INFILTRATION ANESTHETICS
E938.6 | PERIPHERAL NERVE AND PLEXUS BLOCKING ANESTHETICS
E938.7 | SPINAL ANESTHETICS
E938.9 | OTHER AND UNSPECIFIED LOCAL ANESTHETICS
POISONING BY OTHER CENTRAL NERVOUS SYSTEM DEPRESSANTS AND ANESTHETICS:
968.1 | HALOTHANE
968.2 | OTHER GASEOUS ANESTHETICS
968.3 | INTRAVENEOUS ANESTHETICS
968.4 | OTHER AND UNSPECIFIED GENERAL ANESTHETICS
968.7 | SPINAL ANESTHETICS
Anoxic brain injury
ICD-9-CM diagnosis codes:
348.1 | ANOXIC BRAIN DAMAGE
Birth trauma
ICD-9-CM diagnosis codes:
767.0 | SUBDURAL AND CEREBRAL HEMORRHAGE (DUE TO TRAUMA OR TO INTRAPARTUM ANOXIA OR HYPOXIA)
767.3 | INJURIES TO SKELETON (EXCLUDES CLAVICLE)
767.4 | INJURY TO SPINE AND SPINAL CORD
767.7 | OTHER CRANIAL AND PERIPHERAL NERVE INJURIES
767.8 | OTHER SPECIFIED BIRTH TRAUMA
767.9 | BIRTH TRAUMA, UNSPECIFIED
Bone malignancy
ICD-9-CM diagnosis codes (all 4^th^ and 5^th^ digits) :
170 | MALIGNANT NEOPLASM OF BONE AND ARTICULAR CARTILAGE
Cancer
ICD-9-CM diagnosis codes( all 4^th^ and 5^th^ digits):
140 | MALIGNANT NEOPLASM OF LIP
141 | MALIGNANT NEOPLASM OF TONGUE
142 | MALIGNANT NEOPLASM OF MAJORITY SALIVARY GLANDS
143 | MALIGNANT NEOPLASM OF GUM
144 | MALIGNANT NEOPLASM OF FLOOR OF MOUTH
145 | MALIGNANT NEOPLASM OF OTHER AND UNSPECIFIED PARTS OF MOUTH
146 | MALIGNANT NEOPLASM OF OROPHARYNX
147 | MALIGNANT NEOPLASM OF NASOPHARYNX
148 | MALIGNANT NEOPLASM OF HYPOPHARYNX
149 | MALIGNANT NEOPLASM OF OTHER AND ILL-DEFINED SITES WITHIN THE LIP, ORAL CAVITY, AND PHARYNX
150 | MALIGNANT NEOPLASM OF ESOPHAGUS
151 | MALIGNANT NEOPLASM OF STOMACH
152 | MALIGNANT NEOPLASM OF SMALL INTESTINE, INCLUDING DUODENUM
153 | MALIGNANT NEOPLASM OF COLON
154 | MALIGNANT NEOPLASM OF RECTUM, RECTOSIGMOID JUNCTION, AND ANUS
155 | MALIGNANT NEOPLASM OF LIVER AND INTRAHEPATIC BILE DUCTS
156 | MALIGNANT NEOPLASM OF GALLBLADDER AND EXTRAHEPATIC BILE DUCTS
157 | MALIGNANT NEOPLASM OF PANCREAS
158 | MALIGNANT NEOPLASM OF RETROPERITONEUM AND PERITONEUM
159 | MALIGNANT NEOPLASM OF OTHER AND ILL-DEFINED SITES WITHIN THE DIGESTIVE ORGANS AND PERITONEUM
160 | MALIGNANT NEOPLASM OF NASAL CAVITIES, MIDDLE EAR, AND ACCESSORY SINUSES
161 | MALIGNANT NEOPLASM OF LARYNX
162 | MALIGNANT NEOPLASM OF TRACHEA, BRONCHUS, AND LUNG
163 | MALIGNANT NEOPLASM OF PLEURA
164 | MALIGNANT NEOPLASM OF THYMUS, HEART, AND MEDIASTINUM
165 | MALIGNANT NEOPLASM OF OTHER AND ILL-DEFINED SITES WITHIN THE RESPIRATORY SYSTEM AND INTRATHORACIC ORGANS
170 | MALIGNANT NEOPLASM OF BONE AND ARTICULAR CARTILAGE
171 | MALIGNANT NEOPLASM OF CONNECTIVE AND OTHER SOFT TISSUE
172 | MALIGNANT MELANOMA OF SKIN
174 | MALIGNANT NEOPLASM OF FEMALE BREAST
175 | MALIGNANT NEOPLASM OF MALE BREAST
176 | KARPOSI'S SARCOMA
179 | MALIGNANT NEOPLASM OF UTERUS, PART UNSPECIFIED
180 | MALIGNANT NEOPLASM OF CERVIX UTERI
181 | MALIGNANT NEOPLASM OF EYE
182 | MALIGNANT NEOPLASM OF BODY OF UTERUS
183 | MALIGNANT NEOPLASM OF OVARY AND OTHER UTERINE ADNEXA
184 | MALIGNANT NEOPLASM OF OTHER AND UNSPECIFIED FEMALE GENITAL ORGANS
185 | MALIGNANT NEOPLASM OF OTHER AND UNSPECIFIED FEMALE GENITAL ORGANS
186 | MALIGNANT NEOPLASM OF TESTIS
187 | MALIGNANT NEOPLASM OF PENIS AND OTHER MALE GENITAL ORGANS
188 | MALIGNANT NEOPLASM OF BLADDER
189 | MALIGNANT NEOPLASM OF KIDNEY AND OTHER AND UNSPECIFIED URINARY ORGANS
190 | MALIGNANT NEOPLASM OF EYE
191 | MALIGNANT NEOPLASM OF BRAIN
192 | MALIGNANT NEOPLASM OF OTHER AND UNSPECIFIED PARTS OF NERVOUS SYSTEM
193 | MALIGNANT NEOPLASM OF THYROID GLAND
194 | MALIGNANT NEOPLASM OF OTHER ENDOCRINE GLANDS AND RELATED STRUCTURES
195 | MALIGNANT NEOPLASM OF OTHER, AND ILL-DEFINED SITES
196 | SECONDARY AND UNSPECIFIED MALIGNANT NEOPLASM OF LYMPH NODES
197 | SECONDARY MALIGNANT NEOPLASM OF RESPIRATORY AND DIGESTIVE SYSTEMS
198 | SECONDARY MALIGNANT NEOPLASM OF OTHER SPECIFIED SITES
199 | MALIGNANT NEOPLASM WITHOUT SPECIFICATION OF SITE
200 | LYMPHOSARCOMA AND RETICULOSARCOMA
201 | HODGKIN'S DISEASE
202 | OTHER MALIGNANT NEOPLASMS OF LYMPHOID AND HISTIOCYTIC TISSUES
203 | MULTIPLE MYELOMA AND IMMUNOPROLIFERATIVE NEOPLASMS
204 | LYMPHOID LEUKEMIA
205 | MYELOID LEUKEMIA
206 | MONOCYTIC LEUKEMIA
207 | OTHER SPECIFIED LEUKEMIA
208 | LEUKEMIA OF UNSPECIFIED CELL TYPE
238.6 | NEOPLASM OF UNCERTAIN BEHAVIOR OF OTHER AND UNSPECIFIED SITES AND TISSUES, PLASMA CELLS
273.3 | DISORDERS OF PLASMA PROTEIN METABOLISM-MACROGLOBULINEMIA
PERSONAL HISTORY OF MALIGNANT NEOPLASM:
V10.00 | GASTROINTESTINAL TRACT, UNSPECIFIED
V10.01 | TONGUE
V10.02 | OTHER AND UNSPECIFIED ORAL CAVITY AND PHARYNX
V10.03 | ESOPHAGUS
V10.04 | STOMACH
V10.05 | LARGE INTESTINE
V10.06 | RECTUM, RECTOSIGMOID JUNCTION, AND ANUS
V10.07 | LIVER
V10.09 | OTHER GASTROINTESTINAL TRACT
V10.11 | BRONCHUS AND LUNG
V10.12 | TRACHEA
V10.20 | RESPIRATORY ORGAN, UNSPECIFIED
V10.21 | LARYNX
V10.22 | NASAL CAVITIES, MIDDLE EAR, AND ACCESSORY SINUSES
V10.29 | OTHER RESPIRATORYAND INTRATHORACIC ORGANS
V10.3 | BREAST
V10.40 | FEMALE GENITAL ORGAN, UNSPECIFIED
V10.41 | CERVIX UTERI
V10.42 | OTHER PARTS OF UTERUS
V10.43 | OVARY
V10.44 | OTHER FEMALE GENITAL ORGANS
V10.45 | MALE GENITAL ORGAN, UNSPECIFIED
V10.46 | PROSTATE
V10.47 | TESTIS
V10.48 | EPIDIDYMIS
V10.49 | OTHER MALE GENITAL ORGANS
V10.50 | URINARY ORGAN, UNSPECIFIED
V10.51 | BLADDER
V10.52 | KIDNEY
V10.59 | OTHER URINARY ORGAN
V10.60 | LYMPHOSARCOMA AND RETICULOSARCOMA
V10.61 | HODGKINS DISEASE
V10.62 | MYELOID LEUKEMIA
V10.63 | MONOCYTIC LEUKEMIA
V10.69 | OTHER LEUKEMIA
V10.71 | LYMPHOSARCOMA AND RETICULOSARCOMA
V10.72 | HODGKINS DISEASE
V10.79 | OTHER LYMPHATIC AND HEMATOPOIETIC NEOPLASM
V10.81 | BONE
V10.82 | MALIGNANT MELANOMA OF SKIN
V10.83 | OTHER MALIGNANT NEOPLASM OF SKIN
V10.84 | EYE
V10.85 | BRAIN
V10.86 | OTHER PARTS OF NERVOUS SYSTEM
V10.87 | THYROID
V10.88 | OTHER ENDOCRINE GLANDS AND RELATED STRUCTURES
V10.89 | OTHER NEOPLASM
V10.9 | UNSPECIFIED PERSONAL HISTORY OF MALIGNANT NEOPLASM
Diagnostic Related Groups (DRGS)
010 | NERVOUS SYSTEM NEOPLASMS WITH CC
011 | NERVOUS SYSTEM NEOPLASMS WITHOUT CC
064 | EAR, NOSE, MOUTH AND THROAT MALIGNANCY
082 | RESPIRATORY NEOPLASMS
172 | DIGESTIVE MALIGNANCY WITH CC
173 | DIGESTIVE MALIGNANCY WITHOUT CC
199 | HEPATOBILIARY DIAGNOSTIC PROCEDURE FOR MALIGNANCY
203 | MALIGNANCY OF HEPATOBILIARY SYSTEM OR PANCREAS
239 | PATHOLOGICAL FRACTURES AND MUSCULOSKELETAL AND CONNECTIVE TISSUE MALIGNANCY
257 | TOTAL MASTECTOMY FOR MALIGNANCY WITH CC
258 | TOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
259 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITH CC
260 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
274 | MALIGNANT BREAST DISORDERS WITH CC
275 | MALIGNANT BREAST DISORDERS WITHOUT CC
303 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NEOPLASM
318 | KIDNEY AND URINARY TRACT NEOPLSMS WITH CC
319 | KIDNEY AND URINARY TRACT NEOPLASMS WITHOUT CC
338 | TESTES PROCEDURES FOR MALIGNANCY
344 | OTHER MALE REPRODUCTIVE SYSTEM OR PROCEDURES FOR MALIGNANCY
346 | MALIGNANCY OF MALE REPRODUCTIVE SYSTEM WITH CC
347 | MALIGNANCY OF MALE REPRODUCTIVE SYSTEM WITHOUT CC
354 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITH CC
355 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITHOUT CC
357 | UTERINE AND ADNEXA PROCEDURES FOR OVARIAN OR ADNEXAL MALIGNANCY
363 | D AND C, CONIZATION AND RADIOIMPLANT FOR MALIGNANCY
367 | MALIGNANCY OF FEMALE REPRODUCTIVE SYSTEM WITHOUT CC
400 | LYMPHOMA AND LEUKEMIA WITH MAJOR OR PROCEDURES
401 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITH CC
402 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITHOUT CC
403 | LYMPHOMA AND NONACUTE LEUKEMIA WITH CC
404 | LYMPHOMA AND NONACUTE LEUKEMIA WITHOUT CC
405 | ACUTE LEUKEMIAWITHOUT MAJOR OR PROCEDURE, AGE 0–17
406 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURES WITH CC
407 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURE WITHOUT CC
408 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH OTHER OR PROCEDURES
409 | RADIOTHERAPY
410 | CHEMOTHERAPY WITHOUT ACUTE LEUKEMIA AS SECONDARY DIAGNOSIS
411 | HISTORY OF MALIGNANCY WITHOUT ENDOSCOPY
412 | HISTORY OF MALIGNANCY WITH ENDOSCOPY
413 | OTHER MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASM DIAGNOSES WITH CC
414 | OTHER MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASM DIAGNOSES WITHOUT CC
473 | ACUTE LEUKEMIA WITHOUT MAJOR OR PROCEDURE, AGE GREATER THAN 17
492 | CHEMOTHERAPY WITH ACUTE LEUKEMIA AS SECONDARY DIAGNOSIS
Cardiac arrest
ICD-9-CM codes:
427.5 | CARDIAC ARREST
Cardiac arrhythmia
ICD-9-CM diagnosis codes:
426.0 | ATRIOVENTRICULAR BLOCK, COMPLETE
427.0 | PAROXYSMAL SUPRAVENTRICULAR TACHYCARDIA
427.1 | PAROXYSMAL VENTRICULAR TACHYCARDIA
427.2 | PAROXYSMAL TACHYCARDIA, UNSPECIFIED
427.31 | ATRIAL FIBRILLATION
427.32 | ATRIAL FLUTTER
427.41 | VENTRICULAR FIBRILLATION
427.42 | VENTRICULAR FLUTTER
427.9 | CARDIAC DYSRHYTHMIA
Diagnostic Related Groups (DRGs):
138 | CARDIAC ARRHYTHMIA AND CONDUCTION DISORDERS WITH CC
139 | CARDIAC ARRHYTHMIA AND CONDUCTION DISORDERS WITHOUT CC
Cardiac surgery
Diagnostic Related Groups (DRGs):
103 | HEART TRANSPLANT
104 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITH CARDIAC CATHETERIZATION
105 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITHOUT CARDIAC CATHETERIZATION
106 | CORONARY BYPASS WITH PTCA
107 | CORONARY BYPASS WITH CARDIAC CATHETERIZATION
108 | OTHER CARDIOTHORACIC PROCEDURES
109 | CORONARY BYPASS WITHOUT CARDIAC CATHETERIZATION
110 | MAJOR CARDIOVASCULAR PROCEDURES WITH CC
111 | MAJOR CARDIOVASCULAR PROCEDURES WITHOUT CC
Cesarean delivery
Diagnostic related groups (DRGs):
370 | CESAREAN SECTION WITH CC
371 | CESAREAN SECTION WITHOUT CC
Coma
ICD-9-CM diagnosis codes:
251.0 | OTHER DISORDERS OF PANCREATIC INTERNAL SECRETION, HYPOGLYCEMIC COMA
572.2 | LIVER ABSCESS AND SEQUELAE OF CHRONIC LIVER DISEASE, HEPATIC COMA
780.01 | GENERAL SYMPTOMS, ALTERATION OF CONSCIOUSNESS, COMA
250.20 | DIABETES WITH HYPEROSMOLARITY, TYPE 2 [NONINSULIN DEPENDENT TYPE][NIDDM TYPE][ADULT-ONSET] OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
250.21 | DIABETES WITH HYPEROSMOLARITY, TYPE 1 [INSULIN DEPENDENT TYPE][NIDDM-TYPE] [JUVENILE TYPE], NOT STATED AS UNCONTROLLED
250.22 | DIABETES WITH HYPEROSMOLARITY, TYPE 2
250.23 | DIABETES MELLITUS, DIABETES WITH HYPEROSMOLARITY, TYPE 1 [INSULIN DEPENDENT TYPE][NIDMM-TYPE][JUVENILE TYPE] UNCONTROLLED
250.30 | DIABETES WITH OTHER COMA, TYPE 2 NOT STATED AS UNCONTROLLED
250.31 | DIABETES WITH OTHER COMA, TYPE 1 NOT STATED AS UNCONTROLLED
250.32 | DIABETES MELLITUS, DIABETES WITH OTHER COMA, TYPE 2 UNCONTROLLED
250.33 | DIABETES MELLITUS, DIABETES WITH OTHER COMA, TYPE 1 UNCONTROLLED
780.03 | GENERAL SYMPTOMS, ALTERATION OF CONSCIOUSNESS PERSISTENT VEGETATIVE STATE
Control of postoperative hemorrhage
ICD-9-CM procedure codes:
28.7 | CONTROL OF HEMORRHAGE AFTER TONSILLECTOMY AND ADENOIDECTOMY
38.80 | OTHER SURGICAL OCCLUSION OF UNSPECIFIED SITE
38.81 | OTHER SURGICAL OCCLUSION OF INTRACRANIAL VESSELS
38.82 | OTHER SURGICAL OCCLUSION OF OTHER VESSELS OF HEAD AND NECK
38.83 | OTHER SURGICAL OCCLUSION OF UPPER LIMB VESSELS
38.84 | OTHER SURGICAL OCCLUSION OF AORTA, ABDOMINAL
38.85 | OTHER SURGICAL OCCLUSION OF THORACIC VESSEL
38.86 | OTHER SURGICAL OCCLUSION OF ABDOMINAL ARTERIES
38.87 | OTHER SURGICAL OCCLUSION OF VESSELS ABDOMINAL VEINS
38.88 | OTHER SURGICAL OCCLUSION OF LOWER LIMB ARTERIES
38.89 | OTHER SURGICAL OCCLUSION OF LOWER LIMB VEINS
39.41 | CONTROL OF HEMORRHAGE AFTER TONSILLECTOMY AND ADENOIDECTOMY
39.98 | CONTROL OF HEMORRHAGE NOS
49.95 | CONTROL OF (POSTOPERATIVE) HEMORRHAGE OF ANUS
57.93 | CONTROL OF (POSTOPERATIVE) HEMORRHAGE OF BLADDER
60.94 | CONTROL OF (POSTOPERATIVE) HEMORRHAGE OF PROSTATE
Deep vein thrombosis
ICD-9-CM diagnosis codes:
451.11 | PHLEBITIS AND THROMBOSIS OF FEMORAL VEIN (DEEP) (SUPERFICIAL)
451.19 | PHLEBITIS AND THROMBOPHLEBITIS - OF DEEP VESSEL OF LOWER EXTREMITIES - OTHER
451.2 | PHLEBITIS AND THROMBOPHLEBITIS OF LOWER EXTREMITIES UNSPECIFIED
451.81 | PHLEBITIS AND THROMBOPHLEBITIS OF ILIAC VEIN
451.9 | PHLEBITIS AND THROMBOPHLEBITIS OF OTHER SITES - OF UNSPECIFIED SITE
453.8 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF OTHER SPECIFIED VEINS
453.9 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF UNSPECIFIED SITE
Delirium and other psychoses
ICD-9-CM diagnosis codes (includes all 4^th^ and 5^th^ digits)
290 | SENILE AND PRESENILE ORGANIC PSYCHOTIC CONDITIONS
291 | ALCOHOLIC PSYCHOSES
292 | DRUG PSYCHOSES
293 | TRANSIENT ORGANIC PSYCHOTIC CONDITIONS
294 | OTHER ORGANIC PSYCHOTIC CONDITIONS
295 | SCHIZOPHRENIC DISORDERS
296 | AFFECTIVE PSYCHOSES
297 | PARANOID STATES
298 | OTHER NONORGANIC PSYCHOSES
299 | PSYCHOSES WITH ORIGIN SPECIFIC TO CHILDHOOD
Diabetes
ICD-9-CM diagnosis codes:
250.0 | DIABETES MELLITUS WITHOUT MENTION OF COMPLICATION
250.1 | DIABETES WITH KETOACIDOSIS
250.2 | DIABETES WITH HYPEROSMOLARITY
250.3 | DIABETES WITH OTHER COMA
250.4 | DIABETES WITH RENAL MANIFESTATIONS
250.5 | DIABETES WITH OPHTHALMIC MANIFESTATIONS
250.6 | DIABETES WITH NEUROLOGICAL MANIFESTATIONS
250.7 | DIABETES WITH PERIPHERAL CIRCULATORY DISORDERS
250.8 | DIABETES WITH OTHER SPECIFIED MANIFESTATIONS
250.9 | DIABETES WITH OTHER UNSPECIFIED COMPLICATIONS
Drainage of hematoma
ICD-9-CM procedure codes:
18.09 | OTHER INCISION OF EXTERNAL EAR
54.0 | INCISION OF ABDOMINAL WALL
54.12 | REOPENING OF RECENT LAPAROTOMY SITE
59.19 | OTHER INCISION OF PERIVESICLE TISSUE
61.0 | INCISION AND DRAINAGE OF SCROTUM AND TUNICA VAGINALIS
69.98 | OTHER OPERATIONS ON SUPPORTING STRUCTURES OF UTERUS
70.14 | OTHER VAGINOTOMY
71.09 | OTHER INCISION OF VULVA AND PERINEUM
75.91 | EVACUATION OF OBSTETRICAL INCISIONAL HEMATOMA OF PERINEUM
75.92 | EVACUATION OF OTHER HEMATOMA OF VULVA OR VAGINA
86.04 | OTHER INCISION WITH DRAINAGE OF SKIN AND SUBCUTANEOUS TISSUE
Elective
ADMISSION TYPE IS RECORDED AS ELECTIVE (ATYPE = 3)
Foreign body left in during procedure
ICD-9-CM diagnosis codes:
998.4 | FOREIGN BODY ACCIDENTALLY LEFT DURING A PROCEDURE
998.7 | ACUTE REACTION TO FOREIGN SUBSTANCE ACCIDENTALLY LEFT DURING A PROCEDURE
FOREIGN BODY LEFT IN DURING:
E871.0 | SURGICAL OPERATION
E871.1 | INFUSION OR TRANSFUSION
E871.2 | KIDNEY DIALYSIS OR OTHER PERFUSION
E871.3 | INJECTION OR VACCINATION
E871.4 | ENDOSCOPIC EXAMINATION
E871.5 | ASPIRATION OF FLUID OR TISSUE, PUNCTURE, AND CATHETERIZATION
E871.6 | HEART CATHETERIZATION
E871.7 | REMOVAL OF CATHETER OR PACKING
E871.8 | OTHER SPECIFIED PROCEDURES
E871.9 | UNSPECIFIED PROCEDURE
Gastrointestinal (GI) hemorrhage
ICD-9-CM diagnosis codes:
456.0 | ESOPHAGEAL VARICES WITH BLEEDING
456.20 | ESOPHAGEAL VARICES IN DISEASES CLASSIFIED ELSEWHERE WITH BLEEDING
530.7 | GASTROESOPHAGEAL LACERATION-HEMORRHAGE SYNDROME
530.82 | ESOPHAGEAL HEMORRHAGE
531.00 | GASTRIC ULCER ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
531.01 | GASTRIC ULCER ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
531.20 | GASTRIC ULCER ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.21 | GASTRIC ULCER, ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
531.40 | GASTRIC ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
531.41 | GASTRIC ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITH OBSTRUCTION
531.60 | GASTRIC ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.61 | GASTRIC ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
532.00 | DUODENAL ULCER ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
532.01 | DUODENAL ULCER ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
532.20 | DUODENAL ULCER ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
532.21 | DUODENAL ULCER ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
532.40 | DUODENAL ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
532.41 | DUODENAL ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITH OBSTRUCTION
532.60 | DUODENAL ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
532.61 | DUODENAL ULCER CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
533.00 | PEPTIC ULCER, SITE UNSPECIFIED ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
533.01 | PEPTIC ULCER, SITE UNSPECIFIED, ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
533.20 | PEPTIC ULCER, SITE UNSPECIFIED, ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
533.21 | PEPTIC ULCER, SITE UNSPECIFIED, ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
533.40 | PEPTIC ULCER, SITE UNSPECIFIED CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
533.41 | PEPTIC ULCER, SITE UNSPECIFIED, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITH OBSTRUCTION
533.60 | PEPTIC ULCER, SITE UNSPECIFIED, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
533.61 | PEPTIC ULCER, SITE UNSPECIFIED, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
534.00 | GASTROJEJUNAL ULCER, ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
534.01 | GASTROJEJUNAL ULCER, ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
534.20 | GASTROJEJUNAL ULCER, ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.21 | GASTROJEJUNAL ULCER, ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
534.40 | GASTROJEJUNAL ULCER, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
534.41 | GASTROJEJUNAL ULCER, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE - WITH OBSTRUCTION
534.60 | GASTROJEJUNAL ULCER, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.61 | GASTROJEJUNAL ULCER, CHRONIC OR UNSPECIFIED WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
535.01 | GASTRITIS AND DUODENITIS, ACUTE GASTRITIS WITH HEMORRHAGE
535.11 | GASTRITIS AND DUODENITIS, ATROPHIC GASTRITIS WITH HEMORRHAGE
535.21 | GASTRITIS AND DUODENITIS, GASTRIC MUCOSAL HYPERTROPHY, WITH HEMORRHAGE
535.31 | GASTRITIS AND DUODENITIS, ALCOHOLIC GASTRITIS, WITH HEMORRHAGE
535.41 | GASTRITIS AND DUODENITIS, OTHER SPECIFIED GASTRITIS - WITH HEMORRHAGE
535.51 | GASTRITIS AND DUODENITIS, UNSPECIFIED GASTRITIS AND GASTRODUODENITIS - WITH HEMORRHAGE
535.61 | GASTRITIS AND DUODENITIS, DUODENITIS - WITH HEMORRHAGE
537.83 | OTHER SPECIFIED DISORDERS OF STOMACH AND DUODENUM, ANGIODYSPLASIA OF STOMACH AND DUODENUM - WITH HEMORRHAGE
562.02 | DIVERTICULOSIS OF SMALL INTESTINE - WITH HEMORRHAGE
562.03 | DIVERTICULITIS OF SMALL INTESTINE - WITH HEMORRHAGE
562.12 | DIVERTICULOSIS OF COLON - WITH HEMORRHAGE
562.13 | DIVERTICULITIS OF COLON - WITH HEMORRHAGE
569.3 | HEMORRHAGE OF RECTUM AND ANUS
569.85 | ANGIODYSPLASIA OF INTESTINE - WITH HEMORRHAGE
578.0 | GASTROINTESTINAL HEMORRHAGE, HEMATEMESIS
578.1 | GASTROINTESTINAL HEMORRHAGE, BLOOD IN STOOL
578.9 | GASTROINTESTINAL HEMORRHAGE, HEMORRHAGE OF GASTROINTESTINAL TRACT, UNSPECIFIED
Hemiplegia, paraplegia, or quadriplegia
ICD-9-CM diagnosis codes (includes all 4^th^ and 5^th^ digits):
342.0 | FLACCID HEMIPLEGIA
342.1 | SPASTIC HEMIPLEGIA
342.8 | OTHER SPECIFIED HEMIPLEGIA
342.9 | HEMIPLEGIA, UNSPECIFIED
343.0 | INFANTILE CEREBRAL PALSY, DIPLEGIC
343.1 | INFANTILE CEREBRAL PALSY, HEMIPLEGIC
343.2 | INFANTILE CEREBRAL PALSY, QUADRIPLEGIC
343.3 | INFANTILE CEREBRAL PALSY, MONOPLEGIC
343.4 | INFANTILE CEREBRAL PALSY INFANTILE HEMIPLEGIA
343.8 | INFANTILE CEREBRAL PALSY OTHER SPECIFIED INFANTILE CEREBRAL PALSY
343.9 | INFANTILE CEREBRAL PALSY, INFANTILE CEREBRAL PALSY, UNSPECIFIED
344.0 | QUADRIPLEGIA AND QUADRIPARESIS
344.1 | PARAPLEGIA
344.2 | DIPLEGIA OF UPPER LIMBS
344.3 | MONOPLEGIA OF LOWER LIMB
344.4 | MONOPLEGIA OF UPPER LIMB
344.5 | UNSPECIFIED MONOPLEGIA
344.6 | CAUDA EQUINA SYNDROME
344.8 | OTHER SPECIFIED PARALYTIC SYNDROMES
344.9 | PARALYSIS, UNSPECIFIED
438.2 | HEMIPLEGIA/HEMIPARESIS
438.3 | MONOPLEGIA OF UPPER LIMB
438.4 | MONOPLEGIA OF LOWER LIMB
438.5 | OTHER PARALYTIC SYNDROME
Hemorrhage
ICD-9-CM diagnosis codes:
285.1 | ACUTE POSTHEMORRHAGIC ANEMIA
459.0 | OTHER DISORDERS OF CIRCULATORY SYSTEM, HEMORRHAGE, UNSPECIFIED
958.2 | CERTAIN EARLY COMPLICATIONS OF TRAUMA, SECONDARY AND RECURRENT HEMORRHAGE
998.11 | HEMORRHAGE COMPLICATING A PROCEDURE
Hip fracture
ICD-9-CM diagnosis codes: (includes all 5^th^ digits)
820.0 | FRACTURE OF NECK OF FEMUR-TRANSCERVICAL FRACTURE, CLOSED
820.1 | FRACTURE OF NECK OF FEMUR-TRANSCERVICAL FRACTURE, OPEN
820.2 | FRACTURE OF NECK OF FEMUR-PERTROCHANTERIC FRACTURE, CLOSED
820.3 | FRACTURE OF NECK OF FEMUR-PERTROCHANTERIC FRACTURE, OPEN
820.8 | UNSPECIFIED PART OF NECK OF FEMUR, CLOSED
820.9 | UNSPECIFIED PART OF NECK OF FEMUR, OPEN
Immunocompromised
ICD-9-CM diagnosis codes (includes all 4th and 5th digits)
042 | HUMAN IMMUNODEFICIENCY VIRUS DISEASE
136.3 | PNEUMOCYSTOSIS
279.0 | DEFFICIENCY OF HUMORAL IMMUNITY
279.1 | DEFFICIENCY OF CELL-MEDIATED IMMUNITY
279.2 | COMBINED IMMUNITY DEFFICIENCY
279.3 | UNSPECIFIED IMMUNITY DEFFICIENCY
279.4 | AUTOIMMUNE DISEASE, NOT ELSEWHERE CLASSIFIED
279.8 | OTHER SPECIFIED DISORDERS INVOLVING THE IMMUNE MECHANISM
279.9 | UNSPECIFIED DISORDER OF IMMUNE MECHANISM
996.8 | COMPLICATIONS OF TRANSPLANTED ORGAN
V42.0 | KIDNEY REPLACED BY TRANSPLANT
V42.1 | HEART REPLACED BY TRANSPLANT
V42.6 | LUNG REPLACED BY TRANSPLANT
V42.7 | LIVER REPLACED BY TRANSPLANT
V42.81 | BONE MARROW SPECIFIED BY TRANSPLANT
V42.82 | PERIPHERAL STEM CELLS REPLACED BY TRANSPLANT
V42.83 | PANCREAS REPLACED BY TRANSPLANT
V42.84 | INTESTINES REPLACED BY TRANSPLANT
V42.89 | OTHER REPLACED BY TRANSPLANT
ICD-9-CM procedure codes (includes 4th and 5th digits:)
33.5 | LUNG TRANSPLANT
33.6 | COMBINED HEART-LUNG TRANSPLANTATION
37.5 | HEART TRANSPLANTATION
41.0 | OPERATIONS ON BONE MAROW AND SPLEEN
50.5 | LIVER TRANSPLANT
55.69 | OTHER KIDNEY TRANSPLANTATION
52.80 | PANCREATIC TRANSPLANT, NOS
52.81 | REIMPLANTATION OF PANCREATIC TISSUE
52.83 | HETEROTRANSPLANT OF PANCREAS
52.85 | ALLOTRANSPLANTATION OF CELLS OF ISLETS OF LANGERHANS
52.86 | TRANSPLANTATION OF CELLS OF ISLETS OF LANGERHANS, NOS
Diagnostic Related Groups (DRGs):
488 | HIV WITH EXTENSIVE OR PROCEDURE
489 | HIV WITH MAJOR RELATED CONDITION
490 | HIV WITH OR WITHOUT OTHER RELATED CONDITION
Indications of current drug abuse
ICD-9-CM diagnosis codes
TOXIC EFFECT OF ALCOHOL:
980.0 | ETHYL ALCOHOL
980.1 | METHYL ALCOHOL
980.2 | ISOPROPYL ALCOHOL
980.3 | FUSEL OIL
981 | TOXIC EFFECT OF PETROLEUM PRODUCTS
SOLVENTS OTHER THAN PETROLEUM-BASED:
982.0 | BENZENE AND HOMOLOGUES
982.1 | CARBON TETRACHLORIDE
982.2 | CARBON DISULFIDE
982.3 | OTHER CHLORINATED HYDROCARBON SOLVENTS
982.4 | NITROGLYCOL
982.8 | OTHER NONPETROLEUM-BASED SOLVENTS
983.0 | TOXIC EFFECT OF CORROSIVE AROMATICS
983.1 | TOXIC EFFECT OF ACIDS
983.2 | TOXIC EFFECT OF CAUSTIC ALKALIDES
983.9 | TOXIC EFFECT OF CAUSTIC, UNSPECIFIED
TOXIC EFFECT OF LEAD AND ITS COMPOUNDS (INCLUDING FUMES):
984.0 | INORGANIC LEAD COMPOUNDS
984.1 | ORGANIC LEAD COMPOUNDS
984.8 | OTHER LEAD COMPOUNDS
984.9 | UNSPECIFIED LEAD COMPOUND
TOXIC EFFECT OF OTHER METALS:
985.0 | MERCURY AND ITS COMPOUNDS
985.1 | ARSENIC AND ITS COMPOUNDS
985.2 | MANGANESE AND ITS COMPOUNDS
985.3 | BERYLLIUM AND ITS COMPOUNDS
985.4 | ANTIMONY AND ITS COMPOUNDS
985.5 | CADMIUM AND ITS COMPOUNDS
985.6 | CHROMIUM
985.8 | OTHER SPECIFIED METALS
985.9 | UNSPECIFIED METAL
986 | TOXIC EFFECT OF CARBON MONOXIDE
TOXIC EFFECT OF OTHER GASES, FUMES, OR VAPORS:
987.0 | LIQUEFIED PETROLEUM GASES
987.1 | OTHER HYDROCARBON GAS
987.2 | NITROGEN OXIDES
987.3 | SULFUR DIOXIDE
987.4 | FREON
987.5 | LACRIMOGENIC GAS
987.6 | CHLORINE GAS
987.7 | HYDROCYANIC ACID GAS
987.8 | OTHER SPECIFIED GASES, FUMES, OR VAPORS
987.9 | UNSPECIFIED GAS, FUME, OR VAPOR
NOXIOUS SUBSTANCES EATEN AS FOOD:
988.0 | FISH AND SHELLFISH
988.1 | MUSHROOMS
988.2 | BERRIES AND OTHER PLANTS
988.8 | OTHER SPECIFIED NOXIOUS SUBSTANCES EATEN AS FOOD
TOXIC EFFECT OF OTHER SUBSTANCES, CHIEFLY NONMEDICINAL AS TO SOURCE:
989.0 | HYDROCYANIC ACID AND CYANIDES
989.1 | STRYCHNINE AND SALTS
989.2 | CHLORINATED HYDROCARBONS
989.3 | ORGANOPHOSPHATE AND CARBAMATE
989.4 | OTHER PESTICIDES, NEC
989.5 | VENOM
989.6 | SOAPS AND DETERGENTS
989.7 | AFLATOXIN AND OTHER MYCOTOXIN [FOOD CONTAMINANTS]
989.8 | OTHER SUBSTANCES, CHIEFLY NONMEDICIAN AS TO SOURCE
989.9 | UNSPECIFIED SUBSTANCE, CHIEFLY NONMEDICINAL AS TO SOURCE
291.0 | ALCOHOL WITHDRAWAL DELIRIUM
291.1 | ALCOHOL AMNESTIC SYNDROME
291.2 | OTHER ALCOHOLIC DEMENTIA
291.3 | ALCOHOL WITHDRAWL HALLUCINOSIS
291.4 | IDIOSYNCRATIC ALCOHOL INTOXICATION
291.5 | ALCOHOL JEALOUSY
291.8 | OTHER SPECIFIED ALCOHOLIC PSYCHOSIS
291.81 | ALCOHOL WITHDRAWAL
291.9 | ALCOHOLIC PSYCHOSES
DRUG PSYCHOSES:
292.0 | DRUG WITHDRAWL SYNDROME
292.11 | DRUG-INDUCED ORGANIC DELUSIONAL SYNDROME
292.12 | DRUG- INDUCED HALLUCINOSIS
292.2 | PATHOLOGICAL DRUG INTOXICATION
292.81 | DRUG-INDUCED DELIRIUM
292.82 | DRUG-INDUCED DEMENTIA
292.83 | DRUG-INDUCED AMNESTIC SYNDROME
292.84 | DRUG-INDUCED ORGANIC AFFECTIVE SYNDROME
292.89 | OTHER SPECIFIED DRUG-INDUCED MENTAL DISORDERS
292.9 | UNSPECIFIED DRUG-INDUCED MENTAL DISORDER
(includes all 4^th^ and 5^th^ digits)
303.0 | ACUTE ALCOHOLIC INTOXICATION
303.9 | OTHER AND UNSPECIFIED ALCOHOL.\DEPENDENCE
304.0 | OPIOID TYPE DEPENDENCE
304.1 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC DEPENDENCE
304.2 | COCAINE DEPENDENCE
304.3 | CANNABIS DEPENDENCE
304.4 | AMPHETAMINE AND OTHER PSYCHOSTIMULANT DEPENDENCE
304.5 | HALLUCINOGEN DEPENDENCE
304.6 | OTHER SPECIFIED DRUG DEPENDENCE
304.7 | COMBINATIONS OF OPIOID TYPE DRUG WITH ANY OTHER
304.8 | COMBINATIONS OF DRUG DEPENDENCE EXCLUDING OPIOID TYPE DRUG
304.9 | UNSPECIFIED DRUG DEPENDENCE
305.0 | ALCOHOL ABUSE
305.2 | CANNABIS ABUSE
305.3 | HALLUCINOGEN ABUSE
305.4 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE
305.5 | OPIOID ABUSE
305.6 | COCAINE ABUSE
305.7 | AMPHETAMINE OR RELATED ACTING SYMPATHOMIMETIC ABUSE
305.8 | ANTIDEPRESSANT TYPE ABUSE
305.9 | OTHER MIXED OR UNSPECIFIED DRUG ABUSE
Infection
ICD-9-CM diagnosis codes:
540.0 | ACUTE APPENDICITIS WITH GENERALIZED PERITONITIS
540.1 | ACUTE APPENDICITIS WITH PERITONEAL ABSCESS
540.9 | ACUTE APPENDICITIS WITHOUT MENTION OF PERITONITIS
541 | APPENDICITIS, UNQUALIFIED
542 | OTHER APPENDICITIS
562.01 | DIVERTICULITIS OF SMALL INTESTINE (WITHOUT MENTION OF HEMORRHAGE)
562.03 | DIVERTICULITIS OF SMALL INTESTINE WITH HEMORRHAGE
562.11 | DIVERTICULITIS OF COLON (WITHOUT MENTION OF HEMORRHAGE)
562.13 | DIVERTICULITIS OF COLON WITH HEMORRHAGE
566 | ABSCESS OF ANAL AND RECTAL REGIONS
567.0 | PERITONITIS IN INFECTIOUS DISEASES CLASSIFIED ELSEWHERE
567.1 | PNEUMOCOCCAL PERITONITIS
567.2 | OTHER SUPPURATIVE PERITONITIS
567.8 | OTHER SPECIFIED PERITONITIS
567.9 | UNSPECIFIED PERITONITIS
569.5 | ABSCESS OF INTESTINE
569.61 | INFECTION OF COLOSTOMY OR ENTEROSTOMY
572.0 | ABSCESS OF LIVER
572.1 | PORTAL PYEMIA
574.00 | CALCULUS OF GALLBLADDER WITH ACUTE CHOLECYSTITIS - WITHOUT MENTION OF OBSTRUCTION
574.01 | CALCULUS OF GALLBLADDER WITH ACUTE CHOLECYSTITS - WITH OBSTRUCTION
574.30 | CALCULUS OF BILE DUCT WITH ACUTE CHOLECYSTITIS - WITHOUT MENTION OF OBSTRUCTION
574.31 | CALCULUS OF BILE DUCT WITH ACUTE CHOLECYSTITIS - WITH OBSTRUCTION
574.60 | CALCULUS OF GALLBLADDER AND BILE DUCT WITH ACUTE CHOLECYSTITIS - WITHOUT MENTION OF OBSTRUCTION
574.61 | CALCULUS OF GALLBLADDER AND BILE DUCT WITH ACUTE CHOLECYSTITIS - WITH OBSTRUCTION
574.80 | CALCULUS OF GALLBLADDER AND BILE DUCT WITH ACUTE AND CHRONIC CHOLECYSTITIS - WITHOUT MENTION OF OBSTRUCTION
574.81 | CALCULUS OF GALLBLADDER AND BILE DUCT WITH ACUTE AND CHRONIC CHOLECYSTITIS - WITH OBSTRUCTION
575.0 | ACUTE CHOLECYSTITIS
575.4 | PERFORATION OF GALLBLADDER
576.1 | CHOLANGITIS
576.3 | PERFORATION OF BILE DUCT
Diagnostic Related Groups (DRGs)
020 | NERVOUS SYSTEM INFECTION EXCEPT VIRAL MENINGITIS
068 | OTITIS MEDIA AND URI, AGE GREATER THAN 17 WITH CC
069 | OTITIS MEDIA AND URI, AGE GREATER THAN 17 WITHOUT CC
079 | RESPIRATORY INFECTIONS AND INFLAMMATIONS, AGE GREATER THAN 17 WITH CC
080 | RESPIRATORY INFECTIONS AND INFLAMMATIONS, AGE GREATER THAN 17 WITHOUT CC
089 | SIMPLE PNEUMONIA AND PLEURISY, AGE GREATER THAN 17 WITH CC
090 | SIMPLE PNEUMONIA AND PLEURISY, AGE GREATER THAN 17 WITHOUT CC
126 | ACUTE AND SUBACUTE ENDOCARDITIS
238 | OSTEOMYELITIS
242 | SEPTIC ARTHRITIS
277 | CELLULITIS, AGE GREATER THAN 17 WITH CC
278 | CELLULITIS, AGE GREATER THAN 17 WITHOUT CC
320 | KIDNEY AND URINARY TRACT INFECTIONS, AGE GREATER THAN 17 WITH CC
321 | KIDNEY AND URINARY TRACT INFECTIONS, AGE GREATER THAN 17 WITHOUT CC
368 | INFECTIONS OF FEMALE REPRODUCTIVE SYSTEM
416 | SEPTICEMIA, AGE GREATER THAN 17
Instrument assisted delivery
ICD-9-CM procedure codes
72.0 | LOW FORCEPS OPERATION
72.1 | LOW FORCEPS OPERATION WITH EPISIOTOMY
72.21 | MID FORCEPS OPERATION WITH EPISIOTOMY
72.29 | OTHER MID FORCEPS OPERATION
72.31 | HIGH FORCEPS OPERATION WITH EPISIOTOMY
72.39 | OTHER HIGH FORCEPS OPERATION
72.4 | FORCEPS ROTATION OF FETAL HEAD
72.51 | PARTIAL BREECH EXTRACTION WITH FORCEPS TO AFTERCOMING HEAD
72.53 | TOTAL BREECH EXTRACTION WITH FORCEPS TO AFTERCOMING HEAD
72.6 | FORCEPS APPLICATION TO AFTERCOMING HEAD
72.71 | VACUUM EXTRACTION WITH EPISIOTOMY
72.8 | OTHER SPECIFIED INSTRUMENTAL DELIVERY
72.9 | UNSPECIFIED INSTRUMENTAL DELIVERY
Liveborn
Diagnostic Related Groups (DRG):
385 | NEONATES, DIED OR TRANSFERRED TO ANOTHER ACUTE CARE FACILITY
386 | EXTREME IMMATURITY OR RESPIRATORY DISTRESS SYNDROME OF NEONATE
387 | PREMATURITY WITH MAJOR PROBLEMS
388 | PREMATURITY WITHOUT MAJOR PROBLEMS
389 | FULL TERM NEONATE WITH MAJOR PROBLEMS
390 | NEONATE WITH OTHER SIGNIFICANT PROBLEMS
391 | NORMAL NEWBORN
AND
ICD-9-CM diagnosis codes (includes 4th and 5th digits)
Admission type recorded as (4):
764 | SLOW FETAL GROWTH AND FETAL MALNUTRITION
765 | DISORDERS RELATING TO SHORT GESTATION AND UNSPECIFIED LOW BIRTH WEIGHT
766 | DISORDERS RELATING TO LONG GESTATION AND HIGH BIRTH WEIGHT
767 | BIRTH TRAUMA
768 | INTRAUTERINE HYPOXIA AND BIRTH ASPHYXIA
769 | RESPIRATORY DISTRESS SYNDROME
770 | OTHER RESPIRATORY CONDITIONS OF FETUS AND NEWBORN
V30 | SINGLE LIVEBORN
V31 | TWIN, MATE LIVEBORN
V32 | TWIN, MATE STILLBORN
V33 | TWIN, UNSPECIFIED
V34 | OTHER MULTIPLE, MATES ALL LIVEBORN
V35 | OTHER MULTIPLE, MATE ALL STILLBORN
V36 | OTHER MULTIPLE, MATES LIVE- AND STILLBORN
V37 | OTHER MULTIPLE, UNSPECIFIED
V39 | UNSPECIFIED
Long term care facility
ADMISSION SOURCE IS RECORDED AS LONGTERM CARE FACILITY (ASOURCE=3)
Low mortality
Diagnostic Related Groups DRGs
MEDICAL:
015 | TRANSIENT ISCHEMIC ATTACK AND PRECEREBRAL OCCLUSIONS
021 | VIRAL MENINGITIS
030 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE 0–17
031 | CONCUSSION, AGE GREATER THAN 17 WITH CC
032 | CONCUSSION, AGE GREATER THAN 17 WITHOUT CC
044 | ACUTE MAJOR EYE INFECTIONS
045 | NEUROLOGICAL EYE DISORDERS
065 | DYSEQUILIBRIUM
068 | OTITIS MEDIA AND URI, AGE GREATER THAN 17 WITH CC
071 | LARYNGOTRACHEITIS
096 | BRONCHITIS AND ASTHMA, AGE GREATER THAN 17 WITH CC
097 | BRONCHITIS AND ASTHMA, AGE GREATER THAN 17 WITHOUT CC
125 | CIRCULATORY DISORDERS EXCEPT ACUTE MYOCARDIAL INFARCTION WITH CARDIAC CATHETERIZATION WITHOUT COMPLEX DIAGNOSIS
134 | HYPERTENSION
140 | ANGINA PECTORIS
141 | SYNCOPE AND COLLAPSE WITH CC
142 | SYNCOPE AND COLLAPSE WITHOUT CC
143 | CHEST PAIN
237 | SPRAINS, STRAINS AND DISLOCATIONS OF HIP, PELVIS AND THIGH
243 | MEDICAL BACK PROBLEMS
246 | NONSPECIFIC ARTHROPATHIES
295 | DIABETES, AGE 0–35
317 | ADMISSION FOR RENAL DIALYSIS
323 | URINARY STONES WITH CC AND/OR ESW LITHOTRIPSY
324 | URINARY STONES WITHOUT CC
351 | STERILIZATION, MALE
369 | MENSTRUAL AND OTHER FEMALE REPRODUCTIVE SYSTEM DISORDERS
421 | VIRAL ILLNESS, AGE GREATER THAN 17
PEDIATRIC MEDICAL:
026 | SEIZURE AND HEADACHE, AGE 0–17
033 | CONCUSSION, AGE 0–17
070 | OTITIS MEDIA AND URI, AGE 0–17
074 | OTHER EAR, NOSE, MOUTH AND THROAT DIAGNOSES, AGE 0–17
091 | SIMPLE PNEUMONIA AND PLEURISY, AGE 0–17
098 | BRONCHITIS AND ASTHMA, AGE 0–17
184 | ESOPHAGITIS, GASTROENTERITIS AND MISCELLANEOUS DIGESTIVE DISORDERS, AGE 0–17
190 | OTHER DIGESTIVE SYSTEM DIAGNOSES, AGE 0–17
252 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF FOREARM, HAND AND FOOT, AGE 0–17
255 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF UPPER ARM AND LOWER LEG EXCEPT FOOT, AGE 0–17
279 | CELLULITIS, AGE 0–17
282 | TRAUMA TO SKIN, SUBCUTANEOUS TISSUE AND BREAST, AGE 0–17
298 | NUTRITIONAL AND MISCELLANEOUS METABOLIC DISORDERS, AGE GREATER THAN 17 WITHOUT CC
322 | KIDNEY AND URINARY TRACT INFECTION, AGE 0–17
333 | OTHER KIDNEY AND URINARY TRACT DIAGNOSES, AGE 0–17
396 | RED BLOOD CELL DISORDERS, AGE 0–17
422 | VIRAL ILLNESS AND FEVER OF UNKNOWN ORIGIN, AGE 0–17
446 | TRAUMATIC INJURY, AGE 0–17
448 | ALLERGIC REACTIONS, AGE 0–17
451 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE 0–17
SURGICAL:
036 | RETINAL PROCEDURES
037 | ORBITAL PROCEDURES
042 | INTRAOCULAR PROCEDURES
050 | SIALOADENECTOMY
052 | CLEFT LIP AND PALATE REPAIR
053 | SINUS AND MASTOID PROCEDURES, AGE GREATER THAN 17
055 | MISCELLANEOUS EAR, NOSE, MOUTH AND THROAT PROCEDURES
057 | TONSILLECTOMY AND ADENOIDECTOMY PROCEDURES EXCEPT TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE GREATER THAN 17
063 | OTHER EAR, NOSE, MOUTH AND THROAT OR PROCEDURES
166 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITH CC
167 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITHOUT CC
218 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITH CC
219 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITHOUT CC
223 | MAJOR SHOULDER, ELBOW PROCEDURES OR OTHER UPPER EXTREMITY PROCEDURES WITH CC
224 | SHOULDER, ELBOW OR FOREARM PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
225 | FOOT PROCEDURES
228 | MAJOR THUMB OR JOINT PROCEDURES OR OTHER HAND OR WRIST PROCEDURES WITH CC
229 | HAND OR WRIST PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
232 | ARTHROSCOPY
257 | TOTAL MASTECTOMY FOR MALIGNANCY WITH CC
258 | TOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
261 | BREAST PROCEDURE FOR NONMALIGNANCY EXCEPT BIOPSY AND LOCAL EXCISION
262 | BREAST BIOPSY AND LOCAL EXCISION OF NONMALIGNANCY
267 | PERIANAL AND PILONICAL PROCEDURES
289 | PARATHYROID PROCEDURES
290 | THYROID PROCEDURES
293 | OTHER ENDOCRINE, NUTRITIONAL AND METABOLIC OR PROCEDURES WITHOUT CC
334 | MAJOR MALE PELVIC PROCEDURES WITH CC
335 | MAJOR MALE PELVIC PROCEDURES WITHOUT CC
336 | TRANSURETHRAL PROSTATECTOMY WITH CC
337 | TRANSURETHRAL PROSTATECTOMY WITHOUT CC
356 | FEMALE REPRODUCTION SYSTEM RECONCSTRUCTIVE PROCEDURES
358 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITH CC
359 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITHOUT CC
360 | VAGINA, CERVIX AND VULVA PROCEDURES
361 | LAPAROSCOPY AND INCISIONAL TUBAL INTERRUPTION
362 | ENDOSCOPIC TUBAL INTERRUPTION
364 | D AND C, CONIZATION EXCEPT FOR MALIGNANCY
439 | SKIN GRAFTS FOR INJURIES
441 | HAND PROCEDURES FOR INJURIES
491 | MAJOR JOINT AND LIMB REATTACHMENT PROCEUDRES OF UPPER EXTREMITY
499 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITH CC
500 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITHOUT CC
PEDIATRIC SURGICAL:
060 | TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE 0–17
062 | MYRINGOTOMY WITH TUBE INSERTION, AGE 0–17
156 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE 0–17
163 | HERNIA PROCEDURES, AGE 0–17
212 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURES, AGE 0–17
220 | LOWER EXTREMITY AND HUMEROUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE 0–17
393 | SPLENECTOMY, AGE 0–17
OBSTETRIC:
370 | CESAREAN SCTION WITH CC
371 | CESAREAN SECTION WITHOUT CC
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY WITH STERILIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
377 | POSTPARTUM AND POSTABORTION DIAGNOSES WITH OR PROCEDURE
378 | ECTOPIC PREGNANCY
379 | THREATENED ABORTION
380 | ABORTION WITHOUT D AND C
381 | ABORTION WITH D AND C, ASPIRATION CURETTAGE OR HYTEROTOMY
382 | FALSE LABOR
383 | OTHER ANTEPARTUM DIAGNOSES WITH MEDICAL COMPLICATIONS
384 | OTHER ANTEPARTUM DIAGNOSES WITHOUT MEDICAL COMPLICATIONS
NEONATAL:
386 | EXTREME IMMATURITY OR RESPIRATORY DISTRESS SYNDROME OF NEONATE
387 | PREMATURITY WITH MAJOR PROBLEMS
388 | PREMATURITY WITHOUT MAJOR PROBLEMS
390 | NEONATE WITH OTHER SIGNIFICANT PROBLEMS
391 | NORMAL NEWBORN
PSYCHIATRIC:
425 | ACUTE ADJUSTMENT REACTIONS AND DISTURBANCES OF PSYCHOSOCIAL DYSFUNCTION
426 | DEPRESSIVE NEUROSES
427 | NEUROSIES EXCEPT DEPRESSIVE
428 | DISORDERS OF PERSONALITY AND IMPULSE CONTROL
431 | CHILDHOOD MENTAL DISORDERS
432 | OTHER MENTAL DISORDER DIAGNOSES
434 | ALCOHOL/DRUG ABUSE OR DEPENDENCE, DETOXIFICATION OR OTHER SYMPTOMATIC TREATMENT WITH CC
435 | ALCOHOL/DRUG ABUSE OR DEPENDENCE, DETOXIFICATION OR OTHER SYMPTOMATIC TREATMENT WITHOUT CC
436 | ALCOHOL/DRUG DEPENDENCE WITH REHABILITATION THERAPY
Lung or pleural biopsy
ICD-9-CM Procedure codes:
332.6 | CLOSED [PERCUTANEOUS] [NEEDLE] BIOPSY OF LUNG
332.8 | OPEN BIOPSY OF LUNG
342.4 | PLEURAL BIOPSY
Lymphoid malignancy
ICD-9-CM diagnosis codes( includes 4^th^ and 5^th^ digits):
200 | LYMPHOSARCOMA AND RETICULOSARCOMA
201 | HODGKINS DISEASE
202 | OTHER MALIGNANT NEOPLASMS OF LYMPHOID AND HISTIOCYTIC TISSUE
203 | MULTIPLE MYELOMA AND IMMUNOPROLIFERATIVE NEOPLASMS
204 | LYMPHOID LEUKEMIA
205 | MYELOID LEUKEMIA
206 | MONOCYTIC LEUKEMIA
207 | OTHER SPECIFIED LEUKEMIA
208 | LEUKEMIA OF UNSPECIFIED CELL TYPE
Medical
Diagnostic Related Groups (DRGs):
009 | SPINAL DISORDERS AND INJURIES
010 | NERVOUS SYSTEM NEOPLASMS WITH CC
011 | NERVOUS SYSTEM NEOPLASMS WITH CC
012 | DEGENERATIVE NERVOUS SYSTEM DISORDERS
013 | MULTIPLE SCLEROSIS AND CEREBELLAR ATAXIA
014 | SPECIFIC CEREBROVASCULAR DISORDERS EXCEPT TRANSIENT ISCHEMIC ATTACK
015 | TRANSIENT ISCHEMIC ATTACK AND PRECEREBRAL OCCLUSIONS
016 | NONSPECIFIC CEREBROVASCULAR DISORDERS WITH CC
017 | NONSPECIFIC CEREBROVASCULAR DISORDERS WITHOUT CC
018 | CRANIAL AND PERIPHERAL NERVE DISORDERS WITH CC
019 | CRANIAL AND PERIPHERAL NERVE DISORDERS WITHOUT CC
020 | NERVOUS SYSTEM INFECTION EXCEPT VIRAL MENINGITIS
021 | VIRAL MENINGITIS
022 | HYPERTENSIVE ENCEPHALOPATHY
023 | NONTRAUMATIC STUPOR AND COMA
024 | SEIZURE AND HEADACHE, AGE GREATER THAN 17 WITH CC
025 | SEIZURE AND HEADACHE, AGE GREATER THAN 17 WITHOUT CC
026 | SEIZURE AND HEADACHE, AGE 0–17
027 | TRAUMATIC STUPOR AND COMA, COMA GREATER THAN ONE HOUR
028 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 19 WITH CC
029 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 17 WITHOUT CC
030 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE 0–17
031 | CONCUSSION, AGE GREATER THAN 17 WITH CC
032 | CONCUSSION, AGE GREATER THAN 17 WITHOUT CC
033 | CONCUSSION, AGE 0–17
034 | OTHER DISORDERS OF NERVOUS SYSTEM WITH CC
035 | OTHER DISORDERS OF NERVOUS SYSTEM WITHOUT CC
043 | HYPHEMA
044 | ACUTE MAJOR EYE INFECTIONS
045 | NEUROLOGICAL EYE DISORDERS
046 | OTHER DISORDERS OF THE EYE, AGE GREATER THAN 17 WITH CC
047 | OTHER DISORDER OF THE EYE, AGE GREATER THAN 17 WITHOUT CC
048 | OTHER DISORDERS OF THE EYE, AGE 0–17
064 | EAR, NOSE, MOUTH AND THROAT MALIGNANCY
065 | DISEQUILIBRIA
066 | EPISTAXIS
067 | EPIGLOTITIS
068 | OTITIS MEDIA AND URI, AGE GREATER THAN 17 WITH CC
069 | OTITIS MEDIA AND URI, AGE GREATER THAN 17 WITHOUT CC
070 | OTITIS MEDIA AND URI, AGE 0–17
071 | LARYNGOTRACHEITIS
072 | NASAL TRAUMA AND DEFORMITY
073 | OTHER EAR, NOSE, MOUTH AND THROAT DIAGNOSES, AGE GREATER THAN 17
074 | OTHER EAR, NOSE, MOUTH AND THROAT DIAGNOSES, AGE 0–17
078 | PULMONARY EMBOLISM
079 | RESPIRATORY INFECTIONS AND INFLAMMATIONS, AGE GREATER THAN 17 WITH CC
080 | RESPIRATORY INFECTIONS AND INFLAMMATIONS, AGE GREATER THAN 17 WITHOUT CC
081 | SIMPLE PNEUMONIA AND PLEURISY, AGE GREATER THAN 17 WITH CC
082 | RESPIRATORY NEOPLASMS
083 | MAJOR CHEST TRAUMA WITH CC
084 | MAJOR CHEST TRAUMA WITHOUT CC
085 | PLEURAL EFFUSION WITH CC
086 | PLEURAL EFFUSION WITHOUT CC
087 | PULMONARY EDEMA AND RESPIRATORY FAILURE
088 | CHRONIC OBSTRUCTIVE PULMONARY DISEASE
089 | SIMPLE PNEUMONIA AND PLEURISY, AGE GREATER THAN 17 WITH CC
090 | SIMPLE PNEUMONIA AND PLEURISY, AGE GREATER THAN 17 WITHOUT CC
091 | SIMPLE PNEUMONIA AND PLEURISY, AGE 0–17
092 | INTERSTITIAL LUNG DISEASE WITH CC
093 | INTERSTITIAL LUNG DISEASE WITHOUT CC
094 | PNEUMOTHORAX WITH CC
095 | PNEUMOTHORAX WITHOUT CC
096 | BRONCHITIS AND ASTHMA, AGE GREATER THAN 17 WITH CC
097 | BRONCHITIS AND ASTHMA, AGE GREATER THAN 17 WITHOUT CC
098 | BRONCHITIS AND ASTHMA, AGE 0–17
099 | RESPIRATORY SIGNS AND SYMPTOMS WITH CC
100 | RESPIRATORY SIGNS AND SYMPTOMS WITHOUT CC
101 | OTHER RESPIRATORY SYSTEM DIAGNOSES WITH CC
102 | OTHER RESPIRATORY SYSTEM DIAGNOSES WITHOUT CC
121 | CIRCULATORY DISORDERS WITH ACUTE MYOCARDIAL INFARCTION AND MAJOR COMPLICATION, DISCHARGED ALIVE
122 | CIRCULATORY DISORDERS WITH ACUTE MYOCARDIAL INFARCTION WITHOUT MAJOR COMPLICATION, DISCHARGED ALIVE
123 | CIRCULATORY DISORDERS WITH ACUTE MYOCARDIAL INFARCTION, EXPIRED
124 | CIRCULATORY DISORDERS EXCEPT ACUTE MYOCARDIAL INFARCTION WITH CARDIAC CATHETERIZATION AND COMPLEX DIAGNOSIS
125 | CIRCULATORY DISORDERS EXCEPT ACUTE MYOCARDIAL INFARCTION WITH CARDIAC CATHETERIZATION WITHOUT COMPLEX DIAGNOSIS
126 | ACUTE AND SUB ACUTE ENDOCARDITIS
127 | HEART FAILURE AND SHOCK
128 | DEEP VEIN THROMBOPHLEBITIS
129 | CARDIAC ARREST, UNEXPLAINED
130 | PERIPHERAL VASCULAR DISORDERS WITH CC
131 | PERIPHERAL VASCULAR DISORDERS WITHOUT CC
132 | ATHEROSCLEROSIS WITH CC
133 | ATHEROSCLEROSIS WITHOUT CC
134 | HYPERTENSION
135 | CARDIAC CONGENITAL AND VALVULAR DISORDERS, AGE GREATER THAN 17 WITH CC
136 | CARDIAC CONGENITAL AND VALVULAR DISORDERS, AGE GREATER THAN 17 WITHOUT CC
137 | CARDIAC CONGENITAL AND VALVULAR DISORDERS, AGE GREATER THAN 17 WITHOUT CC
138 | CARDIAC ARRHYTHMIA AND CONDUCTION DISORDERS WITH CC
139 | CARDIAC ARRHYTHMIA AND CONDUCTION DISORDERS WITHOUT CC
140 | ANGINA PECTORIS
141 | SYNCOPE AND COLLAPSE WITH CC
142 | SYNCOPE AND COLLAPSE WITHOUT CC
143 | CHEST PAIN
144 | OTHER CIRCULATORY SYSTEM DIAGNOSES WITH CC
145 | OTHER CIRCULATORY SYSTEM DIAGNOSES WITHOUT CC
172 | DIGESTIVE MALIGNANCY WITH CC
173 | DIGESTIVE MALIGNANCY WITHOUT CC
174 | GI HEMORRHAGE WITH CC
175 | GI HEMORRHAGE WITHOUT CC
176 | COMPLICATED PEPTIC ULCER
177 | UNCOMPLICATED PEPTIC ULCER WITH CC
178 | UNCOMPLICATED PEPTIC ULCER WITHOUT CC
179 | INFLAMMATORY BOWEL DISEASE
180 | GI OBSTRUCTION WITH CC
181 | GI OBSTRUCTION WITHOUT CC
182 | ESOPHAGITIS, GASTROENTERITIS AND MISCELLANEOUS DIGESTIVE DISORDERS, AGE GREATER THAN 17 WITH CC
183 | ESOPHAGITIS, GASTROENTERITIS AND MISCELLANEOUS DIGESTIVE DISORDERS, AGE GREATER THAN 17 WITHOUT CC
184 | ESOPHAGITIS, GASTROENTERITIS AND MISCELLANEOUS DIGESTIVE DISORDERS, AGE 0–17
185 | DENTAL AND ORAL DISEASES EXCEPT EXTRACTIONS AND RESTORATIONS, AGE GREATER THAN 17
186 | DENTAL AND ORAL DISEASES EXCEPT EXTRACTIONS AND RESTORATIONS, AGE 0–17
187 | DENTAL EXTRACTIONS AND RESTORATIONS
188 | OTHER DIGESTIVE SYSTEM DIAGNOSES, AGE GREATER THAN 17 WITH CC
189 | OTHER DIGESTIVE SYSTEM DIAGNOSES, AGE GREATER THAN 17 WITHOUT CC
190 | OTHER DIGESTIVE SYSTEM DIAGNOSES, AGE 0–17
202 | CIRRHOSIS AND ALCOHOLIC HEPATITIS
203 | MALIGNANCY OF HEPATOBILIARY SYSTEM OR PANCREAS
204 | DISORDERS OF PANCREAS EXCEPT MALIGNANCY
205 | DISORDERS OF LIVER EXCEPT MALIGNANCY, CIRRHOSIS AND ALCOHOLIC HEPATITIS WITH CC
206 | DISORDERS OF LIVER EXCEPT MALIGNANCY, CIRRHOSIS AND ALCOHOLIC HEPATITIS WITHOUT CC
207 | DISORDERS OF THE BILIARY TRACT WITH CC
208 | DISORDERS OF THE BILIARY TRACT WITHOUT CC
235 | FRACTURES OF FEMUR
236 | FRACTURES OF HIP AND PELVIS
237 | SPRAINS, STRAINS AND DISLOCATIONS OF HIP, PELVIS AND THIGH
238 | OSTEOMYELITIS
239 | PATHOLOGICAL FRACTURES AND MUSCULOSKELETAL AND CONNECTIVE TISSUE MALIGNANCY
240 | CONNECTIVE TISSUE DISORDERS WITH CC
241 | CONNECTIVE TISSUE DISORDERS WITHOUT CC
242 | SEPTIC ARTHRITIS
243 | MEDICAL BACK PROBLEMS
244 | BONE DISEASES AND SPECIFIC ARTHROPATHIES WITH CC
245 | BONE DISEASES AND SPECIFIC ARTHROPATHIES WITHOUT CC
246 | NONSPECIFIC ARTHROPATHIES
247 | SIGNS AND SYMPTOMS OF MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE
248 | TENDONITIS, MYOSITIS AND BURSITIS
249 | AFTERCARE, MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE
250 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF FOREARM, HAND AND FOOT, AGE GREATER THAN 17 WITH CC
251 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF FOREARM, HAND AND FOOT, AGE GREATER THAN 17 WITHOUT CC
252 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF FOREARM, HAND AND FOOT, AGE 0–17
253 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF UPPER ARM AND LOWER LEG EXCEPT FOOT, AGE GREATER THAN 17 WITH CC
254 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF UPPER ARM AND LOWER LEG EXCEPT FOOT, AGE GREATER THAN 17 WITHOUT CC
255 | FRACTURES, SPRAINS, STRAINS AND DISLOCATIONS OF UPPER ARM AND LOWER LEG EXCEPT FOOT, AGE 0–17
256 | OTHER MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE DIAGNOSES
271 | SKIN ULCERS
272 | MAJOR SKIN DISORDERS WITH CC
273 | MAJOR SKIN DISORDERS WITHOUT CC
274 | MALIGNANT BREAST DISORDERS WITH CC
275 | MALIGNANT BREAST DISORDERS WITHOUT CC
276 | NONMALIGNANT BREAST DISORDERS
277 | CELLULITIS, AGE GREATER THAN 17 WITH CC
278 | CELLULITIS, AGE GREATER THAN 17 WITHOUT CC
279 | CELLULITIS, AGE 0–17
280 | TRAUMA TO SKIN, SUBCUTANEOUS TISSUE AND BREAST, AGE GREATER THAN 17 WITH CC
281 | TRAUMA TO SKIN, SUBCUTANEOUS TISSUE AND BREAST, AGE GREATER THAN 17 WITHOUT CC
282 | TRAUMA TO SKIN, SUBCUTANEOUS TISSUE AND BREAST, AGE 0–17
283 | MINOR SKIN DISORDERS WITH CC
284 | MINOR SKIN DISORDERS WITHOUT CC
294 | DIABETES, AGE GREATER THAN 35
295 | DIABETES, AGE 0–35
296 | NUTRITIONAL AND MISCELLANEOUS METABOLIC DISORDERS, AGE GREATER THAN 17 WITH CC
297 | NUTRITIONAL AND MISCELLANEOUS METABOLIC DISORDERS, AGE GREATER THAN 17 WITHOUT CC
298 | NUTRITIONAL AND MISCELLANEOUS METABOLIC DISORDERS, AGE 0–17
299 | INBORN ERRORS OF METABOLISM
300 | ENDOCRINE DISORDERS WITH CC
301 | ENDOCRINE DISORDERS WITHOUT CC
316 | RENAL FAILURE
317 | ADMISSION FOR RENAL DIALYSIS
318 | KIDNEY AND URINARY TRACT NEOPLASMS WITH CC
319 | KIDNEY AND URINARY TRACT NEOPLASMS WITHOUT CC
320 | KIDNEY AND URINARY TRACT INFECTIONS, AGE GREATER THAN 17 WITH CC
321 | KIDNEY AND URINARY TRACT INFECTIONS, AGE GREATER THAN 17 WITHOUT CC
322 | KIDNEY AND URINARY TRACT INFECTION, AGE 0–17
323 | URINARY STONES WITH CC AND/ OR ESW LITHOTRIPSY
324 | URINARY STONES WITHOUT CC
325 | KIDNEY AND URINARY TRACT SIGNS AND SYMPTOMS, AGE GREATER THAN 17 WITH CC
326 | KIDNEY AND URINARY TRACT SIGNS AND SYMPTOMS, AGE GREATER THAN 17 WITHOUT CC
327 | KIDNEY AND URINARY TRACT SIGNS AND SYMPTOMS, AGE 0–17
328 | URETHRAL STRICTURE, AGE GREATER THAN 17 WITH CC
329 | URETHRAL STRICTURE, AGE GREATER THAN 17 WITHOUT CC
330 | URETHRAL STRICTURE, AGE 0–17
331 | OTHER KIDNEY AND URINARY TRACT DIAGNOSES, AGE GREATER THAN 17 WITH CC
332 | OTHER KIDNEY AND URINARY TRACT DIAGNOSES, AGE GREATER THAN 17 WITHOUT CC
333 | OTHER KIDNEY AND URINARY TRACT DIAGNOSES, AGE 0–17
346 | MALIGNANCY OF MALE REPRODUCTIVE SYSTEM WITH CC
347 | MALIGNANCY OF MALE REPRODUCTIVE SYSTEM WITHOUT CC
348 | BENIGN PROSTATIC HYPERTROPHY WITH CC
349 | BENIGN PROSTATIC HYPERTROPHY WITHOUT CC
350 | INFLAMMATION OF THE MALE REPRODUCTIVE SYSTEM
351 | STERILIZATION, MALE
352 | OTHER MALE REPRODUCTIVE SYSTEM DIAGNOSES
366 | MALIGNANCY OF FEMALE REPRODUCTIVE SYSTEM WITH CC
367 | MALIGNANCY OF FEMALE REPRODUCTIVE SYSTEM WITHOUT CC
368 | INFECTIONS OF FEMALE REPRODUCTIVE SYSTEM
369 | MENSTRUAL AND OTHER FEMALE REPRODUCTIVE SYSTEM DISORDERS
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
376 | POSTPARTUM AND POSTABORTION DIAGNOSES WITHOUT OR PROCEDURE
378 | ECTOPIC PREGNANCY
379 | THREATENED ABORTION
380 | ABORTION WITHOUT D AND C
382 | FALSE LABOR
383 | OTHER ANTEPARTUM DIAGNOSES WITH MEDICAL COMPLICATIONS
384 | OTHER ANTEPARTUM DIAGNOSES WITHOUT MEDICAL COMPLICATIONS
395 | RED BLOOD CELL DISORDERS, AGE GREATER THAN 17
396 | RED BLOOD CELL DISORDERS, AGE 0–17
397 | COAGULATION DISORDERS
398 | RETICULOENDOTHELIAL AND IMMUNITY DISORDERS WITH CC
399 | RETICULOENDOTHELIAL AND IMMUNITY DISORDERS WITHOUT CC
403 | LYMPHOMA AND NONACUTE LEUKEMIA WITH CC
404 | LYMPHOMA AND NONACUTE LEUKEMIA WITHOUT CC
405 | ACUTE LEUKEMIA WITHOUT MAJOR OR PROCEDURE, AGE 0–17
409 | RADIOTHERAPY
410 | CHEMOTHERAPY WITHOUT ACUTE LEUKEMIA AS SECONDARY DIAGNOSIS
411 | HISTORY OF MALIGNANCY WITHOUT ENDOSCOPY
412 | HISTORY OF MALIGNANCY WITH ENDOSCOPY
413 | OTHER MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASM DIAGNOSES WITH CC
414 | OTHER MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASM DIAGNOSES WITHOUT CC
416 | SEPTICEMIA, AGE GREATER THAN 17
417 | SEPTICEMIA, AGE 0–17
418 | POSTOPERATIVE AND POSTTRAUMATIC INFECTIONS
419 | FEVER OF UNKNOWN ORIGIN, AGE GREATER THAN 17 WITH CC
420 | FEVER OF UNKNOWN ORIGIN, AGE GREATER THAN 17 WITHOUT CC
421 | VIRAL ILLNESS, AGE GREATER THAN 17
422 | VIRAL ILLNESS AND FEVER OF UNKNOWN ORIGIN, AGE 0–17
423 | OTHER INFECTIOUS AND PARASITIC DISEASES DIAGNOSES
425 | ACUTE ADJUSTMENT REACTIONS AND DISTURBANCES OF PSYCHOSOCIAL DYSFUNCTION
426 | DEPRESSIVE NEUROSES
427 | NEUROSES EXCEPT DEPRESSIVE
428 | DISORDERS OF PERSONALITY AND IMPULSE CONTROL
429 | ORGANIC DISTURBANCES AND MENTAL RETARDATION
430 | PSYCHOSES
431 | CHILDHOOD MENTAL DISORDERS
432 | OTHER MENTAL DISORDER DIAGNOSES
433 | ALCOHOL/DRUG ABUSE OR DEPENDENCE, LEFT AGAINST MEDICAL ADVICE
434 | ALCOHOL/DRUG ABUSE OR DEPENDENCE, DETOXIFICATION OR OTHER SYMPTOMATIC TREATMENT WITH CC
435 | ALCOHOL/DRUG ABUSE OR DEPENDENCE, DETOXIFICATION OR OTHER SYMPTOMATIC TREATMENT WITHOUT CC
436 | ALCOHOL/DRUG DEPENDENCE WITH REHABILITATION THERAPY
437 | ALCOHOL DRUG DEPENDENCE WITH COMBINED REHABILITATION AND DETOXIFICATION THERAPY
444 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITH CC
445 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITHOUT CC
446 | TRAUMATIC INJURY, AGE 0–17
447 | ALLERGIC REACTIONS, AGE GREATER THAN 17
448 | ALLERGIC REACTIONS, AGE 0–17
449 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITH CC
450 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITHOUT CC
451 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE 0–17
452 | COMPLICATIONS OF TREATMENT WITH CC
453 | COMPLICATIONS OF TREATMENT WITHOUT CC
454 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITH CC
455 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITHOUT CC
456 | NO LONGER VALID
457 | NO LONGER VALID
460 | NO LONGER VALID
462 | REHABILITATION
463 | SIGNS AND SYMPTOMS WITH CC
464 | SIGNS AND SYMPTOMS WITHOUT CC
465 | AFTERCARE WITH HISTORY OF MALIGNANCY AS SECONDARY DIAGNOSIS
466 | AFTERCARE WITHOUT HISTORY OF MALIGNANCY AS SECONDARY DIAGNOSIS
467 | OTHER FACTORS INFLUENCING HEALTH STATUS
473 | ACUTE LEUKEMIA WITHOUT MAJOR OR PROCEDURE, AGE GREATER THAN 17
474 | NO LONGER VALID
475 | RESPIRATORY SYSTEM DIAGNOSIS WITH VENTILATOR SUPPORT
487 | OTHER MULTIPLE SIGNIFICANT TRAUMA
489 | HIV WITH MAJOR RELATED CONDITION
490 | HIV WITH OR WITHOUT OTHER RELATED CONDITION
492 | CHEMOTHERAPY WITH ACUTE LEUKEMIA AS SECONDARY DIAGNOSIS
Metastatic cancer
ICD-9-CM diagnosis codes (includes all 4^th^ and 5^th^ digits):
196 | SECONDARY AND UNSPECIFIED MALIGNANT NEOPLASM OF LYMPH NODES
197 | SECONDARY MALIGNANT NEOPLASM OF RESPIRATORY AND DIGESTIVE SYSTEMS
198 | SECONDARY MALIGNANT NEOPLASM OF OTHER SPECIFIED SITES
1990 | MALIGNANT NEOPLASM WITHOUT SPECIFICATION OF SITE, DISSEMINATED
Obstetric trauma
ICD-9-CM diagnosis codes:
664.30,1,4 | TRAUMA TO PERINEUM AND VULVA DURING DELIVERY, FOURTH-DEGREE PERINEAL LACERATION
665.30, 1, 4 | OTHER OBSTETRICAL TRAUMA, LACERATION OF CERVIX
665.40, 1, 4 | OTHER OBSTETRICAL TRAUMA, HIGH VAGINAL LACERATIONS
665.50, 1, 4 | OTHER OBSTETRICAL TRAUMA, OTHER INJURY TO PELVIC ORGANS
ICD-9-CM procedure codes:
75.50 | REPAIR OF CURRENT OBSTETRIC LACERATIONS UTERUS
75.51 | REPAIR OF CURRENT OBSTETRIC LACERATIONS OF CERVIX
75.52 | REPAIR OF CURRENT OBSTETRIC LACERATIONS OF CORPUS UTERI
75.61 | REPAIR OF CURRENT OBSTETRIC LACERATION OF BLADDER AND URETHRA
75.62 | REPAIR OF CURRENT OBSTETRIC LACERATION OF RECTUM AND SPHINCTER ANI
Physiologic and metabolic derangements
ICD-9-CM diagnosis codes:
DIABETES WITH KETOACIDOSIS:
250.10 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
250.11 | TYPE 1 NOT STATED AS UNCONTROLLED
250.12 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
250.13 | TYPE 1 UNCONTROLLED
DIABETES WITH HYPEROSMOLARITY:
250.20 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
250.21 | TYPE 1 NOT STATED AS UNCONTROLLED
250.22 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
250.23 | TYPE 1 UNCONTROLLED
DIABETES WITH OTHER COMA:
250.30 | TYPE 2, OR UNSPECIFIED TYPE, NOT STATED AS UNCONTROLLED
250.31 | TYPE 1 NOT STATED AS UNCONTROLLED
250.32 | TYPE 2 OR UNSPECIFIED TYPE, UNCONTROLLED
250.33 | TYPE 1 UNCONTROLLED
ACUTE RENAL FAILURE:
584.5 | WITH LESION OF TUBULAR NECROSIS
584.6 | WITH LESION OF RENAL CORTICAL NECROSIS
584.7 | WITH LESION OF RENAL MEDULLARY [PAPILLARY] NECROSIS
584.8 | WITH OTHER SPECIFIED PATHOLOGICAL LESION IN KIDNEY
584.9 | ACUTE RENAL FAILURE, UNSPECIFIED
Poisoning
ICD-9-CM diagnosis codes (includes 4^th^ and 5^th^ digits):
960 | POISONING BY ANTIBIOTICS
961 | POISONING BY OTHER ANTI-INFECTIVES
962 | POISONING BY HORMONES AND SYNTHETIC SUBSTITUTES
963 | POISONING BY PRIMARILY SYSTEMIC AGENTS
964 | POISONING BY AGENTS PRIMARILY AFFECTING BLOOD CONSTITUENTS
965 | POISONING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
966 | POISONING BY ANTICONVULSANTS AND ANTI-PARKINSONISM DRUGS
967 | POISONING BY SEDATIVES AND HYPNOTICS
968 | POISONING BY OTHER CENTRAL NERVOUS SYSTEM DEPRESSANTS AND ANESTHETICS
969 | POISONING BY PSYCHOTROPIC AGENTS
970 | POISONING BY CENTRAL NERVOUS SYSTEM STIMULANTS
971 | POISONING BY DRUGS PRIMARILY AFFECTING THE AUTONOMIC NERVOUS SYSTEM
972 | POISONING BY AGENTS PRIMARILY AFFECTING THE CARDIOVASCULAR SYSTEM
973 | POISONING BY AGENTS PRIMARILY AFFECTING THE GASTROINTESTINAL SYSTEM
974 | POISONING BY WATER, MINERAL, AND URIC ACID METABOLISM DRUGS
975 | POISONING BY AGENTS PRIMARILY ACTING ON THE SMOOTH AND SKELETAL MUSCLES AND RESPIRATORY SYSTEM
976 | POISONING BY AGENTS PRIMARILY AFFECTING SKIN AND MUCOUS MEMBRANE, OPTHAMOLOGICAL, OTORHINOLARYNCOLOGICAL AND DENTAL DRUGS
977 | POISONING BY OTHER AND UNSPECIFIED DRUGS AND MEDICINAL SUBSTANCES
978 | POISONING BY BACTERIAL VACCINES
979 | POISONING BY OTHER VACCINES AND BIOLOGICAL SUBSTANCES
E850 | ACCIDENTAL POISONING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
E851 | ACCIDENTAL POISONING BY BARBITURATES
E852 | ACCIDENTAL POISONING BY OTHER SEDATIVES AND HYPNOTICS
E853 | ACCIDENTAL POISONING BY TRANQUILIZERS
E854 | ACCIDENTAL POISONING BY OTHER PSYCHOTROPIC AGENTS
E855 | ACCIDENTAL POISONING BY OTHER DRUGS ACTING ON CENTRAL AND AUTONOMIC NERVOUS SYSTEM
E856 | ACCIDENTAL POISONING BY ANTIBIOTICS
E857 | ACCIDENTAL POISONING BY OTHER ANTI-INFECTIVES
E858 | ACCIDENTAL POISONING BY OTHER DRUGS
E860 | ACCIDENTAL POISONING BY ALCOHOL, NEC
E861 | ACCIDENTAL POISONING BY CLEANING AND POLISHING AGENTS, DISINFECTANTS, PAINTS, AND VARNISHES
E862 | ACCIDENTAL POISONING BY PETROLEUM PRODUCTS, OTHER SOLVENTS AND THEIR VAPORS, NEC
E863 | ACCIDENTAL POISONONING BY AGRICULTURAL AND HORTICULTURAL CHEMICAL AND PHARMACEUTICAL PREPARATIONS OTHER THAN PLANT FOODS AND FERTILIZERS
E864 | ACCIDENTAL POISONING BY CORROSIVES AND CAUSTICS, NEC
E865 | ACCIDENTAL POISONING FROM POISONOUS FOODSTUFFS AND POISONOUS PLANTS
E866 | ACCIDENTAL POISONG BY OTHER AND UNSPECIFIED SOLID AND LIQUID SUBSTANCES
E867 | ACCIDENTAL POISONOING BY GAS DISTRIBUTED BY PIPELINE
E868 | ACCIDENTAL POISONING BY OTHER UTILITY GAS AND OTHER CARBON MONOXIDE
E869 | ACCIDENTAL POISONING BY OTHER GASES AND VAPORS
E951 | SUICIDE AND SELF-INFLICTED POISONING BY GASES IN DOMESTIC USE
E952 | SUICIDE AND SELF-INFLICTED POISONING BY OTHER GASES AND VAPORS
E962 | ASSAULT BY POISONING
E980 | POISONING BY SOLID OR LIQUID SUBSTANCES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E981 | POISONING BY GASES IN DOMESTIC USE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E982 | POISONING BY OTHER GASES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
Postoperative hematoma
ICD-9-CM diagnosis codes:
998.12 | HEMATOMA COMPLICATING A PROCEDURE
Postoperative hemorrhage or hematoma
ICD-9-CM diagnosis codes:
998.11 | HEMORRHAGE COMPLICATING A PROCEDURE
Preterm infant
ICD-9-CM diagnosis codes:
765.01–765.08 EXTREME IMMATURITY
765.11–765.18 OTHER PRETERM INFANTS
Pulmonary embolism
ICD-9-CM diagnosis codes:
415.11 | IAGTROGENIC PULMONARY EMBOLISM AND INFARCTION
415.19 | OTHER PULMONARY EMBOLISM
Seizure
ICD-9-CM diagnosis codes:
345.00 | GENERALIZED NONCONVULSIVE EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.01 | GENERALIZED NONCONVULSIVE EPILEPSY - WITH INTRACTABLE EPILEPSY
345.10 | GENERALIZED CONVULSIVE EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.11 | GENERALIZED CONVULSIVE EPILEPSY - WITH INTRACTABLE EPILEPSY
345.2 | EPILEPSY-PETIT MAL STATUS
345.3 | EPILEPSY-GRAND MAL STATUS
345.40 | PARTIAL EPILEPSY, WITH IMPAIRMENT OF CONSCIOUSNESS - WITH INTRACTABLE EPILEPSY
345.41 | PARTIAL EPILEPSY, WITH IMPAIRMENT OF CONSCIOUSNESS - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.50 | PARTIAL EPILEPSY, WITHOUT MENTION OF IMPAIRMENT OF CONSCIOUSNESS, - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.51 | PARTIAL EPILEPSY, WITHOUT MENTION OF IMPAIRMENT OF CONSCIOUSNESS - WITH INTRACTABLE EPILEPSY
345.60 | INFANTILE SPASMS - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.61 | INFANTILE SPASMS - WITH INTRACTABLE EPILEPSY
345.70 | EPILEPSIA PARTIALIS CONTINUA - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.71 | EPILEPSIA PARTIALIS CONTINUA - WITH INTRACTABLE EPILEPSY
345.80 | OTHER FORMS OF EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.81 | OTHER FORMS OF EPILEPSY - WITH INTRACTABLE EPILEPSY
345.90 | EPILEPSY, UNSPECIFIED - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.91 | EPILEPSY, UNSPECIFIED - WITH INTRACTABLE EPILEPSY
780.31 | FEBRILE CONVULSIONS
780.39 | OTHER CONVULSIONS
780.3 | CONVULSIONS (OLD CODE NO LONGER VALID)
Self inflicted injury
ICD-9-CM diagnosis codes:
SUICIDE AND SELF-INFLICTED POISONING BY SOLID OR LIQUID SUBSTANCE:
E950.0 | ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
E950.1 | BARBITURATES
E950.2 | OTHER SEDATIVE AND HYPNOTICS
E950.3 | TRANQUILIZIERS AND OTHER PSYCHOTROPIC AGENTS
E950.4 | OTHER SPECIFIED DRUGS AND MEDICINAL SUBSTANCES
E950.5 | UNSPECIFIED DRUG OR MEDICINAL SUBSTANCE
E950.6 | AGRICULTURAL AND HORTICULTURAL CHEMICAL AND PHARMACEUTICAL PREPARATIONS OTHER THAN PLANT FOODS AND FERTILIZERS
E950.7 | CORROSIVE AND CAUSTIC SUBSTANCES
E950.8 | ARSENIC AND ITS COMPOUNDS
E950.9 | OTHER AND UNSPECIFIED SOLID AND LIQUID SUBSTANCES
SUICIDE AND SELF-INFLICED POISONING BY GASES IN DOMESTIC USE:
E951.0 | GAS DISTRIBUTED BY PIPELINE
E951.1 | LIQUEFIED PETROLEUM GAS DISTRIBUTED IN MOBILE CONTAINERS
E951.8 | OTHERS UTILITY GASES
E952.0 | MOTOR VEHICLE EXHAUST GAS
E952.1 | OTHER CARBON MONOXIDE
E952.8 | OTHER SPECIFIED GASES AND VAPORS
E952.9 | UNSPECIFIED GASES AND VAPORS
SUICIDE AND SELF-INFLICTED INJURY BY HANGING, STRANGULATION, AND SUFFOCATION:
E953.0 | HANGING
E953.1 | SUFFOCATION BY PLASTIC BAG
E953.8 | OTHER SPECIFIED MEANS
E954 | SUICIDE AND SELF-INFLICTED INJURY BY SUBMERSION [DROWNING]
SUICIDE AND SELF-INFLICTED INJURY BY FIREARMS AND EXPLOSIVES:
E955.0 | HANDGUN
E955.1 | SHOTGUN
E955.2 | HUNTING RIFLE
E955.3 | MILITARY FIREARMS
E955.4 | OTHER AND UNSPECIFIED FIREARMS
E955.5 | EXPLOSIVES
E955.9 | UNSPECIFIED
E956 | SUICIDE AND SELF INFLICTED INJURY BY CUTTING AND PIERCING INSTRUMENT
SUICIDE AND SELF-INFLICTED INJURY BY JUMPING FROM A HIGH PLACE:
E957.0 | RESIDENTIAL PREMISES
E957.1 | OTHER MAN-MADE STRUCTURES
E957.2 | NATURAL SITES
E957.3 | UNSPECIFIED
SUICIDE AND SELF-INFLICTED INJURY BY OTHER AND UNSPECIFIED MEANS:
E958.0 | JUMPING OR LYING BEFORE MOVING OBJECT
E958.1 | BURNS, FIRE
E958.2 | SCALD
E958.3 | EXTREMES OF COLD
E958.4 | ELECTROCUTION
E958.5 | CRASHING OF MOTOR VEHICLE
E958.6 | CRASHING OF AIRCRAFT
E958.7 | CAUSTIC SUBSTANCES EXCEPT POISONING
E958.8 | OTHER SPECIFIED MEANS
E958.9 | UNSPECIFIED MEANS
Sepsis
ICD-9-CM diagnosis codes:
038.0 | STREPTOCOCCAL SEPTICEMIA
038.10 | STAPHYLOCOCCAL SEPTICEMIA, UNSPECIFIED
038.11 | STAPHYLOCOCCUS AUREUS SEPTICEMIA
038.19 | OTHER STAPHYLOCOCCAL SEPTICEMIA
038.2 | PNEUMOCOCCAL SEPTICEMIA (STREPTOCOCCUS PNEUMONIAE SEPTICEMIA)
038.3 | SEPTICEMIA DUE TO ANAEROBES
SEPTICEMIA DUE TO
038.40 | GRAM-NEGATIVE ORGANISM, UNSPECIFIED
038.41 | HEMOPHILUS INFLUENZAE
038.42 | ESCHERICHIA COLI
038.43 | PSEUDOMONAS
038.44 | SERRATIA
038.49 | SEPTICEMIA DUE TO OTHER GRAM-NEGATIVE ORGANISMS
038.8 | OTHER SPECIFIED SEPTICEMIAS
038.9 | UNSPECIFIED SEPTICEMIA
Shock
ICD-9-CM diagnosis codes:
SHOCK WITHOUT MENTION OF TRAUMA:
785.50 | SHOCK, UNSPECIFIED
785.51 | CARDIOGENIC SHOCK
785.59 | OTHER
Stroke
ICD-9-CM diagnosis codes:
430 | SUBARACHNOID HEMORRHAGE
431 | INTRACEREBRAL HEMORRHAGE
432.0 | NONTRAUMATIC EXTRADURAL HEMORRHAGE
432.1 | SUBDURAL HEMORRHAGE
432.9 | UNSPECIFIED INTRACRANIAL HEMORRHAGE
436 | ACUTE, BUT ILL-DEFINED CEREBROVASCULAR DISEASE
OCCLUSION AND STENOSIS OF PRECEREBRAL ARTERIES:
433.01 | BASILAR ARTERY, WITH CEREBRAL INFARCTION
433.11 | CAROTID ARTERY, WITH CEREBRAL INFARCTION
433.21 | VERTEBRAL ARTERY, WITH CEREBRAL INFARCTION
433.31 | MULTIPLE AND BILATERAL WITH CEREBRAL INFARCTION
433.81 | OTHER SPECIFIED PRECEREBRAL ARTERY WITH CEREBRAL INFARCTION
433.91 | OCCLUSION AND STENOSIS OF PRECEREBRAL ARTERIES, UNSPECIFIED PRECEREBRAL ARTERY WITH CEREBRAL INFARCTION
OCCLUSION OF CEREBRAL ARTERIES:
434.01 | CEREBRAL THROMBOSIS - WITH CEREBRAL INFARCTION
434.11 | CEREBRAL EMBOLISM - WITH CEREBRAL INFARCTION
434.91 | CEREBRAL ARTERY OCCLUSION, UNSPECIFIED - WITH CEREBRAL INFARCTION
Surgical
Diagnostic Related Groups (DRGs):
001 | CRANIOTOMY, AGE GREATER THAN 17 EXCEPT FOR TRAUMA
002 | CRANIOTOMY FOR TRAUMA, AGE GREATER THAN 17
003 | CRANIOTOMY, AGE 0–17
004 | SPINAL PROCEDURES
005 | EXTRACRANIAL VASCULAR PROCEDURES
006 | CARPAL TUNNEL RELEASE
007 | PERIPHERAL AND CRANIAL NERVE AND OTHER NERVOUS SYSTEM PROCEDURES WITH CC
008 | PERIPHERAL AND CRANIAL NERVE AND OTHER NERVOUS SYSTEM PROCEDURES WITHOUT CC
036 | RETINAL PROCEDURES
037 | ORBITAL PROCEDURES
038 | PRIMARY IRIS PROCEDURES
039 | LENS PROCEDURES WITH OR WITHOUT VITRECTOMY
040 | EXTRAOCULAR PROCEDURES EXCEPT ORBIT, AGE GREATER THAN 17
041 | EXTRAOCULAR PROCEDURES EXCEPT ORBIT, AGE 0–17
042 | INTRAOCULAR PROCEDURES EXCEPT RETINA, IRIS AND LENS
049 | MAJOR HEAD AND NECK PROCEDURES
050 | SIALOADENECTOMY
051 | SALIVARY GLAND PROCEDURES EXCEPT SIALOADENECTOMY
052 | CLEFT LIP AND PALATE REPAIR
053 | SINUS AND MASTOID PROCEDURES, AGE GREATER THAN 17
054 | SINUS AND MASTOID PROCEDURES, AGE 0–17
055 | MISCELLANEOUS EAR, NOSE, MOUTH AND THROAT PROCEDURES
056 | RHINOPLASTY
057 | TONSILLECTOMY AND ADENOIDECTOMY PROCEDURES EXCEPT TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE GREATER THAN 17
058 | TONSILLECTOMY AND ADENOIDECTOMY PROCEDURES EXCEPT TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE 0–17
059 | TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE GREATER THAN 17
060 | TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE 0–17
061 | MYRINGOTOMY WITH TUBE INSERTION, AGE GREATER THAN 17
062 | MYRINGOTOMY WITH TUBE INSERTION, AGE 0–17
063 | OTHER EAR, NOSE, MOUTH AND THROAT OR PROCEDURES
075 | MAJOR CHEST PROCEDURES
076 | OTHER RESPIRATORY SYSTEM OR PROCEDURES WITH CC
077 | OTHER RESPIRATORY SYSTEM OR PROCEDURES WITHOUT CC
103 | HEART TRANSPLANT
104 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITH CARDIAC CATHETERIZATION
105 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITHOUT CARDIAC CATHETERIZATION
106 | CORONARY BYPASS WITH PTCA
107 | CORONARY BYPASS WITH CARDIAC CATHETERIZATION
108 | OTHER CARDIOTHORACIC PROCEDURES
109 | CORONARY BYPASS WITHOUT CARDIAC CATHETERIZATION
110 | MAJOR CARDIOVASCULAR PROCEDURES WITH CC
111 | MAJOR CARDIOVASCULAR PROCEDURES WITHOUT CC
112 | PERCUTANEOUS CARDIOVASCULAR PROCEDURES
113 | AMPUTATION FOR CIRCULATORY SYSTEM DISORDERS EXCEPT UPPER LIMB AND TOE
114 | UPPER LIMB AND TOES AMPUTATION FOR CIRCULATORY SITE
115 | PERMANENT CARDIAC PACEMAKER IMPLANT WITH ACUTE MYOCARDIAL INFARCTION, HEART FAILURE OR SHOCK OR ACID LEAD OR GENERATOR PROCEDURE
116 | OTHER PERMANENT CARDIAC PACEMAKER IMPLANT OR PTCA WITH CORONARY ARTERIAL STENT
117 | CARDIAC PACEMAKER REVISION EXCEPT DEVICE REPLACEMENT
118 | CARDIAC PACEMAKER DEVICE REPLACEMENT
119 | VEIN LIGATION AND STRIPPING
120 | OTHER CIRCULATORY SYSTEM OR PROCEDURES
146 | RECTAL RESECTION WITH CC
147 | RECTAL RESECTION WITHOUT CC
148 | MAJOR SMALL AND LARGE BOWEL PROCEDURES WITH CC
149 | MAJOR SMALL AND LARGE BOWEL PROCEDURES WITHOUT CC
150 | PERITONEAL ADHESIOLYSIS WITH CC
151 | PERITONEAL ADHESIOLYSIS WITHOUT CC
152 | MINOR SMALL AND LARGE BOWEL PROCEDURES WITH CC
153 | MINOR SMALL AND LARGE BOWEL PROCEDURES WITHOUT CC
154 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE GREATER THAN 17 WITH CC
155 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE GREATER THAN 17 WIHOUT CC
156 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE 0–17
157 | ANAL AND STOMAL PROCEDURES WITH CC
158 | ANAL AND STOMAL PROCEDURES WITHOUT CC
159 | HERNIA PROCEDURES EXCEPT INGUINAL AND FEMORAL, AGE GREATER THAN 17 WITH CC
160 | HERNIA PROCEDURES EXCEPT INGUINAL AND FEMORAL, AGE GREATER THAN 17 WITHOUT CC
161 | INGUINAL AND FEMORAL HERNIA PROCEDURES, AGE GREATER THAN 17 WITH CC
162 | INGUINAL AND FEMORAL HERNIA PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
163 | HERNIA PROCEDURES, AGE 0–17
164 | APPENDECTOMY WITH COMPLICATED PRINCIPAL DIAGNOSIS WITH CC
165 | APPENDECTOMY WITH COMPLICATED PRINCIPAL DIAGNOSIS WITHOUT CC
166 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITH CC
167 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITHOUT CC
168 | MOUTH PROCEDURES WITH CC
169 | MOUTH PROCEDURES WITHOUT CC
170 | OTHER DIGESTIVE SYSTEM OR PROCEDURES WITH CC
171 | OTHER DIGESTIVE SYSTEM OR PROCEDURES WITHOUT CC
191 | PANCREAS, LIVER AND SHUNT PROCEDURES WITH CC
192 | PANCREAS, LIVER AND SHUNT PROCEDURES WITHOUT CC
193 | BILIARY TRACT PROCEDURES EXCEPT ONLY CHOLECYSTECTOMY WITH OR WITHOUT COMMON DUCT EXPLORATION WITH CC
194 | BILIARY TRACT PROCEDURES EXCEPT ONLY CHOLECYSTECTOMY WITH OR WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
195 | CHOLECYSTECTOMY WITH COMMON DUCT EXPLORATION WITH CC
196 | CHOLECYSTECTOMY WITH COMMON DUCT EXPLORATION WITHOUT CC
197 | CHOLECYSTECTOMY EXCEPT BY LAPAROSCOPE WITHOUT COMMON DUCT EXPLORATION WITH CC
198 | CHOLECYSTECTOMY EXCEPT BY LAPAROSCOPE WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
199 | HEPATOBILIARY DIAGNOSTIC PROCEDURE FOR MALIGNANCY
200 | HEPATOBILIARY DIAGNOSTIC PROCEDURE FOR NONMALIGNANCY
201 | OTHER HEPATOBILIARY OR PANCREAS OR PROCEDURES
209 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF LOWER EXTREMITY
210 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURES, AGE GREATER THAN 17 WITH CC
211 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
212 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURE, AGE 0–17
213 | AMPUTATION FOR MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE DISORDERS
214 | NO LONGER VALID
215 | NO LONGER VALID
216 | BIOPSIES OF MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE
217 | WOUND DEBRIDEMENT AND SKIN GRAFT EXCEPT HAND FOR MUSCULOSKELETAL AND CONNECTIVE TISSUE DISORDERS
218 | LOWER EXTREMITY AND HUMERUS PROCEURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITH CC
219 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITHOUT CC
220 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE 0–17
221 | NO LONGER VALID
222 | NO LONGER VALID
223 | MAJOR SHOULDER/ELBOW PROCEDURES OR OTHER UPPER EXTREMITY PROCEDURES WITH CC
224 | SHOULDER, ELBOW OR FOREARM PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
225 | FOOT PROCEDURES
226 | SOFT TISSUE PROCEDURES WITH CC
227 | SOFT TISSUE PROCEDURES WITHOUT CC
228 | MAJOR THUMB OR JOINT PROCEDURES OR OTHER HAND OR WRIST PROCEDURES WITH CC
229 | HAND OR WRIST PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
230 | LOCAL EXCISION AND REMOVAL OF INTERNAL FIXATION DEVICES OF HIP AND FEMUR
231 | LOCAL EXCISION AND REMOVAL OF INTERNAL FIXATION DEVICES EXCEPT HIP AND FEMUR
232 | ARTHROSCOPY
233 | OTHER MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE OR PROCEDURES WITH CC
234 | OTHER MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE OR PROCEDURES WITHOUT CC
257 | TOTAL MASTECTOMY FOR MALIGNANCY WITH CC
258 | TOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
259 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITH CC
260 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
261 | BREAST PROCEDURE FOR NONMALIGNANCY EXCEPT BIOPSY AND LOCAL EXCISION
262 | BREAST BIOPSY AND LOCAL EXCISION FOR NONMALIGNANCY
263 | SKIN GRAFT AND/OR DEBRIDEMENT FOR SKIN ULCER OR CELLULITIS WITH CC
264 | SKIN GRAFT AND OR DEBRIDEMENT FOR SKIN ULCER OR CELLULITIS WITHOUT CC
265 | SKIN GRAFT AND OR DEBRIDEMENT EXCEPT FOR SKIN ULCER OR CELLULITIS WITH CC
266 | SKIN GRAFT AND/OR DEBRIDEMENT EXCEPT FOR SKIN ULCER OR CELLULITIS WITHOUT CC
267 | PERIANAL AND PILONIDAL PROCEDURES
268 | SKIN, SUBCUTANEOUS TISSUE AND BREAST PLASTIC PROCEDURES
269 | OTHER SKIN, SUBCUTANEOUS TISSUE AND BREAST PROCEDURES WITH CC
270 | OTHER SKIN, SUBCUTANEOUS TISSUE AND BREAST PROCEDURS WITHOUT CC
285 | AMPUTATION OF LOWER LIMB FOR ENDOCRINE, NUTRITIONAL AND METABOLIC DISORDERS
286 | ADRENAL AND PITUITARY PROCEDURES
287 | SKIN GRAFTS AND WOUND DEBRIDEMENTS FOR ENDOCRINE, NUTRITIONAL AND METABOLIC DISORDERS
288 | OR PROCEDURES FOR OBESITY
289 | PARATHYROID PROCEDURES
290 | THYROID PROCEDURES
291 | THYROGLOSSAL PROCEDURES
292 | OTHER ENDOCRINE, NUTRITIONAL AND METABOLIC OR PROCEDURES WITH CC
293 | OTHER ENDOCRINE, NUTRITIONAL AND METABOLIC OR PROCEDURES WITHOUT CC
302 | KIDNEY TRANSPLANT
303 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NEOPLASM
304 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NONNEOPLASMS WITH CC
305 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NONNEOPLASMS WITHOUT CC
306 | PROSTATECTOMY WITH CC
307 | PROSTATECTOMY WITHOUT CC
308 | MINOR BLADDER PROCEDURES WITH CC
309 | MINOR BLADDER PROCEDURES WITHOUT CC
310 | TRANSURETHRAL PROCEDURES WITH CC
311 | TRANSURETHRAL PROCEDURES WITHOUT CC
312 | URETHRAL PROCEDURES, AGE GREATER THAN 17 WITH CC
313 | URETHRAL PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
314 | URETHRAL PROCEDURES, AGE 0–17
315 | OTHER KIDNEY AND URINARY TRACT OR PROCEDURES
334 | MAJOR MALE PELVIC PROCEDURES WITH CC
335 | MAJOR MALE PELVIC PROCEDURES WITHOUT CC
336 | TRANSURETHRAL PROSTATECTOMY WITH CC
337 | TRANSURETHRAL PROSTATECTOMY WITHOUT CC
338 | TESTES PROCEDURES FOR MALIGNANCY
339 | TESTES PROCEDURES FOR NONMALIGNANCY, AGE GREATER THAN 17
340 | TESTES PROCEDURES FOR NONMALIGNANCY, AGE 0–17
341 | PENIS PROCEDURES
342 | CIRCUMCISION, AGE GREATER THAN 17
343 | CIRCUMCISION, AGE 0–17
344 | OTHER MALE REPRODUCTIVE SYSTEM OR PROCEDURES FOR MALIGNANCY
345 | OTHER MALE REPRODUCTIVE SYSTEM OR PROCEDURES EXCEPT FOR MALIGNANCY
353 | PELVIC EVISCERATION, RADICAL HYSTERECTOMY AND RADICAL VULVECTOMY
354 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITH CC
355 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITHOUT CC
356 | FEMALE REPRODUCTIVE SYSTEM RECONSTRUCTIVE PROCEDURES
357 | UTERINE AND ADNEXA PROCEDURES FOR OVARIAN OR ADNEXAL MALIGNANCY
358 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITH CC
359 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITHOUT CC
360 | VAGINA, CERVIX AND VULVA PROCEDURES
361 | LAPAROSCOPY AND INCISIONAL TUBAL INTERRUPTION
362 | ENDOSCOPIC TUBAL INTERRUPTION
363 | D AND C, CONIZATION AND RADIOIMPLANT FOR MALIGNANCY
364 | D AND C, CONIZATION EXCEPT FOR MALIGNANCY
365 | OTHER FEMALE REPRODUCTIVE SYSTEM OR PROCEDURES
370 | CESAREAN SECTION WITH CC
371 | CESAREAN SECTION WITHOUT CC
374 | VAGINAL DELIVERY WITH STERILIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
377 | POSTPARTUM AND POSTABORTION DIAGNOSES WITH OR PROCEDURE
381 | ABORTION WITH D AND C ASPIRATION CURETTAGE OR HYSTERECTOMY
392 | SPLENECTOMY, AGE GREATER THAN 17
393 | SPLENECTOMY, AGE 0–17
394 | OTHER OR PROCEDURES OF THE BLOOD AND BLOOD-FORMING ORGANS
400 | LYMPHOMA AND LEUKEMIA WITH MAJOR OR PROCEDURES
401 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITH CC
402 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITHOUT CC
406 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURES WITH CC
407 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURES WITHOUT CC
408 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH OTHER OR PROCEDURES
415 | OR PROCEDURE FOR INFECTIOUS AND PARASITIC DISEASES
424 | OR PROCEDURES WITH PRINCIPAL DIAGNOSIS OF MENTAL ILLNESS
439 | SKIN GRAFTS FOR INJURIES
440 | WOUND DEBRIDEMENTS FOR INJURIES
441 | WOUND HAND PROCEDURES FOR INJURIES
442 | OTHER OR PROCEDURES FOR INJURIES WITH CC
443 | OTHER OR PROCEDURES FOR INJURIES
458 | NO LONGER VALID
459 | NO LONGER VALID
461 | OR PROCEDURES WITH DIAGNOSES OF OTHER CONTACT WITH HEALTH SERVICES
468 | EXTENSIVE OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
471 | BILATERAL OR MULTIPLE MAJOR JOINT PROCEDURES OF LOWER EXTREMITY
472 | NO LONGER VALID
476 | PROSTATIC OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
477 | NONEXTENSIVE OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
478 | OTHER VASCULAR PROCEDURES WITH CC
479 | OTHER VASCULAR PROCEDURES WITHOUT CC
480 | LIVER TRANSPLANT
481 | BONE MARROW TRANSPLANT
482 | TRACHEOSTOMY FOR FACE, MOUTH AND NECK DIAGNOSES
483 | TRACHEOSTOMY EXCEPT FOR FACE, MOUTH AND NECK DIAGNOSES
484 | CRANIOTOMY FOR MULTIPLE SIGNIFICANT TRAUMA
485 | LIMB REATTACHMENT, HIP AND FEMUR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
486 | OTHER OR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
488 | HIV WITH EXTENSIVE OR PROCEDURE
491 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF UPPER EXTREMITY
493 | LAPAROSCOPIC CHOLECYSTECTOMY WITHOUT COMMON DUCT EXPLORATION WITH CC
494 | LAPAROSCOPIC CHOLECYSTECTOMY WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
495 | LUNG TRANSPLANT
496 | COMBINED ANTERIOR/POSTERIOR SPINAL FUSION
497 | SPINAL FUSION WITH CC
498 | SPINAL FUSION WITHOUT CC
499 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITH CC
500 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITHOUT CC
501 | KNEE PROCEDURES WITH PRINCIPAL DIAGNOSIS OF INFECTION, WITH CC
502 | KNEE PROCEDURES WITH PRINCIPAL DIAGNOSIS OF INFECTION, WITHOUT CC
503 | KNEE PROCEDURES WITHOUT PRINCIPAL DIAGNOSIS OF INFECTION
Syncope
ICD-9-CM diagnosis codes:
780.2 | SYNCOPE AND COLLAPSE
Technical difficulty
ICD-9-CM diagnosis codes:
ACCIDENTAL CUT, PUNCTURE, PERFORATION, OR HEMORRHAGE DURING:
E870.0 | SURGICAL OPERATION
E870.1 | INFUSION OR TRANSFUSION
E870.2 | KIDNEY DIALYSIS OR OTHER PERFUSION
E870.3 | INJECTION OR VACCINATION
E870.4 | ENDOSCOPIC EXAMINATION
E870.5 | ASPIRATION OF FLUID OR TISSUE, PUNCTURE, AND CATHETERIZATION
E870.6 | HEART CATHETERIZATION
E870.7 | ADMINISTRATION OF ENEMA
E870.8 | OTHER SPECIFIED MEDICAL CARE
E870.9 | UNSPECIFIED MEDICAL CARE
998.2 | ACCIDENTAL PUNCTURE OR LACERATION DURING A PROCEDURE
Thoracic surgery
ICD-9-CM procedure codes:
31.21 | MEDIASTINAL TRACHEOSTOMY
31.45 | OPEN BIOPSY OF LARYNX OR TRACHEA
31.73 | CLOSURE OF OTHER FISTULA OF TRACHEA
31.79 | OTHER REPAIR AND PLASTIC OPERATIONS ON TRACHEA
31.99 | OTHER OPERATIONS ON TRACHEA
32.09 | OTHER LOCAL EXCISION OR DESTRUCTION OF LESION OR TISSUE OF BRONCHUS
32.1 | OTHER EXCISION OF BRONCHUS
32.21 | PLICATION OF EMPHYSEMATIOUS BLEB
32.22 | LUNG VOLUME REDUCTION SURGERY
32.28 | ENDOSCOPIC EXCISION OR DESTRUCTION OF LESION OR TISSUE OF LUNG
32.29 | OTHER LOCAL EXCISION OR DESTRUCTION OF LESION OR TISSUE OF LUNG
32.3 | SEGMENTAL RESECTION OF LUNG
32.4 | LOBECTOMY OF LUNG
32.5 | COMPLETE PNEUMONECTOMY
32.6 | RADICAL DISSECTION OF THORACIC STRUCTURES
32.9 | OTHER EXCISION OF LUNG
33.0 | INCISION OF BRONCHUS
33.1 | INCISION OF LUNG
33.25 | OPEN BIOPSY OF BRONCHUS
33.26 | CLOSED [PERCUTANEOUS][NEEDLE] BIOPSY OF LUNG
33.27 | CLOSED ENDOSCOPIC BIOPSY OF LUNG
33.28 | OPEN BIOPSY OF LUNG
33.31 | DESTRUCTION OF PHRENIC NERVE FOR COLLAPSE OF LUNG (NO LONGER PERFORMED)
33.32 | ARTIFICAL PNEUMOTHORAX FOR COLLAPSE OF LUNG
33.34 | THORACOPLASTY
33.39 | OTHER SURGICAL COLLAPSE OF LUNG
33.41 | SUTURE OF LACERATION OF BRONCHUS
33.42 | CLOSURE OF BRONCHIAL FISTULA
33.43 | CLOSURE OF LACERATION OF LUNG
33.48 | OTHER REPAIR AND PLASTIC OPERATIONS ON BRONCHUS
33.49 | OTHER REPAIR AND PLASTIC OPERATIONS ON LUNG
33.50 | LUNG TRANSPLANTATION, NOS
33.51 | UNILATERAL LUNG TRANSPLANTATION
33.52 | BILATERAL LUNG TRANSPLANTATION
33.6 | COMBINED HEART-LUNG TRANSPLANTATION
33.92 | LIGATION OF BRONCHUS
33.93 | PUNCTURE OF LUNG
33.98 | OTHER OPERATIONS ON BRONCHUS
33.99 | OTHER OPERATIONS ON LUNG
33.29 | OTHER DIAGNOSTIC PROCEDURE ON LUNG AND BRONCHUS
33.33 | PNEUMOPERITONEUM FOR COLLAPSE OF LUNG
34.01 | INCISION OF CHEST WALL
34.02 | EXPLORATORY THORACOTOMY
34.03 | REOPENING OF RECENT THORACOTOMY SITE
34.05 | CREATION OF PLEUROPERITONEAL SHUNT
34.09 | OTHER INCISION OF PLEURA
34.1 | INCISION OF MEDIASTINUM
34.21 | TRANSPLEURAL THORACOSOCOPY
34.22 | MEDIASTINOSCOPY
34.23 | BIOPSY OF CHEST WALL
34.24 | PLEURAL BIOPSY
34.25 | CLOSED [PERCUTANEOUS][NEEDLE] BIOPSY OF MEDIASTINUM
34.26 | OPEN BIOPSY OF MEDIASTINUM
34.27 | BIOPSY OF DIAPHRAGM
34.28 | OTHER DIAGNOSTIC PROCEDURES ON CHEST WALL, PLEURA, AND DIAPHRAGM
34.29 | OTHER DIAGNOSTIC PROCEDURES ON MEDIASTINUM
34.3 | EXCISION OR DESTRUCTION OF LESION OR TISSUE OF MEDIASTINUM
34.4 | EXCISION OR DESTRUCTION OF LESION OF CHEST WALL
34.51 | DECORTICATION OF LUNG
34.59 | OTHER EXCISION OF PLEURA
34.71 | SUTURE OF LACERATION OF CHEST WALL
34.72 | CLOSURE OF THORACOSTOMY
34.73 | CLOSURE OF OTHER FISTULA OF THORAX
34.74 | REPAIR OF PECTUS DEFORMITY
34.79 | OTHER REPAIR OF CHEST WALL
34.81 | EXCISION OF LESION OR TISSUE OF DIAPHRAGM
34.82 | SUTURE OF LACERATION OF DIAPHRAGM
34.83 | CLOSURE OF FISTULA OF DIAPHRAGM
34.84 | OTHER REPAIR OF DIAPHRAGM
34.85 | IMPLANTATION OF DIAPHRAGMATIC PACEMAKER
34.89 | OTHER OPERATIONS ON DIAPHRAGM
34.93 | REPAIR OF PLEURA
34.99 | OTHER
40.61 | CANNULATION OF THORACIC DUCT
40.62 | FISTULIZATION OF THORACIC DUCT
40.63 | CLOSURE OF FISTULA OF THORACIC DUCT
40.64 | LIGATION OF THORACIC DUCT
40.69 | OTHER OPERATIONS ON THORACIC DUCT
42.01 | INCISION OF ESOPHAGEAL WEB
42.09 | OTHER INCISION OF ESOPHAGUS
42.10 | ESOPHAGOSTOMY, NOS
42.11 | CERVICAL ESOPHAGOSTOMY
42.12 | EXTERIORIZATION OF ESOPHAGEAL POUCH
42.19 | OTHER EXTERNAL FISTULIZATION OF ESOPHAGUS
42.21 | OPERATIVE ESOPHAGOSCOPY BY INCISION
42.25 | OPEN BIOPSY OF ESOPHAGUS
42.31 | LOCAL EXCISION OF ESOPHAGEAL DIVERTICULUM
42.32 | LOCAL EXCISION OF OTHER LESION OR TISSUE OF ESOPHAGUS
42.39 | OTHER DESTRUCTION OF LESION OR TISSUE OF ESOPHAGUS
42.40 | ESOPHAGECTOMY, NOS
42.41 | PARTIAL ESOPHAGECTOMY
42.42 | TOTAL ESOPHAGECTOMY
42.51 | INTRATHORACIC ESOPHAGOESOPHAGOSTOMY
42.52 | INTRATHORACIC ESOPHAGOGASTROSTOMY
42.53 | INTRATHORACIC ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF SMALL BOWEL
42.54 | OTHER INTRATHORACIC ESOPHAGOENTEROSTOMY
42.55 | INTRATHORACIC ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF COLON
42.56 | OTHER INTRATHORACIC ESOPHAGOCOLOSTOMY
42.58 | INTRATHORACIC ESOPHAGEAL ANASTOMOSIS WITH OTHER INTERPOSITION
42.59 | OTHER INTRATHORACIC ANASTOMOSIS OF ESOPHAGUS
42.61 | ANTESTERNAL ESOPHAGOESOPHAGOSTOMY
42.62 | ANTESTERNAL ESOPHAGOGASTROSTOMY
42.63 | ANTESTERNAL ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF SMALL BOWEL
42.64 | OTHER ANTESTERNAL ESOPHAGOENTEROSTOMY
42.65 | ANTESTERNAL ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION OF COLON
42.66 | OTHER ANTESTERNAL ESOPHAGOCOLOSTOMY
42.68 | OTHER ANTESTERNAL ESOPHAGEAL ANASTOMOSIS WITH INTERPOSITION
42.69 | OTHER ANTESTERNAL ANASTOMOSIS OF ESOPHAGUS
42.7 | ESOPHAGOMYOTOMY
42.81 | INSERTION OF PERMANENT TUBE INTO ESOPHAGUS
42.82 | SUTURE OF LACERATION OF ESOPHAGUS
42.83 | CLOSURE OF ESOPHAGOSTOMY
42.84 | REPAIR OF ESOPHAGEAL FISTULA, NEC
42.85 | REPAIR OF ESOPHAGEAL STRICTURE
42.86 | PRODUCTION OF SUBCUTANEOUS TUNNEL WITHOUT ESOPHAGEAL ANASTOMOSIS
42.87 | OTHER GRAFT OF ESOPHAGUS
42.89 | OTHER REPAIR OF ESOPHAGUS
44.65 | ESOPHAGOGASTROPLASTY
44.66 | OTHER PROCEDURES FOR CREATION OF ESOPHAGOGASTRIC SPHINCTERIC COMPETENCE
81.04 | DORSAL AND DORSO-LUMBAR FUSION, ANTERIOR TECHNIQUE
Transferred to acute care facility
DISCHARGE DISPOSITION RECORDED AS TRANSFER TO ANOTHER ACUTE CARE FACILITY
Transferred from acute care facility
ADMISSION SOURCE IS RECORDED AS ACUTE CARE FACILITY
Transfusion reaction
ICD-9-CM diagnosis codes:
999.6 | ABO INCOMPATIBILITY REACTION
999.7 | RH INCOMPATIBILITY REACTION
E876.0 | MISMATCHED BLOOD IN TRANSFUSION
Trauma
ICD-9-CM diagnosis codes ( includes 4^th^ and 5^th^ digits):
800 | FRACTURE OF VAULT OF SKULL
801 | FRACTURE OF BASE OF SKULL
802 | FRACTURE OF FACE BONES
803 | OTHER AND UNQUALIFIED SKULL FRACTURES
804 | MULTIPLE FRACTURES INVOLVING SKULL OR FACE WITH OTHER BONES
805 | FRACTURE OF VERTEBRAL COLUMN WITHOUT MENTION OF SPINAL CORD INJURY
806 | FRACTURE OF VERTEBRAL COLUMN WITH SPINAL CORD INJURY
807 | FRACTURE OF RIB[S] STERNUM, LARYNX, AND TRACHEA
808 | FRACTURE OF PELVIS
809 | ILL-DEFINED FRACTURES OF BONES OF TRUNK
810 | FRACTURE OF CLAVICLE
811 | FRACTURE OF SCAPULA
812 | FRACTURE OF HUMEROUS
813 | FRACTURE OF RADIUS AND ULNA
814 | FRACTURE OF CARPAL BONE[S]
815 | FRACTURE OF METACARPAL BONE[S]
817 | MULTIPLE FRACTURES OF HAND BONES
818 | ILL-DEFINED FRACTURES OF UPPER LIMB
819 | MULTIPLE FRACTURES INVOLVING BOTH UPPER LIMBS, AND UPPER LIMB WITH RIB AND STERNUM
820 | FRACTURE OF NECK OF FEMUR
821 | FRACTURE OF OTHER AND UNSPECIFIED PARTS OF FEMUR
822 | FRACTURE OF PATELLA
823 | FRACTURE OF TIBIA AND FIBULA
824 | FRACTURE OF ANKLE
825 | FRACTURE OF ONE OR MORE TARSAL AND METATARSAL BONES
827 | OTHER, MULTIPLE, AND ILL-DEFINED FRACTURES OF LOWER LIMB
828 | MULTIPLE FRACTURES INVOLVING BOTH LOWER LIMBS, LOWER WITH UPPER LIMB, AND LOWER LIMB WITH RIB AND STERNUM
829 | FRACTURE OF UNSPECIFIED BONES
830 | DISLOCATION OF JAW
831 | DISLOCATION OF SHOULDER
832 | DISLOCATION OF ELBOW
833 | DISLOCATION OF WRIST
835 | DISLOCATION OF HIP
836 | DISLOCATION OF KNEE
837 | DISLOCATION OF ANKLE
838 | DISLOCATION OF FOOT
839 | OTHER, MULTIPLE, AND ILL-DEFINED DISLOCATIONS
850 | CONCUSSION
851 | CEREBRAL LACERATION AND CONTUSION
852 | SUBARACHNOID, SUBDURAL, AND EXTRADURAL HEMORRHAGE, FOLLOWING INJURY
853 | OTHER AND UNSPECIFIED INTRACRANIAL HEMORRHAGE FOLLOWING INJURY
854 | INTRACRANIAL INJURY OF OTHER AND UNSPECIFIED NATURE
860 | TRAUMATIC PNEUMOTHORAX
861 | INJURY TO HEART AND LUNG
862 | INJURY TO OTHER AND UNSPECIFIED INTRATHORACIC ORGANS
863 | INJURY TO GASTROINTESTINAL TRACT
864 | INJURY TO LIVER
865 | INJURY TO SPLEEN
866 | INJURY TO KIDNEY
867 | INJURY TO PELVIC ORGANS
868 | INJURY TO OTHER INTRA-ABDOMINAL ORGANS
869 | INTERNAL INJURY TO UNSPECIFIED OR ILL-DEFINED ORGANS
870 | OPEN WOUND OF OCULAR ADNEXA
871 | OPEN WOUND OF EYEBALL
872 | OPEN WOUND OF EAR
873 | OTHER OPEN WOUND OF HEAD
874 | OPEN WOUND OF NECK
875 | OPEN WOUND OF CHEST [WALL]
876 | OPEN WOUND OF BACK
877 | OPEN WOUND OF BUTTOCK
878 | OPEN WOUND OF GENITAL ORGANS [EXTERNAL] INCLUDING TRAUMATIC AMPUTATION
879 | OPEN WOUND OF OTHER AND UNSPECIFIED SITES, EXCEPT LIMBS
880 | OPEN WOUND OF SHOULDER AND UPPER ARM
881 | OPEN WOUND OF ELBOW, FOREARM, AND WRIST
882 | OPEN WOUND OF HAND EXCEPT FINGER ALONE
884 | MULTIPLE AND UNSPECIFIED OPEN WOUND OF UPPER LIMB
887 | TRAUMATIC AMPUTATION OF ARM AND HAND (COMPLETE) (PARTIAL)
890 | OPEN WOUND OF HIP AND THIGH
891 | OPEN WOUND OF KNEE, LEG (EXCEPT THIGH) AND ANKLE
892 | OPEN WOUND OF FOOT EXCEPT TOE ALONE
894 | MULTIPLE AND UNSPECIFIED OPEN WOUND OF LOWER LIMB
896 | TRAUMATIC AMPUTATION OF FOOT (COMPLETE) (PARTIAL)
897 | TRAUMATIC AMPUTATION OF LEG(S) (COMPLETE) (PARTIAL)
900 | INJURY TO BLOOD VESSELS OF HEAD AND NECK
901 | INJURY TO BLOOD VESSELS OF THORAX
902 | INJURY TO BLOOD VESSELS OF ABDOMEN AND PELVIS
903 | INJURY TO BLOOD VESSELS OF UPPER EXTREMITY
904 | INJURY TO BLOOD VESSELS OF LOWER EXTREMITY AND UNSPECIFIED SITES
925 | CRUSHING INJURY OF FACE, SCALP, AND NECK
926 | CRUSHING INJURY OF TRUNK
927 | CRUSHING INJURY OF UPPER LIMB
928 | CRUSHING INJURY OF LOWER LIMB
929 | CRUSHING INJURY OF MULTIPLE AND UNSPECIFIED SITES
940 | BURN CONFINED TO EYE AND ADNEXA
941 | BURN OF FACE, HEAD, AND NECK
942 | BURN OF TRUNK
943 | BURN OF UPPER LIMB, EXCEPT WRIST AND HAND
944 | BURN OF WRIST[S] AND HAND[S]
945 | BURN OF LOWER LIMB[S]
946 | BURNS OF MULTIPLE SPECIFIED SITES
947 | BURN OF INTERNAL ORGANS
948 | BURNS CLASSIFIED ACCORDING TO EXTENT OF BODY SURFACE INVOLVED
949 | BURN, UNSPECIFIED
952 | SPINAL CHORD INJURY WITHOUT EVIDENCE OF SPINAL BONE INJURY
953 | INJURY TO NERVE ROOTS AND SPINAL PLEXUS
958 | CERTAIN EARLY COMPLICATIONS OF TRAUMA
E800 | RAILWAY ACCIDENT INVOLVING COLLISION WITH ROLLING STOCK
E801 | RAILWAY ACCIDENT INVOLVING COLLISION WITH OTHER OBJECT
E802 | RAILWAY ACCIDENT INVOLVING DERAILMENT WITHOUT ANTECEDENT COLLISION
E803 | RAILWAY ACCIDENT INVOLVING EXPLOSION, FIRE, OR BURNING
E804 | FALL IN, ON, OR FROM RAILWAY TRAIN
E805 | HIT BY ROLLING STOCK
E806 | OTHER SPECIFIED RAILWAY ACCIDENT
E807 | RAILWAY ACCIDENT OF UNSPECIFIED NATURE
E810 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH TRAIN
E811 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING RE-ENTERANT COLLISION WITH ANOTHER MOTOR VEHICLE
E812 | OTHER MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH MOTOR VEHICLE
E813 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH OTHER VEHICLE
E814 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH PEDESTRIAN
E815 | OTHER MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION ON THE HIGHWAY
E816 | MOTOR VEHICLE TRAFFIC ACCIDENT DUE TO LOSS OF CONTROL, WITHOUT COLLISION ON THE HIGHWAY
E817 | NONCOLLISION MOTOR VEHICLE TRAFFIC ACCIDENT WHILE BOARDING OR ALIGHTING
E818 | OTHER NONCOLLISION MOTOR VEHICLE TRAFFIC ACCIDENT
E819 | MOTOR VEHICLE TRAFFIC ACCIDENT OF UNSPECIFIED NATURE
E820 | NONTRAFFIC ACCIDENT INVOLVING MOTOR-DRIVEN SNOW VEHICLE
E821 | NONTRAFFIC ACCIDENT INVOLVING OTHER OFF-ROAD MOTOR VEHICLE
E822 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT INVOLVING COLLISION WITH MOVING OBJECT
E823 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT INVOLVING COLLISION WITH STATIONARY OBJECT
E824 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT WHILE BOARDING AND ALIGHTING
E825 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT OF OTHER AND UNSPECIFIED NATURE
E826 | PEDAL CYCLE ACCIDENT
E827 | ANIMAL-DRAWN VEHICLE ACCIDENT
E828 | ACCIDENT INVOLVING ANIMAL BEING RIDDEN
E829 | OTHER ROAD VEHICLE ACCIDENTS
E830 | ACCIDENT TO WATERCRAFT CAUSING SUBMERSION
E831 | ACCIDENT TO WATERCRAFT CAUSING OTHER INJURY
E832 | OTHER ACCIDENTAL SUBMERSION OR DROWNING IN WATER TRANSPORT ACCIDENT
E833 | FALL ON STAIRS OR LADDERS IN WATER TRANSPORT
E834 | OTHER FALL FROM ONE LEVEL TO ANOTHER IN WATER TRANSPORT
E835 | OTHER AND UNSPECIFIED FALL IN WATER TRANSPORT
E836 | MACHINERY ACCIDENT IN WATER TRANSPORT
E837 | EXPLOSION, FIRE, OR BURNING IN WATERCRAFT
E838 | OTHER AND UNSPECIFIED WATER TRANSPORT ACCIDENT
E840 | ACCIDENT TO POWERED AIRCRAFT AT TAKEOFF OR LANDING
E841 | ACCIDENT TO POWERED AIRCRAFT, OTHER AND UNSPECIFIED
E842 | ACCIDENT TO UNPOWERED AIRCRAFT
E843 | FALL IN, ON, OR FROM AIRCRAFT
E844 | OTHER SPECIFIED AIR TRANSPORT ACCIDENTS
E845 | ACCIDENT INVOLVING SPACECRAFT
E846 | ACCIDENTS INVOLVING POWERED VEHICLES USED SOLELY WITHIN THE BUILDINGS AND PREMISES AND INDUSTRIAL OR COMMERCIAL ESTABLISHMENT
E847 | ACCIDENTS TO UNPOWERED AIRCRAFT
E848 | ACCIDENTS INVOLVING OTHER VEHICLES, NEC
E849 | PLACE OF OCCURRENCE
E880 | FALL ON OR FROM STAIRS OR STEPS
E881 | FALL ON OR FROM LADDERS OR SCAFFOLDING
E882 | FALL FROM OR OUT OF BUILDING OR OTHER STRUCTURE
E883 | FALL INTO HOLE OR OTHER OPENING IN SURFACE
E884 | OTHER FALL FROM ONE LEVEL TO ANOTHER
E885 | FALL ON SAME LEVEL FROM SLIPPING, TRIPPING, OR STUMBLING
E886 | FALL ON SAME LEVEL FROM COLLISION, PUSHING, OR SHOVING BY OR WITH OTHER PERSON
E887 | FRACTURE, CAUSE UNSPECIFIED
E888 | OTHER AND UNSPECIFIED FALL
E890 | CONFLAGRATION IN PRIVATE DWELLING
E891 | CONFLAGRATION IN OTHER AND UNSPECIFIED BUILDING OR STRUCTURE
E892 | CONFLAGRATION NOT IN BUILDING OR STRUCTURE
E893 | ACCIDENT CAUSED BY IGNITION OF CLOTHING
E894 | IGNITION OF HIGHLY INFLAMMABLE MATERIAL
E895 | ACCIDENT CAUSED BY CONTROLLED FIRE IN PRIVATE DWELLING
E896 | ACCIDENT CAUSE BY CONTROLLED FIRE IN OTHER AND UNSPECIFIED BUILDING OR STRUCTURE
E897 | ACCIDENT CAUSED BY CONTROLLED FIRE NOT IN BUILDING OR STRUCTURE
E898 | ACCIDENT CAUSED BY OTHER SPECIFIED FIRE AND FLAMES
E899 | ACCIDENT CAUSED BY UNSPECIFIED FIRE
E910 | ACCIDENTAL DROWNING AND SUBMERSION
E913 | ACCIDENTAL MECHANICAL SUFFOCATION
E914 | FOREIGN BODY ACCIDENTALLY ENTERING EYE AND ADNEXA
E915 | FOREIGN BODY ACCIDENTALLY ENTERING OTHER ORIFICE
E916 | STRUCK ACCIDENTALLY BY FALLING OBJECT
E917 | STRIKING AGAINST OR STRUCK ACCIDENTALLY BY OBJECTS OR PERSONS
E918 | CAUGHT ACCIDENTALLY IN OR BETWEEN OBJECTS
E919 | ACCIDENTS CAUSED BY MACHINERY
E920 | ACCIDENTS CAUSED BY CUTTING AND PIERCING INSTRUMENTS OR OBJECTS
E921 | ACCIDENT CAUSED BY EXPLOSION OF PRESSURE VESSEL
E922 | ACCIDENT CAUSED BY FIREARM AND AIR GUN MISSILE
E923 | ACCIDENT CAUSED BY EXPLOSIVE MATERIAL
E924 | ACCIDENT CAUSED BY HOT SUBSTANCE OR OBJECT, CAUSTIC OR CORROSIVE MATERIAL, AND STEAM
E925 | ACCIDENT CAUSED BY ELECTRIC CURRENT
E926 | EXPOSURE TO RADIATION
E927 | OVEREXERTION AND STRENUOUS MOVEMENTS
E928 | OTHER AND UNSPECIFIED ENVIRONMENTAL AND ACCIDENTAL CAUSES
E960 | FIGHT, BRAWL, RAPE
E961 | ASSAULT BY CORROSIVE OR CAUSTIC SUBSTANCE, EXCEPT POISONING
E962 | ASSAULT BY POISONING
E963 | ASSAULT BY HANGING AND STRANGULATION
E964 | ASSAULT BY SUBMERSION [DROWNING]
E965 | ASSAULT BY FIREARMS AND EXPLOSIVES
E966 | ASSAULT BY CUTTING AND PIERCING INSTRUMENT
E967 | PERPETRATOR OF CHILD AND ADULT ABUSE
E968 | ASSAULT BY OTHER AND UNSPECIFIED MEANS
E969 | LATE EFFECTS OF INJURY PURPOSELY INFLICTED BY OTHER PERSON
E970 | INJURY DUE TO LEGAL INTERVENTION BY FIREARMS
E971 | INJURY DUE TO LEGAL INTERVENTION BY EXPLOSIVES
E972 | INJURY DUE TO LEGAL INTERVENTION BY GAS
E973 | INJURY DUE TO LEGAL INTERVENTION BY BLUNT OBJECT
E974 | INJURY DUE TO LEGAL INTERVENTION BY CUTTING AND PIERCING INSTRUMENT
E975 | INJURY DUE TO LEGAL INTERVENTION BY OTHER SPECIFIED MEANS
E976 | INJURY DUE TO LEGAL INTERVENTION BY UNSPECIFIED MEANS
E977 | LATE EFFECTS OF INJURIES DUE TO LEGAL INTERVENTION
E978 | LEGAL EXECUTION
E980 | POISONING BY SOLID OR LIQUID SUBSTANCES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E981 | POISONING BY GASES IN DOMESTIC USE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E982 | POISONING BY OTHER GASES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E983 | HANGING, STRANGULATION, OR SUFFOCATION, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E984 | SUBMERSION [DROWNING] UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E985 | INJURY BY FIREARMS, AIR GUNS AND EXPLOSIVES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E986 | INJURY BY CUTTING AND PIERCING INSTRUMENTS, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E987 | FALLING FROM HIGH PLACE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E988 | INJURY BY OTHER AND UNSPECIFIED MEANS, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E989 | LATE EFFECTS OF INJURY, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E990 | INJURY DUE TO WAR OPERATIONS BY FIRES AND CONFLAGRATIONS
E991 | INJURY DUE TO WAR OPERATIONS BY BULLETS AND FRAGMENTS
E992 | INJURY DUE TO WAR OPERATIONS BY EXPLOSION OF MARINE WEAPONS
E993 | INJURY DUE TO WAR OPERATIONS BY OTHER EXPLOSION
E994 | INJURY DUE TO WAR OPERATIONS BY DESTRUCTION OF AIRCRAFT
E995 | INJURY DUE TO WAR OPERATIONS BY OTHER AND UNSPECIFIED FORMS OF CONVENTIONAL WARFARE
E996 | INJURY DUE TO WAR OPERATIONS BY NUCLEAR WEAPONS
E997 | INJURY DUE TO WAR OPERATIONS BY OTHER FORMS OF UNCONVENTIONAL WARFARE
E998 | INJURY DUE TO WAR OPERATIONS BUT OCCURRING AFTER CESSATION OF HOSTILITIES
E999 | LATE EFFECT OF INJURY DUE TO WAR OPERATIONS
Diagnostic Related Groups (DRGs):
002 | CRANIOTOMY FOR TRAUMA, AGE GREATER THAN 17
027 | TRAUMATIC STUPOR AND COMA, COMA GREATER THAN ONE HOUR
028 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 17 WITH CC
029 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 17 WITHOUT CC
031 | CONCUSSION, AGE GREATER THAN 17 WITH CC
032 | CONCUSSION, AGE GREATER THAN 17 WITHOUT CC
072 | NASAL TRAUMA AND DEFORMITY
083 | MAJOR CHEST TRAUMA WITH CC
084 | MAJOR CHEST TRAUMA WITHOUT CC
235 | FRACTURES OF FEMUR
236 | FRACTURE OF HIP AND PELVIS
237 | SPRAINS, STRAINS AND DISLOCATIONS OF HIP, PELVIS AND THIGH
440 | WOUND DEBRIDEMENTS FOR INJURIES
441 | HAND PROCEDURES FOR INJURIES
442 | OTHER OR PROCEDURES FOR INJURIES WITH CC
443 | OTHER OR PROCEDURES FOR INJURIES WITHOUT CC
444 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITH CC
445 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITHOUT CC
446 | TRAUMATIC INJURY, AGE 0–17
447 | ALLERGIC REACTIONS, AGE GREATER THAN 17
448 | ALLERGIC REACTIONS, AGE 0–17
449 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITH CC
450 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITHOUT CC
451 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE 0–17
452 | COMPLICATIONS OF TREATMENT WITH CC
453 | COMPLICATIONS OF TREATMENT WITHOUT CC
454 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITH CC
455 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITHOUT CC
460 | NO LONGER VALID
484 | CRANIOTOMY FOR MULTIPLE SIGNIFICANT TRAUMA
485 | LIMB REATTACHMENT, HIP AND FEMUR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
486 | OTHER OR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
487 | OTHER MULTIPLE SIGNIFICANT TRAUMAS
491 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF UPPER EXTREMITY
Vaginal delivery
Diagnostic Related Groups (DRGs):
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY WITH STERILIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
FTR-FAILURE TO RESCUE
FTR-Acute Renal Failure
ICD-9-CM diagnosis codes (all 4^th^ and 5^th^ digits included):
ACUTE RENAL FAILURE:
584.5 | WITH LESION OF TUBULAR NECROSIS
584.6 | WITH LESION OF RENAL CORTICAL NECROSIS
584.7 | WITH LESION OF RENAL MEDULLARY [PAPILLARY] NECROSIS
584.8 | WITH OTHER SPECIFIED PATHOLOGICAL LESION IN KIDNEY
584.9 | ACUTE RENAL FAILURE, UNSPECIFIED
ICD-9-CM diagnosis codes exclude:
PRINCIPAL DIAGNOSIS OF [AMI], [CARDIAC ARRHYTHMIA], [SHOCK] OR [CARDIAC ARREST], [HEMORRHAGE]
FTR-DVT/PE
Include
ICD-9-CM diagnosis codes:
PHLEBITIS AND THROMBOPHLEBITIS OF:
451.11 | FEMORAL VEIN (DEEP) (SUPERFICIAL)
451.19 | OTHER
451.2 | LOWER EXTREMITIES
451.81 | ILIAC VEIN
451.9 | UNSPECIFIED SITE
ACUTE PULMONARY HEART DISEASE:
415.11 | IATROGENIC PULMONARY EMBOLISM AND INFARCTION
415.19 | OTHER
453.8 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF OTHER SPECIFIED VEINS
453.9 | OTHER VENOUS EMBOLISM AND THROMBOSIS OF UNSPECIFIED SITE
Exclude
ICD-9-CM codes:
PRINCIPAL DIAGNOSIS OF [DEEP VEIN THROMBOSIS]
FTR-Pneumonia
Include
ICD-9-CM diagnosis codes:
507.0 | DUE TO INHALATION OF FOOD OR VOMITUS
514 | PULMONARY CONGESTION AND HYPOSTASIS
OTHER BACTERIAL PNEUMONIA:
482.0 | PNEUMONIA DUE TO KLEBSIELLA PNEUMONIAE
482.1 | PNEUMONIA DUE TO PSEUDOMONAS
482.2 | PNEUMONIA DUE TO HEMOPHILUS INFLUENZAE [H. INFLUENZAE]
482.30 | PNEUMONIA DUE TO STREPTOCOCCUS - STREPTOCOCCUS, UNSPECIFIED
482.31 | PNEUMONIA DUE TO STREPTOCOCCUS - GROUP A
482.32 | PNEUMONIA DUE TO STREPTOCOCCUS - GROUP B
482.39 | PNEUMONIA DUE TO STREPTOCOCCUS - OTHER STREPTOCOCCUS
482.40 | PNEUMONIA DUE TO STAPHYLOCOCCUS-PNEUMONIA DUE TO STAPHYLOCOCCUS, UNSPECIFIED
482.41 | PNEUMONIA DUE TO STAPHYLOCOCCUS-PNEUMONIA DUE TO STAPHYLOCCOCCUS AUREUS
482.49 | PNEUMONIA DUE TO STAPHYLOCOCCUS-OTHER STAPHYLOCOCCUS PNEUMONIA
482.81 | PNEUMONIA DUE TO OTHER SPECIFIED BACTERIA -ANAEROBES
482.82 | PNEUMONIA DUE TO OTHER SPECIFIED BACTERIA - ESCHERICHIA COLI [E COLI]
482.83 | PNEUMONIA DUE TO OTHER SPECIFIED BACTERIA - OTHER GRAM-NEGATIVE BACTERIA
482.84 | PNEUMONIA DUE TO OTHER SPECIFIED BACTERIA - LEGIONNAIRES' DISEASE
482.89 | PNEUMONIA DUE TO OTHER SPECIFIED BACTERIA - OTHER SPECIFIED BACTERIA
482.9 | BACTERIAL PNEUMONIA UNSPECIFIED
485 | BRONCHOPNEUMONIA, ORGANISM UNSPECIFIED
486 | PNEUMONIA, ORGANISM UNSPECIFIED
Exclude
ICD-9-CM principal diagnosis codes:
480 | VIRAL PNEUMONIA
481 | PNEUMOCOCCAL PNEUMONIA [STREPTOCOCCUS PNEUMONIAE PNEUMONIA]
482 | OTHER BACTERIAL PNEUMONIA
483 | PNEUMONIA DUE TO OTHER SPECIFIED ORGANISM
484 | PNEUMONIA IN INFECTIOUS DISEASES CLASSIFIED ELSEWHERE
485 | BRONCHOPNEUMONIA, ORGANISM UNSPECIFIED
486 | PNEUMONIA, ORGANISM UNSPECIFIED
487 | INFLUENZA
507.0 | DUE TO INHALATION OF FOOD OR VOMITUS
514 | PULMONARY CONGESTION AND HYPOSTASIS
997.3 | RESPIRATORY COMPLICATIONS
MDC 4 | DISEASES AND DISORDERS OF THE RESPIRATORY SYSTEM
ICD-9-CM secondary diagnosis codes:
480 | VIRAL PNEUMONIA
481 | PNEUMOCOCCAL PNEUMONIA [STREPTOCOCCUS PNEUMONIAE PNEUMONIA]
483 | PNEUMONIA DUE TO OTHER SPECIFIED ORGANISM
484 | PNEUMONIA IN INFECTIOUS DISEASES CLASSIFIED ELSEWHERE
487 | INFLUENZA
[IMMUNOCOMPROMISED] STATES
FTR-Sepsis
Include
ICD-9-CM diagnosis codes:
790.7 | OTHER NONSPESIFIC FINDINGS ON EXAMINATION OF BLOOD
SEPTICEMIA:
038.0 | STREPTOCOCCAL SEPTICEMIA
038.1X | STAPHYLOCOCCAL SEPTICEMIA
038.2 | PNEUMOCOCCAL SEPTICEMIA [STREPTOCOCCUS PNEUMONIAE SEPTICEMIA]
038.3 | SEPTICEMIA DUE TO ANAEROBES
038.40 | SEPTICEMIA DUE TO GRAM NEGATIVE ORGANISM, UNSPECIFIED
038.41 | HEMOPHILUS INFLUENZE [H. INFLUENZAE]
038.42 | ESCHERICHIA COLI [E COLI]
038.43 | PSEUDOMONAS
038.44 | SERRATIA
038.49 | OTHER
038.8 | OTHER SPECIFIED SEPTICEMIAS
038.9 | UNSPECIFIED SEPTICEMIA
Exclude
ICD-9-CM diagnosis codes
[IMMUNOCOMPROMISED]
LOS>3 DAYS
[INFECTION]
FTR-Shock or cardiac arrest
Include
ICD-9-CM diagnosis codes:
995.0 | OTHER ANAPHYLACTIC SHOCK
995.4 | SHOCK DUE TO ANESTHESIA
998.0 | POSTOPERATIVE SHOCK
SHOCK DURING OR FOLLOWING LABOR AND DELIVERY:
669.10 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY - UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
669.11 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY - DELIVERED, WITH OR WITHOUT MENTION OF ANTEPARTUME CONDITION
669.12 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY - DELIVERED, WITH MENTION OF POSTPARTUM COMPLICATION
669.13 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY - ANTEPARTUM CONDITION OR COMPLICATION
669.14 | SHOCK DURING OR FOLLOWING LABOR AND DELIVERY - POSTPARTUM CONDITION OR COMPLICATION
999.4 | ANAPHYLACTIC SHOCK DUE TO SERUM
427.5 | CARDIAC ARREST
785.5 | SHOCK WITHOUT MENTION OF TRAUMA
785.50 | SHOCK, UNSPECIFIED
785.51 | CARDIOGENIC SHOCK
785.59 | SHOCK WITHOUT MENTION OF TRAUMA- OTHER
799.1 | RESPIRATORY ARREST
ICD-9-CM procedure codes:
93.93 | NONMECHANICAL METHODS OF RESUSCITATION
99.60 | CARDIOPULMONARY RESUSCITATION, NOS
99.63 | CLOSED CHEST CARDIAC MASSAGE
Exclude:
ICD-9-CM diagnosis codes:
MDC 4 | DISEASES AND DISORDERS OF THE RESPIRATORY SYSTEM
MDC 5 | DISEASES AND DISORDERS OF THE CIRCULATORY SYSTEM
Exclude principal diagnosis of [hemorrhage] or [trauma]
FTR-GI hemorrhage/acute ulcer
Include:
ICD-9-CM diagnosis codes:
456.0 | ESOPHAGEAL VARICES WITH BLEEDING
546.20 | ESOPHAGEAL VARICES IN DISEASES CLASSIFIED ELSEWHERE WITH BLEEDING
GASTRIC ULCER:
531.30 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.31 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
531.90 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.91 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
DUODENAL ULCER:
532.30 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WTHOUT MENTION OF OBSTRUCTION
532.31 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
532.90 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
532.91 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
PEPTIC ULCER:
533.30 | SITE UNSPECIFIED ACUTE WITHOUT MENTION OF HEMORRHAGE AND PERFFORATION - WITHOUT MENTION OF OBSTRUCTION
533.31 | SITE UNSPECIFIED ACUTE WITHOUT MENTION OF HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
533.90 | SITE UNSPECIFIED UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
533.91 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
GASTROJEJUNAL ULCER:
534.30 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.31 | ACUTE WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
534.90 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.91 | UNSPECIFIED AS ACUTE OR CHRONIC, WITHOUT MENTION OF HEMORRHAGE OR PERFORATION - WITH OBSTRUCTION
530.7 | GASTROESOPHAGEAL LACERATION-HEMORRHAGE SYNDROME
530.82 | ESOPHAGEAL HEMORRHAGE
GASTRIC ULCER:
531.00 | ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
531.01 | ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
531.10 | ACUTE WITH PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.11 | ACUTE WITH PERFORATION - WITH OBSTRUCTION
531.20 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
531.21 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
DUODENAL ULCER:
532.00 | ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
532.01 | ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
532.10 | ACUTE WITH PERFORATION - WITHOUT MENTION OF OBSTRUCTION
532.11 | ACUTE WITH PERFORATION - WITH OBSTRUCTION
532.20 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
532.21 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
PEPTIC ULCER:
533.00 | SITE UNSPECIFIED ACUTE WITH HEMORRHAGE - WITHOUT MENTION OF OBSTRUCTION
533.01 | SITE UNSPECIFIED ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
533.10 | SITE UNSPECIFIED ACUTE WITH PERFORATION - WITHOUT MENTION OF OBSTRUCTION
533.11 | SITE UNSPECIFIED ACUTE WITH - PERFORATION WITH OBSTRUCTION
533.20 | SITE UNSPECIFIED ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
533.21 | SITE UNSPECIFIED ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
GASTROJEJUNAL ULCER:
534.00 | ACUTE WITH HEMORRHAGE -WITHOUT MENTION OF OBSTRUCTION
534.01 | ACUTE WITH HEMORRHAGE - WITH OBSTRUCTION
534.10 | ACUTE WITH PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.11 | ACUTE WITH PERFORATION - WITH OBSTRUCTION
534.20 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITHOUT MENTION OF OBSTRUCTION
534.21 | ACUTE WITH HEMORRHAGE AND PERFORATION - WITH OBSTRUCTION
GASTRITIS AND DUODENITIS:
535.01 | ACUTE GASTRITIS - WITH HEMORRHAGE
535.11 | ATROPHIC GASTRITIS - WITH HEMORRHAGE
535.21 | GASTRIC MUCOSAL HYPERTROPHY - WITH HEMORRHAGE
535.31 | ALCOHOLIC GASTRITIS - WITH HEMORRHAGE
535.41 | OTHER SPECIFIED GASTRITIS - WITH HEMORRHAGE
535.51 | UNSPECIFIED GASTRITIS AND GASTRODUODENITIS - WITH HEMORRHAGE
535.61 | DUODENITIS - WITH HEMORRHAGE
537.83 | ANGIODYSPLASIA OF STOMACH AND DUODENUM WITH HEMORRHAGE
562.02 | DIVERTICULOSIS OF SMALL INTESTINE WITH HEMORRHAGE
562.03 | DIVERTICULITIS OF SMALL INTESTINE WITH HEMORRHAGE
562.12 | DIVERTICULOSIS OF COLON WITH HEMORRHAGE
562.13 | DIVERTICULITIS OF COLON WITH HEMORRHAGE
569.3 | HEMORRHAGE OF RECTUM AND ANUS
569.85 | ANGIODYSPLASIA OF INTESTINE WITH HEMORRHAGE
578.0 | HEMATEMESIS
578.1 | BLOOD IN STOOL
578.9 | HEMORRHAGE OF GASTROINTESTINAL TRACT, UNSPECIFIED
Exclude
MDC 6 | DISEASES AND DISORDERS OF THE DIGESTIVE SYSTEM
MDC 7 | DISEASES AND DISORDERS OF THE HEPATOBILIARY SYSTEM AND PANCREAS
ICD-9-CM principal diagnosis codes:
280.0 | SECONDARY TO BLOOD LOSS [CHRONIC]
285.1 | ACUTE POSTHEMORRHAGIC ANEMIA
TRAUMA OR BURN OR ALCHOLISM

## Section 2A. Accepted Area-Level Indicator Definitions

Items in bold and brackets are fully specified in the ICD-9-CM and DRG listings in Section 1B, “Coding Details for Accepted Hospital-Level Indicators.”

Indicator Name | Definition and Numerator | Denominator
• Foreign body left in during procedure | Discharges with ICD-9-CM codes for [foreign body left in during procedure] in any diagnosis field per 100 surgical discharges. | All [surgical] and [medical] discharges.
• Iatrogenic pneumothorax | Discharges with ICD-9-CM code of 512.1 in any diagnosis field per 100 discharges. | All discharges.
| | Exclude patients with any diagnosis of [trauma].
| | Exclude patients with any code indicating [thoracic surgery] or [lung or pleural biopsy] or assigned to [cardiac surgery].
• Infection due to medical care | Discharges with ICD-9-CM code of 999.3 or 996.62 in any diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Excludes patients with any diagnosis code for [immunocompromised] state or [cancer].
• Technical difficulty with medical care | Discharges with ICD-9-CM code denoting an [technical difficulty] (e.g. accidental cut, puncture, perforation or laceration during a procedure) in any diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Transfusion reaction | Discharges with ICD-9-CM codes for [transfusion reaction] in any diagnosis field per 100 discharges. | All [medical] and [surgical] discharges.
• Postoperative wound dehiscence | Discharges with ICD-9-CM codes for reclosure of postoperative disruption of abdominal wall (54.61) in any procedure field per 100 discharges. | All [abdominopelvic] surgical discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).

## Section 3A. Experimental Provider-Level Indicator Definitions

Items in bold and brackets are fully specified in Section 3B, “Coding Details for Experimental Indicators,” after this table.

INDICATOR NAME | DEFINITION and NUMERATOR | POPULATION AT RISK (DENOMINATOR)
• Aspiration pneumonia | Discharges with ICD-9-CM codes for [aspiration pneumonia] in any secondary diagnosis field per 100 surgical discharges. | All [elective][surgical] discharges.
| | Exclude patients with a principal diagnosis of [seizure], [trauma], [drug overdose], or [poisoning].
| | Exclude all obstetric admissions (MDC 14 and 15).
• CABG following PTCA | Discharges with ICD-9-CM codes for [CABG] in any procedure field per 100 discharges with PTCA in any procedure field. | All discharges with ICD-9-CM code for [PTCA] in any procedure field.
| CABG must occur on the same day or the day after the PTCA procedure.
• Decubitus ulcer in high risk patients | Discharges with ICD-9-CM code for decubitus ulcer (707.0) in any secondary diagnosis code per 100 at risk population. | All patients with any diagnosis of [hemiplegia, paraplegia, or quadriplagia] or patients admitted from a [long term care facility].
| | Exclude patients with a length of stay less than or equal to 4 days.
| | Exclude patients with diseases and disorders of the skin, subcutaneous tissue and breast ( MDC 9).
• In-hospital fractures possibly related to falls | Discharges with ICD-9-CM code for [fracture] in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude all patients with diseases and disorders of the musculoskeletal system and connective tissue (MDC 8).
| | Excludes patients with principal diagnosis codes for [seizure], [syncope], [stroke], [coma], [cardiac arrest], [anoxic brain injury], [poisoning], [delirium or other psychoses], [trauma], [minor trauma and/or physical abuse], indication of [alcohol or drug abuse], or [self-inflicted injury].
| | Exclude patients with any diagnosis of [metastatic cancer], [lymphoid malignancy] or [bone malignancy].
• Intraoperative nerve compression injuries | Discharges with ICD-9-CM code for [nerve compression injuries] AND a diagnosis code of 997.09 in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude patients with a principal diagnosis of [trauma].
| | Exclude patients with a principal diagnosis of [disorders of the peripheral nervous system] or [dorsopathies].
• Malignant hyperthermia | Discharges with ICD-9-CM codes for malignant hyperthermia (995.86) in any diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative iatrogenic complications - cardiac system | Discharges with ICD-9-CM codes of 997.1 in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative iatrogenic complications - nervous system | Discharges with ICD-9-CM codes of [iatrogenic nervous system complications] in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges.
| | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative acute myocardial infarction | Discharges with ICD-9-CM codes for [Acute Myocardial Infarction] in any secondary diagnosis field per 100 non-cardiac surgical discharges. | [Elective], [surgical] discharges.
| | Exclude patients undergoing [cardiac surgery].
| | Exclude all obstetric admissions (MDC 14 and 15).
• Reopening of a surgical site | Discharges with ICD-9-CM codes for [reopening of a surgical site] in any secondary procedure field per 100 surgical discharges. | All [surgical] discharges.
| Reopening of surgical site must occur at least one day after the principal procedure.
| Revision of vascular procedure 39.49 must occur within 24 hours of principal procedure.
• Suture of laceration | Discharges with ICD-9-CM codes for [suture of laceration] in any secondary procedure field per 100 surgical discharges. | All [surgical] discharges.
| Suture of laceration must occur on the same day or after the principal procedure. | Exclude patients with any diagnosis code for [foreign body] or [trauma].
| | Exclude all obstetric admissions (MDC 14 and 15).
• Other obstetric complication of delivery | Discharges with ICD-9-CM codes for [other obstetrical complications] in any diagnosis field per 100 deliveries. | All [deliveries].
• Obstetric wound complications - cesarean section delivery | Discharges with ICD-9-CM codes for [cesarean wound complications] in any diagnosis field per 100 deliveries. | All [cesarean delivery] discharges.
• Obstetric wound complications - vaginal delivery | Discharges with ICD-9-CM codes for [perineal wound complications] in any diagnosis field per 100 deliveries. | All [vaginal delivery DRGs].
• Post-partum urinary tract infection | Discharges with ICD-9-CM code of 646.62 or 646.64 in any diagnosis per 100 deliveries. | All ([cesarean delivery] and [vaginal delivery] discharges)
• Third or fourth degree obstetric lacerations | Discharges with ICD-9-CM codes for [3^rd^ or fourth degree lacerations] in any diagnosis field per 100 vaginal deliveries. | All [vaginal deliveries during stay].
| | Exclude patients with a procedure code for [cesarean section delivery] or diagnosis code for [abortion].
• Uterine rupture | Discharges with ICD-9-CM codes for [rupture of uterus during or after labor] in any diagnosis field per 100 deliveries with trial of labor. | All deliveries with a [trial of labor].

## Section 3B. Coding Details for Experimental Indicators

Acute myocardial infarction | 267
Alcohol or drug abuse | 267
Aspiration pneumonia | 268
CABG | 268
Cardiac surgery | 268
Cesarean section delivery | 268
Cesarean section wound complications | 268
Deliveries | 268
Disorders of the peripheral nervous system | 269
Dorsopathies | 269
Drug overdose | 269
Elective | 270
Foreign body | 270
Fracture | 270
Hemiplegia, paraplegia, or quadriplegia | 270
Iatrogenic nervous system complications | 270
Long term care | 270
Nerve compression injuries | 270
Other obstetrical complications | 270
Perineal wound complications | 271
Poisoning | 271
PTCA | 272
Reopening of a surgical site | 272
Rupture of uterus during or after labor | 272
Seizure | 272
Surgical | 273
Suture of laceration | 276
Third or fourth degree obstetric lacerations | 276
Trauma | 276
Trial of labor | 280
Vaginal delivery | 280
Vaginal delivery during stay | 281

Acute myocardial infarction
ICD-9-CM diagnosis codes:
410.00 | AMI OF ANTEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.01 | AMI OF ANTEROLATERAL WALL - INITIAL EPISODE OF CARE
410.10 | AMI OF OTHER ANTERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.11 | AMI OF OTHER ANTERIOR WALL - INITIAL EPISODE OF CARE
410.20 | AMI OF INFEROLATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.21 | AMI OF INFEROLATERAL WALL - INITIAL EPISODE OF CARE
410.30 | AMI OF INFEROPOSTERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.31 | AMI OF INFEROPOSTERIOR WALL - INITIAL EPISODE OF CARE
410.40 | AMI OF INFERIOR WALL - EPISODE OF CARE UNSPECIFIED
410.41 | AMI OF INFERIOR WALL - INITIAL EPISODE OF CARE
410.50 | AMI OF OTHER LATERAL WALL - EPISODE OF CARE UNSPECIFIED
410.51 | AMI OF OTHER LATERAL WALL - INITIAL EPISODE OF CARE
410.60 | AMI TRUE POSTERIOR WALL INFARCTION - EPISODE OF CARE UNSPECIFIED
410.61 | AMI TRUE POSTERIOR WALL INFARCTION - INITIAL EPISODE OF CARE
410.70 | AMI SUBENDOCARDIAL INFARCTION - EPISODE OF CARE UNSPECIFIED
410.71 | AMI SUBENDOCARDIAL INFARCTION - INITIAL EPISODE OF CARE
410.80 | AMI OF OTHER SPECIFIED SITES - EPISODE OF CARE UNSPECIFIED
410.81 | AMI OF OTHER SPECIFIED SITES - INITIAL EPISODE OF CARE
410.90 | AMI UNSPECIFIED SITE - EPISODE OF CARE UNSPECIFIED
410.91 | AMI UNSPECIFIED SITE - INITIAL EPISODE OF CARE
Alcohol or drug abuse
ICD-9-CM diagnosis codes:
(includes all 4^th^ and 5^th^ digits)
291 | ALCOHOLIC PSYCHOSES
292 | DRUG PSYCHOSES
303 | ALCOHOL DEPENDENCE SYNDROME
304 | DRUG DEPENDENCE
305.0 | ALCOHOL ABUSE
305.2 | CANNABIS ABUSE
305.3 | HALLUCINOGEN ABUSE
305.4 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE
305.5 | OPIOID ABUSE
305.6 | COCAINE ABUSE
305.7 | AMPHETAMINE OR RELATED ACTING SYMPATHOMIMETIC ABUSE
305.8 | ANTIDEPRESSANT TYPE ABUSE
305.9 | OTHER MIXED OR UNSPECIFIED DRUG ABUSE
980 | TOXIC EFFECT OF ALCOHOL
981 | TOXIC EFFECT OF PETROLEUM PRODUCTS
982 | TOXIC EFFECT OF SOLVENTS OTHER THAN PETROLEUM-BASED
983 | TOXIC EFFECT OF CORROSIVE AROMATICS, ACIDS, AND CAUSTIC ALKALIS
984 | TOXIC EFFECT OF LEAD AND ITS COMPOUNDS (INCLUDING FUMES)
985 | TOXIC EFFECT OF OTHER METALS
986 | TOXIC EFFECT OF CARBON MONOXIDE
987 | TOXIC EFFECT OF OTHER GASES, FUMES, OR VAPORS
988 | TOXIC EFFECT OF NOXIOUS SUBSTANCES EATEN AS FOOD
989 | TOXIC EFFECT OF OTHER SUBSTANCES, CHIEFLY NONMEDICINAL AS TO SOURCE
Aspiration pneumonia
ICD-9-CM diagnosis codes:
507.0 | PNEUMONITIS DUE TO SOLIDS AND LIQUIDS, DUE TO INHALATION OF FOOD OR VOMITUS
E911 | INHALATION AND INGESTION OF FOOD CAUSING OBSTRUCTION OF RESPIRATORY TRACT OR SUFFOCATION
E912 | INHALATION AND INGESTION OF OTHER OBJECT CAUSING OBSTRUCTION OF RESPIRATORY TRACT OR SUFFOCATION
CABG
ICD-9-CM procedure codes
36.10 | BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION
36.11 | OPEN HEART VALVULOPLASTY WITHOUT REPLACEMENT
36.12 | AORTOCORONARY BYPASS OF TWO CORONARY ARTERIES
36.13 | AORTOCORONARY BYPASS OF THREE CORONARY ARTERIES
36.14 | AORTOCORONARY BYPASS OF FOUR OR MORE CORONARY ARTERIES
36.15 | SINGLE INTERNAL MAMMARY-CORONARY ARTERY BYPASS
36.16 | BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION, DOUBLE INTERNAL MAMMARY-CORONARY ARTERY BYPASS
36.17 | ABDOMINAL-CORONARY ARTERY BYPASS
36.19 | OTHER BYPASS ANASTOMOSIS FOR HEART REVASCULARIZATION
Cardiac surgery
Diagnostic Related Groups (DRGs):
103 | HEART TRANSPLANT
104 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITH CARDIAC CATHETERIZATION
105 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITHOUT CARDIAC CATHETERIZATION
106 | CORONARY BYPASS WITH PTCA
107 | CORONARY BYPASS WITH CARDIAC CATHETERIZATION
108 | OTHER CARDIOTHORACIC PROCEDURES
110 | MAJOR CARDIOVASCULAR PROCEDURES WITH CC
111 | MAJOR CARDIOVASCULAR PROCEDURES WITHOUT CC
112 | PERCUTANEOUS CARDIOVASCULAR PROCEDURES
Cesarean section delivery
ICD-9-CM procedure codes:
74.0 | CLASSICAL CESAREAN SECTION
74.1 | LOW CERVICAL CESAREAN SECTION
74.2 | EXTRAPERITONEAL CESAREAN SECTION
74.4 | CESAREAN SECTION OF OTHER SPECIFIED TYPE
74.99 | OTHER CESAREAN SECTION OF UNSPECIFIED TYPE
Cesarean section wound complications
ICD-9-CM diagnosis codes:
67410 | DISRUPTION OF CESAREAN WOUND-UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
67412 | DISRUPTION OF CESAREAN WOUND-DELIVERED, WITH MENTION OF POSTPARTUM COMPLICATION
67414 | DISRUPTION OF CESAREAN WOUND-POSTPARTUM CONDITION OR COMPLICATION
67430 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
67432 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-DELIVERED, WITH MENTION OF POSTPARTUM COMPLICATION
67434 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-POSTPARTUM CONDITION OR COMPLICATION
Deliveries
Diagnostic Related Groups(DRGs):
370 | CESAREAN SECTION WITH CC
371 | CESAREAN SECTION WITHOUT CC
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY WITH STERILIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
Disorders of the peripheral nervous system
ICD-9-CM diagnosis codes:
350 | TRIGEMINAL NERVE DISORDERS
351 | FACIAL NERVE DISORDERS
352 | DISORDERS OF OTHER CRANIAL NERVES
353 | NERVE ROOT AND PLEXUS DISORDERS
354 | MONOEURITIS OF UPPER LIMB AND MONOEURITIS MULTIPLEX
355 | MONOEURITIS OF LOWER LIMB
356 | HEREDITARY AND IDIOPATHIC PERIPHERAL NEUROPATHY
357 | INFLAMMATORY AND TOXIC NEUROPATHY
358 | MYONEURAL DISORDERS
359 | MUSCULAR DYSTROPHIES AND OTHER MYOPATHIES
Dorsopathies
ICD-9-CM diagnosis codes:
720 | ANKYLOSING SPONDYLITIS AND OTHER INFLAMMATORY SPONDYLOPATHIES
721 | SPONDYLOSIS AND ALLIED DISORDERS
722 | INTERVERTEBRAL DISC DISORDERS
723 | OTHER DISORDERS OF CERVICAL REGION
724 | OTHER AND UNSPECIFIED DISORDERS OF BACK
Drug overdose
ICD-9-CM diagnosis codes:
291 | ALCOHOLIC PSYCHOSES
292 | DRUG PSYCHOSES
303.00 | ACUTE ALCOHOLIC INTOXICATION - UNSPECIFIED
303.01 | ACUTE ALCOHOLIC INTOXICATION - CONTINUOUS
303.02 | ACUTE ALCOHOLIC INTOXICATION - EPISODIC
NONDEPENDENT ABUSE OF DRUGS:
305.00 | ALCOHOL ABUSE - UNSPECIFIED
305.01 | ALCOHOL ABUSE - CONTINUOUS
305.02 | ALCOHOL ABUSE - EPISODIC
305.20 | CANNABIS ABUSE - UNSPECIFIED
305.21 | CANNABIS ABUSE - CONTINUOUS
305.22 | CANNABIS ABUSE - EPISODIC
305.30 | HALLUCINOGEN ABUSE - UNSPECIFIED
305.31 | HALLUCINOGEN ABUSE - CONTINUOUS
305.32 | HALLUCINOGEN ABUSE - EPISODIC
305.40 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE - UNSPECIFIED
305.41 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE - CONTINUOUS
305.42 | BARBITURATE AND SIMILARLY ACTING SEDATIVE OR HYPNOTIC ABUSE - EPISODIC
305.50 | OPIOID ABUSE - UNSPECIFIED
305.51 | OPIOID ABUSE - CONTINUOUS
305.52 | OPIOID ABUSE - EPISODIC
305.70 | AMPHETAMINE OR RELATED ACTING - UNSPECIFIED
305.71 | AMPHETAMINE OR RELATED ACTING - CONTINUOUS
305.72 | AMPHETAMINE OR RELATED ACTING - EPISODIC
305.80 | ANTIDEPRESSANT TYPE ABUSE - UNSPECIFIED
305.81 | ANTIDEPRESSANT TYPE ABUSE - CONTINUOUS
305.82 | ANTIDEPRESSANT TYPE ABUSE - EPISODIC
305.90 | OTHER MIXED, OR UNSPECIFIED DRUG ABUSE - UNSPECIFIED
305.91 | OTHER MIXED, OR UNSPECIFIED DRUG ABUSE - CONTINUOUS
305.92 | OTHER MIXED, OR UNSPECIFIED DRUG ABUSE - EPISODIC
965.0 | POISONING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS, OPIATES AND RELATED NARCOTICS
967.0 | POISONING BY SEDATIVES AND HYPNOTICS
968.5 | POISONING BY OTHER CENTRAL NERVOUS SYSTEM DEPRESSANT AND ANESTHETICS SURFACE [TOPICAL] AND INFILTRATION ANESTHETICS
969 | POISONING BY PSYCHOTROPIC AGENTS
980 | TOXIC EFFECT OF ALCOHOL
ACCIDENTAL POISONING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEYUMATICS:
E850.0 | HEROIN
E850.1 | METHADONE
E850.2 | OTHER OPIATES AND RELATED NARCOTICS
E851 | ACCIDENTAL POISONING BY BARBITURATES
E852 | ACCIDENTAL POISONING BY OTHER SEDATIVES AND HYPNOTICS
E853 | ACCIDENTAL POISONING BY TRANQUILIZERS
E854 | ACCIDENTAL POISONING BY OTHER PSYCHOTROPIC AGENTS
E860 | ACCIDENTAL POISONING BY ALCOHOL, NEC
SUICIDE AND SELF-INFLICTED POISONING BY SOLID OR LIQUID SUBSTANCES:
E950.0 | ANALGESICS, ANTIPYRETICS, AND ANTIRHEYMATICS
E950.1 | BARBITURATES
E950.2 | OTHER SEDATIVES AND HYPNOTICS
E950.3 | TRANQUILIZERS AND OTHER PSYCHOTROPIC AGENTS
E950.4 | OTHER SPECIFIED DRUGS AND MEDICINAL SUBSTANCES
E950.5 | UNSPECIFIED DRUG OR MEDICINAL SUBSTANCE
E980.0 | UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED - ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
E980.1 | UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED - BARBITURATES
E980.2 | UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED - OTHER SEDATIVES AND HYPNOTICS
E980.3 | UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED - TRANQUILIZERS AND OTHER PSYCHOTROPIC AGENTS
Elective
ADMISSION TYPE IS RECORDED AS ELECTIVE
Foreign body
ICD-9-CM diagnosis codes:
FOREIGN BODY IN:
933.0 | PHARYNX
933.1 | LARYNX
934.0 | TRACHEA
934.1 | MAIN BRONCHUS
934.8 | OTHER SPECIFIED PARTS
935.1 | MOUTH
935.2 | ESOPHAGUS
936 | INTESTINE AND COLON
937 | ANUS AND RECTUM
938 | DIGESTIVE SYSTEM UNSPECIFIED
939.0 | GENITOURINARY TRACT, BLADDER AND URETHRA
939.1 | FOREIGN BODY IN GENITOURINARY TRACT, UTERUS, ANY PART
Fracture
ICD-9-CM diagnosis codes ( include 4^th^ or 5^th^ digits):
FRACTURE OF VERTEBRAL COLUMN WITH SPINAL CORD INJURY:
806.6 | SACRUM AND COCYX CLOSED
806.7 | SACRUM AND COCYX OPEN
808 | FRACTURE OF PELVIS
810 | FRACTURE OF CLAVICLE
811 | FRACTURE OF SCAPULA
812 | FRACTURE OF HUMERUS
813 | FRACUTRE OF RADIUS AND ULNA
820 | FRACTURE OF NECK OF FEMUR
821 | FRACTURE OF OTHER AND UNSPECIFIED PARTS OF FEMUR
822 | FRACTURE OF PATELLA
823 | FRACTURE OF TIBIA AND FIBULA
824 | FRACTURE OF ANKLE
825 | FRACTURE OF ONE OR MORE TARSAL AND METATARSAL BONES
826 | FRACTURE OF ONE OR MORE PHALANGES OF FOOT
827 | OTHER, MULTIPLE, AND ILL-DEFINED FRACTURE OF LOWER LIMB
828 | MULTIPLE FRACTURE INVOLVING BOTH LOWER LIMBS, LOWER WITH UPPER LIMB, AND LOWER LIMB(S) WITH RIB(S) AND STERNUM
829 | FRACTURE OF UNSPECIFIED BONES
Hemiplegia, paraplegia, or quadriplegia
ICD-9-CM diagnosis codes (includes 5^th^ digits):
342.0 | FLACCID HEMIPLEGIA
342.1 | SPASTIC HEMIPLEGIA
342.8 | OTHER SPECIFIED HEMIPLEGIA
342.9 | HEMIPLEGIA, UNSPECIFIED
343.0 | INFANTILE CEREBRAL PALSY, DIPLEGIC
343.1 | INFANTILE CEREBRAL PALSY, HEMIPLEGIC
343.2 | INFANTILE CEREBRAL PALSY, QUADRIPLEGIC
343.3 | INFANTILE CEREBRAL PALSY, MONOPLEGIC
343.4 | INFANTILE CEREBRAL PALSY INFANTILE HEMIPLEGIA
343.8 | INFANTILE CEREBRAL PALSY OTHER SPECIFIED INFANTILE CEREBRAL PALSY
343.9 | INFANTILE CEREBRAL PALSY, INFANTILE CEREBRAL PALSY, UNSPECIFIED
344.0 | QUADRIPLEGIA AND QUADRIPARESIS
344.1 | PARAPLEGIA
344.2 | DIPLEGIA OF UPPER LIMBS
344.3 | MONOPLEGIA OF LOWER LIMB
344.4 | MONOPLEGIA OF UPPER LIMB
344.5 | UNSPECIFIED MONOPLEGIA
344.6 | CAUDA EQUINA SYNDROME
344.8 | OTHER SPECIFIED PARALYTIC SYNDROMES
344.9 | PARALYSIS, UNSPECIFIED
438.2 | HEMIPLEGIA/HEMIPARESIS
438.3 | MONOPLEGIA OF UPPER LIMB
438.4 | MONOPLEGIA OF LOWER LIMB
438.5 | OTHER PARALYTIC SYNDROME
Iatrogenic nervous system complications
ICD-9-CM diagnosis codes:
997.00 | NERVOUS SYSTEM COMPLICATION, UNSPECIFIED
997.01 | CENTRAL NERVOUS SYSTEM COMPLICATIONS
997.02 | IATROGENIC CEREBROVASCULAR INFARCTION OR HEMORRHAGE
997.09 | OTHER NERVOUS SYSTEM COMPLICATIONS
Long term care
ADMISSION TYPE/SOURCE IS RECORDED AS LONG TERM CARE FACILITY
Nerve compression injuries
ICD-9-CM diagnosis codes:
353.0 | BRACHIAL PLEXUS LESIONS
355.1 | MERALGIA PARESTHETICA
355.3 | LESION OF LATERAL POPLITEAL NERVE
Other obstetrical complications
ICD-9-CM diagnosis codes:
(includes 5th digits):
668.0 | PULMONARY COMPLICATIONS
668.1 | CARDIAC COMPLICATIONS
668.2 | CENTRAL NERVOUS SYSTEM COMPLICATIONS
668.8 | OTHER COMPLICATIONS OF ANESTHESIA OR OTHER SEDATION IN LABOR AND DELIVERY
668.9 | UNSPECIFIED COMPLICATION OF ANESTHESIA AND OTHER SEDATION
669.1 | OTHER COMPLICATIONS OF LABOR AND DELIVERY, NOT ELSEWHERE CLASSIFIED, SHOCK DURING OR FOLLOWING LABOR AND DELIVERY
669.4 | OTHER COMPLICATIONS OF OBSTETRICAL SURGERY AND PROCEDURES
669.30, 2, 4 | ACUTE RENAL FAILURE FOLLOWING LABOR AND DELIVERY
Perineal wound complications
ICD-9-CM diagnosis codes:
674.20 | DISRUPTION OF PERINEAL WOUND-UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
674.22 | DISRUPTION OF PERINEAL WOUND-DELIVERY, WITH MENTION OF POSTPARTUM COMPLICATION
674.24 | DISRUPTION OF PERINEAL WOUND-POSTPARTUM CONDITION OR COMPLICATION
664.5 | VULVAL AND PERINEAL HEMATOMA
665.7 | PELVIC HEMATOMA
674.30 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
674.32 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-DELIVERED, WITH MENTION OF POSTPARTUM COMPLICATION
674.34 | OTHER COMPLICATIONS OF OBSTETRICAL SURGICAL WOUNDS-POSTPARTUM CONDITION OR COMPLICATION
Poisoning
ICD-9-CM diagnosis codes (includes 4^th^ and 5^th^ digits):
960 | POISONING BY ANTIBIOTICS
961 | POISONING BY OTHER ANTI-INFECTIVES
962 | POISONING BY HORMONES AND SYNTHETIC SUBSTITUTES
963 | POISONING BY PRIMARILY SYSTEMIC AGENTS
964 | POISONING BY AGENTS PRIMARILY AFFECTING BLOOD CONSTITUENTS
965 | POISONOING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
966 | POISONING BY ANTICONVULSANTS AND ANTI-PARKINSONISM DRUGS
967 | POISONING BY SEDATIVES AND HYPNOTICS
968 | POISONING BY OTHER CENTRAL NERVOUS SYSTEM DEPRESSANTS AND ANESTHETICS
969 | POISONING BY PSYCHOTROPIC AGENTS
970 | POISONING BY CENTRAL NERVOUS SYSTEM STIMULANTS
971 | POISONING BY DRUGS PRIMARILY AFFECTING THE AUTONOMIC NERVOUS SYSTEM
972 | POISONING BY AGENTS PRIMARILY AFFECTING THE CARDIOVASCULAR SYSTEM
973 | POISOING BY AGENTS PRIMARILY AFFECTING THE GASTROINTESTINAL SYSTEM
974 | POISONING BY WATER, MINERAL, AND URIC ACID METABOLSIM DRUGS
975 | POISONING BY AGENTS PRIMARILY ACTING ON THE SMOOTH AND SKELETAL MUSCLES AND RESPIRATORY SYSTEM
976 | POISONING BY AGENTS PRIMARILY AFFECTING SKIN AND MUCOUS MEMBRANE, OPTHAMOLOGICAL, OTORHINOLARYNCOLOGICAL AND DENTAL DRUGS
977 | POISONING BY OTHER AND UNSPECIFIED DRUGS AND MEDICINAL SUBSTANCES
978 | POISONING BY BACTERIAL VACCINES
979 | POISONING BY OTHER VACCINES AND BIOLOGICAL SUBSTANCES
E850 | ACCIDENTAL POISONING BY ANALGESICS, ANTIPYRETICS, AND ANTIRHEUMATICS
E851 | ACCIDENTAL POISONING BY BARBITURATES
E852 | ACCIDENTAL POISONING BY OTHER SEDATIVES AND HYPNOTICS
E853 | ACCIDENTAL POISONING BY TRANQUILIZERS
E854 | ACCIDENTAL POISONING BY OTHER PSYCHOTROPIC AGENTS
E855 | ACCIDENTAL POISONING BY OTHER DRUGS ACTING ON CENTRAL AND AUTONOMIC NERVOUS SYSTEM
E856 | ACCIDENTAL POISONING BY ANTIBIOTICS
E857 | ACCIDENTAL POISONING BY OTHER ANTI-INFECTIVES
E858 | ACCIDENTAL POISONING BY OTHER DRUGS
E860 | ACCIDENTAL POISONING BY ALCOHOL, NEC
E861 | ACCIDENTAL POISONING BY CLEANING AND POLISHING AGENTS, DISINFECTANTS, PAINTS, AND VARNISHES
E862 | ACCIDENTAL POISONING BY PETROLEUM PRODUCTS, OTHER SOLVENTS AND THEIR VAPORS, NEC
E863 | ACCIDENTAL POISONING BY AGRICULTURAL AND HORTICULTURAL CHEMICAL AND PHARMACEUTICAL PREPARATIONS OTHER THAN PLANT FOODS AND FERTILIZERS
E864 | ACCIDENTAL POISONING BY CORROSIVES AND CAUSTICS, NEC
E865 | ACCIDENTAL POISONING FROM POISONOUS FOODSTUFFS AND POISONOUS PLANTS
E866 | ACCIDENTAL POISONG BY OTHER AND UNSPECIFIED SOLID AND LIQUID SUBSTANCES
E867 | ACCIDENTAL POISONOING BY GAS DISTRIBUTED BY PIPELINE
E868 | ACCIDENTAL POISONING BY OTHER UTILITY GAS AND OTHER CARBON MONOXIDE
E869 | ACCIDENTAL POISONING BY OTHER GASES AND VAPORS
E951 | SUICIDE AND SELF-INFLICTED POISONING BY GASES IN DOMESTIC USE
E952 | SUICIDE AND SELF-INFLICTED POISONING BY OTHER GASES AND VAPORS
E962 | ASSAULT BY POISONING
E980 | POISONING BY SOLID OR LIQUID SUBSTANCES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E981 | POISONING BY GASES IN DOMESTIC USE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E982 | POISONING BY OTHER GASES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
PTCA
ICD-9-CM procedure codes:
36.01 | SINGLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLASTY [PTCA] OR CORONARY ATHERECTOMY WITHOUT MENTION OF THROMBOLYTIC AGENT
36.02 | SINGLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLASTY [PTCA] OR CORONARY ATHERECTOMY WITH MENTION OF THROMBOLYTIC AGENT
36.05 | MULTIPLE VESSEL PERCUTANEOUS TRANSLUMINAL CORONARY ANGIOPLSTY [PTCA] OR CORONARY ATHERECTOMY PERFORMED DURING THE SAME OPERATION, WITH OR WITHOUT MENTION OF THROMBOLYTIC AGENT
36.06 | INSERTION OF CORONARY ARTERY STENTS
Reopening of a surgical site
ICD-9-CM procedure codes:
12.3 | REOPENING OF CRANIOTOMY SITE
30.2 | REOPENING OF LAMINECTOMY SITE
60.2 | REOPENING OF WOUND OF THYROID FIELD
34.03 | REOPENING OF RECENT THORACOTOMY SITE
39.49 | OTHER REVISION OF VASCULAR PROCEDURE
54.12 | REOPENING OF RECENT LAPAROTOMY SITE
Rupture of uterus during or after labor
ICD-9-CM diagnosis codes:
665.10 | RUPTURE OF UTERUS DURING LABOR-UNSPECIFIED AS TO EPISODE OF CARE OR NOT APPLICABLE
665.11 | RUPTURE OF UTERUS DURING LABOR-DELIVERED, WITH OR WITHOUT MENTION OF ANTEPARTUM CONDITION
Seizure
ICD-9-CM diagnosis codes:
345.00 | GENERALIZED NONCONVULSIVE EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.01 | GENERALIZED NONCONVULSIVE EPILEPSY - WITH INTRACTABLE EPILEPSY
345.10 | GENERALIZED CONVULSIVE EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.11 | GENERALIZED CONVULSIVE EPILEPSY - WITH INTRACTABLE EPILEPSY
345.2 | EPILEPSY-PETIT MAL STATUS
345.3 | EPILEPSY-GRAND MAL STATUS
345.40 | PARTIAL EPILEPSY, WITH IMPAIRMENT OF CONSCIOUSNESS - WITH INTRACTABLE EPILEPSY
345.41 | PARTIAL EPILEPSY, WITH IMPAIRMENT OF CONSCIOUSNESS - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.50 | PARTIAL EPILEPSY, WITHOUT MENTION OF IMPAIRMENT OF CONSCIOUSNESS, - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.51 | PARTIAL EPILEPSY, WITHOUT MENTION OF IMPAIRMENT OF CONSCIOUSNESS - WITH INTRACTABLE EPILEPSY
345.60 | INFANTILE SPASMS - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.61 | INFANTILE SPASMS - WITH INTRACTABLE EPILEPSY
345.70 | EPILEPSIA PARTIALIS CONTINUA - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.71 | EPILEPSIA PARTIALIS CONTINUA - WITH INTRACTABLE EPILEPSY
345.80 | OTHER FORMS OF EPILEPSY - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.81 | OTHER FORMS OF EPILEPSY - WITH INTRACTABLE EPILEPSY
345.90 | EPILEPSY, UNSPECIFIED - WITHOUT MENTION OF INTRACTABLE EPILEPSY
345.91 | EPILEPSY, UNSPECIFIED - WITH INTRACTABLE EPILEPSY
780.3 | CONVULSIONS (OLD CODE NO LONGER VALID)
780.31 | FEBRILE CONVULSIONS
780.39 | OTHER CONVULSIONS
Surgical
Diagnostic Related Groups (DRGs)
001 | CRANIOTOMY, AGE GREATER THAN 17 EXCEPT FOR TRAUMA
002 | CRANIOTOMY FOR TRAUMA, AGE GREATER THAN 17
003 | CRANIOTOMY, AGE 0–17
004 | SPINAL PROCEDURES
005 | EXTRACRANIAL VASCULAR PROCEDURES
006 | CARPAL TUNNEL RELEASE
007 | PERIPHERAL AND CRANIAL NERVE AND OTHER NERVOUS SYSTEM PROCEDURES WITH CC
008 | PERIPHERAL AND CRANIAL NERVE AND OTHER NERVOUS SYSTEM PROCEDURES WITHOUT CC
036 | RETINAL PROCEDURES
037 | ORBITAL PROCEDURES
038 | PRIMARY IRIS PROCEDURES
039 | LENS PROCEDURES WITH OR WITHOUT VITRECTOMY
040 | EXTRAOCULAR PROCEDURES EXCEPT ORBIT, AGE GREATER THAN 17
041 | EXTRAOCULAR PROCEDURES EXCEPT ORBIT, AGE 0–17
042 | INTRAOCULAR PROCEDURES EXCEPT RETINA, IRIS AND LENS
049 | MAJOR HEAD AND NECK PROCEDURES
050 | SIALOADENECTOMY
051 | SALIVARY GLAND PROCEDURES EXCEPT SIALOADENECTOMY
052 | CLEFT LIP AND PALATE REPAIR
053 | SINUS AND MASTOID PROCEDURES, AGE GREATER THAN 17
054 | SINUS AND MASTOID PROCEDURES, AGE 0–17
055 | MISCELLANEOUS EAR, NOSE, MOUTH AND THROAT PROCEDURES
056 | RHINOPLASTY
057 | TONSILLECTOMY AND ADENOIDECTOMY PROCEDURES EXCEPT TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE GREATER THAN 17
058 | TONSILLECTOMY AND ADENOIDECTOMY PROCEDURES EXCEPT TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE 0–17
059 | TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE GREATER THAN 17
060 | TONSILLECTOMY AND/OR ADENOIDECTOMY ONLY, AGE 0–17
061 | MYRINGOTOMY WITH TUBE INSERTION, AGE GREATER THAN 17
062 | MYRINGOTOMY WITH TUBE INSERTION, AGE 0–17
063 | OTHER EAR, NOSE, MOUTH AND THROAT OR PROCEDURES
075 | MAJOR CHEST PROCEDURES
076 | OTHER RESPIRATORY SYSTEM OR PROCEDURES WITH CC
077 | OTHER RESPIRATORY SYSTEM OR PROCEDURES WITHOUT CC
103 | HEART TRANSPLANT
104 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITH CARDIAC CATHETERIZATION
105 | CARDIAC VALVE AND OTHER MAJOR CARDIOTHORACIC PROCEDURES WITHOUT CARDIAC CATHETERIZATION
106 | CORONARY BYPASS WITH PTCA
107 | CORONARY BYPASS WITH CARDIAC CATHETERIZATION
108 | OTHER CARDIOTHORACIC PROCEDURES
109 | CORONARY BYPASS WITHOUT CARDIAC CATHETERIZATION
110 | MAJOR CARDIOVASCULAR PROCEDURES WITH CC
111 | MAJOR CARDIOVASCULAR PROCEDURES WITHOUT CC
112 | PERCUTANEOUS CARDIOVASCULAR PROCEDURES
113 | AMPUTATION FOR CIRCULATORY SYSTEM DISORDERS EXCEPT UPPER LIMB AND TOE
114 | UPPER LIMB AND TOES AMPUTATION FOR CIRCULATORY SITE
115 | PERMANENT CARDIAC PACEMAKER IMPLANT WITH ACUTE MYOCARDIAL INFARCTION, HEART FAILURE OR SHOCK OR ACID LEAD OR GENERATOR PROCEDURE
116 | OTHER PERMANENT CARDIAC PACEMAKER IMPLANT OR PTCA WITH CORONARY ARTERIAL STENT
117 | CARDIAC PACEMAKER REVISION EXCEPT DEVICE REPLACEMENT
118 | CARDIAC PACEMAKER DEVICE REPLACEMENT
119 | VEIN LIGATION AND STRIPPING
120 | OTHER CIRCULATORY SYSTEM OR PROCEDURES
146 | RECTAL RESECTION WITH CC
147 | RECTAL RESECTION WITHOUT CC
148 | MAJOR SMALL AND LARGE BOWEL PROCEDURES WITH CC
149 | MAJOR SMALL AND LARGE BOWEL PROCEDURES WITHOUT CC
150 | PERITONEAL ADHESIOLYSIS WITH CC
151 | PERITONEAL ADHESIOLYSIS WITHOUT CC
152 | MINOR SMALL AND LARGE BOWEL PROCEDURES WITH CC
153 | MINOR SMALL AND LARGE BOWEL PROCEDURES WITHOUT CC
154 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE GREATER THAN 17 WITH CC
155 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE GREATER THAN 17 WIHOUT CC
156 | STOMACH, ESOPHAGEAL AND DUODENAL PROCEDURES, AGE 0–17
157 | ANAL AND STOMAL PROCEDURES WITH CC
158 | ANAL AND STOMAL PROCEDURES WITHOUT CC
159 | HERNIA PROCEDURES EXCEPT INGUINAL AND FEMORAL, AGE GREATER THAN 17 WITH CC
160 | HERNIA PROCEDURES EXCEPT INGUINAL AND FEMORAL, AGE GREATER THAN 17 WITHOUT CC
161 | INGUINAL AND FEMORAL HERNIA PROCEDURES, AGE GREATER THAN 17 WITH CC
162 | INGUINAL AND FEMORAL HERNIA PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
163 | HERNIA PROCEDURES, AGE 0–17
164 | APPENDECTOMY WITH COMPLICATED PRINCIPAL DIAGNOSIS WITH CC
165 | APPENDECTOMY WITH COMPLICATED PRINCIPAL DIAGNOSIS WITHOUT CC
166 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITH CC
167 | APPENDECTOMY WITHOUT COMPLICATED PRINCIPAL DIAGNOSIS WITHOUT CC
168 | MOUTH PROCEDURES WITH CC
169 | MOUTH PROCEDURES WITHOUT CC
170 | OTHER DIGESTIVE SYSTEM OR PROCEDURES WITH CC
171 | OTHER DIGESTIVE SYSTEM OR PROCEDURES WITHOUT CC
191 | PANCREAS, LIVER AND SHUNT PROCEDURES WITH CC
192 | PANCREAS, LIVER AND SHUNT PROCEDURES WITHOUT CC
193 | BILIARY TRACT PROCEDURES EXCEPT ONLY CHOLECYSTECTOMY WITH OR WITHOUT COMMON DUCT EXPLORATION WITH CC
194 | BILIARY TRACT PROCEDURES EXCEPT ONLY CHOLECYSTECTOMY WITH OR WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
195 | CHOLECYSTECTOMY WITH COMMON DUCT EXPLORATION WITH CC
196 | CHOLECYSTECTOMY WITH COMMON DUCT EXPLORATION WITHOUT CC
197 | CHOLECYSTECTOMY EXCEPT BY LAPAROSCOPE WITHOUT COMMON DUCT EXPLORATION WITH CC
198 | CHOLECYSTECTOMY EXCEPT BY LAPAROSCOPE WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
199 | HEPATOBILIARY DIAGNOSTIC PROCEDURE FOR MALIGNANCY
200 | HEPATOBILIARY DIAGNOSTIC PROCEDURE FOR NONMALIGNANCY
201 | OTHER HEPATOBILIARY OR PANCREAS OR PROCEDURES
209 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF LOWER EXTREMITY
210 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURES, AGE GREATER THAN 17 WITH CC
211 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
212 | HIP AND FEMUR PROCEDURES EXCEPT MAJOR JOINT PROCEDURE, AGE 0–17
213 | AMPUTATION FOR MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE DISORDERS
214 | NO LONGER VALID
215 | NO LONGER VALID
216 | BIOPSIES OF MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE
217 | WOUND DEBRIDEMENT AND SKIN GRAFT EXCEPT HAND FOR MUSCULOSKELETAL AND CONNECTIVE TISSUE DISORDERS
218 | LOWER EXTREMITY AND HUMERUS PROCEURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITH CC
219 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE GREATER THAN 17 WITHOUT CC
220 | LOWER EXTREMITY AND HUMERUS PROCEDURES EXCEPT HIP, FOOT AND FEMUR, AGE 0–17
221 | NO LONGER VALID
222 | NO LONGER VALID
223 | MAJOR SHOULDER/ELBOW PROCEDURES OR OTHER UPPER EXTREMITY PROCEDURES WITH CC
224 | SHOULDER, ELBOW OR FOREARM PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
225 | FOOT PROCEDURES
226 | SOFT TISSUE PROCEDURES WITH CC
227 | SOFT TISSUE PROCEDURES WITHOUT CC
228 | MAJOR THUMB OR JOINT PROCEDURES OR OTHER HAND OR WRIST PROCEDURES WITH CC
229 | HAND OR WRIST PROCEDURES EXCEPT MAJOR JOINT PROCEDURES WITHOUT CC
230 | LOCAL EXCISION AND REMOVAL OF INTERNAL FIXATION DEVICES OF HIP AND FEMUR
231 | LOCAL EXCISION AND REMOVAL OF INTERNAL FIXATION DEVICES EXCEPT HIP AND FEMUR
232 | ARTHROSCOPY
233 | OTHER MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE OR PROCEDURES WITH CC
234 | OTHER MUSCULOSKELETAL SYSTEM AND CONNECTIVE TISSUE OR PROCEDURES WITHOUT CC
257 | TOTAL MASTECTOMY FOR MALIGNANCY WITH CC
258 | TOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
259 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITH CC
260 | SUBTOTAL MASTECTOMY FOR MALIGNANCY WITHOUT CC
261 | BREAST PROCEDURE FOR NONMALIGNANCY EXCEPT BIOPSY AND LOCAL EXCISION
262 | BREAST BIOPSY AND LOCAL EXCISION FOR NONMALIGNANCY
263 | SKIN GRAFT AND/OR DEBRIDEMENT FOR SKIN ULCER OR CELLULITIS WITH CC
264 | SKIN GRAFT AND OR DEBRIDEMENT FOR SKIN ULCER OR CELLULITIS WITHOUT CC
265 | SKIN GRAFT AND OR DEBRIDEMENT EXCEPT FOR SKIN ULCER OR CELLULITIS WITH CC
266 | SKIN GRAFT AND/OR DEBRIDEMENT EXCEPT FOR SKIN ULCER OR CELLULITIS WITHOUT CC
267 | PERIANAL AND PILONIDAL PROCEDURES
268 | SKIN, SUBCUTANEOUS TISSUE AND BREAST PLASTIC PROCEDURES
269 | OTHER SKIN, SUBCUTANEOUS TISSUE AND BREAST PROCEDURES WITH CC
270 | OTHER SKIN, SUBCUTANEOUS TISSUE AND BREAST PROCEDURS WITHOUT CC
285 | AMPUTATION OF LOWER LIMB FOR ENDOCRINE, NUTRITIONAL AND METABOLIC DISORDERS
286 | ADRENAL AND PITUITARY PROCEDURES
287 | SKIN GRAFTS AND WOUND DEBRIDEMENTS FOR ENDOCRINE, NUTRITIONAL AND METABOLIC DISORDERS
288 | OR PROCEDURES FOR OBESITY
289 | PARATHYROID PROCEDURES
290 | THYROID PROCEDURES
291 | THYROGLOSSAL PROCEDURES
292 | OTHER ENDOCRINE, NUTRITIONAL AND METABOLIC OR PROCEDURES WITH CC
293 | OTHER ENDOCRINE, NUTRITIONAL AND METABOLIC OR PROCEDURES WITHOUT CC
302 | KIDNEY TRANSPLANT
303 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NEOPLASM
304 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NONNEOPLASMS WITH CC
305 | KIDNEY, URETER AND MAJOR BLADDER PROCEDURES FOR NONNEOPLASMS WITHOUT CC
306 | PROSTATECTOMY WITH CC
307 | PROSTATECTOMY WITHOUT CC
308 | MINOR BLADDER PROCEDURES WITH CC
309 | MINOR BLADDER PROCEDURES WITHOUT CC
310 | TRANSURETHRAL PROCEDURES WITH CC
311 | TRANSURETHRAL PROCEDURES WITHOUT CC
312 | URETHRAL PROCEDURES, AGE GREATER THAN 17 WITH CC
313 | URETHRAL PROCEDURES, AGE GREATER THAN 17 WITHOUT CC
314 | URETHRAL PROCEDURES, AGE 0–17
315 | OTHER KIDNEY AND URINARY TRACT OR PROCEDURES
334 | MAJOR MALE PELVIC PROCEDURES WITH CC
335 | MAJOR MALE PELVIC PROCEDURES WITHOUT CC
336 | TRANSURETHRAL PROSTATECTOMY WITH CC
337 | TRANSURETHRAL PROSTATECTOMY WITHOUT CC
338 | TESTES PROCEDURES FOR MALIGNANCY
339 | TESTES PROCEDURES FOR NONMALIGNANCY, AGE GREATER THAN 17
340 | TESTES PROCEDURES FOR NONMALIGNANCY, AGE 0–17
341 | PENIS PROCEDURES
342 | CIRCUMCISION, AGE GREATER THAN 17
343 | CIRCUMCISION, AGE 0–17
344 | OTHER MALE REPRODUCTIVE SYSTEM OR PROCEDURES FOR MALIGNANCY
345 | OTHER MALE REPRODUCTIVE SYSTEM OR PROCEDURES EXCEPT FOR MALIGNANCY
353 | PELVIC EVISCERATION, RADICAL HYSTERECTOMY AND RADICAL VULVECTOMY
354 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITH CC
355 | UTERINE AND ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXA PROCEDURES FOR NONOVARIAN/ADNEXAL MALIGNANCY WITHOUT CC
356 | FEMALE REPRODUCTIVE SYSTEM RECONSTRUCTIVE PROCEDURES
357 | UTERINE AND ADNEXA PROCEDURES FOR OVARIAN OR ADNEXAL MALIGNANCY
358 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITH CC
359 | UTERINE AND ADNEXA PROCEDURES FOR NONMALIGNANCY WITHOUT CC
360 | VAGINA, CERVIX AND VULVA PROCEDURES
361 | LAPAROSCOPY AND INCISIONAL TUBAL INTERRUPTION
362 | ENDOSCOPIC TUBAL INTERRUPTION
363 | D AND C, CONIZATION AND RADIOIMPLANT FOR MALIGNANCY
364 | D AND C, CONIZATION EXCEPT FOR MALIGNANCY
365 | OTHER FEMALE REPRODUCTIVE SYSTEM OR PROCEDURES
370 | CESAREAN SECTION WITH CC
371 | CESAREAN SECTION WITHOUT CC
374 | VAGINAL DELIVERY WITH STERILIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
377 | POSTPARTUM AND POSTABORTION DIAGNOSES WITH OR PROCEDURE
381 | ABORTION WITH D AND C ASPIRATION CURETTAGE OR HYSTERECTOMY
392 | SPLENECTOMY, AGE GREATER THAN 17
393 | SPLENECTOMY, AGE 0–17
394 | OTHER OR PROCEDURES OF THE BLOOD AND BLOOD-FORMING ORGANS
400 | LYMPHOMA AND LEUKEMIA WITH MAJOR OR PROCEDURES
401 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITH CC
402 | LYMPHOMA AND NONACUTE LEUKEMIA WITH OTHER OR PROCEDURE WITHOUT CC
406 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURES WITH CC
407 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH MAJOR OR PROCEDURES WITHOUT CC
408 | MYELOPROLIFERATIVE DISORDERS OR POORLY DIFFERENTIATED NEOPLASMS WITH OTHER OR PROCEDURES
415 | OR PROCEDURE FOR INFECTIOUS AND PARASITIC DISEASES
424 | OR PROCEDURES WITH PRINCIPAL DIAGNOSIS OF MENTAL ILLNESS
439 | SKIN GRAFTS FOR INJURIES
440 | WOUND DEBRIDEMENTS FOR INJURIES
441 | WOUND HAND PROCEDURES FOR INJURIES
442 | OTHER OR PROCEDURES FOR INJURIES WITH CC
443 | OTHER OR PROCEDURES FOR INJURIES
458 | NO LONGER VALID
459 | NO LONGER VALID
461 | OR PROCEDURES WITH DIAGNOSES OF OTHER CONTACT WITH HEALTH SERVICES
468 | EXTENSIVE OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
471 | BILATERAL OR MULTIPLE MAJOR JOINT PROCEDURES OF LOWER EXTREMITY
472 | NO LONGER VALID
476 | PROSTATIC OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
477 | NONEXTENSIVE OR PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
478 | OTHER VASCULAR PROCEDURES WITH CC
479 | OTHER VASCULAR PROCEDURES WITHOUT CC
480 | LIVER TRANSPLANT
481 | BONE MARROW TRANSPLANT
482 | TRACHEOSTOMY FOR FACE, MOUTH AND NECK DIAGNOSES
483 | TRACHEOSTOMY EXCEPT FOR FACE, MOUTH AND NECK DIAGNOSES
484 | CRANIOTOMY FOR MULTIPLE SIGNIFICANT TRAUMA
485 | LIMB REATTACHMENT, HIP AND FEMUR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
486 | OTHER OR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
488 | HIV WITH EXTENSIVE OR PROCEDURE
491 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF UPPER EXTREMITY
493 | LAPAROSCOPIC CHOLECYSTECTOMY WITHOUT COMMON DUCT EXPLORATION WITH CC
494 | LAPAROSCOPIC CHOLECYSTECTOMY WITHOUT COMMON DUCT EXPLORATION WITHOUT CC
495 | LUNG TRANSPLANT
496 | COMBINED ANTERIOR/POSTERIOR SPINAL FUSION
497 | SPINAL FUSION WITH CC
498 | SPINAL FUSION WITHOUT CC
499 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITH CC
500 | BACK AND NECK PROCEDURES EXCEPT SPINAL FUSION WITHOUT CC
501 | KNEE PROCEDURES WITH PRINCIPAL DIAGNOSIS OF INFECTION, WITH CC
502 | KNEE PROCEDURES WITH PRINCIPAL DIAGNOSIS OF INFECTION, WITHOUT CC
503 | KNEE PROCEDURES WITHOUT PRINCIPAL DIAGNOSIS OF INFECTION
Suture of laceration
ICD-9-CM procedure codes:
04.3 | SUTURE OF CRANIAL AND PERIPHERAL NERVES
29.51 | SUTURE OF LACERATION OF PHARYNX
31.61 | SUTURE OF LACERATION OF LARYNX
33.41 | SUTURE OF LACERATION OF BRONCHUS
33.43 | CLOSURE OF LACERATION OF LUNG
34.82 | SUTURE OF LACERATION OF DIAPHRAGM
39.30 | SUTURE OF UNSPECIFIED BLOOD VESSEL
39.31 | SUTURE OF ARTERY
39.32 | SUTURE OF VEIN
42.82 | SUTURE OF LACERATION OF ESOPHAGUS
44.61 | SUTURE OF LACERATION OF STOMACH
46.71 | SUTURE OF LACERATION OF DUODENUM
46.73 | SUTURE OF LACERATION OF SMALL INTESTINE, EXCEPT DUODENUM
46.75 | SUTURE OF LACERATION OF LARGE INTESTINE
48.71 | SUTURE OF LACERATION OF RECTUM
49.71 | SUTURE OF LACERATION OF ANUS
55.81 | SUTURE OF LACERATION OF KIDNEY
56.82 | SUTURE OF LACERATION OF URETER
57.81 | SUTURE OF LACERATION OF BLADDER
58.41 | SUTURE OF LACERATION OF URETHRA
50.61 | CLOSURE OF LACERATION OF LIVER
51.91 | REPAIR OF LACERATION OF GALLBLADDER
67.61 | SUTURE OF LACERATION OF CERVIX
69.41 | SUTURE OF LACERATION OF UTERUS
Third or fourth degree obstetric lacerations
ICD-9-CM diagnosis codes:
664.21 | THIRD DEGREE PERINEAL LACERATION-DELIVERED, WITH OR WITHOUT MENTION OF ANTEPARTUM CONDITION
664.31 | FOURTH-DEGREE PERINEAL LACERATION - DELIVERED, WITH OR WITHOUT MENTION OF ANTEPARTUM CONDITION
Trauma
ICD-9-CM diagnosis codes ( includes 4^th^ and 5^th^ digits):
800 | FRACTURE OF VAULT OF SKULL
801 | FRACTURE OF BASE OF SKULL
802 | FRACTURE OF FACE BONES
803 | OTHER AND UNQUALIFIED SKULL FRACTURES
804 | MULTIPLE FRACTURES INVOLVING SKULL OR FACE WITH OTHER BONES
805 | FRACTURE OF VERTEBRAL COLUMN WITHOUT MENTION OF SPINAL CHORD INJURY
806 | FRACTURE OF VERTEBRAL COLUMN WITH SPINAL CORD INJURY
807 | FRACTURE OF RIB[S] STERNUM, LARYNX, AND TRACHEA
808 | FRACTURE OF PELVIS
809 | ILL-DEFINED FRACTURES OF BONES OF TRUNK
810 | FRACTURE OF CLAVICLE
811 | FRACTURE OF SCAPULA
812 | FRACTURE OF HUMEROUS
813 | FRACTURE OF RADIUS AND ULNA
814 | FRACTURE OF CARPAL BONE[S]
815 | FRACTURE OF METACARPAL BONE[S]
817 | MULTIPLE FRACTURES OF HAND BONES
818 | ILL-DEFINED FRACTURES OF UPPER LIMB
819 | MULTIPLE FRACTURES INVOLVING BOTH UPPER LIMBS, AND UPPER LIMB WITH RIB AND STERNUM
820 | FRACTURE OF NECK OF FEMUR
821 | FRACTURE OF OTHER AND UNSPECIFIED PARTS OF FEMUR
822 | FRACTURE OF PATELLA
823 | FRACTURE OF TIBIA AND FIBULA
824 | FRACTURE OF ANKLE
825 | FRACTURE OF ONE OR MORE TARSAL AND METATARSAL BONES
827 | OTHER, MULTIPLE, AND ILL-DEFINED FRACTURES OF LOWER LIMB
828 | MULTIPLE FRACTURES INVOLVING BOTH LOWER LIMBS, LOWER WITH UPPER LIMB, AND LOWER LIMB WITH RIB AND STERNUM
829 | FRACTURE OF UNSPECIFIED BONES
830 | DISLOCATION OF JAW
831 | DISLOCATION OF SHOULDER
832 | DISLOCATION OF ELBOW
833 | DISLOCATION OF WRIST
835 | DISLOCATION OF HIP
836 | DISLOCATION OF KNEE
837 | DISLOCATION OF ANKLE
838 | DISLOCATION OF FOOT
839 | OTHER, MULTIPLE, AND ILL-DEFINED DISLOCATIONS
850 | CONCUSSION
851 | CEREBRAL LACERATION AND CONTUSION
852 | SUBARACHNOID, SUBDURAL, AND EXTRADURAL HEMORRHAGE, FOLLOWING INJURY
853 | OTHER AND UNSPECIFIED INTRACRANIAL HEMORRHAGE FOLLOWING INJURY
854 | INTRACRANIAL INJURY OF OTHER AND UNSPECIFIED NATURE
860 | TRAUMATIC PNEUMOTHORAX
861 | INJURY TO HEART AND LUNG
862 | INJURY TO OTHER AND UNSPECIFIED INTRATHORACIC ORGANS
863 | INJURY TO GASTROINTESTINAL TRACT
864 | INJURY TO LIVER
865 | INJURY TO SPLEEN
866 | INJURY TO KIDNEY
867 | INJURY TO PELVIC ORGANS
868 | INJURY TO OTHER INTRA-ABDOMINAL ORGANS
869 | INTERNAL INJURY TO UNSPECIFIED OR ILL-DEFINED ORGANS
870 | OPEN WOUND OF OCULAR ADNEXA
871 | OPEN WOUND OF EYEBALL
872 | OPEN WOUND OF EAR
873 | OTHER OPEN WOUND OF HEAD
874 | OPEN WOUND OF NECK
875 | OPEN WOUND OF CHEST [WALL]
876 | OPEN WOUND OF BACK
877 | OPEN WOUND OF BUTTOCK
878 | OPEN WOUND OF GENITAL ORGANS [EXTERNAL] INCLUDING TRAUMATIC AMPUTATION
879 | OPEN WOUND OF OTHER AND UNSPECIFIED SITES, EXCEPT LIMBS
880 | OPEN WOUND OF SHOULDER AND UPPER ARM
881 | OPEN WOUND OF ELBOW, FOREARM, AND WRIST
882 | OPEN WOUND OF HAND EXCEPT FINGER ALONE
884 | MULTIPLE AND UNSPECIFIED OPEN WOUND OF UPPER LIMB
887 | TRAUMATIC AMPUTATION OF ARM AND HAND (COMPLETE) (PARTIAL)
890 | OPEN WOUND OF HIP AND THIGH
891 | OPEN WOUND OF KNEE, LEG (EXCEPT THIGH) AND ANKLE
892 | OPEN WOUND OF FOOT EXCEPT TOE ALONE
894 | MULTIPLE AND UNSPECIFIED OPEN WOUND OF LOWER LIMB
896 | TRAUMATIC AMPUTATION OF FOOT (COMPLETE) (PARTIAL)
897 | TRAUMATIC AMPUTATION OF LEG(S) (COMPLETE) (PARTIAL)
900 | INJURY TO BLOOD VESSELS OF HEAD AND NECK
901 | INJURY TO BLOOD VESSELS OF THORAX
902 | INJURY TO BLOOD VESSELS OF ABDOMEN AND PELVIS
903 | INJURY TO BLOOD VESSELS OF UPPER EXTREMITY
904 | INJURY TO BLOOD VESSELS OF LOWER EXTREMITY AND UNSPECIFIED SITES
925 | CRUSHING INJURY OF FACE, SCALP, AND NECK
926 | CRUSHING INJURY OF TRUNK
927 | CRUSHING INJURY OF UPPER LIMB
928 | CRUSHING INJURY OF LOWER LIMB
929 | CRUSHING INJURY OF MULTIPLE AND UNSPECIFIED SITES
940 | BURN CONFINED TO EYE AND ADNEXA
941 | BURN OF FACE, HEAD, AND NECK
942 | BURN OF TRUNK
943 | BURN OF UPPER LIMB, EXCEPT WRIST AND HAND
944 | BURN OF WRIST[S] AND HAND[S]
945 | BURN OF LOWER LIMB[S]
946 | BURNS OF MULTIPLE SPECIFIED SITES
947 | BURN OF INTERNAL ORGANS
948 | BURNS CLASSIFIED ACCORDING TO EXTENT OF BODY SURFACE INVOLVED
949 | BURN, UNSPECIFIED
952 | SPINAL CHORD INJURY WITHOUT EVIDENCE OF SPINAL BONE INJURY
953 | INJURY TO NERVE ROOTS AND SPINAL PLEXUS
958 | CERTAIN EARLY COMPLICATIONS OF TRAUMA
E800 | RAILWAY ACCIDENT INVOLVING COLLISION WITH ROLLING STOCK
E801 | RAILWAY ACCIDENT INVOLVING COLLISION WITH OTHER OBJECT
E802 | RAILWAY ACCIDENT INVOLVING DERAILMENT WITHOUT ANTECEDENT COLLISION
E803 | RAILWAY ACCIDENT INVOLVING EXPLOSION, FIRE, OR BURNING
E804 | FALL IN, ON, OR FROM RAILWAY TRAIN
E805 | HIT BY ROLLING STOCK
E806 | OTHER SPECIFIED RAILWAY ACCIDENT
E807 | RAILWAY ACCIDENT OF UNSPECIFIED NATURE
E810 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH TRAIN
E811 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING RE-ENTERANT COLLISION WITH ANOTHER MOTOR VEHICLE
E812 | OTHER MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH MOTOR VEHICLE
E813 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH OTHER VEHICLE
E814 | MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION WITH PEDESTRIAN
E815 | OTHER MOTOR VEHICLE TRAFFIC ACCIDENT INVOLVING COLLISION ON THE HIGHWAY
E816 | MOTOR VEHICLE TRAFFIC ACCIDENT DUE TO LOSS OF CONTROL, WITHOUT COLLISION ON THE HIGHWAY
E817 | NONCOLLISION MOTOR VEHICLE TRAFFIC ACCIDENT WHILE BOARDING OR ALIGHTING
E818 | OTHER NONCOLLISION MOTOR VEHICLE TRAFFIC ACCIDENT
E819 | MOTOR VEHICLE TRAFFIC ACCIDENT OF UNSPECIFIED NATURE
E820 | NONTRAFFIC ACCIDENT INVOLVING MOTOR-DRIVEN SNOW VEHICLE
E821 | NONTRAFFIC ACCIDENT INVOLVING OTHER OFF-ROAD MOTOR VEHICLE
E822 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT INVOLVING COLLISION WITH MOVING OBJECT
E823 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT INVOLVING COLLISION WITH STATIONARY OBJECT
E824 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT WHILE BOARDING AND ALIGHTING
E825 | OTHER MOTOR VEHICLE NONTRAFFIC ACCIDENT OF OTHER AND UNSPECIFIED NATURE
E826 | PEDAL CYCLE ACCIDENT
E827 | ANIMAL-DRAWN VEHICLE ACCIDENT
E828 | ACCIDENT INVOLVING ANIMAL BEING RIDDEN
E829 | OTHER ROAD VEHICLE ACCIDENTS
E830 | ACCIDENT TO WATERCRAFT CAUSING SUBMERSION
E831 | ACCIDENT TO WATERCRAFT CAUSING OTHER INJURY
E832 | OTHER ACCIDENTAL SUBMERSION OR DROWNING IN WATER TRANSPORT ACCIDENT
E833 | FALL ON STAIRS OR LADDERS IN WATER TRANSPORT
E834 | OTHER FALL FROM ONE LEVEL TO ANOTHER IN WATER TRANSPORT
E835 | OTHER AND UNSPECIFIED FALL IN WATER TRANSPORT
E836 | MACHINERY ACCIDENT IN WATER TRANSPORT
E837 | EXPLOSION, FIRE, OR BURNING IN WATERCRAFT
E838 | OTHER AND UNSPECIFIED WATER TRANSPORT ACCIDENT
E840 | ACCIDENT TO POWERED AIRCRAFT AT TAKEOFF OR LANDING
E841 | ACCIDENT TO POWERED AIRCRAFT, OTHER AND UNSPECIFIED
E842 | ACCIDENT TO UNPOWERED AIRCRAFT
E843 | FALL IN, ON, OR FROM AIRCRAFT
E844 | OTHER SPECIFIED AIR TRANSPORT ACCIDENTS
E845 | ACCIDENT INVOLVING SPACECRAFT
E846 | ACCIDENTS INVOLVING POWERED VEHICLES USED SOLELY WITHIN THE BUILDINGS AND PREMISES AND INDUSTRIAL OR COMMERCIAL ESTABLISHMENT
E847 | ACCIDENTS TO UNPOWERED AIRCRAFT
E848 | ACCIDENTS INVOLVING OTHER VEHICLES, NEC
E849 | PLACE OF OCCURRENCE
E880 | FALL ON OR FROM STAIRS OR STEPS
E881 | FALL ON OR FROM LADDERS OR SCAFFOLDING
E882 | FALL FROM OR OUT OF BUILDING OR OTHER STRUCTURE
E883 | FALL INTO HOLE OR OTHER OPENING IN SURFACE
E884 | OTHER FALL FROM ONE LEVEL TO ANOTHER
E885 | FALL ON SAME LEVEL FROM SLIPPING, TRIPPING, OR STUMBLING
E886 | FALL ON SAME LEVEL FROM COLLISION, PUSHING, OR SHOVING BY OR WITH OTHER PERSON
E887 | FRACTURE, CAUSE UNSPECIFIED
E888 | OTHER AND UNSPECIFIED FALL
E890 | CONFLAGRATION IN PRIVATE DWELLING
E891 | CONFLAGRATION IN OTHER AND UNSPECIFIED BUILDING OR STRUCTURE
E892 | CONFLAGRATION NOT IN BUILDING OR STRUCTURE
E893 | ACCIDENT CAUSED BY IGNITION OF CLOTHING
E894 | IGNITION OF HIGHLY INFLAMMABLE MATERIAL
E895 | ACCIDENT CAUSED BY CONTROLLED FIRE IN PRIVATE DWELLING
E896 | ACCIDENT CAUSE BY CONTROLLED FIRE IN OTHER AND UNSPECIFIED BUILDING OR STRUCTURE
E897 | ACCIDENT CAUSED BY CONTROLLED FIRE NOT IN BUILDING OR STRUCTURE
E898 | ACCIDENT CAUSED BY OTHER SPECIFIED FIRE AND FLAMES
E899 | ACCIDENT CAUSED BY UNSPECIFIED FIRE
E910 | ACCIDENTAL DROWNING AND SUBMERSION
E913 | ACCIDENTAL MECHANICAL SUFFOCATION
E914 | FOREIGN BODY ACCIDENTALLY ENTERING EYE AND ADNEXA
E915 | FOREIGN BODY ACCIDENTALLY ENTERING OTHER ORIFICE
E916 | STRUCK ACCIDENTALLY BY FALLING OBJECT
E917 | STRIKING AGAINST OR STRUCK ACCIDENTALLY BY OBJECTS OR PERSONS
E918 | CAUGHT ACCIDENTALLY IN OR BETWEEN OBJECTS
E919 | ACCIDENTS CAUSED BY MACHINERY
E920 | ACCIDENTS CAUSED BY CUTTING AND PIERCING INSTRUMENTS OR OBJECTS
E921 | ACCIDENT CAUSED BY EXPLOSION OF PRESSURE VESSEL
E922 | ACCIDENT CAUSED BY FIREARM AND AIR GUN MISSILE
E923 | ACCIDENT CAUSED BY EXPLOSIVE MATERIAL
E924 | ACCIDENT CAUSED BY HOT SUBSTANCE OR OBJECT, CAUSTIC OR CORROSIVE MATERIAL, AND STEAM
E925 | ACCIDENT CAUSED BY ELECTRIC CURRENT
E926 | EXPOSURE TO RADIATION
E927 | OVEREXERTION AND STRENUOUS MOVEMENTS
E928 | OTHER AND UNSPECIFIED ENVIRONMENTAL AND ACCIDENTAL CAUSES
E960 | FIGHT, BRAWL, RAPE
E961 | ASSAULT BY CORROSIVE OR CAUSTIC SUBSTANCE, EXCEPT POISONING
E962 | ASSAULT BY POISONING
E963 | ASSAULT BY HANGING AND STRANGULATION
E964 | ASSAULT BY SUBMERSION [DROWNING]
E965 | ASSAULT BY FIREARMS AND EXPLOSIVES
E966 | ASSAULT BY CUTTING AND PIERCING INSTRUMENT
E967 | PERPETRATOR OF CHILD AND ADULT ABUSE
E968 | ASSAULT BY OTHER AND UNSPECIFIED MEANS
E969 | LATE EFFECTS OF INJURY PURPOSELY INFLICTED BY OTHER PERSON
E970 | INJURY DUE TO LEGAL INTERVENTION BY FIREARMS
E971 | INJURY DUE TO LEGAL INTERVENTION BY EXPLOSIVES
E972 | INJURY DUE TO LEGAL INTERVENTION BY GAS
E973 | INJURY DUE TO LEGAL INTERVENTION BY BLUNT OBJECT
E974 | INJURY DUE TO LEGAL INTERVENTION BY CUTTING AND PIERCING INSTRUMENT
E975 | INJURY DUE TO LEGAL INTERVENTION BY OTHER SPECIFIED MEANS
E976 | INJURY DUE TO LEGAL INTERVENTION BY UNSPECIFIED MEANS
E977 | LATE EFFECTS OF INJURIES DUE TO LEGAL INTERVENTION
E978 | LEGAL EXECUTION
E980 | POISONING BY SOLID OR LIQUID SUBSTANCES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E981 | POISONING BY GASES IN DOMESTIC USE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E982 | POISONING BY OTHER GASES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E983 | HANGING, STRANGULATION, OR SUFFOCATION, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E984 | SUBMERSION [DROWNING] UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E985 | INJURY BY FIREARMS, AIR GUNS AND EXPLOSIVES, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E986 | INJURY BY CUTTING AND PIERCING INSTRUMENTS, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E987 | FALLING FROM HIGH PLACE, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E988 | INJURY BY OTHER AND UNSPECIFIED MEANS, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E989 | LATE EFFECTS OF INJURY, UNDETERMINED WHETHER ACCIDENTALLY OR PURPOSELY INFLICTED
E990 | INJURY DUE TO WAR OPERATIONS BY FIRES AND CONFLAGRATIONS
E991 | INJURY DUE TO WAR OPERATIONS BY BULLETS AND FRAGMENTS
E992 | INJURY DUE TO WAR OPERATIONS BY EXPLOSION OF MARINE WEAPONS
E993 | INJURY DUE TO WAR OPERATIONS BY OTHER EXPLOSION
E994 | INJURY DUE TO WAR OPERATIONS BY DESTRUCTION OF AIRCRAFT
E995 | INJURY DUE TO WAR OPERATIONS BY OTHER AND UNSPECIFIED FORMS OF CONVENTIONAL WARFARE
E996 | INJURY DUE TO WAR OPERATIONS BY NUCLEAR WEAPONS
E997 | INJURY DUE TO WAR OPERATIONS BY OTHER FORMS OF UNCONVENTIONAL WARFARE
E998 | INJURY DUE TO WAR OPERATIONS BUT OCCURRING AFTER CESSATION OF HOSTILITIES
E999 | LATE EFFECT OF INJURY DUE TO WAR OPERATIONS
DIAGNOSTIC RELATED GROUPS (DRGS)
002 | CRANIOTOMY FOR TRAUMA, AGE GREATER THAN 17
027 | TRAUMATIC STUPOR AND COMA, COMA GREATER THAN ONE HOUR
028 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 17 WITH CC
029 | TRAUMATIC STUPOR AND COMA, COMA LESS THAN ONE HOUR, AGE GREATER THAN 17 WITHOUT CC
031 | CONCUSSION, AGE GREATER THAN 17 WITH CC
032 | CONCUSSION, AGE GREATER THAN 17 WITHOUT CC
072 | NASAL TRAUMA AND DEFORMITY
083 | MAJOR CHEST TRAUMA WITH CC
084 | MAJOR CHEST TRAUMA WITHOUT CC
235 | FRACTURES OF FEMUR
236 | FRACTURE OF HIP AND PELVIS
237 | SPRAINS, STRAINS AND DISLOCATIONS OF HIP, PELVIS AND THIGH
440 | WOUND DEBRIDEMENTS FOR INJURIES
441 | HAND PROCEDURES FOR INJURIES
442 | OTHER OR PROCEDURES FOR INJURIES WITH CC
443 | OTHER OR PROCEDURES FOR INJURIES WITHOUT CC
444 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITH CC
445 | TRAUMATIC INJURY, AGE GREATER THAN 17 WITHOUT CC
446 | TRAUMATIC INJURY, AGE 0–17
447 | ALLERGIC REACTIONS, AGE GREATER THAN 17
448 | ALLERGIC REACTIONS, AGE 0–17
449 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITH CC
450 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE GREATER THAN 17 WITHOUT CC
451 | POISONING AND TOXIC EFFECTS OF DRUGS, AGE 0–17
452 | COMPLICATIONS OF TREATMENT WITH CC
453 | COMPLICATIONS OF TREATMENT WITHOUT CC
454 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITH CC
455 | OTHER INJURY, POISONING AND TOXIC EFFECT DIAGNOSES WITHOUT CC
460 | NO LONGER VALID
484 | CRANIOTOMY FOR MULTIPLE SIGNIFICANT TRAUMA
485 | LIMB REATTACHMENT, HIP AND FEMUR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
486 | OTHER OR PROCEDURES FOR MULTIPLE SIGNIFICANT TRAUMA
487 | OTHER MULTIPLE SIGNIFICANT TRAUMAS
491 | MAJOR JOINT AND LIMB REATTACHMENT PROCEDURES OF UPPER EXTREMITY
Trial of labor
Diagnostic Related Groups (DRGs)
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY WITH STERILZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH OR PROCEDURE EXCEPT STERILIZATION AND/OR D AND C
or
ICD-9-CM diagnosis codes (includes all 4th and 5th digits):
653 | DISPROPORTION
660 | OBSTRUCTED LABOR
661 | ABNORMALITY OF FORCES OF LABOR
662 | LONG LABOR
(Includes all 5th digits):
652.1 | BREECH OR OTHER MALPRESENTATION SUCCESSFULLY CONVERTED TO CEPHALIC PRESENTATION
659.0 | FAILED MECHANICAL INDUCTION
659.1 | FAILED MEDICAL OR UNSPECIFIED INDUCTION
659.2 | MATERNAL PYREXIA DURING LABOR, UNSPECIFIED
659.3 | GENERALIZED INFECTION DURING LABOR
656.3 | FETAL DISTRESS
663.0 | PROLAPSE OF CORD
663.1 | CORD AROUND NECK, WITH COMPRESSION
663.2 | OTHER AND UNSPECIFIED CORD ENTANGLEMENT, WITH COMPRESSION
663.3 | OTHER AND UNSPECIFIED CORD ENTANGLEMENT, WITHOUT MENTION OF COMPRESSION
663.4 | SHORT CORD
663.5 | VASA PREVIA
663.6 | VASCULAR LESIONS OF CORD
663.8 | OTHER UMBILICAL CORD COMPLICATIONS
663.9 | UNSPECIFIED UMBILICAL CORD COMPLICATION
Vaginal delivery
Diagnostic Related Groups (DRGs):
372 | VAGINAL DELIVERY WITH COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY WITHOUT COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY WITH STERILAIZATION AND/OR D AND C
375 | VAGINAL DELIVERY WITH/ OR PROCEDURE EXCEPT STERILIZATION AND/ OR D AND C
Vaginal delivery during stay
ICD-9-CM diagnosis codes (includes all 4th digits, #1 and # 2 5th digits):
640.8 | OTHER SPECIFIED HEMORRHAGE IN EARLY PREGNANCY
640.9 | UNSPECIFIED HEMORRHAGE IN EARLY PREGNANCY
641 | ANTEPARTUM HEMORRHAGE, ABRUPTIO PACENTAE, AND PLACENTA PREVIA
642 | HYPERTENSION COMPLICATING PREGNANCY, CHILDBIRTH, AND THE PUERPERIUM
643 | EXCESSIVE VOMITING IN PREGNANCY
644 | EARLY OR THREATENED LABOR
645 | LATE PREGNANCY
646 | OTHER COMPLICATIONS OF PREGNANCY, NEC
647 | INFECTIOUS AND PARASITIC CONDITIONS IN THE MOTHER CLASSIFIABLE ELSEWHERE, BUT COMPLICATING PREGNANCY, CHILDBIRTH, OR THE PUERPERIUM
648 | OTHER CURRENT CONDITIONS IN THE MOTHER CLASSIFIABLE ELSEWHERE, BUT COMPLICATING PREGNANCY, CHILDBIRTH, OR THE PUERPERIUM
650 | NORMAL DELIVERY
651 | MULTIPLE GESTATION
652 | MALPOSITION AND MALPRESENTATION OF FETUS
653 | DISPROPORTION
654 | ABNORMALITY OF ORGANS AND SOFT TISSUES OF PELVIS
655 | KNOWN OR SUSPECTED FETAL ABNORMALITY AFFECTING MANAGEMENT OF MOTHER
656 | OTHER FETAL AND PLACENTAL PROBLEMS AFFECTING MANAGEMENT OF MOTHER
657 | POLYHYDRAMNIOS
658 | OTHER PROBLEMS ASSOCIATED WITH AMNIOTIC CAVITY AND MEMBRANES
659 | OTHER INDICATION FOR CARE OR INTERVENTION RELATED TO LABOR AND DELIVERY, NEC
660 | OBSTRUCTED LABOR
661 | ABNORMALITY OF FORCES OF LABOR
662 | LONG LABOR
663 | UMBILICAL CORD COMPLICATIONS
664 | TRAUMA TO PERINEUM AND VULVA DURING DELIVERY
665 | OTHER OBSTETRICAL TRAUMA
666 | POSTPARTUM HEMORRHAGE
667 | RETAINED PLACENTA OR MEMBRANES, WITHOUT HEMORRHAGE
668 | COMPLICATIONS OF THE ADMINISTRATION OF ANESTHETIC OR OTHER SEDATION IN LABOR AND DELIVERY
669 | OTHER COMPLICATIONS OF LABOR AND DELIVERY, NEC
670 | MAJOR PUERPERAL INFECTION
671 | VENOUS COMPLICATIONS IN PREGNANCY AND THE PUERPERIUM
672 | PYREXIA OF UNKNOWN ORIGIN DURING THE PUERPERIUM
673 | OBSTETRICAL PULMONARY EMBOLISM
674 | OTHER AND UNSPECIFIED COMPLICATIONS OF THE PUERPERIUM, NEC
675 | INFECTIONS OF THE BREAST AND NIPPLE ASSOCIATED WITH CHILDBIRTH
676.91 | UNSPECIFIED DISORDER OF LACTATION - DELIVERED, WITH OR WITHOUT MENTION OF ANTEPARTUM CONDITION
or
V27.0 | SINGLE LIVEBORN
V27.1 | SINGLE STILLBORN
V27.2 | TWINS, BOTH LIVEBORN
V27.3 | TWINS, ONE LIVEBORN AND ONE STILLBORN
V27.4 | TWINS, BOTH STILLBORN
V27.5 | OTHER MULTIPLE BIRTH, ALL LIVEBORN
V27.6 | OTHER MULTIPLE BIRTH, SOME LIBEBORN
V27.7 | OTHER MULTIPLE BIRTH, ALL STILLBORN
V27.9 | UNSPECIFIED OUTCOME OF DELIVERY

## Section 4A. Definitions of Rejected Indicators (after panel discussion and rating)

Denominator items in bold and brackets are fully specified in Section 1B, “Coding Details for Accepted Hospital-Level Indicators.”

Indicator | Definition and Numerator | Population at Risk (Denominator)
• Obstetric thrombosis or embolism | Discharges with ICD-9-CM codes for obstetric thrombosis or embolism [DVT - postpartum unspecified (671.40), DVT- delivered with mention of postpartum complication (671.42), DVT - postpartum condition or complication (671.44), Obstetric pulmonary embolism (673.20)] in any diagnosis field per 100 deliveries. | All deliveries ([vaginal delivery],[cesarean delivery]).
• Puerperal infection | Discharges with ICD-9-CM codes for major puerperal infection [Major puerperal infection, unspecified as to episode of care (670.00), Major puerperal infection, delivered with mention of post-partum complication (670.02), Major puerperal infection, post-partum condition or complication (670.04)] in any diagnosis field per 100 deliveries. | All deliveries ([vaginal delivery],[cesarean delivery]).
| | Exclude patients with a diagnosis code of antepartum infection of amniotic cavity [65840, 1, 3].
• Postoperative pneumonia | Discharges with ICD-9-CM codes for pneumonia [pneumococcal pneumonia (481), other bacterial pneumonia {Klebsiella pneumoniae, pseudomoniae, pseudomonas, Hemophilis pneumoniae, streptococcus, stapnylococcus, anaerobes, E. coli, other gram negative, Legionnaires disease} (482.0–482.99)] in any secondary diagnosis field per 100 surgical discharges. | All [surgical] discharges
| | Exclude patients in MDC 4.
| | Exclude patients with any diagnosis of [immunocompromised] state (including any diagnosis of AIDS), or [cancer]
• Iatrogenic hypotension | Discharges with ICD-9-CM code of 458.2 in any diagnosis field per 100 discharges. | Exclude all obstetric admissions (MDC 14 and 15).
| | Exclude patients with any diagnosis of [trauma]
• Intestinal infection due to Clostridium difficile | Discharges with ICD-9-CM code of 008.45 in any secondary diagnosis field per 100 discharges. | Exclude all obstetric admissions (MDC 14 and 15).
• Dosage complications | Discharges with ICD-9-CM code denoting a dosage complication [Failure in dosage. Excessive amount of blood or other fluid during transfusion or infusion (E873.0), Failure in dosage. Incorrect dilution of fluid during infusion. (E873.1), Failure in dosage. Overdose of radiation in therapy (E873.2) Failure in dosage. Inadvertent exposure of patient to radiation during medical care (E873.3) Failure in dosage in electroshock or insulin-shock therapy (E873.4), Failure in dosage. Inappropriate too hot or too cold temperature in local application and packing (E873.5), Failure in dosage, Non-administration of necessary drug or medicinal substance (E873.6), Other specific failure in dosage excludes accidental overdose of drug (E873.8) Unspecified failure in dosage (E873.9), Wrong fluid in infusion (E876.1)] in any diagnosis field per 100 discharges. | Exclude all obstetric admissions (MDC 14 and 15).
• Postoperative iatrogenic complications - digestive | Secondary dx codes of iatrogenic complication of digestive system (997.4) | [Surgical] patients
• Postoperative iatrogenic complications - respiratory | Secondary dx code of iatrogenic complication of respiratory system (997.3) | [Surgical] patients
• Postoperative iatrogenic complications - urinary | Secondary dx code of iatrogenic complications of urinary system (997.5) | [Surgical] patients
• Postoperative iatrogenic complications - vascular | Secondary dx code of iatrogenic peripheral vascular complication (997.2) | [Surgical] patients
• Unexpected LOS/Conditional LOS | Unexpected: For each patient a predicted length of stay is calculated using a multiple linear regression model. The predicted length of stay depends on the principal diagnosis, age, and comorbidities of the patient. Then, an unexpected length of stay percentage is calculated: (actual LOS - predicted LOS)/predicted LOS. Patients whose percentage is in the upper quartile (top 25%) are considered to have unusually long lengths of stay. (Kuykendall, 1995) | All [Surgical] and [Medical] patients.
| Conditional: Patients with an extended length of stay have a hospital stay that is longer than the “extended length of stay point” defined as the point in the distribution (days stayed) where, for any particular DRG, the rate of discharge changes from increasing to decreasing. In other words, at some point, for a group of patients within a DRG, fewer patients are discharged than were discharged on the previous day, and more patients are held in the hospital for longer stays (Silber, 1999).