# Empirical Methods Details

This appendix gives details about risk adjustment (DRG and comorbidity) and death in low mortality DRGs.

Section 1 lists adjacent DRGs which differ by the distinction of “with comorbidities and complications” as opposed to “without comorbidities and complications” that were grouped for the purpose of risk adjustment.

Section 2 lists the super-MDC categories and non-valid DRGs that were excluded from risk adjustment.

Section 3 lists details of the adaptation of the AHRQ Comorbidity Software, with the rationale for each adaptation.

Section 4 lists the DRGs included in the denominator of the indicator “Death in low mortality DRGs” by stratification.

## Section 1. DRG Categories Grouped in the PSI Risk Adjustment

DRG | DRG Label
007 | PERIPH & CRANIAL NERVE & OTHER NERV SYST PROC W CC
008 | W/O CC
010 | NERVOUS SYSTEM NEOPLASMS W CC
011 | W/O CC
016 | NONSPECIFIC CEREBROVASCULAR DISORDERS W CC
017 | W/O CC
018 | CRANIAL & PERIPHERAL NERVE DISORDERS W CC
019 | CRANIAL & PERIPHERAL NERVE DISORDERS W/O CC
024 | SEIZURE & HEADACHE AGE >17 W CC
025 | W/O CC
028 | TRAUMATIC STUPOR & COMA, COMA <1 HR AGE >17 W CC
029 | W/O CC
031 | CONCUSSION AGE >17 W CC
032 | W/O CC
034 | OTHER DISORDERS OF NERVOUS SYSTEM W CC
035 | W/O CC
046 | OTHER DISORDERS OF THE EYE AGE >17 W CC
047 | W/O CC
068 | OTITIS MEDIA & URI AGE >17 W CC
069 | W/O CC
076 | OTHER RESP SYSTEM O.R. PROCEDURES W CC
077 | W/O CC
079 | RESPIRATORY INFECTIONS & INFLAMMATIONS AGE >17 W CC
080 | W/O CC
083 | MAJOR CHEST TRAUMA W CC
084 | W/O CC
085 | PLEURAL EFFUSION W CC
086 | W/O CC
089 | SIMPLE PNEUMONIA & PLEURISY AGE >17 W CC
090 | W/O CC
092 | INTERSTITIAL LUNG DISEASE W CC
093 | W/O CC
094 | PNEUMOTHORAX W CC
095 | W/O CC
096 | BRONCHITIS & ASTHMA AGE >17 W CC
097 | W/O CC
099 | RESPIRATORY SIGNS & SYMPTOMS W CC
100 | W/O CC
101 | OTHER RESPIRATORY SYSTEM DIAGNOSES W CC
102 | W/O CC
110 | MAJOR CARDIOVASCULAR PROCEDURES W CC
111 | W/O CC
121 | CIRCULATORY DISORDERS W AMI & MAJOR COMP, DISCHARGED ALIVE
122 | W/O MAJOR COMP, DISCHARGED ALIVE
123 | CIRCULATORY DISORDERS EXCEPT AMI, W CARD CATH & COMPLEX DIAG
124 | W/O COMPLEX DIAG
130 | PERIPHERAL VASCULAR DISORDERS W CC
131 | W/O CC
132 | ATHEROSCLEROSIS W CC
133 | W/O CC
135 | CARDIAC CONGENITAL & VALVULAR DISORDERS AGE >17 W CC
136 | W/O CC
138 | CARDIAC ARRHYTHMIA & CONDUCTION DISORDERS W CC
139 | W/O CC
141 | SYNCOPE & COLLAPSE W CC
142 | W/O CC
144 | OTHER CIRCULATORY SYSTEM DIAGNOSES W CC
145 | W/O CC
146 | RECTAL RESECTION W CC
147 | W/O CC
148 | MAJOR SMALL & LARGE BOWEL PROCEDURES W CC
149 | W/O CC
150 | PERITONEAL ADHESIOLYSIS W CC
151 | W/O CC
152 | MINOR SMALL & LARGE BOWEL PROCEDURES W CC
153 | W/O CC
154 | STOMACH, ESOPHAGEAL & DUODENAL PROCEDURES AGE >17 W CC
155 | W/O CC
157 | ANAL & STOMAL PROCEDURES W CC
158 | W/O CC
159 | HERNIA PROCEDURES EXCEPT INGUINAL & FEMORAL AGE >17 W CC
160 | W/O CC
161 | INGUINAL & FEMORAL HERNIA PROCEDURES AGE >17 W CC
162 | W/O CC
164 | APPENDECTOMY W COMPLICATED PRINCIPAL DIAG W CC
165 | W/O CC
166 | APPENDECTOMY W/O COMPLICATED PRINCIPAL DIAG W CC
167 | W/O CC
168 | MOUTH PROCEDURES W CC
169 | W/O CC
170 | OTHER DIGESTIVE SYSTEM O.R. PROCEDURES W CC
171 | W/O CC
172 | DIGESTIVE MALIGNANCY W CC
173 | W/O CC
174 | G.I. HEMORRHAGE W CC
175 | W/O CC
177 | UNCOMPLICATED PEPTIC ULCER W CC
178 | W/O CC
180 | G.I. OBSTRUCTION W CC
181 | W/O CC
182 | ESOPHAGITIS, GASTROENT & MISC DIGEST DISORDERS AGE >17 W CC
183 | W/O CC
188 | OTHER DIGESTIVE SYSTEM DIAGNOSES AGE >17 W CC
189 | W/O CC
191 | PANCREAS, LIVER & SHUNT PROCEDURES W CC
192 | W/O CC
193 | BILIARY TRACT PROC EXCEPT ONLY CHOLECYST W OR W/O C.D.E. W CC
194 | W/O CC
195 | CHOLECYSTECTOMY W C.D.E. W CC
196 | W/O CC
197 | CHOLECYSTECTOMY EXCEPT BY LAPAROSCOPE W/O C.D.E. W CC
198 | W/O CC
205 | DISORDERS OF LIVER EXCEPT MALIG,CIRR,ALC HEPA W CC
206 | W/O CC
207 | DISORDERS OF THE BILIARY TRACT W CC
208 | W/O CC
210 | HIP & FEMUR PROCEDURES EXCEPT MAJOR JOINT AGE >17 W CC
211 | W/O CC
218 | LOWER EXTREM & HUMER PROC EXCEPT HIP,FOOT,FEMUR AGE >17 W CC
219 | W/O CC
223 | MAJOR SHOULDER/ELBOW PROC, OR OTHER UPPER EXTREMITY PROC W CC
224 | SHOULDER,ELBOW OR FOREARM PROC,EXC MAJOR JOINT PROC, W/O CC
226 | SOFT TISSUE PROCEDURES W CC
227 | W/O CC
228 | MAJOR THUMB OR JOINT PROC,OR OTH HAND OR WRIST PROC W CC
229 | HAND OR WRIST PROC, EXCEPT MAJOR JOINT PROC, W/O CC
233 | OTHER MUSCULOSKELET SYS & CONN TISS O.R. PROC W CC
234 | W/O CC
240 | CONNECTIVE TISSUE DISORDERS W CC
241 | W/O CC
244 | BONE DISEASES & SPECIFIC ARTHROPATHIES W CC
245 | W/O CC
250 | FX, SPRN, STRN & DISL OF FOREARM, HAND, FOOT AGE >17 W CC
251 | W/O CC
253 | FX, SPRN, STRN & DISL OF UPARM,LOWLEG EX FOOT AGE >17 W CC
254 | W/O CC
257 | TOTAL MASTECTOMY FOR MALIGNANCY W CC
258 | W/O CC
259 | SUBTOTAL MASTECTOMY FOR MALIGNANCY W CC
260 | W/O CC
263 | SKIN GRAFT &/OR DEBRID FOR SKN ULCER OR CELLULITIS W CC
264 | W/O CC
265 | SKIN GRAFT &/OR DEBRID EXCEPT FOR SKIN ULCER OR CELLULITIS W CC
266 | W/O CC
269 | OTHER SKIN, SUBCUT TISS & BREAST PROC W CC
270 | W/O CC
272 | MAJOR SKIN DISORDERS W CC
273 | W/O CC
274 | MALIGNANT BREAST DISORDERS W CC
275 | W/O CC
277 | CELLULITIS AGE >17 W CC
278 | W/O CC
280 | TRAUMA TO THE SKIN, SUBCUT TISS & BREAST AGE >17 W CC
281 | W/O CC
283 | MINOR SKIN DISORDERS W CC
284 | W/O CC
292 | OTHER ENDOCRINE, NUTRIT & METAB O.R. PROC W CC
293 | W/O CC
296 | NUTRITIONAL & MISC METABOLIC DISORDERS AGE >17 W CC
297 | W/O CC
300 | ENDOCRINE DISORDERS W CC
301 | W/O CC
304 | KIDNEY,URETER & MAJOR BLADDER PROC FOR NON-NEOPL W CC
305 | W/O CC
306 | PROSTATECTOMY W CC
307 | W/O CC
308 | MINOR BLADDER PROCEDURES W CC
309 | W/O CC
310 | TRANSURETHRAL PROCEDURES W CC
311 | W/O CC
312 | URETHRAL PROCEDURES, AGE >17 W CC
313 | W/O CC
318 | KIDNEY & URINARY TRACT NEOPLASMS W CC
319 | W/O CC
320 | KIDNEY & URINARY TRACT INFECTIONS AGE >17 W CC
321 | W/O CC
323 | URINARY STONES W CC, &/OR ESW LITHOTRIPSY
324 | W/O CC
325 | KIDNEY & URINARY TRACT SIGNS & SYMPTOMS AGE >17 W CC
326 | W/O CC
328 | URETHRAL STRICTURE AGE >17 W CC
329 | W/O CC
331 | OTHER KIDNEY & URINARY TRACT DIAGNOSES AGE >17 W CC
332 | W/O CC
334 | MAJOR MALE PELVIC PROCEDURES W CC
335 | W/O CC
336 | TRANSURETHRAL PROSTATECTOMY W CC
337 | W/O CC
346 | MALIGNANCY, MALE REPRODUCTIVE SYSTEM, W CC
347 | W/O CC
348 | BENIGN PROSTATIC HYPERTROPHY W CC
349 | W/O CC
354 | UTERINE,ADNEXA PROC FOR NON-OVARIAN/ADNEXAL MALIG W CC
355 | W/O CC
358 | UTERINE & ADNEXA PROC FOR NON-MALIGNANCY W CC
359 | W/O CC
366 | MALIGNANCY, FEMALE REPRODUCTIVE SYSTEM W CC
367 | W/O CC
370 | CESAREAN SECTION W CC
371 | W/O CC
398 | RETICULOENDOTHELIAL & IMMUNITY DISORDERS W CC
399 | W/O CC
401 | LYMPHOMA & NON-ACUTE LEUKEMIA W OTHER O.R. PROC W CC
402 | W/O CC
403 | LYMPHOMA & NON-ACUTE LEUKEMIA W CC
404 | W/O CC
406 | MYELOPROLIF DISORD OR POORLY DIFF NEOPL W MAJ O.R.PROC W CC
407 | W/O CC
413 | OTHER MYELOPROLIF DIS OR POORLY DIFF NEOPL DIAG W CC
414 | W/O CC
419 | FEVER OF UNKNOWN ORIGIN AGE >17 W CC
420 | W/O CC
434 | ALC/DRUG ABUSE OR DEPEND, DETOX OR OTH SYMPT TREAT W CC
435 | W/O CC
442 | OTHER O.R. PROCEDURES FOR INJURIES W CC
443 | W/O CC
444 | TRAUMATIC INJURY AGE >17 W CC
445 | W/O CC
449 | POISONING & TOXIC EFFECTS OF DRUGS AGE >17 W CC
450 | W/O CC
452 | COMPLICATIONS OF TREATMENT W CC
453 | W/O CC
454 | OTHER INJURY, POISONING & TOXIC EFFECT DIAG W CC
455 | W/O CC
463 | SIGNS & SYMPTOMS W CC
464 | W/O CC
478 | OTHER VASCULAR PROCEDURES W CC
479 | W/O CC
493 | LAPAROSCOPIC CHOLECYSTECTOMY W/O C.D.E. W CC
494 | W/O CC
497 | SPINAL FUSION W CC
498 | W/O CC
499 | BACK & NECK PROCEDURES EXCEPT SPINAL FUSION W CC
500 | W/O CC
501 | KNEE PROCEDURES W PDX OF INFECTION W CC
502 | W/O CC

## Section 2. Super-MDC and Invalid DRGs Excluded from DRG Risk-Adjustment

DRG | DRG Label
214 | NO LONGER VALID
215 | NO LONGER VALID
221 | NO LONGER VALID
222 | NO LONGER VALID
438 | NO LONGER VALID
468 | EXTENSIVE O.R. PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
469 | PRINCIPAL DIAGNOSIS INVALID AS DISCHARGE DIAGNOSIS
470 | UNGROUPABLE
474 | NO LONGER VALID
476 | PROSTATIC O.R. PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
477 | NON-EXTENSIVE O.R. PROCEDURE UNRELATED TO PRINCIPAL DIAGNOSIS
482 | TRACHEOSTOMY FOR FACE, MOUTH & NECK DIAGNOSES
483 | TRACHEOSTOMY EXCEPT FOR FACE, MOUTH & NECK DIAGNOSES

## Section 3. AHRQ Comorbidity Software Coding Changes

Comorbidity Category | ICD-9 Code Deleted | ICD-9 Code Added
Congestive Heart Failure | | 40201, 40401, 40403
Peripheral Vascular Disorder | | 44100, 44101, 44102, 44103, 4411, 4412, 4413, 4414, 4415, 4416, 4417, 4419
Hypertension, uncomplicated | | 64200, 64201, 64202, 64203, 64204
Hypertension, complicated | | 4010, 40200, 40201, 40211, 40291, 40300, 40301, 40310, 40311, 40390, 40391, 40400, 40401, 40402, 40403, 40411, 40412, 40413, 40491, 40492, 40493, 40501, 40509, 64210, 64211, 64212, 64213, 64214, 64220, 64221, 64222, 64223, 64224, 64270, 64271, 64272, 64273, 64274, 64290, 64291, 64292, 64293, 64294
Paralysis | | 43820, 43821, 43822, 43830, 43831, 43832, 43840, 43841, 43842, 43850, 43851, 43852, 43853
Other neurological | | 3300, 3301, 3302, 3303, 3308, 3309, 3310, 3311, 3312, 3313, 3314, 3317, 33181, 33189,3452, 3453, 34560, 34561, 34570, 34571, 78039
Chronic pulmonary disease | | 49392
Diabetes | | 64800, 64801, 64802, 64803, 64804
Diabetes, complicated | | 25080, 25081, 25082, 25083
Renal failure | | 40301,40402, 40403, 40413, 40493,V561, V562
Liver disease | | 07022, 07023, 07044
Peptic ulcer disease including bleeding | V1271 | 53171, 53191, 53271, 53291, 53371, 53391, 53471, 53491
Lymphoma | | 20300, 20301, 20380, 20381
Blood loss anemia | | 64820, 64821, 64822, 64823, 64824
Alcohol abuse | | 2910, 2913, 30300, 30301, 30302, 30303
Drug abuse | | 64830, 64831, 64832, 64833, 64834

In selecting an appropriate comorbidity adjustment approach, we decided against the use of a pre-scored index, instead allowing the comorbidity weights to differ across indicators. In choosing among different approaches, we gravitated toward Elixhauser et al. (Medical Care 1998;36:8–27), because the comorbidity list is more complete than alternatives such as the Charlson list, incorporates earlier work by Iezzoni and Krakauer, and has passed peer review. The Elixhauser et al. list has been independently validated by Stukenborg (Medical Care 2001;39:727–39). Nonetheless, there are four issues with applying the Elixhauser et al. comorbidity list to the patient safety indicators:

1 Some of the comorbidity definitions are conditions likely to represent complications in certain settings, such as after elective surgery. The DRG screens help, but do not completely resolve this problem.
2 Several comorbidity definitions exclude “acute on chronic” comorbidities, even though there is no alternative code for the chronic component of the comorbidity. Unless the comorbidity definitions capture these “acute on chronic” comorbidities, some patients with especially severe comorbidities will be mislabeled as not having conditions of interest.
3 The comorbidity definitions do not include obstetric comorbidity codes, which are relevant for the obstetric indicators. The ICD-9-CM Coding Handbook instructs coders that
- “Conditions classified in other chapters of ICD-9-CM are reclassified in chapter 11 when they complicate the obstetrical experience or are themselves complicated by the fact that the patient is pregnant...Some codes for such complications are very specific, and others are very broad. When a code from chapter 11 describes the condition adequately, only that code is assigned. It is appropriate, however, to assign an additional code (from a different chapter) when it provides needed specificity.”
4 The comorbidity definitions need to be updated based on recent ICD-9-CM code changes.

### Issue #1. Comorbidities as Complications

The following three comorbidities are the most likely to be complications in certain settings. The number refers to the order of the comorbidity definitions in the AHRQ software.

2. “Cardiac arrhythmias” includes some conditions which are generally considered trivial or inconsequential, such as first degree AV block (426.11), right bundle branch block (426.4), premature beats (427.60), unspecified tachycardia (785.0), and cardiac pacemaker in situ (V45.01). Because of the fact that these conditions are unlikely to affect treatment of hospitalized patients, they are unlikely to be coded. See, for example, Coding Clinic 1993;10(5):12, “although it can be argued that sick sinus syndrome is an ongoing condition...no code assignment is required if no attention or treatment is provided to the condition or device. This differs from the ongoing medication administration provided for conditions such as CHF, hypertension, or diabetes (which justifies code assignment)...the use of V45.0...is optional.” It is impossible to generate an unbiased estimate of the true effect of these comorbidities using administrative data, due to nondifferential misclassification (i.e., information bias). Even more importantly, some cardiac arrhythmias are well described as postoperative complications - most notably paroxysmal SVT (427.0), atrial fibrillation (427.31), and unspecified tachycardia (785.0), although virtually all of these codes except V45.0x and V53.0x COULD represent complications. And even these V codes are problematic, because a properly functioning pacemaker (or prosthetic valve) should eliminate the patient's additional risk.

21. “Coagulopathy” includes several conditions that are well described as postoperative complications - most notably “hemorrhagic disorder due to circulating anticoagulants” (286.5), which is the code for excessive heparin, “defibrination syndrome” (286.6), which is the code for DIC (disseminated intravascular coagulation) syndrome, “acquired coagulation factor deficiency” (286.7), which is the code for hypoprothrombinemia due to warfarin, and “secondary thrombocytopenia” (287.4), which is the code for drug-induced or transfusion-induced thrombocytopenia. Although the approach could try to narrow the definition of this comorbidity to include only congenital disorders such as hemophilia, such a modification would substantially reduce its frequency and might eliminate its importance as a predictor.

24. “Fluid and electrolyte disorders” includes several conditions that are well described as postoperative complications - most notably hyponatremia (276.1) and fluid overload (276.6). Virtually all of these codes COULD represent complications.

SOLUTION: THESE THREE COMORBIDITIES WILL BE EXCLUDED FROM THE COMORBIDITY ADJUSTMENT FOR THE PATIENT SAFETY INDICATORS.

### Issue #2. Acute on Chronic Comorbidities

The following comorbidities are acute complications of chronic conditions not coded separately. The number refers to the order of the comorbidity definitions in the AHRQ software.

1. “Congestive heart failure” excludes all codes for heart failure due to hypertension which is described as malignant during the current episode of care (402.01, 404.01, 404.03). This is problematic because these codes substitute for (and do not supplement) other codes for congestive heart failure (428.x). In adjusting for any increased risk that congestive heart failure may confer, the approach should not exclude any etiologic subset of such patients from the definition. As noted below, malignant hypertension almost always occurs in the setting of underlying chronic hypertension.

SOLUTION: CONGESTIVE HEART FAILURE WILL BE REDEFINED TO INCLUDE 402.01, 404.01, AND 404.03, IN ADDITION TO THE OTHER CODES CONTAINED IN ELIXHAUSER'S ORIGINAL DEFINITION.

5. “Peripheral vascular disorders” excludes all codes for ruptured or dissecting aneurysms. This is problematic because these codes substitute for (and do not supplement) other aneurysm codes. In adjusting for any increased risk that peripheral vascular disease may confer, the approach should not exclude the most severely affected patients from the definition. Aneurysm rupture may be an acute, occasionally preventable complication, but it occurs in the setting of an underlying aneurysm.

SOLUTION: PERIPHERAL VASCULAR DISORDERS WILL BE REDEFINED TO INCLUDE ALL 441.XX CODES, IN ADDITION TO THE OTHER CODES CONTAINED IN ELIXHAUSER'S ORIGINAL DEFINITION.

6. “Hypertension” excludes all codes for malignant hypertension (401.0x, 402.0x, 403.0x, 404.0x, 405.0x), and all codes for hypertension with either congestive heart failure (402.x1), renal failure (403.xx), or both (404.x1, 404.x2, 404.x3). This is problematic because these codes substitute for (and do not supplement) the codes for complicated hypertension. In other words, the current comorbidity definition would MISS a substantial proportion of patients with chronic hypertension, because they also have heart or renal disease secondary to their hypertension. Similarly, malignant hypertension arises in the setting of chronic hypertension, which the current comorbidity definition would miss. In adjusting for any increased risk that hypertension may confer, the approach should not exclude the most severely affected the patients from the definition.

SOLUTION: HYPERTENSION, COMPLICATED WILL BE REDEFINED AS: 401.0, 402.XX, 403.XX, 404.XX, 405.XX. THE DEFINITION OF HYPERTENSION, UNCOMPLICATED WILL REMAIN UNCHANGED. PATIENTS WHO HAVE CODES CONSISTENT WITH BOTH COMORBIDITIES WILL BE CLASSIFIED AS COMPLICATED.

8. “Other neurological disorders” excludes codes for “petit mal status” (345.2) and “grand mal status” (345.3), which are simply acute manifestations of underlying chronic comorbidities. In adjusting for any increased risk that epilepsy may confer, the approach should not exclude the most severely affected patients from the definition. Epileptic status may be an iatrogenic complication, but it occurs in the setting of an underlying neurologic disorder. Similarly, cerebral degeneration occurs in the setting of an underlying degenerative disorder.

SOLUTION: OTHER NEUROLOGICAL DISORDERS WILL BE REDEFINED TO INCLUDE ALL 330.X, 331.X, AND 345.XX CODES, IN ADDITION TO THE OTHER CODES CONTAINED IN ELIXHAUSER'S ORIGINAL DEFINITION (SEE ALSO CODING UPDATE BELOW).

11. “Diabetes” excludes codes for “diabetes with other specified manifestations” (250.8x), such as hypoglycemia. This is problematic because this code substitutes for (and does not supplement) other diabetes codes. In other words, the current comorbidity definition would MISS patients with diabetes who suffer from other specified complications, such as hypoglycemia, during their hospital stay. See Coding Clinic 1994;11(2):12 - “what is the appropriate diagnosis code for...necrotizing fasciitis secondary to NIDDM?...assign code 250.80...as the principal diagnosis.” In adjusting for any increased risk that diabetes may confer, the approach should not exclude the most severely affected patients from the definition. Diabetic hypoglycemia may be an iatrogenic complication, but it occurs in the setting of an underlying endocrine disorder.

SOLUTION: DIABETES, COMPLICATED WILL BE REDEFINED AS 250.40–250.93 AND REFERS ONLY TO CHRONIC COMPLICATIONS; ACUTE HYPERGLYCEMIC COMPLICATIONS ARE CODED AS 250.10–250.33.

THE DEFINITION OF DIABETES, UNCOMPLICATED WILL REMAIN UNCHANGED. PATIENTS WHO HAVE CODES CONSISTENT WITH BOTH COMORBIDITIES WILL BE CLASSIFIED AS COMPLICATED. IF A PSI WILL BE APPLIED TO THE NEONATAL POPULATION, THEN THE DEFINITION OF DIABETES, COMPLICATED WILL ALSO INCLUDE 775.1 (NEONATAL DIABETES).

13. “Renal failure” excludes “hypertensive heart and renal disease with congestive heart failure and heart failure” (404.13, 404.93). These codes indicate the presence of BOTH renal failure and congestive heart failure in the same patient. They substitute for other renal failure codes (585–587) in all patients with hypertension, even if the patient's renal failure is not clearly attributable to hypertension. In addition, the current definition excludes any renal failure associated with malignant hypertension (403.01, 404.02, 404.03), even when the patient's renal failure is not clearly attributable to malignant hypertension. In adjusting for any increased risk that chronic renal failure may confer, the comorbidity definition does not want to exclude any etiologic subset of such patients from the definition. As noted above, malignant hypertension almost always occurs in the setting of underlying chronic hypertension.

SOLUTION: RENAL FAILURE WILL BE REDEFINED TO INCLUDE 403.01, 404.02, 404.03, 404.13, AND 404.93, IN ADDITION TO THE OTHER CODES CONTAINED IN ELIXHAUSER'S ORIGINAL DEFINITION (SEE ALSO CODING UPDATE BELOW).

14. “Liver disease” excludes “chronic viral hepatitis B with hepatic coma” with or without hepatitis delta (070.22–070.23) and “chronic hepatitis C with hepatic coma” (070.44), which are simply acute manifestations of underlying chronic comorbidities. In adjusting for any increased risk that chronic viral hepatitis may confer, the comorbidity definition does not want to exclude the most severely affected patients from the definition. Coma may be an acute, occasionally preventable complication, but it occurs in the setting of underlying chronic hepatitis.

SOLUTION: LIVER DISEASE WILL BE REDEFINED TO INCLUDE 070.22, 070.23, AND 070.44, IN ADDITION TO THE OTHER CODES CONTAINED IN ELIXHAUSER'S ORIGINAL DEFINITION.

15. “Peptic ulcer disease” excludes all acute ulcers, but also all chronic ulcers that present with hemorrhage, perforation, or obstruction (or any combination thereof). This is problematic because many chronic ulcers hemorrhage or obstruct. In fact, obstruction is a common presentation for chronic ulcers, and is relatively unusual among acute or iatrogenic ulcers. The problem here is that ICD-9-CM fails to distinguish “chronic” from “unspecified” ulcers. By contrast, all of the other comorbidities on this “acute on chronic” list are either inherently chronic (i.e., hypertension and cardiac/renal complications thereof, diabetes, peripheral vascular disease, epilepsy) or are clearly identified as chronic in ICD-9-CM (i.e., viral hepatitis). We cannot be certain that all ulcers labeled as “chronic or unspecified” are actually chronic. However, given the time required for an ulcer to cause obstruction, this finding strongly suggests chronicity (especially in the absence of hemorrhage or perforation).

SOLUTION: PEPTIC ULCER DISEASE WILL BE REDEFINED AS: 531.70–531.71, 531.90–531.91, 532.70–532.71, 532.90–532.91, 533.70–533.71, 533.90–533.91, 534.70–534.71, 534.90–534.91.

27. “Alcohol abuse” (291.8x) excludes alcohol withdrawal delirium (291.0) and alcohol withdrawal hallucinosis (291.3), despite the fact that these acute conditions occur only in the setting of chronic alcohol abuse. Coding Clinic for ICD-9-CM (Second Quarter 1991, p. 11) notes that code 291.0 and 291.3 take “precedence over 291.8,” making it inappropriate to include 291.8x and omit 291.0 and 291.3. “If the patient is admitted in withdrawal or if withdrawal develops after admission, the withdrawal code is designated as the principal diagnosis.” The current definition also excludes acute alcoholic intoxication superimposed on alcohol dependence (303.0x), which is the sole ICD-9-CM code used to describe chronic alcoholic patients who are intoxicated upon presentation. 303.0x substitutes for any other 303 or 305.0 code in this common situation. In adjusting for any increased risk that alcoholism may confer, the comorbidity definition does not want to exclude the most severely affected patients from the definition.

SOLUTION: ALCOHOL ABUSE WILL BE REDEFINED AS: 291.0–291.3, 291.5, 291.8X, 291.9, 303.00–303.93, 305.00–305.03.

### Issue #3. Obstetric Codes

The obstetric comorbidity code is either an exact match, or broader or narrower than the comorbidity definition based on non-obstetric codes. When the match is exact or narrower (highlighted in bold), the obstetric code was added to the comorbidity definition for obstetric cases because coders are likely to use the obstetric code INSTEAD of the nonobstetric code. This is especially true when the nonobstetric codes are accompanied by specific “excludes” notes for pregnancy and the puerperium (highlighted in italics). When the match is broader, one might argue that the obstetric code does not “describe the condition adequately,” and should therefore be accompanied by the more specific nonobstetric code (which would more effectively capture the cases of interest). In this situation, the obstetric code should NOT be added to the cormorbidity definition, because doing so might add numerous patients who do not actually have the condition of interest.

1–4. CHF/arrhythmias/valvular disease/pulmonary circulation - 648.6x (“other cardiovascular diseases”). Broader, in that all heart disease (390–398, 410–429) is included.

5. Peripheral vascular - 648.9x (“other current conditions classifiable elsewhere”). Broader, in that all nutritional and vascular problems (260–269, 440–459) are included.

6. Hypertension - Uncomplicated 642.0x (“benign essential hypertension...”). Complicated 642.1x (“hypertension secondary to renal disease...”), 642.2x (“other pre-existing hypertension...”), 642.7x (“pre-eclampsia or eclampsia superimposed on pre-existing hypertension”), 642.9x (“unspecified hypertension...”). Exact match (if comorbidity definition is expanded as I suggest in response to problem #2), with excludes notes for nonobstetric codes.

SOLUTION: ADD TO COMORBIDITY DEFINITION.

10. Diabetes - 648.0x (“diabetes mellitus”). Exact match (when comorbidity definition is expanded to 250.xx as I suggested above in response to issue #2).

SOLUTION: ADD TO COMORBIDITY DEFINITION.

12. Hypothyroidism - 648.1x (“thyroid dysfunction”). Broader, in that all thyroid disease (240–246) is included.

13. Renal failure - 646.2x (“unspecified renal disease in pregnancy...”). Broader, in that all renal disease is included.

14. Liver disease - 646.7x (“liver disorders in pregnancy”). Broader, in that all liver disease is included.

16. AIDS - 647.6x (“other viral diseases”). Broader, in that all viral diseases except rubella (042, 050–055, 057–079) are included.

20. Rheumatoid/collagen vascular diseases - 648.7x (“bone and joint disorders of back, pelvis, and lower limbs”). Narrower, in that lupus and other diffuse connective tissue diseases are excluded, but broader, in that all dorsopathies and arthropathies (711–738) are included.

SOLUTION: ADD TO COMORBIDITY DEFINITION

22. Obesity - 646.1x (“edema or excessive weight gain in pregnancy...”). Broader, in that edema is also included.

23. Weight loss - 648.9x (“other current conditions classifiable elsewhere”). Broader, in that all nutritional and vascular problems (260–269, 440–459) are included.

25–26. Blood loss/Deficiency anemias - 648.2x (“anemia”). Broader, in that all anemias (280–285) are included, but excludes notes apply to nonobstetric codes.

SOLUTiON: THE EXCLUDES NOTE REQUIRES THAT THE CODE BE ADDED TO THE COMORBIDITY DEFINITION.

27. Alcohol abuse - 648.4x (“mental disorders”). Broader, in that all mental disorders (290–303, 305–319) are included.

28. Drug abuse - 648.3x (“drug dependence”). Narrower (matches to 304.xx), in that nondependent abuse of drugs is omitted.

SOLUTION: ADD TO COMORBIDITY DEFINITION.

29. Psychoses - 648.41, 648.43 (“mental disorders”). Broader, in that all mental disorders (290–303, 305–319) are included.

The other comorbidites (e.g., neurologic, pulmonary, gastroenterologic, oncologic, coagulopathy, fluid/electrolyte) have no matching obstetric codes in Chapter 11.

### Issue #4. Coding Updates

ICD-9 coding changes affect the following comorbidities, although the current AHRQ comorbidity software is robust to most of these coding changes:

2. Cardiac arrhythmias - V45.0 is now V45.0x (or V45.00–V45.09) to identify the specific cardiac device, as of 10/1/94. V53.3 is now V53.3x (or V53.30–V53.39) to identify the specific cardiac device, as of 10/1/94.

SOLUTION: AHRQ SOFTWARE INCLUDES BOTH OLD AND NEW CODES. NO CHANGE IS NECESSARY.

7. Paralysis - Paralysis due to late effects of cerebrovascular disease was reassigned from 342 or 344.3–344.4 to new codes under 438 (438.2x = hemiplegia/hemiparesis, 438.3x = monoplegia of upper limb, 438.4x = monoplegia of lower limb, 438.5x = other paralytic syndrome) on 10/1/97.

SOLUTION: 438.2X–438.5X WAS ADDED TO THE DEFINITION.

8. Other neurological disorders - 780.3 was split into 780.31 (febrile convulsions) and 780.39 (other convulsions) on 10/1/97.

SOLUTION: ONLY 780.39 IS RELEVANT (FEBRILE CONVULSIONS ARE A BENIGN CONDITION OF YOUNG CHILDREN), SO THIS CODE WAS ADDED TO THE DEFINITION.

9. Chronic pulmonary disease - 493.x2 (i.e., 493.92) was added 10/1/00 to denote “acute exacerbation” of asthma. 494 was split into 494.0 (without acute exacerbation) and 494.1 (with acute exacerbation) on 10/1/00.

SOLUTION: CURRENT AHRQ SOFTWARE INCLUDES 493.02, 493.12, AND 493.22, BUT NOT 493.92, WHICH WAS ADDED TO THE DEFINITION. NO CHANGE REQUIRED TO THE 494 CODES (NEW CODES ALREADY INCLUDED).

13. Renal failure - V56.1 (fitting and adjustment of extracorporeal dialysis catheter) was added 10/1/95. V56.2 (fitting and adjustment of peritoneal dialysis catheter) was added 10/1/98.

SOLUTION: V56.1 AND V56.2 WERE ADDED TO THE DEFINITION.

16. AIDS - 043 and 044 were deleted 10/1/94.

SOLUTION: AHRQ SOFTWARE INCLUDES BOTH OLD AND NEW CODES. NO CHANGE IS NECESSARY.

17. Lymphoma - 203.0 was split into 203.00 (without mention of remission) and 203.01 (in remission) on 10/1/91. 203.8 was split into 203.80 (without mention of remission) and 203.81 (in remission) on 10/1/91.

SOLUTION: 203.001–203.01 AND 203.80–203.81 WERE ADDED TO THE DEFINITION.

22. Obesity - 278.0 was split into 278.00 (obesity unspecified) and 278.01 (morbid obesity) on 10/1/95.

SOLUTION: AHRQ SOFTWARE INCLUDES BOTH OLD AND NEW CODES. NO CHANGE IS NECESSARY.

26. Deficiency anemia - A new set of codes for “anemia in chronic illness” (285.21 = end-stage renal disease, 285.22 = neoplastic disease, 285.29 = other chronic illness) was added on 10/1/00.

SOLUTION: AHRQ SOFTWARE INCLUDES BOTH OLD AND NEW CODES. NO CHANGE IS NECESSARY.

27. Alcohol abuse - 291.8 was split into 291.81 (alcohol withdrawal) and 291.89 (other specified alcoholic psychosis) on 10/1/96.

SOLUTION: AHRQ SOFTWARE INCLUDES BOTH OLD AND NEW CODES. NO CHANGE IS NECESSARY.

## Section 4. Low Mortality DRGs Listed by Strata

DRG | DRG Label
| Medical (Adult)
015 | TRANSIENT ISCHEMIC ATTACK & PRECEREBRAL OCCLUSIONS
021 | VIRAL MENINGITIS
030 | TRAUMATIC STUPOR & COMA, COMA <1 HR AGE 0–17
031 | CONCUSSION AGE >17 W CC
032 | CONCUSSION AGE >17 W/O CC
044 | ACUTE MAJOR EYE INFECTIONS
045 | NEUROLOGICAL EYE DISORDERS
065 | DYSEQUILIBRIUM
068 | OTITIS MEDIA & URI AGE >17 W CC
071 | LARYNGOTRACHEITIS
096 | BRONCHITIS & ASTHMA AGE >17 W CC
097 | BRONCHITIS & ASTHMA AGE >17 W/O CC
125 | CIRCULATORY DISORDERS EXCEPT AMI, W CARD CATH W/O COMPLEX DIAG
134 | HYPERTENSION
140 | ANGINA PECTORIS
141 | SYNCOPE & COLLAPSE W CC
142 | SYNCOPE & COLLAPSE W/O CC
143 | CHEST PAIN
237 | SPRAINS, STRAINS, & DISLOCATIONS OF HIP, PELVIS & THIGH
243 | MEDICAL BACK PROBLEMS
246 | NON-SPECIFIC ARTHROPATHIES
295 | DIABETES AGE 0–35
317 | ADMIT FOR RENAL DIALYSIS
323 | URINARY STONES W CC, &/OR ESW LITHOTRIPSY
324 | URINARY STONES W/O CC
351 | STERILIZATION, MALE
369 | MENSTRUAL & OTHER FEMALE REPRODUCTIVE SYSTEM DISORDERS
421 | VIRAL ILLNESS AGE >17
| Medical (Pediatric)
026 | SEIZURE & HEADACHE AGE 0–17
033 | CONCUSSION AGE 0–17
070 | OTITIS MEDIA & URI AGE 0–17
074 | OTHER EAR, NOSE, MOUTH & THROAT DIAGNOSES AGE 0–17
091 | SIMPLE PNEUMONIA & PLEURISY AGE 0–17
098 | BRONCHITIS & ASTHMA AGE 0–17
184 | ESOPHAGITIS, GASTROENT & MISC DIGEST DISORDERS AGE 0–17
190 | OTHER DIGESTIVE SYSTEM DIAGNOSES AGE 0–17
252 | FX, SPRN, STRN & DISL OF FOREARM, HAND, FOOT AGE 0–17
255 | FX, SPRN, STRN & DISL OF UPARM,LOWLEG EX FOOT AGE 0–17
279 | CELLULITIS AGE 0–17
282 | TRAUMA TO THE SKIN, SUBCUT TISS & BREAST AGE 0–17
298 | NUTRITIONAL & MISC METABOLIC DISORDERS AGE 0–17
322 | KIDNEY & URINARY TRACT INFECTIONS AGE 0–17
333 | OTHER KIDNEY & URINARY TRACT DIAGNOSES AGE 0–17
396 | RED BLOOD CELL DISORDERS AGE 0–17
422 | VIRAL ILLNESS & FEVER OF UNKNOWN ORIGIN AGE 0–17
446 | TRAUMATIC INJURY AGE 0–17
448 | ALLERGIC REACTIONS AGE 0–17
451 | POISONING & TOXIC EFFECTS OF DRUGS AGE 0–17
| Surgical (Adult)
036 | RETINAL PROCEDURES
037 | ORBITAL PROCEDURES
042 | INTRAOCULAR PROCEDURES EXCEPT RETINA, IRIS & LENS
050 | SIALOADENECTOMY
052 | CLEFT LIP & PALATE REPAIR
053 | SINUS & MASTOID PROCEDURES AGE >17
055 | MISCELLANEOUS EAR, NOSE, MOUTH & THROAT PROCEDURES
057 | T&A PROC, EXCEPT TONSILLECTOMY &/OR ADENOIDECTOMY ONLY, AGE >17
063 | OTHER EAR, NOSE, MOUTH & THROAT O.R. PROCEDURES
166 | APPENDECTOMY W/O COMPLICATED PRINCIPAL DIAG W CC
167 | APPENDECTOMY W/O COMPLICATED PRINCIPAL DIAG W/O CC
218 | LOWER EXTREM & HUMER PROC EXCEPT HIP, FOOT, FEMUR AGE >17 W CC
219 | LOWER EXTREM & HUMER PROC EXCEPT HIP, FOOT, FEMUR AGE >17 W/O CC
223 | MAJOR SHOULDER/ELBOW PROC, OR OTHER UPPER EXTREMITY PROC W CC
224 | SHOULDER,ELBOW OR FOREARM PROC,EXC MAJOR JOINT PROC, W/O CC
225 | FOOT PROCEDURES
228 | MAJOR THUMB OR JOINT PROC, OR OTH HAND OR WRIST PROC W CC
229 | HAND OR WRIST PROC, EXCEPT MAJOR JOINT PROC, W/O CC
232 | ARTHROSCOPY
257 | TOTAL MASTECTOMY FOR MALIGNANCY W CC
258 | TOTAL MASTECTOMY FOR MALIGNANCY W/O CC
261 | BREAST PROC FOR NON-MALIGNANCY EXCEPT BIOPSY & LOCAL EXCISION
262 | BREAST BIOPSY & LOCAL EXCISION FOR NON-MALIGNANCY
267 | PERIANAL & PILONIDAL PROCEDURES
289 | PARATHYROID PROCEDURES
290 | THYROID PROCEDURES
293 | OTHER ENDOCRINE, NUTRIT & METAB O.R. PROC W/O CC
334 | MAJOR MALE PELVIC PROCEDURES W CC
335 | MAJOR MALE PELVIC PROCEDURES W/O CC
336 | TRANSURETHRAL PROSTATECTOMY W CC
337 | TRANSURETHRAL PROSTATECTOMY W/O CC
356 | FEMALE REPRODUCTIVE SYSTEM RECONSTRUCTIVE PROCEDURES
358 | UTERINE & ADNEXA PROC FOR NON-MALIGNANCY W CC
359 | UTERINE & ADNEXA PROC FOR NON-MALIGNANCY W/O CC
360 | VAGINA, CERVIX & VULVA PROCEDURES
361 | LAPAROSCOPY & INCISIONAL TUBAL INTERRUPTION
362 | ENDOSCOPIC TUBAL INTERRUPTION
364 | D&C, CONIZATION EXCEPT FOR MALIGNANCY
439 | SKIN GRAFTS FOR INJURIES
441 | HAND PROCEDURES FOR INJURIES
491 | MAJOR JOINT & LIMB REATTACHMENT PROCEDURES OF UPPER EXTREMITY
499 | BACK & NECK PROCEDURES EXCEPT SPINAL FUSION W CC
500 | BACK & NECK PROCEDURES EXCEPT SPINAL FUSION W/O CC
| Surgical (Pediatric)
060 | TONSILLECTOMY &/OR ADENOIDECTOMY ONLY, AGE 0–17
062 | MYRINGOTOMY W TUBE INSERTION AGE 0–17
156 | STOMACH, ESOPHAGEAL & DUODENAL PROCEDURES AGE 0–17
163 | HERNIA PROCEDURES AGE 0–17
212 | HIP & FEMUR PROCEDURES EXCEPT MAJOR JOINT AGE 0–17
220 | LOWER EXTREM & HUMER PROC EXCEPT HIP,FOOT,FEMUR AGE 0–17
393 | SPLENECTOMY AGE 0–17
| Neonatal
386 | EXTREME IMMATURITY OR RESPIRATORY DISTRESS SYNDROME, NEONATE
387 | PREMATURITY W MAJOR PROBLEMS
388 | PREMATURITY W/O MAJOR PROBLEMS
390 | NEONATE W OTHER SIGNIFICANT PROBLEMS
391 | NORMAL NEWBORN
| Obstetric
370 | CESAREAN SECTION W CC
371 | CESAREAN SECTION W/O CC
372 | VAGINAL DELIVERY W COMPLICATING DIAGNOSES
373 | VAGINAL DELIVERY W/O COMPLICATING DIAGNOSES
374 | VAGINAL DELIVERY W STERILIZATION &/OR D&C
375 | VAGINAL DELIVERY W O.R. PROC EXCEPT STERIL &/OR D&C
377 | POSTPARTUM & POST ABORTION DIAGNOSES W O.R. PROCEDURE
378 | ECTOPIC PREGNANCY
379 | THREATENED ABORTION
380 | ABORTION W/O D&C
381 | ABORTION W D&C, ASPIRATION CURETTAGE OR HYSTEROTOMY
382 | FALSE LABOR
383 | OTHER ANTEPARTUM DIAGNOSES W MEDICAL COMPLICATIONS
384 | OTHER ANTEPARTUM DIAGNOSES W/O MEDICAL COMPLICATIONS
| Psychiatric
425 | ACUTE ADJUSTMENT REACTION & PSYCHOSOCIAL DYSFUNCTION
426 | DEPRESSIVE NEUROSES
427 | NEUROSES EXCEPT DEPRESSIVE
428 | DISORDERS OF PERSONALITY & IMPULSE CONTROL
431 | CHILDHOOD MENTAL DISORDERS
432 | OTHER MENTAL DISORDER DIAGNOSES
434 | ALC/DRUG ABUSE OR DEPEND, DETOX OR OTH SYMPT TREAT W CC
435 | ALC/DRUG ABUSE OR DEPEND, DETOX OR OTH SYMPT TREAT W/O CC
436 | ALC/DRUG DEPENDENCE W REHABILITATION THERAPY