# Sample of Information Sent to Panelists

This appendix duplicates materials sent to panelists.

Section 1 includes the instructions and definitions sent to panelists, as well as a key illustrating the indicator definitions in Sections 2 and 3.

Section 2 includes a sample indicator definition sheet sent prior to the conference call.

Section 3 includes a sample indicator definition sheet sent after the conference call.

Section 4 includes the questionnaire for rating each indicator sent before and after the conference call.

## Section 1. Directions sent to panelists

The questionnaires in this packet each describe one potential patient safety indicator and ask for your feedback on specific aspects of that indicator. You must fill out one questionnaire for each indicator. Please answer all questions on this form. You may comment in the sections provided below each question, or on a separate sheet of paper. Comments are not required. We expect that completing each form will take about 15–20 minutes to complete.

All indicators are defined using ICD-9-CM diagnostic and procedure codes, obtained from administrative data. We do not expect that most physicians or nurses will be familiar with these codes and thus we provide explanations of all codes.

- ICD-9-CM codes are usually assigned using the physician's charted notes by trained coders.
- Each patient discharged from an inpatient facility is given a principal diagnosis, which represents the condition principally responsible for occasioning the patient' admission, and a list of secondary diagnosis codes.
- Major procedures that involve use of the operating room or risk to the patient are also coded.
- Codes between 996 and 999 are always “complications of surgical and medical care.”
- Codes beginning with ‘E’ refer to the external cause of any injury that the patient sustained.

Some indicators limit eligible patients to certain groups, including DRGs and MDCs.

- DRGs are “Diagnostic Related Groups.” They are defined by the Health Care Financing Administration (HCFA). One DRG is assigned to each patient per admission. The assigned DRG reflects many factors including the principal diagnosis, listed secondary diagnoses, age, and major procedures.
- MDCs are “Major Diagnostic Categories” and are defined using DRGs. DRGs involving the same body system are generally grouped together to form one MDC.
- All other eligible patient limitations (e.g. trauma, immunocompromised) are derived from ICD-9 codes alone.

For the purpose of this study we will use the definitions of Brennan et al ^1^ of negligence and complications (adverse events). We have created a standard definition of preventable.

1 Brennan, TA, Leape, LL, Laird, NM, Herbert, L et al. Incidence of adverse events and negligence in hospitalized patients. Results of the Harvard Medical Practice Study I. New Engl J Med, 1997 Feb 7;324(6):370–6.

- Negligence (medical error): Care that falls below the standard reasonably expected of average physicians in their community.
- Complication: An injury that is caused by medical management (rather than the underlying disease) and that prolongs the hospitalization, or produces a disability at the time of discharge, or both.
- Preventable: Condition for which reasonable clinical steps may reduce (but not necessarily eliminate) the risk of that complication occurring.

## Section 2. Example indicator definition sheet sent to panelists prior to conference call

POSTOPERATIVE ACUTE MYOCARDIAL INFARCTION
Relationship to quality: Identifies cases of potentially preventable myocardial infarction following a surgical procedure.
Indicator definition:
Number of patients with postoperative AMIs (see definition and exclusions below) per 100 eligible surgical admissions (population at risk).
Definition of AMI: | Definition of population at risk:
| Patients eligible to be included in this indicator:
Secondary diagnosis code for AMI:; - Acute myocardial infarction (includes only unspecified or initial episode of care for cardiac infarction, coronary embolism, occlusion, rupture or thrombosis) [410.00–410.91 except if 5^th^ digit = 2] | a All non-cardiac surgical patients.; b Patient must not be undergoing cardiac surgery.; c Patient must not be in the following MDCs:; - Diseases and Disorders of the Circulatory System [5]
Clinical rationale
This indicator is intended to flag cases of postoperative AMI. It is identical to an indicator developed by Lisa Iezzoni as part of the Complications Screening Program. Codes denoting a “subsequent episode of care” for AMI are not included. This indicator limits AMI codes to secondary diagnosis codes in order to eliminate AMIs that were present on admission. It further excludes patients which have major circulatory disorders, or who are undergoing cardiac surgery, as these patients may be more likely to develop an AMI peri-operatively.

## Section 3. Example indicator definition sheet sent to panelists after conference call

Note: Bold “Changes to indicator” text was added for post-panel conference call review.

POSTOPERATIVE ACUTE MYOCARDIAL INFARCTION
Relationship to quality: Identifies cases of potentially preventable myocardial infarction following a surgical procedure.
Indicator definition:
Number of patients with postoperative AMIs (see definition and exclusions below) per 100 eligible surgical admissions (population at risk).
Definition of AMI: | Definition of population at risk:
| Patients eligible to be included in this indicator:
Secondary diagnosis code for AMI:; - Acute myocardial infarction (includes only unspecified or initial episode of care for cardiac infarction, coronary embolism, occlusion, rupture or thrombosis) [410.00–410.91 except if 5^th^ digit = 2] | a All non-cardiac elective surgical patients.; b Patient must not be undergoing cardiac surgery.
Clinical rationale
This indicator is intended to flag cases of postoperative AMI. It is identical to an indicator developed by Lisa Iezzoni as part of the Complications Screening Program. Codes denoting a “subsequent episode of care” for AMI are not included. This indicator limits AMI codes to secondary diagnosis codes in order to eliminate AMIs that were present on admission. It further excludes patients which have major circulatory disorders, or who are undergoing cardiac surgery, as these patients may be more likely to develop an AMI peri-operatively.
Changes to indicator
1 The eligible population was restricted to elective surgeries only. The panel was concerned that this complication is less preventable after emergency surgery than after elective surgery, because there is little opportunity for preoperative assessment and risk reduction before emergency surgery. The weighing of risks and benefits in high-risk patients does not apply to emergency surgery. Therefore, we have now proposed focusing this indicator only on elective surgery patients, for whom postponement or cancellation of surgery, and perioperative beta blockade, are usually viable options.; 2 The exclusion for patients in MDC 5 was eliminated, such that vascular surgery patients would be included. Panelists felt that this was a group for which postoperative AMI was a serious complication that could be preventable in some cases. Patients undergoing cardiac surgery continue to be excluded from this indicator.

## Section 4. Questionnaire sent before and after panel discussion

Panelist name:
Indicator name: POSTOPERATIVE ACUTE MYOCARDIAL INFARCTION
1. To what extent is this indicator likely to identify the occurrence of an adverse event or complication (as opposed to having the condition present on admission)?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Not at all likely | | | | | | | | Very likely
Comments:
2. To what extent is the occurrence of this complication likely to be preventable (as opposed to being an expected result of the patient's underlying conditions and/or procedures)?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Not at all likely | | | | | | | | Very likely
Comments:
3. To what extent is this complication likely to represent true medical error or negligence (as opposed to lack of ideal or perfect medical care)?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Not at all likely | | | | | | | | Very likely
Comments:
4. How often is this complication, when it occurs, clearly charted in medical records by physicians?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Never charted | | | | | | | | Always charted
Comments:
5. To what extent is this indicator subject to bias (meaning that some hospitals will be judged as low quality because they systematically differ from other hospitals in some aspect, such as severity of the case mix, that is not due to poor quality care)?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Not at all biased | | | | | | | | Very biased
What are the factors that contribute to the bias?
6. Are there ways that providers or health systems could easily appear to better their performance on this indicator, without actually improving the quality of care that they provide?
7. Are there adverse outcomes that could result from implementing this indicator?
8. What is your overall rating of the usefulness of this indicator?
1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9
Highly discourage use | | | | | | | | Highly recommend use
Please discuss you reasons for assigning the overall rating above.
9. Would you suggest any changes to the definition of this indicator? Please specify changes and give rationale supporting proposed changes.
10. Is there anything else that you would like us to know about this indicator?