# Clinician Review Panels

This appendix includes information about the composition of the eight multi-specialty panels, and the three surgical panels. Following the identifying name for each panel, the indicators reviewed are shown, and then the members of the panel are listed. Finally, the professional organization that nominated the panelist is listed.

## MEDICAL COMPLICATIONS 1 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Decubitus ulcer
- Infection due to medical care
- Intestinal infection due to C. difficile
- In-hospital hip fracture and falls
- In hospital fractures possibly related to falls
- Septicemia

- Desmond Birkett, MD, Surgeon
- Burlington, MA
- Department of General Surgery, Lahey Clinic
- Nominated by the American College of Surgeons

- Eric A. Coleman, MD, MPH, Geriatrician
- Denver, CO
- University of Colorado Health Science Center
- Nominated by the American Geriatric Society

- John Crabtree, MD, Surgeon
- Bellflower, CA
- Kaiser Permanente Bellflower Medical Center
- Nominated by the American College of Surgeons

- Kathleen Ellstrom, MS, PhD, Critical care nurse
- Grand Terrace, CA
- Kaiser Foundation Hospital — Riverside
- Nominated by the American Association of Critical-Care Nurses

- Sunil Kripalani, MD, MSc, Hospitalist
- Atlanta, GA
- Emory University School of Medicine
- Nominated by the National Association of Inpatient Physicians

- Peter Lindenauer MD, MSc, Hospitalist
- Springfield, MA
- Baystate Medical Center, Division of Healthcare Quality
- Tufts University School of Medicine
- Nominated by the National Association of Inpatient Physicians

- Jim Webster, MD, MS, Internist
- Chicago, IL
- Northwestern University Medical School
- Nominated by the American College of Physicians

## MEDICAL COMPLICATIONS 2 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Dosage complications
- Unexpected LOS / Conditional LOS
- Failure to rescue (2 definitions)
- Death in low mortality DRGs

- Michael Barrett, MD, Internist and Cardiologist
- Blue Bell, PA
- Medical College of Pennsylvania Hospital
- Nominated by the American College of Physicians

- William Golden, MD, Professor of medicine, Internist
- Little Rock, AR
- University of Arkansas for Medical Sciences
- Nominated by the American College of Physicians

- Constantine Manthous, MD, Critical care physician
- Hamden CT
- Yale University
- Nominated by the American Thoracic Society

- Brenda Snyder, RN, MS, CNS, CCRN, Critical care nurse
- Evans, CO
- University of Northern Colorado
- Nominated by the American Association of Critical-Care Nurses

- Mark W. Thomas, RPh, MS, Pharmacist, Pediatrics
- Minneapolis, MN
- Children's Hospital and Clinics-Minneapolis, St. Paul
- Nominated by the American Society of Health-system Pharmacists

- Mark Williams, MD, Hospitalist
- Atlanta, GA
- Emory University of Medicine
- Nominated by the National Association of Inpatient Physicians

- Charles Yowler, MD, Surgeon, Critical Care - Burn Surgery
- Cleveland, OH
- Case Western Reserve University
- Nominated by the American College of Surgeons

## OBSTETRIC COMPLICATIONS OF DELIVERY 1 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Birth trauma - injury to neonate
- Complications of therapeutic abortion (removed due to operationalization concerns)
- Fetal Death (removed due to operationalization concerns
- Obstetric trauma - cesarean section
- Obstetric trauma - vaginal with instrument
- Obstetric trauma - vaginal without instrument

- Patricia Creehan, RNC, MSN, Perinatal clinical nurse specialist
- Palos Heights, IL
- Palos Community Hospital
- Nominated by the Association of Women's Health - Obstetric and Neonatal Nurses

- Neal F. Devitt, MD, Family practitioner
- Santa Fe, NM
- University of New Mexico
- Nominated by the American Academy of Family Physicians

- Robert B. Gherman, MD, Obstetrician - maternal, fetal medicine
- Chesapeake, VA
- Uniformed Services
- University of the Health Sciences
- Nominated by the American College of Obstetricians and Gynecologists

- Stephen Ratcliffe, MD, MSPH, Family practitioner
- Salt Lake City, UT
- University of Utah
- Nominated by the American Academy of Family Physicians

- Allan T. Sawyer, MD, Obstetrician
- Glendale, AZ
- Thunderbird Samaritan Medical Center
- Nominated by the American College of Obstetricians and Gynecologists

- Joan Slager, CNM, MSN, Certified nurse-Midwife
- Kalamazoo, MI
- Bronson Women's Service
- Nominated by the American College of Nurse-Midwives

- Naomi Stotland, MD, Clinical Instructor, Obstetrician
- San Francisco, CA
- Institute for Health Policy Studies, University of California San Francisco
- Nominated by the EPC Contact

## OBSTETRIC COMPLICATIONS 2 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Puerperal infection
- Obstetric vascular complications
- Obstetric wound complications - cesarean section
- Obstetric wound complications - vaginal delivery
- Other obstetric complications of delivery
- Urinary tract infection

- Mark Deutchman, MD, Family practitioner
- Denver, CO
- University of Colorado
- Nominated by the American Academy of Family Physicians

- Jan Kriebs, CNM, FACNM, Certified nurse-Midwife
- Bowie, MD
- University of Maryland, Assistant Professor
- Nominated by the American College of Nurse-Midwives

- David Nagey, MD, PhD, Obstetrician, maternal-fetal medicine
- Baltimore, MD
- Johns Hopkins University
- Nominated by the American College of Obstetricians and Gynecologists

- Nancy Petit, MD, Obstetrician
- Newark, DE
- Uniformed Services - University of the Health Sciences
- Nominated by the American College of Obstetricians and Gynecologists

- Vickie Waymire, RNC, MSN, Perinatal clinical nurse specialist
- Lincoln, NE
- Saint Elizabeth Regional Medical Center
- Nominated by the Association of Women's Health - Obstetric and Neonatal Nurses

- Cynthia Woo, MD, Obstetrician
- Bay Area, CA
- Stanford Hospital
- EPC Contact

## PROCEDURAL COMPLICATIONS 1 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Iatrogenic hypotension
- Iatrogenic pneumothorax
- CABG following PTCA
- Technical difficulty with procedure
- Postoperative iatrogenic complications — (cardiac, nervous, respiratory, digestive, vascular, urinary)

- W. Barton Campbell, M.D, FACC, Cardiologist and critical care physician
- Nashville, TN
- Vanderbilt University
- Nominated by the American College of Cardiology

- Curtis A. Lewis, MD, Interventional radiologist
- Atlanta, GA
- Emory University School of Medicine
- Nominated by the American College of Radiology

- Patricia A. Numann, MD, Surgeon
- Syracuse, NY
- State University of New York — Upstate Medical University
- Nominated by the American College of Surgeons

- Patricia O'Malley, RN, PhD, CCRN, CNS, Clinical nurse specialist, Cardiology services
- Dayton, OH
- Miami Valley Hospital
- Nominated by the American Association of Critical-Care Nurses

- Paul V. O'Moore, MD, Interventional radiologist
- Abington, PA
- Abington Memorial Hospital
- Nominated by the American College of Radiology

- Josh Ofman, MD, MSHS, Internist and Gastroenterologist
- Beverly Hills, CA
- University of California- Los Angeles School of Medicine
- Nominated by the American College of Physicians

- Jean M. Reeder, PhD,RN, FAAN, Perioperative nurse & Healthcare consultant
- Anacortes, WA
- Nominated by the Association of Peri-Operative Registered Nurses

- Stephen D. Small, MD, Anesthesiologist
- Chicago, IL
- University of Chicago
- Nominated by the American Society of Anesthesiologists

## SURGICAL COMPLICATIONS 1 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Postoperative acute myocardial infarction
- Postoperative hemorrhage and hematoma
- Postoperative pneumonia
- Postoperative pulmonary embolism or deep vein thrombosis

- Charles Bethea, MD, Cardiologist
- Oklahoma City, OK
- Duke Clinical Research Institute
- Nominated by the American College of Cardiology

- John Hunt, MD, MPH, Trauma surgeon, critical care
- New Orleans, LA
- Health Science Center - Louisiana State University
- Nominated by the American College of Surgeons

- Franco Laghi, MD, Critical care physician
- Maywood, IL
- Loyola University
- Nominated by the American Thoracic Society

- John Nelson, MD, FACP, Internist/Hospitalist
- Bellevue, WA
- Overlake Hospital Medical Center
- Nominated by the National Association of Inpatient Physicians

- Carol A. Petersen, RN, BSN, MAOM, CNOR, Perioperative nursing specialist
- Denver, CO
- Center for Nursing Practice
- Nominated by the Association of Peri-Operative Registered Nurses

- Bruce Williams, MSN, RN, Critical care nurse specialist
- Orangeburg, SC
- The Regional Medical Center - of Orangeburg and Calhoun Counties
- Nominated by the American Association of Critical-Care Nurses

- Preston Winters, MD, FACP, Internist
- White Plains, NY
- White Plains Hospital Center
- Nominated by the American College of Physicians

## SURGICAL COMPLICATIONS 2 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Postoperative pulmonary compromise
- Reopening of surgical site
- Suture of laceration
- Postoperative wound dehiscence
- Foreign body left in during procedure

- Robert Kozol, MD, MSA, Surgeon
- Farmington, CT
- University of Connecticut
- Nominated by the American College of Surgeons

- Steven Liu, MD, Hospitalist
- Atlanta, GA
- Emory University School of Medicine
- Nominated by the National Association of Inpatient Physicians

- Lenora Maze, MSN, Critical care nurse
- Indianapolis, IN
- Wishard Health Services
- Nominated by the Substitute for American Association of Critical-Care Nurses Nominee

- Valerie Palda, MD, MSc, Internist
- Toronto, ON
- University of Toronto
- Nominated by the American College of Physicians

- Sanjay Saint, MD, MPH, Hospitalist
- Ann Arbor, MI
- University of Michigan Medical School
- Nominated by the National Association of Inpatient Physicians

- Patrice Spera, RN, MS, Perioperative nurse
- Seminole, FL
- Tampa General Hospital
- Nominated by the Association of Peri-Operative Registered Nurses

## SURGICAL COMPLICATIONS 3 (MULTISPECIALTY)

- [underlined: Indicators Reviewed]
- Aspiration pneumonia
- Transfusion reaction
- Postoperative physiologic and metabolic derangements
- Complications of anesthesia
- Malignant hyperthermia
- Intraoperative physical injuries

- Janet Davies, MSN, Critical care nurse
- Mt. Laurel, NJ
- South Jersey Hospital System
- Nominated by the American Association of Critical-Care Nurses

- Jesse Hall, MD, Critical care physician
- Chicago, IL
- University of Chicago
- Nominated by the American Thoracic Society

- Jeanne M. Huddleston, MD, Hospitalist
- Rochester, MN
- Mayo Clinic
- Nominated by the National Association of Inpatient Physicians

- Deborah G. Spratt, CNOR, CNAA, Nurse manager- surgery
- Avon, NY
- University of Rochester
- Nominated by the Association of Peri-Operative Registered Nurses

- Mary Ellen Warner, MD, Anesthesiologist
- Rochester, MN
- Mayo Clinic
- Nominated by the American Society of Anesthesiologists

## SURGICAL COMPLICATIONS 1 (SURGICAL)

- [underlined: Indicators Reviewed]
- Postoperative acute myocardial infarction
- Postoperative pulmonary embolism or deep vein thrombosis
- Postoperative pneumonia
- Intraoperative physical injuries
- Post-surgical hemorrhage or hematoma

- Rodney Appell, MD, Female urologist
- Houston, TX
- Baylor College of Medicine
- Nominated by the American Urologic Association

- Alan Freeland, MD, Orthopedic surgeon
- Jackson, MS
- University of Mississippi Medical Center
- Nominated by the American Academy of Hand Surgeon)

- Patricia Howson, MD, MSc, Orthopedic surgeon
- Redwood City, CA
- Kaiser Permanente
- Nominated by the American Academy of Orthopedic Surgeons

- William Hozak, MD, Orthopedic surgeon
- Philadelphia, PA
- Jefferson Medical School
- Nominated by the American Association of Hip and Knee Surgeons

- Mathew Indeck, MD, General Surgeon -trauma surgery
- Danville, PA
- Jefferson College of Medicine
- Nominated by the American College of Surgeons

- Bruce Kaufman, MD, Pediatric neurosurgeon
- Milwaukee, WI
- Medical College of Wisconsin
- Nominated by the American Association of Neurological Surgeons

## SURGICAL COMPLICATIONS 2 (SURGICAL)

- [underlined: Indicators Reviewed]
- Foreign body left in during procedure
- Postoperative pulmonary compromise
- Reopening of surgical site
- Suture of laceration
- Postoperative wound dehiscence

- Joseph Basler, MD, PhD, Urologist
- San Antonio, TX
- University of Texas Health Science Center
- Nominated by the American Urologic Association

- John Fung, MD, Transplant surgeon
- Pittsburgh, PA
- University of Pittsburgh
- Nominated by the American Society of Transplant Surgeons

- Charles Kenny, MD, Orthopedic surgeon
- Stockbridge, MA
- Fairview Hospital
- Nominated by the American Academy of Orthopedic Surgeons

- John Kestle, MD, MSc, Pediatric neurosurgeon
- Salt Lake City, UT
- University of Utah
- Nominated by the American Association of Neurological Surgeons

- Michael Klassen, MD, Joint and arthroscopic surgeon
- Monterey, CA
- Community Hospital of the Monterey Peninsula
- Nominated by the American Academy of Orthopedic Surgeons

- George Lucas, MD, Orthopedic surgeon - hand surgery
- Wichita, KS
- University of Kansas, Wichita
- Nominated by the American Academy of Hand Surgeon

- Dennis Maiman, MD, PhD, Neurosurgeon- spine surgery
- Milwaukee, WI
- Froedert Memorial Lutheran Hospital
- Nominated by the North American Spine Society

- Richard Nelson, MD, Colon and rectal surgeon
- Chicago, IL
- University of Illinois
- Nominated by the American Society of Colon and Rectal Surgeons

- Michael Stamos, MD, Colon and rectal surgeon
- Torrance, CA
- University of California - Los Angeles School of Medicine
- Nominated by the American College of Surgeons

## SURGICAL COMPLICATIONS 3 (SURGICAL)

- [underlined: Indicators Reviewed]
- Aspiration pneumonia
- Complications of anesthesia
- Postoperative physiologic and metabolic derangements
- Transfusion reaction
- Malignant Hyperthermia

- Robert Florin, MD, Spine surgeon
- Whittier, CA
- University of Southern California School of Medicine
- Nominated by the American Association of Neurological Surgeons

- Stephen Haines, MD, Pediatric neurosurgeon - skull base lesions
- Charleston, SC
- Medical University of South Carolina
- Nominated by the American Association of Neurological Surgeons

- Goran Klintmalm, MD, PhD, Transplant surgeon - liver transplantation
- Dallas, TX
- Baylor Institute of Transplantation Sciences
- Baylor University Medical Center
- Nominated by the American Society of Transplant Surgeons

- Steven Kraus, MD, Female urologist
- San Antonio, TX
- University of Texas Health Science Center
- Nominated by the American Urologic Association

- Deborah Nagle, MD, Colon and rectal surgeon
- Philadelphia, PA
- Graduate Hospital MCP-Hahnemann
- Nominated by the American Society of Colon and Rectal Surgeons

- Richard Strain, MD, Orthopedic surgeon
- Hollywood, FL
- University of Miami Medical School
- Nominated by the American Academy of Orthopedic Surgeons