# Peer Reviewers

This appendix lists the peer reviewers who who provided comments on the report draft.

The EPC acknowledges the contribution of the following individuals, who provided comments on the report draft. This review was used to improve the final report.

- Dan Berlowitz, MD, MPh
- Associate Director,
- Center for Health Quality, Outcomes and Economic Research (CHQOER)
- Bedford VA Hospital
- Bedford, MA

- Andrew Brown, MD, MPH
- Associate Professor of Medicine and Director
- The University of Mississippi Medical Center
- Jackson, MS

- Timothy Dresselhaus, MD, MPH
- Associate Professor, UCSD Department of Medicine
- Associate Chief, VA Medical Service
- San Diego Center for Patient Safety
- San Diego, California

- William Claiborne Dunagan, MD
- Vice President, Quality
- BJC HealthCare
- St. Louis, MO

- Victoria Fraser, MD
- Associate Professor of Medicine
- Washington University School of Medicine
- St. Louis, MO

- David Gaba, MD
- Professor, Department of Anesthesia at Stanford University
- Director, Patient Safety Center of Inquiry
- Palo Alto Veterans Administration (VAPAHCS)
- Palo Alto, CA

- Lein Fang Han, PhD
- Health Service Researcher
- Quality Measurement and Health Assessment Group
- Centers for Medicare & Medicaid Services
- Baltimore, MD

- John Hickner, MD, MS
- Professor of Family Practice
- Michigan State University College of Human Medicine
- East Lansing, MI

- Lisa I. Iezzoni, MD, MSc
- Professor of Medicine, Harvard Medical School
- Division of General Medicine and Primary Care
- Beth Israel Deaconess Medical Center
- Boston, MA

- Harold Kaplan, MD
- Professor and Director of Clinical Laboratories
- New York Presbyterian Hospital and Columbia Presbyterian Medical Center
- New York, NY

- Ed Kelley, PhD
- Senior Service Fellow, National Healthcare Quality Report
- Center for Quality Improvement and Patient Safety
- Agency for Healthcare Research and Quality (AHRQ)
- Rockville, MD

- Christine Kovner, RN, PhD, FAAN
- Professor, Division of Nursing
- Steinhardt School of Education, New York University
- New York, NY

- Peter Layde, MD, MSc
- Professor and Director Division of Research
- Department of Family and Community Medicine
- Medical College of Wisconsin
- Milwaukee, WI

- Jared Loeb, PhD
- Vice President, Research and Performance Measurement
- JCAHO
- Oakbrook Terrace, IL

- Stephen Luther, PhD
- Evaluation Methodologist
- VISN 8 Patient Safety Center of Inquiry
- James A. Haley, Veterans Administration Hospital
- Tampa, FL

- Colin Mackenzie, MD
- Profesor & Director
- National Study Center for Trauma & EMS
- Baltimore MD

- Steven Meuer, MHS, MBA
- Director, Patient Safety
- BJC HealthCare
- St. Louis, MO

- Jack Needleman, PhD
- Assistant Professor
- Harvard School of Public Health
- Boston, MA

- Peter Pronovost, MD,PhD
- Associate Professor
- Dept of Anesthesiology and Critical Care Medicine
- Johns Hopkins University School of Medicine
- Baltimore, MD

- Amy Rosen, PhD
- Senior Research Scientist and Associate Professor, Health Services
- Center for Health Quality, Outcomes and Economic Research (CHQOER)
- Boston University School of Public Health
- Bedford, MA

- Loel Solomon, PhD
- Deputy Director Health Care Quality and Analysis Division
- Office of Statewide Health Planning and Development
- Sacramento, CA

- Dionyssios Tsilimingras, MD, MPh
- Health Science Specialist
- Center for Health Quality, Outcomes, & Economic Research- VA Medical Center
- Bedford, MA

- Wu Xu, PhD
- Director for Office of Health Care Statistics
- Utah Department of Health
- Salt Lake City, Utah

- Coding Consultant
- Rita A. Scichilone, MHSA, RHIA, CCS, CCS-P, CHC
- Director, Coding Products and Services
- American Health Information Management Association (AHIMA)
- Chicago, IL