# Inventory of Potential Patient Safety Indicators

This appendix lists the indicators identified by the literature review and personal contacts of the project team. To qualify for this list, the indicator needs to measure a potentially preventable complication of care. In addition, it must be possible or likely that the indicator could be defined based on administrative, unlinked data. For each indicator, the current users or developer are shown, whether the indicator was reviewed by a clinical panel in this project, whether the indicator was evaluated empirically, and why it was selected for or excluded from panel review.

INVENTORY OF POTENTIAL PATIENT SAFETY INDICATORS

Measure Type and Clinical Domain | Indicator Name | Current Users or Developers | Panel | Empirical | Reason for selection for or exclusion from clinician panel review.
Proxy-Outcome measures:
| All discharges, length of stay | - HQI ValiData | | | Conceptually less connected to patient safety compared with next two.
| Conditional length of stay | - Literature Silber | x | | Adequate previous validation.
| Unexpected length of stay | - Literature Kuykendall ^1^ | x | | Adequate previous validation.
Outcomes measures:
| Aspiration pneumonia | - Complications Screening Program; - Needleman and Buerhaus ^2^; - University HealthSystem Consortium | x | e | Adequate previous validation.
| Bacteraemia | - Literature: Ansari (Australia) ^3^ | | | Related to septicemia indicator.
| CABG following PTCA | - University HealthSystem Consortium; - Literature ^4^ – ^12^ | x | e | Adequate previous validation.
| Cardiac event or emergency | - Complications Screening Program | | | No previous validation.
| Cellulitis | - Complications Screening Program | | | No previous validation.
| Complications of anesthesia/ Anesthesia related events | - Complications Screening Program | x | x | Final definition differs substantially from original CSP indicator.
| Death in low mortality DRGs | - Hannan et al. ^13^ | x | x | Adequate previous validation.
| Death within one or two days of surgical procedure | - Hannan et al. ^13^; - University HealthSystem Consortium
| Decubitus Ulcer | - Complications Screening Program; - Needleman and Buerhaus ^2^; - American Nurses Association; - California Nursing Outcomes Coalition | | x | Subset of cellulitis indicator. Created after review of ICD-9-CM codes.
| Decubitus Ulcer in High Risk Patient | - none | | e | Suggested by panelists.
| Dosage complications | - none | x | | Created after review of ICD-9-CM codes.
| Failure to rescue (2 alternative definitions) | - Silber et al. ^14^; - Needleman and Buerhaus ^2^ | x | x | Adequate previous validation.
| Foreign body left in during procedure | - Miller et al. ^15^; - McKesson Health Systems Solutions | x | x | Created from codes in sentinel event codes and a review of ICD-9-CM codes.
| Iatrogenic hypotension | - Miller et al PSIs ^15^ | x | | Created after review of ICD-9-CM codes.
| Iatrogenic pneumothorax | - Miller et al PSIs ^15^ | x | x | Created after review of ICD-9-CM codes.
| Infection due to medical care | - Miller et al PSIs ^15^ | x | x | Created after review of ICD-9-CM codes and Complications Screening program.
| In-hospital burns | - Hannan et al. ^13^ | | | Inadequate previous validation.
| In-hospital fractures possibly related to falls | - None | x | e | Suggested by panel as expansion to hip fracture indicator.
| In-hospital hip fracture (and falls) | - Complications Screening Program; - Needleman and Buerhaus ^2^; - American Nurses Association; - California Nursing Outcomes Coalition | x | x | Adequate previous validation. Final definition excluded falls.
| Intestinal infection due to C. difficile | - None | x | | Subset of postoperative infection indicator. Created after review of ICD-9-CM codes.
| Intraoperative nerve compression injuries | - None | x | e | Suggested by panelists.
| Malignant hyperthermia | - None | x | e | Suggested by panelists based on discussion of complications of anesthesia indicator.
| Mechanical complication | - Complications Screening Program; - University HealthSystem Consortium; - HCUP | | | Poor validity in published reports.
| (Device implant)
| Miscellaneous complications | - Complications Screening Program | | | Inadequate previous validation.
| Nosocomial/iatrogenic disease | - Sagamore Health | | | Requires additional data.
| Peri-operative complications | - IMSystem; - University HealthSystem Consortium | | | Proprietary measures.
| Perforation diagnosis | - Miller et al ^15^ | | | Eliminated due to coding concerns
| Post- or intraoperative shock due to anesthesia | - Complications Screening Program | | | Included in original complications of anesthesia indicator.
| Postoperative acute myocardial infarction (AMI) | - Complications Screening Program; - University HealthSystem Consortium; - HCUP | x | e | Adequate previous validation.
| Postoperative cardiac anomaly | - Complications Screening Program | | | No previous validation.
| Postoperative central nervous system (CNS) or peripheral (PNS) complication | - Complications Screening Program; - University HealthSystem Consortium | | | No previous validation.
| Postoperative cerebral infarction | - Complications Screening Program; - University HealthSystem Consortium | | | Poor validity in published reports.
| Postoperative coma | - Complications Screening Program; - Needleman and Buerhaus ^2^ | | | No previous validation.
| Postoperative GI hemorrhage or ulceration following non-GI surgery | - Complications Screening Program; - University HealthSystem Consortium; - HCUP; - Needleman and Buerhaus ^2^ | | | Poor validity in published reports.
| Postoperative hemorrhage or hematoma | - Complications Screening Program; - HCUP; - University HealthSystem Consortium | x | x | Adequate previous validation.
| Postoperative iatrogenic complications - Nervous | - Complications Screening Program; - University HealthSystem Consortium; - HCUP | x | e | Adequate previous validation. Subset of CSP/UHC/HCUP indicator.
| Postoperative Iatrogenic Complications - Cardiac | - Originally part of general iatragenic complications indicator (see above) | x | e | See above
| Postoperative Iatrogenic Complications - Urinary | - See above | x | | See above
| Postoperative Iatrogenic Complications - Respiratory | - See above | x | | See above
| Postoperative Iatrogenic Complications - Digestive | - See above | x | | See above
| Postoperative Iatrogenic Complications - Vascular | - See above | x | | See above
| Postoperative infections (not pneumonia or wound infection) | - Complications Screening Program; - University HealthSyste Consortium; - Needleman and Buerhaus ^2^ | | | Poor validity in published reports.
| Postoperative physiologic and metabolic derangements | - Complications Screening Program; - University HealthSystem Consortium; - Needleman and Buerhaus ^2^; - Hannan et al. ^13^ | x | x | Adequate previous validation.
| Postoperative pneumonia | - Complications Screening Program; - University HealthSystem Consortium; - HCUP | x | | Adequate previous validation.
| Postoperative pulmonary compromise | - Complications Screening Program; - University HealthSystem Consortium; - HCUP; - Needleman and Buerhaus ^2^ | x | x | Adequate previous validation.
| Postoperative thrombosis and embolism | - Complications Screening Program; - Ansari (Australia) ^3^; - HCUP; - Needleman and Buerhaus ^2^; - CMS ^16^ | x | x | Adequate previous validation.
| Postoperative urinary tract complications | - Complications Screening Program; - HCUP | | | No previous validation.
| Postoperative wound dehiscence | - Hannan et al. ^13^ | x | x | Subset of the CSP indicator “Reopening of Surgical Site”
| Primary blood infection | - IMSystem | | | Related to septicemia indicator.
| Reopening of surgical site | - Complications Screening Program; - University HealthSystem Consortium | x | e | Adequate previous validation.
| Return to operating room | - Maryland Quality Indicator; - University HealthSystem Consortium; - Ansari (Australia) ^3^ | | | Requires additional data.
| Septicemia | - Complications Screening Program; - Needleman and Buerhaus ^2^ | x | x | Adequate previous validation.
| Sentinel events | - Complications Screening Program | | | Many specific events included in separate indicators.
| Shock or cardiopulmonary arrest in hospital | - Complications Screening Program; - Needleman and Buerhaus ^2^ | | | Inadequate previous validation.
| Specific drug events/ Complications relating to drugs | - Complications Screening Program; - Hannan ^13^ | | | Poor validity in published reports.
| Surgical patient injury | - University HealthSystem Consortium | | | Proprietary measure.
| Surgical technical difficulty | - University HealthSystem Consortium | | | Proprietary measure.
| Suture of laceration (Laceration, perforation injury) | - Complications Screening Program; - Miller et al. ^15^; - University HealthSystem Consortium | x | e | Suture of laceration is a subset of the CSP indicator.
| Technical difficulty with care (procedure) | - Complications Screening Program; - University HealthSystem Consortium; - McKesson Health Solutions; - Miller et al. ^15^ | x | x | Adequate previous validation.
| Transfer to other hospital | - Literature: Bates et al. ^17^ | | | Requires additional data.
| Transfusion Reaction/ Complications with blood products | - Complications Screening Program; - Miller et al. ^15^ | x | x | Adequate previous validation.
| Vent Pneumonia | - IMSystem | | | Requires additional data.
| Wound Infection/ Surgical site infection | - Complications Screening Program; - IMSystem; - Ansari (Australia); - CARE; - HCUP | | | Poor validity in published reports.
Obstetric
| Fetal death | - none | x | | Created after review of ICD-9-CM codes, but not actually feasible to implement with HCUP data.
| Complications of therapeutic abortion | - none | x | | Created after review of ICD-9-CM codes, but removed due to operationalization concerns.
| Birth trauma-injury to neonate | - Miller et al. ^15^; - McKesson Health Solutions | x | x | Created after review of ICD-9-CM codes.
| Third or fourth degree obstetric laceration | - JCAHO; - McKesson Health Solutions | | e | Panelists preferred to restrict to fourth degree lacerations (part of obstetric trauma indicator).
| Obstetric trauma - vaginal without instrument | - none | x | x | Created after review of ICD-9-CM codes.
| Obstetric trauma, - vaginal with instrument | - none | x | x | Created after review of ICD-9-CM codes.
| Obstetric trauma - cesarean section | - none | x | x | Created after review of ICD-9-CM codes.
| Obstetric wound complications - cesarean section delivery | - none | x | x | Created after review of ICD-9-CM codes.
| Obstetric wound complications - vaginal delivery | - none | x | e | Created after review of ICD-9-CM codes.
| Obstetric vascular complications | - none | x | | Created after review of ICD-9-CM codes.
| Other obstetric complications of delivery | - Miller et al. ^15^ | x | e | Created after review of ICD-9-CM codes.
| Post-partum urinary tract infection | - none | x | x | Suggested by panelists.
| Puerperal infection | - none | x | | Created after review of ICD-9-CM codes.
| Uterine Rupture | - none | x | e | Suggested by panelists.
Psychiatric
| Attempted suicide | - Sagamore Health | | | Requires additional data.
| Psychiatric hospital termination AMA (Against medical advice) | - JCAHO; - University HealthSystem Consortium | | | Requires additional data.

See References at end of table.

Note: Almost without exception, original indicator definition differs from final tested definition, based on panel feedback and coding changes. An “x” in the “Panel” column means that the indicator, in some form, was reviewed by the clinical panels for this project. The “Empirical” column distinguishes between indicators that were accepted (“x”) from those classified as experimental (“e”).

## References for Appendix A

1 Kuykendall DH, Ashton CM, Johnson ML, Geraci JM. Identifying complications and low provider adherence to normative practices using administrative data. Health Serv Res. 1995;30(4):531-54. [pmid: 7591780]. [pmcid: 1070074].
2 Needleman J, Buerhaus PI, Mattke S, Stewart M, Zelevinsky K. Nurse Staffing and Patient Outcomes in Hospitals. Boston, MA: Health Resources Services Administration; 2001 February 28. Report No.: 230-99-0021.
3 Ansari MZ, Collopy BT, McDonald IG. Establishing thresholds for adverse patient outcomes. Int J Qual Health Care. 1996;8(3):223-30. [pmid: 8885186].
4 Ritchie JL, Phillips KA, Luft HS. Coronary angioplasty. Statewide experience in California. Circulation. 1993;88(6):2735-43. [pmid: 8252686].
5 Ritchie JL, Maynard C, Chapko MK, Every NR, Martin DC. Association between percutaneous transluminal coronary angioplasty volumes and outcomes in the Healthcare Cost and Utilization Project 1993-1994. Am J Cardiol. 1999;83(4):493-7. [pmid: 10073849].
6 Ho V. Evolution of the volume-outcome relation for hospitals performing coronary angioplasty. Circulation. 2000;101(15):1806-11. [pmid: 10769281].
7 Maynard C, Every NR, Chapko MK, Ritchie JL. Institutional volumes and coronary angioplasty outcomes before and after the introduction of stenting. Eff Clin Pract. 1999;2(3):108-13. [pmid: 10538258].
8 Jollis JG, Peterson ED, DeLong ER, Mark DB, Collins SR, Muhlbaier LH, et al. The relation between the volume of coronary angioplasty procedures at hospitals treating Medicare beneficiaries and short-term mortality. N Engl J Med. 1994;331(24):1625-9. [pmid: 7969344].
9 Jollis JG, Peterson ED, Nelson CL, Stafford JA, DeLong ER, Muhlbaier LH, et al. Relationship between physician and hospital coronary angioplasty volume and outcome in elderly patients. Circulation. 1997;95(11):2485-91. [pmid: 9184578].
10 Hannan EL, Racz M, Ryan TJ, McCallister BD, Johnson LW, Arani DT, et al. Coronary angioplasty volume-outcome relationships for hospitals and cardiologists. JAMA. 1997;277(11):892-8. [pmid: 9062327].
11 McGrath PD, Wennberg DE, Malenka DJ, Kellett MA Jr, Ryan TJ Jr, JR OM, et al. Operator volume and outcomes in 12,998 percutaneous coronary interventions. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. 1998;31(3):570-6. [pmid: 9502637].
12 McGrath PD, Wennberg DE, Dickens JD Jr, Siewers AE, Lucas FL, Malenka DJ, et al. Relation between operator and hospital volume and outcomes following percutaneous coronary interventions in the era of the coronary stent. Jama. 2000;284(24):3139-44. [pmid: 11135777].
13 Hannan EL, Bernard HR, O'Donnell JF, Kilburn H Jr. A methodology for targeting hospital cases for quality of care record reviews. Am J Public Health. 1989;79(4):430-6. [pmid: 2494893]. [pmcid: 1349969].
14 Silber JH, Rosenbaum PR, Williams SV, Ross RN, Schwartz JS. The relationship between choice of outcome measure and hospital rank in general surgical procedures: implications for quality assessment. Int J Qual Health Care. 1997;9(3):193-200. [pmid: 9209916].
15 Miller M, Elixhauser A, Zhan C, Meyer G. Patient Safety Indicators: Using Administrative Data to Identify Potential Patient Safety Concerns. Health Services Research. 2001;36(6 Part II):110-132. [pmid: 16148964]. [pmcid: 1383610].
16 Dicker R, Han L, Macone J. Quality of Care Surveillance Using Administrative Data, 1996. In: Quality Resume No. 2. Baltimore, MD: HCFA; 1998.
17 Bates DW, O'Neil AC, Petersen LA, Lee TH, Brennan TA. Evaluation of screening criteria for adverse events in medical patients. Med Care. 1995;33(5):452-62. [pmid: 7739271].