# Appendixes

Appendix A Inventory of Potential Patient Safety Indicators

Appendix B Clinician Review Panels

Appendix C Sample of Information Sent to Panelists

Appendix D Empirical Methods Details

Appendix E Details of Indicator Definitions

Appendix F Detailed Results for Rejected Indicators

Appendix G Detailed Empirical Results

Appendix H Comparison of PSIs with CSP Indicators and Miller et al. PSIs

Appendix I Definitions of Indicators Presented to Panelists

Appendix J Peer Reviewers