# References

1 Medicare: a strategy for quality assurance. Washington, D.C.: National Academy Press. 1990.
2 Chassin MR, Galvin RW The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality JAMA 1998 280(11):1000 5 9749483
3 Johantgen M, Elixhauser A, Bali JK, et al Quality indicators using hospital discharge data: state and national applications Jt Comm J Qual Improv 1998 24(2):88 105 9547683
4 1 ed: Agency for Health Care Policy and Research. 1994.
5 Office of Disease Prevention and Health Promotion. U.S. Department of Health and Human Services.
6 McGlynn EA, Asch SM Developing a clinical performance measure Am J Prev Med 1998 14(3 Suppl):14 21 9566932
7 Iezzoni LI, Ash AS, Coffman GA, et al Predicting in-hospital mortality. A comparison of severity measurement approaches Med Care 1992 30(4):347 59 1556882
8 Iezzoni LI, editor. Risk Adjustment for Measuring Health Outcomes. Chicago: Health Administration Press. 1994.
9 Iezzoni LI, Ash AS, Shwartz M, et al Predicting who dies depends on how severity is measured: implications for evaluating patient outcomes Ann Intern Med 1995 123(10):763 70 7574194
10 Iezzoni LI, Shwartz M, Ash AS, et al Predicting in-hospital mortality for stroke patients: results differ across severity-measurement methods Med Decis Making 1996 16(4):348 56 8912296
11 Iezzoni LI, Shwartz M, Ash AS, et al Using severity-adjusted stroke mortality rates to judge hospitals Int J Qual Health Care 1995 7(2):81 94 7655814
12 Iezzoni LI, Ash AS, Shwartz M, et al Judging hospitals by severity-adjusted mortality rates: the influence of the severity-adjustment method Am J Public Health 1996 86(10):1379 87 8876505 1380647
13 Iezzoni LI, Shwartz M, Ash AS, et al Severity measurement methods and judging hospital death rates for pneumonia Med Care 1996 34(1):11 28 8551809
14 Iezzoni LI Assessing quality using administrative data Ann Intern Med 1997 127(8 Pt 2):666 74 9382378
15 Iezzoni LI The risks of risk adjustment JAMA 1997 278(19):1600 7 9370507
16 Iezzoni LI. Risk adjustment for measuring healthcare outcomes. 2nd ed. Chicago, Ill.: Health Administration Press. 1997.
17 Iezzoni LI, Ash AS, Shwartz M, et al Predicting in-hospital deaths from coronary artery bypass graft surgery. Do different severity measures give different predictions? Med Care 1998 36(1):28 39 9431329
18 Iezzoni LI, Shwartz M, Ash AS, et al Using severity measures to predict the likelihood of death for pneumonia inpatients J Gen Intern Med 1996 11(1):23 31 8691283
19 Pine M, Norusis M, Jones B, et al Predictions of hospital mortality rates: a comparison of data sources Ann Intern Med 1997 126(5):347 54 9054278
20 Siu AL, McGlynn EA, Morgenstern H, et al Choosing quality of care measures based on the expected impact of improved care on health Health Serv Res 1992 27(5):619 50 1464537 1069903
21 Donabedian A. Explorations in Quality Assessment and Monitoring. The definition of quality and approaches to its assessment. Ann Arbor, MI: Health Administration Press. 1980.
22 Donabedian A The quality of care: how can it be assessed? JAMA 1988 260(12):1743 1748 3045356
23 Schneider EC, Epstein AM Influence of cardiac-surgery performance reports on referral practices and access to care. A survey of cardiovascular specialists N Engl J Med 1996 335(4):251 6 8657242
24 Mennemeyer ST, Morrisey MA, Howard LZ Death and reputation: how consumers acted upon HCFA mortality information Inquiry 1997 34(2):117 28 9256817
25 Hibbard JH, Jewett JJ Will quality report cards help consumers? Health Aff (Millwood) 1997 16(3):218 28 9141339
26 Normand SL, McNeil BJ, Peterson LE, et al Eliciting expert opinion using the Delphi technique: identifying performance indicators for cardiovascular disease Int J Qual Health Care 1998 10(3):247 60 9661064
27 Veroff DR, Gallagher PM, Wilson V, et al Effective reports for health care quality data: lessons from a CAHPS demonstration in Washington State Int J Qual Health Care 1998 10(6):555 60 9928595
28 Delbanco TL, Stokes DM, Cleary PD, et al Medical patients' assessments of their care during hospitalization: insights for internists J Gen Intern Med 1995 10(12):679 85 8770720
29 Laine C, Davidoff F Patient-centered medicine. A professional evolution JAMA 1996 275(2):152 6 8531314
30 Allen HM, Jr., Rogers WH Consumer surveys of health plan performance: a comparison of content and approach and a look to the future Jt Comm J Qual Improv 1996 22(12):775 94 8986560
31 Cleary PD, Edgman-Levitan S Health care quality. Incorporating consumer perspectives JAMA 1997 278(19):1608 12 9370508
32 American Hospital Association and the Picker InstituteJ Health Care Finance 1997 23(4):2 11 9211147
33 Calnan MW The patient's perspective Int J Technol Assess Health Care 1998 14(1):24 34 9509792
34 Tye L. Patient surveys show how Massachusetts hospitals stack up. Boston Globe 1998 Novemebr 13. 1998.
35 Finkelstein BS, Harper DL, Rosenthal GE Patient assessments of hospital maternity care: a useful tool for consumers? Health Serv Res 1999 34(2):623 40 10357293 1089026
36 Berwick DM, Wald DL Hospital leaders' opinions of the HCFA mortality data JAMA 1990 263(2):247 9 2403602
37 Jencks SF, Daley J, Draper D, et al Interpreting hospital mortality data. The role of clinical risk adjustment JAMA 1988 260(24):3611 6 3057250
38 Park RE, Brook RH, Kosecoff J, et al Explaining variations in hospital death rates. Randomness, severity of illness, quality of care JAMA 1990 264(4):484 90 2195173
39 Localio AR, Hamory BH, Sharp TJ, et al Comparing hospital mortality in adult patients with pneumonia. A case study of statistical methods in a managed care program Ann Intern Med 1995 122(2):125 32 7992987
40 Localio AR, Hamory BH, Fisher AC, et al The public release of hospital and physician mortality data in Pennsylvania. A case study Med Care 1997 35(3):272 286 9071258
41 Hofer TP, Hayward RA Identifying poor-quality hospitals. Can hospital mortality rates detect quality problems for medical diagnoses? Med Care 1996 34(8):737 53 8709656
42 Thomas JW, Hofer TP Accuracy of risk-adjusted mortality rate as a measure of hospital quality of care Med Care 1999 37(1):83 92 10413396
43 Mant J, Hicks N Detecting differences in quality of care: the sensitivity of measures of process and outcome in treating acute myocardial infarction BMJ 1995 311(7008):793 6 7580444 2550793
44 Palmer RH Process-based measures of quality: the need for detailed clinical data in large health care databases Ann Intern Med 1997 127(8 Pt 2):733 8 9382389
45 Eddy DM Performance measurement: problems and solutions Health Aff (Millwood) 1998 17(4):7 25 9691542
46 Harr DS, Balas EA, Mitchell J Developing quality indicators as educational tools to measure the implementation of clinical practice guidelines Am J Med Qual 1996 11(4):179 85 8972934
47 Ellerbeck EF, Jencks SF, Radford MJ, et al Quality of care for Medicare patients with acute myocardial infarction. A four-state pilot study from the Cooperative Cardiovascular Project JAMA 1995 273(19):1509 14 7739077
48 Marciniak TA, Ellerbeck EF, Radford MJ, et al Improving the quality of care for Medicare patients with acute myocardial infarction: results from the Cooperative Cardiovascular Project JAMA 1998 279(17):1351 7 9582042
49 Donabedian A Evaluating the quality of medical care Milbank Mem Fund Q 1966 44(3):Suppl:166 206 5338568
50 Brook RH, McGlynn EA, Cleary PD Quality of health care. Part 2: measuring quality of care N Engl J Med 1996 335(13):966 70 8782507
51 Luft HS, Bunker JP, Enthoven AC Should operations be regionalized? The empirical relation between surgical volume and mortality N Engl J Med 1979 301(25):1364 9 503167
52 Hughes RG, Garnick DW, Luft HS, et al Hospital volume and patient outcomes. The case of hip fracture patients Med Care 1988 26(11):1057 67 3185017
53 Hannan EL, JF OD, Kilburn H, Jr., et al Investigation of the relationship between volume and mortality for surgical procedures performed in New York State hospitals JAMA 1989 262(4):503 10 2491412
54 Hannan EL, Kilburn H, Jr., Bernard H, et al Coronary artery bypass surgery: the relationship between inhospital mortality rate and surgical volume after controlling for clinical risk factors Med Care 1991 29(11):1094 107 1943270
55 Stone VE, Seage GRd, Hertz T, et al The relation between hospital experience and mortality for patients with AIDS JAMA 1992 268(19):2655 61 1433685
56 Hosenpud JD, Breen TJ, Edwards EB, et al The effect of transplant center volume on cardiac transplant outcome. A report of the United Network for Organ Sharing Scientific Registry JAMA 1994 271(23):1844 9 8196141
57 Jones A, O'Driscoll K, Luke LC Head injuries and the observation ward [letter; comment] J Accid Emerg Med 1995 12(2):160 1 7582422
58 Phibbs CS, Bronstein JM, Buxton E, et al The effects of patient volume and level of care at the hospital of birth on neonatal mortality JAMA 1996 276(13):1054 9 8847767
59 Ellis SG, Weintraub W, Holmes D, et al Relation of operator volume and experience to procedural outcome of percutaneous coronary revascularization at hospitals with high interventional volumes Circulation 1997 95(11):2479 84 9184577
60 Jollis JG, Peterson ED, Nelson CL, et al Relationship between physician and hospital coronary angioplasty volume and outcome in elderly patients Circulation 1997 95(11):2485 91 9184578
61 Hannan EL, Racz M, Ryan TJ, et al Coronary angioplasty volume-outcome relationships for hospitals and cardiologists JAMA 1997 277(11):892 8 9062327
62 Dardik A, Burleyson GP, Bowman H, et al Surgical repair of ruptured abdominal aortic aneurysms in the state of Maryland: factors influencing outcome among 527 recent cases J Vasc Surg 1998 28(3):413 20 9737450
63 Rosenthal GE, Shah A, Way LE, et al Variations in standardized hospital mortality rates for six common medical diagnoses: implications for profiling hospital quality Med Care 1998 36(7):955 64 9674614
64 Cebul RD, Snow RJ, Pine R, et al Indications, outcomes, and provider volumes for carotid endarterectomy JAMA 1998 279(16):1282 7 9565009
65 Begg CB, Cramer LD, Hoskins WJ, et al Impact of hospital volume on operative mortality for major cancer surgery JAMA 1998 280(20):1747 51 9842949
66 Thiemann DR, Coresh J, Oetgen WJ, et al The association between hospital volume and survival after acute myocardial infarction in elderly patients N Engl J Med 1999 340(21):1640 8 10341277
67 Pratt R, Burr G, Leelarthaepin B, et al The effects of All-RN and RN-EN staffing on the quality and cost of patient care Aust J Adv Nurs 1993 10(3):27 39 8240762
68 Archibald LK, Manning ML, Bell LM, et al Patient density, nurse-to-patient ratio and nosocomial infection risk in a pediatric cardiac intensive care unit Pediatr Infect Dis J 1997 16(11):1045 8 9384337
69 Blegen MA, Goode CJ, Reed L Nurse staffing and patient outcomes Nurs Res 1998 47(1):43 50 9478183
70 Czaplinski C, Diers D The effect of staff nursing on length of stay and mortality Med Care 1998 36(12):1626 38 9860053
71 Kovner C, Gergen PJ Nurse staffing levels and adverse events following surgery in U.S. hospitals Image J Nurs Sch 1998 30(4):315 21 9866290
72 McCloskey JM Nurse staffing and patient outcomes Nurs Outlook 1998 46(5):199 200 9805336
73 Bond CA, Raehl CL, Pitterle ME, et al Health care professional staffing, hospital characteristics, and hospital mortality rates Pharmacotherapy 1999 19(2):130 8 10030762
74 Wennberg J, Gittelsohn Small area variations in health care delivery Science 1973 182(117):1102 8 4750608
75 Wennberg J, Gittelsohn A Variations in medical care among small areas Sci Am 1982 246(4):120 34 7079718
76 Markowitz JS, Pashko S, Gutterman EM, et al Death rates among patients hospitalized with community-acquired pneumonia: a reexamination with data from three states Am J Public Health 1996 86(8 Pt 1):1152 4 8712278 1380630
77 Hofer TP, Wolfe RA, Tedeschi PJ, et al Use of community versus individual socioeconomic data in predicting variation in hospital use Health Serv Res 1998 33(2 Pt 1):243 59 9618670 1070263
78 Jencks SF, Dobson A Refining case-mix adjustment. The research evidence N Engl J Med 1987 317(11):679 86 3114635
79 Shapiro MF, Park RE, Keesey J, et al The effect of alternative case-mix adjustments on mortality differences between municipal and voluntary hospitals in New York City Health Serv Res 1994 29(1):95 112 8163382 1069990
80 Halm EA, Lee C, Chassin MR. How is volume related to quality in health care? A systematic review of the research literature: Institute of Medicine, National Academy of Sciences, Division of Health Care Services, Committee on Quality of Care in America. 2000 May 1.
81 Thomas J, Holloway J, Guire K Validating risk-adjusted mortality as an indicator for quality of care Inquiry 1993 30(1):6 22 8454316
82 Hofer TP, Hayward RA Can early re-admission rates accurately detect poor-quality hospitals? Med Care 1995 33(3):234 45 7861826
83 Thomas JW Does risk-adjusted readmission rate provide valid information on hospital quality? Inquiry 1996 33(3):258 70 8883460
84 Normand ST, Glickman ME, Sharma RG, et al Using admission characteristics to predict short-term mortality from myocardial infarction in elderly patients. Results from the Cooperative Cardiovascular Project JAMA 1996 275(17):1322 8 8614117
85 Thomas JW, Hofer TP Research evidence on the validity of risk-adjusted mortality rate as a measure of hospital quality of care Med Care Res Rev 1998 55(4):371 404 9844348
86 Hofer TP, Hayward RA, Greenfield S, et al The unreliability of individual physician "report cards" for assessing the costs and quality of care of a chronic disease JAMA 1999 281(22):2098 105 10367820
87 Normand S, Glickman M, Gastonis C Statistical methods for profiling providers of medical care: Issues and applications JASA 1997 92(439):803 814
88 O'Hagan A. Bayesian Inference. In: al. GPe, editor. Kendall's Advanced Theory of Statistics. New York: Halstead Press. 1994.
89 Goldstein H. Multilevel Statistical Models. 2nd ed. New York: Halstead Press. 1995.
90 Wennberg JE, Freeman JL, Shelton RM, et al Hospital use and mortality among Medicare beneficiaries in Boston and New Haven N Engl J Med 1989 321(17):1168 73 2677726
91 Fisher ES, Wennberg JE, Stukel TA, et al Hospital readmission rates for cohorts of Medicare beneficiaries in Boston and New Haven N Engl J Med 1994 331(15):989 95 8084356
92 Miller MG, Miller LS, Fireman B, et al Variation in practice for discretionary admissions. Impact on estimates of quality of hospital care JAMA 1994 271(19):1493 8 8176828
93 Rosenthal GE, Harper DL, Shah A, et al A regional evaluation of variation in low-severity hospital admissions J Gen Intern Med 1997 12(7):416 22 9229280 1497141
94 Fisher ES, Wennberg JE, Stukel TA, et al Associations among hospital capacity, utilization, and mortality of US Medicare beneficiaries, controlling for sociodemographic factors Health Serv Res 2000 34(6):1351 62 10654835 1089085
95 McClellan M, McNeil BJ, Newhouse JP Does more intensive treatment of acute myocardial infarction in the elderly reduce mortality? Analysis using instrumental variables JAMA 1994 272(11):859 66 8078163
96 Iezzoni LI, Heeren T, Foley SM, et al Chronic conditions and risk of in-hospital death Health Serv Res 1994 29(4):435 60 7928371 1070016
97 Jones RH, Hannan EL, Hammermeister KE, et al Identification of preoperative variables needed for risk adjustment of short-term mortality after coronary artery bypass graft surgery. The Working Group Panel on the Cooperative CABG Database Project J Am Coll Cardiol 1996 28(6):1478 87 8917261
98 Khuri SF, Daley J, Henderson W, et al Risk adjustment of the postoperative mortality rate for the comparative assessment of the quality of surgical care: results of the National Veterans Affairs Surgical Risk Study J Am Coll Surg 1997 185(4):315 27 9328380
99 Wray NP, Hollingsworth JC, Peterson NJ, et al Case-mix adjustment using administrative databases: a paradigm to guide future research Med Care Res Rev 1997 54(3):326 56 9437171
100 Kuttner R The risk-adjustment debate N Engl J Med 1998 339(26):1952 6 9874620
101 Block PC, Peterson EC, Krone R, et al Identification of variables needed to risk adjust outcomes of coronary interventions: evidence-based guidelines for efficient data collection J Am Coll Cardiol 1998 32(1):275 82 9669281
102 Richardson D, Tarnow-Mordi WO, Lee SK Risk adjustment for quality improvement Pediatrics 1999 103(1 Suppl E):255 65 9917469
103 Iezzoni LI, Foley SM, Daley J, et al Comorbidities, complications, and coding bias. Does the number of diagnosis codes matter in predicting in-hospital mortality? JAMA 1992 267(16):2197 203 1556797
104 Green J, Wintfeld N How accurate are hospital discharge data for evaluating effectiveness of care? Med Care 1993 31(8):719 31 8336511
105 Malenka DJ, McLerran D, Roos N, et al Using administrative data to describe casemix: a comparison with the medical record J Clin Epidemiol 1994 47(9):1027 32 7730905
106 Jencks SF, Williams DK, Kay TL Assessing hospital-associated deaths from discharge data. The role of length of stay and comorbidities JAMA 1988 260(15):2240 6 3050163
107 Romano PS, Mark DH Bias in the coding of hospital discharge data and its implications for quality assessment Med Care 1994 32(1):81 90 8277803
108 Simborg DW DRG creep: a new hospital-acquired disease N Engl J Med 1981 304(26):1602 4 7015136
109 Keeler EB, Kahn KL, Draper D, et al Changes in sickness at admission following the introduction of the prospective payment system JAMA 1990 264(15):1962 8 2120475
110 Hsia DC, Krushat WM, Fagan AB, et al Accuracy of diagnostic coding for Medicare patients under the prospective-payment system N Engl J Med 1988 318(6):352 355 3123929
111 Green J, Wintfeld N Report cards on cardiac surgeons. Assessing New York State's approach N Engl J Med 1995 332(18):1229 32 7700321
112 Hannan EL, Racz MJ, Jollis JG, et al Using Medicare claims data to assess provider quality for CABG surgery: does it work well enough? Health Serv Res 1997 31(6):659 78 9018210 1070152
113 Romano PS, Chan BK Risk-adjusting acute myocardial infarction mortality: are APR-DRGs the right tool? Health Serv Res 2000 34(7):1469 89 10737448 1975668
114 Goldfield N, Averill R On "risk-adjusting acute myocardial infarction mortality: are APR-DRGs the right tool"? [comment] Health Serv Res 2000 34(7):1491 5 discussion 1495 8 10737449 1975669
115 Jollis JG, Romano PS Pennsylvania's Focus on Heart Attack--grading the scorecard N Engl J Med 1998 338(14):983 7 9521989
116 O'Connor GT, Plume SK, Olmstead EM, et al Multivariate prediction of in-hospital mortality associated with coronary artery bypass graft surgery. Northern New England Cardiovascular Disease Study Group Circulation 1992 85(6):2110 8 1591830
117 O'Connor GT, Plume SK, Olmstead EM, et al A regional intervention to improve the hospital mortality associated with coronary artery bypass graft surgery. The Northern New England Cardiovascular Disease Study Group JAMA 1996 275(11):841 6 8596221
118 Hannan EL, Kilburn H, Jr., Racz M, et al Improving the outcomes of coronary artery bypass surgery in New York State JAMA 1994 271(10):761 6 8114213
119 Knaus WA, Draper EA, Wagner DP, et al An evaluation of outcome from intensive care in major medical centers Ann Intern Med 1986 104(3):410 8 3946981
120 Knaus WA, Wagner DP, Zimmerman JE, et al Variations in mortality and length of stay in intensive care units Ann Intern Med 1993 118(10):753 61 8470850
121 Fine MJ, Auble TE, Yealy DM, et al A prediction rule to identify low-risk patients with community-acquired pneumonia N Engl J Med 1997 336(4):243 50 8995086
122 Cooper GS, Chak A, Harper DL, et al Care of patients with upper gastrointestinal hemorrhage in academic medical centers: a community-based comparison Gastroenterology 1996 111(2):385 90 8690203
123 Krumholz HM, Chen J, Wang Y, et al Comparing AMI mortality among hospitals in patients 65 years of age and older: evaluating methods of risk adjustment Circulation 1999 99(23):2986 92 10368115
124 Luft H, Romano P, Remy L, et al. Second Report of the California Hospital Outcomes Project: Acute Myocardial Infarction. ,Office of Statewide Health Planning and Development.
125 Iezzoni LI, Ash AS, Shwartz M, et al Differences in procedure use, in-hospital mortality, and illness severity by gender for acute myocardial infarction patients: are answers affected by data source and severity measure? Med Care 1997 35(2):158 71 9017953
126 Hibbard JH, Jewett JJ, Legnini MW, et al Choosing a health plan: do large employers use the data? Health Aff (Millwood) 1997 16(6):172 80 9444825
127 Hibbard JH, Jewett JJ, Engelmann S, et al Can Medicare beneficiaries make informed choices? Health Aff (Millwood) 1998 17(6):181 93 9916368
128 Schneider EC, Epstein AM Use of public performance reports: a survey of patients undergoing cardiac surgery JAMA 1998 279(20):1638 42 9613914
129 Booske BC, Sainfort F, Hundt AS Eliciting consumer preferences for health plans Health Serv Res 1999 34(4):839 54 10536973 1089044
130 Rainwater JA, Romano PS, Antonius DM The California Hospital Outcomes Project: how useful is California's report card for quality improvement? Jt Comm J Qual Improv 1998 24(1):31 9 9494872
131 Romano PS, Rainwater JA, Antonius D Grading the graders: how hospitals in California and New York perceive and interpret their report cards Med Care 1999 37(3):295 305 10098573
132 Palmer RH, Louis TA, Peterson HF, et al What makes quality assurance effective? Results from a randomized, controlled trial in 16 primary care group practices Med Care 1996 34(9 Suppl):SS29 39 8792787
133 Duffy SQ, Farley DE Patterns of decline among inpatient procedures Public Health Rep 1995 110(6):674 81 8570816 1381805
134 Rutledge R Can medical school-affiliated hospitals compete with private hospitals in the age of managed care? An 11-state, population-based analysis of 351,201 patients undergoing cholecystectomy J Am Coll Surg 1997 185(3):207 17 9291395
135 Maynard C, Chapko MK, Every NR, et al Coronary angioplasty outcomes in the Healthcare Cost and Utilization Project, 1993-1994 Am J Cardiol 1998 81(7):848 52 9555773
136 Shepardson LB, Youngner SJ, Speroff T, et al Increased risk of death in patients with do-not-resuscitate orders Med Care 1999 37(8):727 37 10448716
137 Layde PM, Broste SK, Desbiens N, et al Generalizability of clinical studies conducted at tertiary care medical centers: a population-based analysis J Clin Epidemiol 1996 49(8):835 41 8699201
138 Hannan EL, Kilburn H, Jr., O'Donnell JF, et al Interracial access to selected cardiac procedures for patients hospitalized with coronary artery disease in New York State Med Care 1991 29(5):430 41 2020208
139 Buckle JM, Horn SD, Oates VM, et al Severity of illness and resource use differences among white and black hospitalized elderly Arch Intern Med 1992 152(8):1596 603 1497393
140 McBean AM, Gornick M Differences by race in the rates of procedures performed in hospitals for Medicare beneficiaries Health Care Financ Rev 1994 15(4):77 90 10172157
141 McBean AM, Warren JL, Babish JD Continuing differences in the rates of percutaneous transluminal coronary angioplasty and coronary artery bypass graft surgery between elderly black and white Medicare beneficiaries Am Heart J 1994 127(2):287 95 8296695
142 Williams JF, Zimmerman JE, Wagner DP, et al African-American and white patients admitted to the intensive care unit: is there a difference in therapy and outcome? Crit Care Med 1995 23(4):626 36 7712752
143 Phillips RS, Hamel MB, Teno JM, et al Race, resource use, and survival in seriously ill hospitalized adults. The SUPPORT Investigators J Gen Intern Med 1996 11(7):387 96 8842929
144 Romano PS, Campa DR, Rainwater JA Elective cervical discectomy in California: postoperative in-hospital complications and their risk factors Spine 1997 22(22):2677 92 9399456
145 Huber TS, Wang JG, Wheeler KG, et al Impact of race on the treatment for peripheral arterial occlusive disease J Vasc Surg 1999 30(3):417 25 10477634
146 Chen J, Radford MJ, Wang Y, et al. Do "America's Best Hospitals" perform better for acute myocardial infarction?. N Engl J Med. 1999;340:286-92. [pmid: 9920954].
147 Hartz AJ, Gottlieb MS, Kuhn EM, et al The relationship between adjusted hospital mortality and the results of peer review Health Serv Res 1993 27(6):765 77 8428812 1069912
148 Hsia DC, Ahern CA, Ritchie BP, et al Medicare reimbursement accuracy under the prospective payment system, 1985 to 1988 JAMA 1992 268(7):896 899 1640619
149 Cullen DJ, Bates DW, Small SD, et al The incident reporting system does not detect adverse drug events: a problem for quality improvement Jt Comm J Qual Improv 1995 21(10):541 8 8556111
150 Kohn L, Corrigan J, Donaldson M, et al., editors. To Err Is Human: Building a Safer Health System. Washington, D.C.: National Academy Press. 2000.
151 Silber JH, Rosenbaum PR, Schwartz JS, et al Evaluation of the complication rate as a measure of quality of care in coronary artery bypass graft surgery JAMA 1995 274(4):317 23 7609261
152 Silber JH, Rosenbaum PR, Ross RN. Comparing the contribution of predictors: which outcomes vary with hospital rather than patient characteristics?. J Am Stat Assoc. 1995;90:7-18.
153 Silber JH, Rosenbaum PR, Williams SV, et al. The relationship between choice of outcome measure and hospital rank in general surgical procedures: implications for quality assessment. Int J Qual Health Care. 1997;9:193-200. [pmid: 9209916].
154 Kahn KL, Brook RH, Draper D, et al Interpreting hospital mortality data. How can we proceed? JAMA 1988 260(24):3625 8 3057252
155 Mullins RJ, Mann NC, Hedges JR, et al Adequacy of hospital discharge status as a measure of outcome among injured patients JAMA 1998 279(21):1727 31 9624026
156 Sands K, Vineyard G, Platt R Surgical site infections occurring after hospital discharge J Infect Dis 1996 173(4):963 70 8603978
157 Sands K, Vineyard G, Livingston J, et al Efficient identification of postdischarge surgical site infections: use of automated pharmacy dispensing information, administrative data, and medical record information J Infect Dis 1999 179(2):434 41 9878028
158 Iezzoni LI, Mackiernan YD, Cahalane MJ, et al Screening inpatient quality using post-discharge events Med Care 1999 37(4):384 98 10213019
159 Omoigui NA, Miller DP, Brown KJ, et al Outmigration for coronary bypass surgery in an era of public dissemination of clinical outcomes Circulation 1996 93(1):27 33 8616936
160 Hannan EL, Siu AL, Kumar D, et al Assessment of coronary artery bypass graft surgery performance in New York. Is there a bias against taking high-risk patients? Med Care 1997 35(1):49 56 8998202
161 Petersen LA, Orav EJ, Teich JM, et al Using a computerized sign-out program to improve continuity of inpatient care and prevent adverse events Jt Comm J Qual Improv 1998 24(2):77 87 9547682
162 Information is good except when its bad. Stanford University Working Paper.
163 Marshall MN, Shekelle PG, Leatherman S, et al The public release of performance data: what do we expect to gain? A review of the evidence Jama 2000 283(14):1866 74 10770149
164 Olfson M, Marcus S, Sackeim HA, et al Use of ECT for the inpatient treatment of recurrent major depression Am J Psychiatry 1998 155(1):22 9 9433334
165 Meurer JR, Kuhn EM, George V, et al Charges for childhood asthma by hospital characteristics Pediatrics 1998 102(6):E7 0 9651459
166 Lanska DJ, Hartz AJ Measurement of quality in health care Neurology 1998 50(3):584 7 9521238
167 Lanska DJ, Kryscio RJ In-hospital mortality following carotid endarterectomy Neurology 1998 51(2):440 7 9710016
168 Schnitzler MA, Lambert DL, Mundy LM, et al Variations in healthcare measures by insurance status for patients receiving ventilator support Clin Perform Qual Health Care 1998 6(1):17 22 10177044
169 Niederman MS, McCombs JS, Unger AN, et al The cost of treating community-acquired pneumonia Clin Ther 1998 20(4):820 37 9737840
170 Zhao SZ, Wong JM, Davis MB, et al The cost of inpatient endometriosis treatment: an analysis based on the Healthcare Cost and Utilization Project Nationwide Inpatient Sample Am J Manag Care 1998 4(8):1127 34 10182888
171 Rentz AM, Halpern MT, Bowden R The impact of candidemia on length of hospital stay, outcome, and overall cost of illness Clin Infect Dis 1998 27(4):781 8 9798034
172 Ritchie JL, Maynard C, Chapko MK, et al Association between percutaneous transluminal coronary angioplasty volumes and outcomes in the Healthcare Cost and Utilization Project 1993-1994 Am J Cardiol 1999 83(4):493 7 10073849
173 Best AE Secondary data bases and their use in outcomes research: a review of the area resource file and the Healthcare Cost and Utilization Project J Med Syst 1999 23(3):175 81 10554733
174 Krumholz HM, Chen YT, Bradford WD, et al Variations in and correlates of length of stay in academic hospitals among patients with heart failure resulting from systolic dysfunction Am J Manag Care 1999 5(6):715 23 10538451
175 Seifeldin R, Hantsch JJ The economic burden associated with colon cancer in the United States Clin Ther 1999 21(8):1370 9 10485508
176 Williams GR, Jiang JG, Matchar DB, et al Incidence and occurrence of total (first-ever and recurrent) stroke Stroke 1999 30(12):2523 8 10582972
177 Kirsner RS, Yang DG, Kerdel FA Dermatologic disease accounts for a large number of hospital admissions annually J Am Acad Dermatol 1999 41(6):970 3 10570382
178 Bethesda (MD),National Library of Medicine.1985-Updated weekly.Available from: National Library of Medicine; BRS Information Technologies, McLean, VA; DIALOG information Services, Inc., Palo Alto, CA
179 Washington (DC),American Psychological Association.1887-Updated monthly (journals), 1987-current (books and chapters).Available from: American Psycological Association, Washinton DC; Ovid Technologies, New York, NY; Silverplatter Information, Norwood, MA
180 Oxford, England,Update Software, Ltd. Available from: Update Software, San Diego, CA.
181 The Netherlands,Elsevier Science Publishers B. V.1974-Updated weekly.Available from: Elsevier Science, Secondary Publishing Division, New York, NY
182 Ingber MJ The current state of risk adjustment technology for capitation J Ambulatory Care Manage 1998 21(4):1 28 10387435
183 Rosenbaum P, Rubin D. Reducing bias in observational studies using subclassification on the propensity score. J Am Stat Assoc. 1894;79:516-24.
184 Glazer J, McGuire T. Minimum variance optimal risk adjustment. American Economic Review. 1999. In Press.
185 Chamberlain G. Panel Data. In: Griliches Z, Intriligator M, editors. Handbook of Economics. New York: Elsevier Science. 1984:p. 1247-1318.
186 Economic Analysis. 2nd ed. New Jersey: Prentice Hall. 1997.
187 McClellan M, Staigner D. The quality of health care providers. National Bureau of Economic Research Working Paper #7327.
188 Manheim LM, Sohn MW, Feinglass J, et al Hospital vascular surgery volume and procedure mortality rates in California, 1982-1994 J Vasc Surg 1998 28(1):45 56 9685130
189 Hannan EL, Popp AJ, Tranmer B, et al Relationship between provider volume and mortality for carotid endarterectomies in New York state Stroke 1998 29(11):2292 7 9804636
190 Dudley RA, Johansen KL, Brand R, et al Selective referral to high-volume hospitals: estimating potentially avoidable deaths JAMA 2000 283(9):1159 66 10703778
191 Ryan TJ, Bauman WB, Kennedy JW, et al Guidelines for percutaneous transluminal coronary angioplasty. A report of the American Heart Association/American College of Cardiology Task Force on Assessment of Diagnostic and Therapeutic Cardiovascular Procedures (Committee on Percutaneous Transluminal Coronary Angioplasty) Circulation 1993 88(6):2987 3007 8252713
192 Kimmel SE, Berlin JA, Laskey WK The relationship between coronary angioplasty procedure volume and major complications Jama 1995 274(14):1137 42 7563484
193 Eagle KA, Guyton RA, Davidoff R, et al ACC/AHA Guidelines for Coronary Artery Bypass Graft Surgery: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Revise the 1991 Guidelines for Coronary Artery Bypass Graft Surgery). American College of Cardiology/American Heart Association J Am Coll Cardiol 1999 34(4):1262 347 10520819
194 Hannan EL, Racz M, Kavey RE, et al Pediatric cardiac surgery: the effect of hospital and surgeon volume on in-hospital mortality Pediatrics 1998 101(6):963 9 9606220
195 Hannan EL, Kilburn H, Jr., O'Donnell JF, et al A longitudinal analysis of the relationship between in-hospital mortality in New York State and the volume of abdominal aortic aneurysm surgeries performed Health Serv Res 1992 27(4):517 42 1399655 1069892
196 Kazmers A, Jacobs L, Perkins A, et al Abdominal aortic aneurysm repair in Veterans Affairs medical centers J Vasc Surg 1996 23(2):191 200 8637096
197 Pronovost PJ, Jenckes MW, Dorman T, et al Organizational characteristics of intensive care units related to outcomes of abdominal aortic surgery JAMA 1999 281(14):1310 7 10208147
198 Patti MG, Corvera CU, Glasgow RE, et al A hospital's annual rate of esophagectomy influences the operative mortality rate J Gastrointest Surg 1998 2(2):186 92 9834415
199 Glasgow RE, Mulvihill SJ Hospital volume influences outcome in patients undergoing pancreatic resection for cancer West J Med 1996 165(5):294 300 8993200 1303846
200 Localio AR, Hamory BH, Sharp TJ, et al Comparing hospital mortality in adult patients with pneumonia. A case study of statistical methods in a managed care program [see comments] Ann Intern Med 1995 122(2):125 32 7992987
201 Hannan EL, Kilburn H, Jr., Lindsey ML, et al Clinical versus administrative data bases for CABG surgery. Does it matter? Med Care 1992 30(10):892 907 1405795
202 Smith DW, Pine M, Bailey RC, et al Using clinical variables to estimate the risk of patient mortality Med Care 1991 29(11):1108 29 1943271
203 Krakauer H, Bailey RC, Skellan KJ, et al Evaluation of the HCFA model for the analysis of mortality following hospitalization Health Serv Res 1992 27(3):317 35 1500289 1069881
204 Landon B, Iezzoni LI, Ash AS, et al Judging hospitals by severity-adjusted mortality rates: the case of CABG surgery Inquiry 1996 33(2):155 66 8675279
205 Pine M, Jones B, Lou YB Laboratory values improve predictions of hospital mortality Int J Qual Health Care 1998 10(6):491 501 9928588
206 Sheiner LB, Easterling MJ, Mozes B, et al Laboratory data predicts survival post hospitalization J Clin Epidemiol 1991 44(12):1387 403 1753270
207 Roos LL, Sharp SM, Cohen MM, et al Risk adjustment in claims-based research: the search for efficient approaches J Clin Epidemiol 1989 42(12):1193 206 2585010
208 Averill RF, Muldoon JH, C.VJ, et al. The evolution of casemix measurement using diagnosis related groups (DRGs). 3M HIS working paper 5-98.
209 Burgess JF, Jr., Christiansen CL, Michalak SE, et al Medical profiling: improving standards and risk adjustments using hierarchical models J Health Econ 2000 19(3):291 309 10977193
210 Donaldson MS, editor. Measuring the Quality of Health Care. A Statement by the National Roundtable on Health Care Quality. Washington, D.C.: National Academy Press. 1999.
211 Palmer RH, Reilly MC Individual and institutional variables which may serve as indicators of quality of medical care Med Care 1979 17(7):693 717 379466
212 Shortell SM, LoGerfo JP Hospital medical staff organization and quality of care: results for myocardial infarction and appendectomy Med Care 1981 19(10):1041 55 7311636
213 Shortell SM, Hughes EF The effects of regulation, competition, and ownership on mortality rates among hospital inpatients N Engl J Med 1988 318(17):1100 7 3127713
214 Hartz AJ, Krakauer H, Kuhn EM, et al Hospital characteristics and mortality rates N Engl J Med 1989 321(25):1720 5 2594031
215 Kuhn EM, Hartz AJ, Gottlieb MS, et al The relationship of hospital characteristics and the results of peer review in six large states Med Care 1991 29(10):1028 38 1921522
216 Brennan TA, Hebert LE, Laird NM, et al Hospital characteristics associated with adverse events and substandard care JAMA 1991 265(24):3265 9 2046108
217 Keeler EB, Rubenstein LV, Kahn KL, et al Hospital characteristics and quality of care JAMA 1992 268(13):1709 14 1527880
218 Ayanian JZ, Weissman JS, Chasan-Taber S, et al Quality of care for two common illnesses in teaching and nonteaching hospitals Health Aff (Millwood) 1998 17(6):194 205 9916369
219 Taylor DH, Jr., Whellan DJ, Sloan FA Effects of admission to a teaching hospital on the cost and quality of care for Medicare beneficiaries N Engl J Med 1999 340(4):293 9 9920955
220 Carson SS, Stocking C, Podsadecki T, et al Effects of organizational change in the medical intensive care unit of a teaching hospital: a comparison of 'open' and 'closed' formats JAMA 1996 276(4):322 8 8656546
221 Stroke Unit Trialists' Collaboration.BMJ 1997 314(7088):1151 9 9146387 2126525
222 Kaste M, Palomaki H, Sarna S Where and how should elderly stroke patients be treated? A randomized trial Stroke 1995 26(2):249 53 7831697
223 Ronning OM, Guldvog B Stroke unit versus general medical wards, II: neurological deficits and activities of daily living: a quasi-randomized controlled trial Stroke 1998 29(3):586 90 9506597
224 Pestotnik SL, Classen DC, Evans RS, et al Implementing antibiotic practice guidelines through computer-assisted decision support: clinical and financial outcomes Ann Intern Med 1996 124(10):884 90 8610917
225 Bates DW, Leape LL, Cullen DJ, et al Effect of computerized physician order entry and a team intervention on prevention of serious medication errors JAMA 1998 280(15):1311 6 9794308
226 Evans RS, Pestotnik SL, Classen DC, et al A computer-assisted management program for antibiotics and other antiinfective agents N Engl J Med 1998 338(4):232 8 9435330
227 Hughes RG, Hunt SS, Luft HS Effects of surgeon volume and hospital volume on quality of care in hospitals Med Care 1987 25(6):489 503 3695658
228 Showstack JA, Rosenfeld KE, Garnick DW, et al Association of volume with outcome of coronary artery bypass graft surgery. Scheduled vs nonscheduled operations JAMA 1987 257(6):785 9 3492614
229 Kelly JV What do mortality studies reveal about hospital volume, teaching status, and ownership? Int J Technol Assess Health Care 1990 6(2):239 52 2203700
230 Farley DE, Ozminkowski RJ Volume-outcome relationships and in-hospital mortality: the effect of changes in volume over time Med Care 1992 30(1):77 94 1729589
231 Byrne MG, Giacomini JC Longitudinal comparison of outcomes for coronary angioplasty at low, medium and high volume hospitals in California for years 1988-1992 Circulation 1995 92(8 SUPPL.):
232 Byrne MG, Reitz BA Longitudinal comparison of outcomes for coronary artery bypass surgery at low, medium and high volume hospitals in California for years 1985-1991 Circulation 1995 92(8 SUPPL.):
233 Hannan EL, Siu AL, Kumar D, et al The decline in coronary artery bypass graft surgery mortality in New York State. The role of surgeon volume JAMA 1995 273(3):209 13 7807659
234 Lavernia CJ, Guzman JF Relationship of surgical volume to short-term mortality, morbidity, and hospital charges in arthroplasty J Arthroplasty 1995 10(2):133 40 7798093
235 Phillips KA, Luft HS, Ritchie JL The association of hospital volumes of percutaneous transluminal coronary angioplasty with adverse outcomes, length of stay, and charges in California Med Care 1995 33(5):502 14 7739274
236 Taylor HD, Dennis DA, Crane HS Relationship between mortality rates and hospital patient volume for Medicare patients undergoing major orthopaedic surgery of the hip, knee, spine, and femur J Arthroplasty 1997 12(3):235 42 9113536
237 McGrath PD, Wennberg DE, Malenka DJ, et al Operator volume and outcomes in 12,998 percutaneous coronary interventions. Northern New England Cardiovascular Disease Study Group J Am Coll Cardiol 1998 31(3):570 6 9502637
238 Glasgow RE, Showstack JA, Katz PP, et al The relationship between hospital volume and outcomes of hepatic resection for hepatocellular carcinoma Arch Surg 1999 134(1):30 5 9927127
239 Luft HS, Hunt SS, Maerki SC The volume-outcome relationship: practice-makes-perfect or selective- referral patterns? Health Serv Res 1987 22(2):157 82 3112042 1065430
240 Hamilton BH, Ho V Does practice make perfect? Examining the relationship between hospital surgical volume and outcomes for hip fracture patients in Quebec Med Care 1998 36(6):892 903 9630130
241 Luft HS, Garnick DW, Mark DH, et al Does quality influence choice of hospital? JAMA 1990 263(21):2899 906 2110985
242 Hamilton BH, Hamilton VH Estimating surgical volume--outcome relationships applying survival models: accounting for frailty and hospital fixed effects Health Econ 1997 6(4):383 95 9285231
243 Tepas JJ, 3rd, Patel JC, DiScala C, et al Relationship of trauma patient volume to outcome experience: can a relationship be defined? J Trauma 1998 44(5):827 30 9603084
244 Phillips KA, Luft HS The policy implications of using hospital and physician volumes as "indicators" of quality of care in a changing health care environment Int J Qual Health Care 1997 9(5):341 8 9394202
245 Finlayson SR, Birkmeyer JD, Tosteson AN, et al Patient preferences for location of care: implications for regionalization Med Care 1999 37(2):204 9 10024124
246 Roos NP, Black CD, Roos LL, et al A population-based approach to monitoring adverse outcomes of medical care Med Care 1995 33(2):127 38 7837821
247 Methods, patient characteristics, and progress Stroke 1991 22(6):711 20 2057968
248 Executive Committee for the Asymptomatic Carotid Atherosclerosis Study.JAMA 1995 273(18):1421 8 7723155
249 Holloway RG, Jr., Witter DM, Jr., Mushlin AI, et al Carotid endarterectomy trends in the patterns and outcomes of care at academic medical centers, 1990 through 1995 Arch Neurol 1998 55(1):25 32 9443708
250 Hsia DC, Moscoe LM, Krushat WM Epidemiology of carotid endarterectomy among Medicare beneficiaries: 1985-1996 update Stroke 1998 29(2):346 50 9472872
251 Tu JV, Hannan EL, Anderson GM, et al The fall and rise of carotid endarterectomy in the United States and Canada N Engl J Med 1998 339(20):1441 7 9811920
252 Barnett HJ, Meldrum HE, Eliasziw M The dilemma of surgical treatment for patients with asymptomatic carotid disease Ann Intern Med 1995 123(9):723 5 7574229
253 Gould DA, Birkmeyer JD Efficacy versus effectiveness of carotid endarterectomy Eff Clin Pract 1999 2(1):30 6 10346551
254 Benavente O, Moher D, Pham B Carotid endarterectomy for asymptomatic carotid stenosis: a meta- analysis BMJ 1998 317(7171):1477 80 9831572 28726
255 Warlow C Carotid endarterectomy for asymptomatic carotid stenosis. Better data, but the case is still not convincing BMJ 1998 317(7171):9831569
256 Mayo SW, Eldrup-Jorgensen J, Lucas FL, et al Carotid endarterectomy after NASCET and ACAS: a statewide study. North American Symptomatic Carotid Endarterectomy Trial. Asymptomatic Carotid Artery Stenosis Study J Vasc Surg 1998 27(6):1017 22 9652463
257 Hallett JW, Jr., Pietropaoli JA, Jr., Ilstrup DM, et al Comparison of North American Symptomatic Carotid Endarterectomy Trial and population-based outcomes for carotid endarterectomy J Vasc Surg 1998 27(5):845 50 9620136
258 Wennberg DE, Lucas FL, Birkmeyer JD, et al Variation in carotid endarterectomy mortality in the Medicare population: trial hospitals, volume, and patient characteristics JAMA 1998 279(16):1278 81 9565008
259 Huber TS, Wheeler KG, Cuddeback JK, et al Effect of the Asymptomatic Carotid Atherosclerosis Study on carotid endarterectomy in Florida Stroke 1998 29(6):1099 105 9626278
260 Chaturvedi S Is the increasing volume of carotid endarterectomy justified? [letter] Stroke 1998 29(11):2444 6 9804662
261 Keller RB, Atlas SJ, Soule DN, et al Relationship between rates and outcomes of operative treatment for lumbar disc herniation and spinal stenosis J Bone Joint Surg Am 1999 81(6):752 62 10391540
262 Leape LL, Hilborne LH, Park RE, et al The appropriateness of use of coronary artery bypass graft surgery in New York State Jama 1993 269(6):753 60 8423656
263 Bernstein SJ, McGlynn EA, Siu AL, et al The appropriateness of hysterectomy. A comparison of care in seven health plans. Health Maintenance Organization Quality of Care Consortium [see comments] Jama 1993 269(18):2398 402 8479066
264 Bernstein SJ, Hilborne LH, Leape LL, et al The appropriateness of use of coronary angiography in New York State Jama 1993 269(6):766 9 8423658
265 Soumerai SB, Ross-Degnan D, Fortess EE, et al Determinants of change in Medicaid pharmaceutical cost sharing: does evidence affect policy? Milbank Q 1997 75(1):11 34 9063299
266 Chassin MR Appropriate use of carotid endarterectomy [editorial; comment] [see comments] N Engl J Med 1998 339(20):1468 71 9811924
267 Kravitz RL, Laouri M, Kahan JP, et al Validity of criteria used for detecting underuse of coronary revascularization JAMA 1995 274(8):632 8 7637144
268 Chassin MR, Brook RH, Park RE, et al Variations in the use of medical and surgical services by the Medicare population N Engl J Med 1986 314(5):285 90 3510394
269 Shekelle PG, Kahan JP, Bernstein SJ, et al The reproducibility of a method to identify the overuse and underuse of medical procedures N Engl J Med 1998 338(26):1888 95 9637810
270 Asaph JW, Janoff K, Wayson K, et al Carotid endarterectomy in a community hospital: a change in physicians' practice patterns Am J Surg 1991 161(5):616 8 2031548
271 Brott TG, Labutta RJ, Kempczinski RF Changing patterns in the practice of carotid endarterectomy in a large metropolitan area Jama 1986 255(19):2609 12 3701975
272 Geller SE, Burns LR, Brailer DJ The impact of nonclinical factors on practice variations: the case of hysterectomies Health Serv Res 1996 30(6):729 50 8591927 1070090
273 Marshak JD, Cooperman BS, Fried WB, et al Prognostic indicators for successful vaginal birth after cesarean delivery Obstet Gynecol 2000 95(4 Suppl 1):S3 8
274 Brook RHI. The RAND/UCLA appropriateness method. In: McCormick KA, Moore SR, Siegel RA, editors. Clinical Practice Guideline Development: Methodology Perspectives, AHCPR Pub. No. 95-0009. Rockville, MD: Public Health Service. 1994:p. 59-70.
275 Billings J, Zeitel L, Lukomnik J, et al Impact of socioeconomic status on hospital use in New York City Health Aff (Millwood) 1993 12(1):162 73 8509018
276 Weissman JS, Gatsonis C, Epstein AM Rates of avoidable hospitalization by insurance status in Massachusetts and Maryland Jama 1992 268(17):2388 94 1404795
277 Gadomski A, Jenkins P, Nichols M Impact of a Medicaid primary care provider and preventive care on pediatric hospitalization Pediatrics 1998 101(3):E 1 9481020
278 Columbia: South Carolina State Budget and Control Board, Office of Research and Statistics. 1995.
279 Schreiber S, Zielinski T The meaning of ambulatory care sensitive admissions: urban and rural perspectives J Rural Health 1997 13(4):276 84 10177149
280 Culler SD, Parchman ML, Przybylski M Factors related to potentially preventable hospitalizations among the elderly Med Care 1998 36(6):804 17 9630122
281 Pappas G, Hadden WC, Kozak LJ, et al Potentially avoidable hospitalizations: inequalities in rates between US socioeconomic groups Am J Public Health 1997 87(5):811 6 9184511 1381055
282 Blustein J, Hanson K, Shea S Preventable hospitalizations and socioeconomic status Health Aff (Millwood) 1998 17(2):177 89 9558796
283 Billings J, Anderson GM, Newman LS Recent findings on preventable hospitalizations Health Aff (Millwood) 1996 15(3):239 49 8854530
284 Bindman AB, Grumbach K, Osmond D, et al Preventable hospitalizations and access to health care JAMA 1995 274(4):305 11 7609259
285 Parchman ML, Culler SD Preventable hospitalizations in primary care shortage areas. An analysis of vulnerable Medicare beneficiaries Arch Fam Med 1999 8(6):487 91 10575386
286 Parchman ML, Culler S Primary care physicians and avoidable hospitalizations J Fam Pract 1994 39(2):123 8 8057062
287 McConnochie KM, Roghmann KJ, Liptak GS Socioeconomic variation in discretionary and mandatory hospitalization of infants: an ecologic analysis Pediatrics 1997 99(6):774 84 9164768
288 Josephson GW, Karcz A The impact of physician economic incentives on admission rates of patients with ambulatory sensitive conditions: an analysis comparing two managed care structures and indemnity insurance Am J Manag Care 1997 3(1):49 56 10169249
289 Chassin MR, Park RE, Lohr KN, et al Differences among hospitals in Medicare patient mortality Health Serv Res 1989 24(1):1 31 2654083 1065550
290 Beguin C, France FR, Ninane J Systematic analysis of in-patients' circumstances and causes of death: a tool to improve quality of care Int J Qual Health Care 1997 9(6):427 33 9466178
291 Dubois RW, Brook RH Preventable deaths: who, how often, and why? Ann Intern Med 1988 109(7):582 9 3421565
292 Rosenthal GE, Quinn L, Harper DL Declines in hospital mortality associated with a regional initiative to measure hospital performance Am J Med Qual 1997 12(2):103 12 9161057
293 HCUPnet, Healthcare Cost and Utilization Project, Agency for Healthcare Reserach and Quality, Rockville, MD.
294 Pearce WH, Parker MA, Feinglass J, et al The importance of surgeon volume and training in outcomes for vascular surgical procedures J Vasc Surg 1999 29(5):768 76 10231626
295 Sollano JA, Gelijns AC, Moskowitz AJ, et al Volume-outcome relationships in cardiovascular operations: New York State, 1990-1995 J Thorac Cardiovasc Surg 1999 117(3):419 28 10047643
296 Dardik A, Lin JW, Gordon TA, et al Results of elective abdominal aortic aneurysm repair in the 1990s: A population-based analysis of 2335 cases J Vasc Surg 1999 30(6):985 95 10587382
297 Owings MF, Kozak LJ Ambulatory and inpatient procedures in the United States, 1996 Vital Health Stat 13 1998(139):1 119
298 Khuri SF, Daley J, Henderson W, et al Relation of surgical volume to outcome in eight common operations: results from the VA National Surgical Quality Improvement Program Ann Surg 1999 230(3):414 29 10493488 1420886
299 Rutledge R, Oller DW, Meyer AA, et al A statewide, population-based time-series analysis of the outcome of ruptured abdominal aortic aneurysm Ann Surg 1996 223(5):492 502 8651740 1235169
300 Katz DJ, Stanley JC, Zelenock GB Operative mortality rates for intact and ruptured abdominal aortic aneurysms in Michigan: an eleven-year statewide experience J Vasc Surg 1994 19(5):804 15 discussion 816 7 8170034
301 Wen SW, Simunovic M, Williams JI, et al Hospital volume, calendar age, and short term outcomes in patients undergoing repair of abdominal aortic aneurysms: the Ontario experience, 1988-92 J Epidemiol Community Health 1996 50(2):207 13 8762390 1060254
302 Amundsen S, Skjaerven R, Trippestad A, et al Abdominal aortic aneurysms. Is there an association between surgical volume, surgical experience, hospital type and operative mortality? Members of the Norwegian Abdominal Aortic Aneurysm Trial Acta Chir Scand 1990 156(4):323 7 discussion 327 8 2190439
303 Kantonen I, Lepantalo M, Brommels M, et al Mortality in ruptured abdominal aortic aneurysms. The Finnvasc Study Group Eur J Vasc Endovasc Surg 1999 17(3):208 12 10092892
304 Pacific Business Group on Health.
305
306 The Asymptomatic Carotid Endarterectomy Trial Collaborators. Study design for randomized prospective trial of carotid endarterectomy for asymtomatic atherosclerosis. Stroke. 1989;20:844-849. [pmid: 2665205].
307 North American Symptomatic Carotid Endarterectomy Trial Collaborators.N Engl J Med 1991 325(7):445 53 1852179
308 Biller J, Feinberg WM, Castaldo JE, et al Guidelines for carotid endarterectomy: a statement for healthcare professionals from a Special Writing Group of the Stroke Council, American Heart Association Circulation 1998 97(5):501 9 9490248
309 Owings MF, Lawrence L Detailed diagnoses and procedures, National Hospital Discharge Survey, 1997 Vital Health Stat 13 1999(145):1 157
310 Karp HR, Flanders WD, Shipp CC, et al Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome Stroke 1998 29(1):46 52 9445327
311 Fisher ES, Malenka DJ, Solomon NA, et al Risk of carotid endarterectomy in the elderly Am J Public Health 1989 79(12):1617 20 2817189 1349764
312 Edwards WH, Morris JA, Jr., Jenkins JM, et al Evaluating quality, cost-effective health care. Vascular database predicated on hospital discharge abstracts Ann Surg 1991 213(5):433 8 2025063 1358467
313 Kantonen I, Lepantalo M, Salenius JP, et al Mortality in abdominal aortic aneurysm surgery--the effect of hospital volume, patient mix and surgeon's case load Eur J Vasc Endovasc Surg 1997 14(5):375 9 9413378
314 Barnett HJ, Taylor DW, Eliasziw M, et al Benefit of carotid endarterectomy in patients with symptomatic moderate or severe stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators N Engl J Med 1998 339(20):1415 25 9811916
315 Crawford FA, Jr., Anderson RP, Clark RE, et al Volume requirements for cardiac surgery credentialing: a critical examination. The Ad Hoc Committee on Cardiac Surgery Credentialing of The Society of Thoracic Surgeons [see comments] Ann Thorac Surg 1996 61(1):12 6 8561536
316 Kozak LJ, Lawrence L National hospital discharge survey: annual summary, 1997 Vital Health Stat 13 1999(144):i iv, 1-46
317 Gray D, Hampton JR, Bernstein SJ, et al Audit of coronary angiography and bypass surgery [see comments] Lancet 1990 335(8701):1317 20 1971385
318 Pacific Business Group on Health.
319 Sowden AJ, Deeks JJ, Sheldon TA Volume and outcome in coronary artery bypass graft surgery: true association or artefact? [see comments] Bmj 1995 311(6998):151 5 7613425 2550219
320 Shroyer AL, Marshall G, Warner BA, et al No continuous relationship between Veterans Affairs hospital coronary artery bypass grafting surgical volume and operative mortality Ann Thorac Surg 1996 61(1):17 20 8561546
321 Kelly JV, Hellinger FJ Physician and hospital factors associated with mortality of surgical patients Med Care 1986 24(9):785 800 3762245
322 Gordon TA, Bowman HM, Bass EB, et al Complex gastrointestinal surgery: impact of provider experience on clinical and economic outcomes J Am Coll Surg 1999 189(1):46 56 10401740
323 Matthews HR, Powell DJ, McConkey CC Effect of surgical experience on the results of resection for oesophageal carcinoma Br J Surg 1986 73(8):621 3 3742172
324 Lieberman MD, Kilburn H, Lindsey M, et al Relation of perioperative deaths to hospital volume among patients undergoing pancreatic resection for malignancy Ann Surg 1995 222(5):638 45 7487211 1234991
325 Sosa JA, Bowman HM, Gordon TA, et al Importance of hospital volume in the overall management of pancreatic cancer Ann Surg 1998 228(3):429 38 9742926 1191507
326 Simunovic M, To T, Theriault M, et al Relation between hospital surgical volume and outcome for pancreatic resection for neoplasm in a publicly funded health care system [see comments] Cmaj 1999 160(5):643 8 10101998 1230109
327 Neoptolemos JP, Russell RC, Bramhall S, et al Low mortality following resection for pancreatic and periampullary tumours in 1026 patients: UK survey of specialist pancreatic units. UK Pancreatic Cancer Group [see comments] Br J Surg 1997 84(10):1370 6 9361591
328 Birkmeyer JD, Finlayson SR, Tosteson AN, et al Effect of hospital volume on in-hospital mortality with pancreaticoduodenectomy Surgery 1999 125(3):250 6 10076608
329 Wade TP, Halaby IA, Stapleton DR, et al Population-based analysis of treatment of pancreatic cancer and Whipple resection: Department of Defense hospitals, 1989-1994 Surgery 1996 120(4):680 5 discussion 686 7 8862378
330 Edge SB, Schmieg RE, Jr., Rosenlof LK, et al Pancreas cancer resection outcome in American University centers in 1989-1990 Cancer 1993 71(11):3502 8 8098265
331 Gordon TA, Bowman HM, Tielsch JM, et al Statewide regionalization of pancreaticoduodenectomy and its effect on in-hospital mortality Ann Surg 1998 228(1):71 8 9671069 1191430
332 Jenkins KJ, Newburger JW, Lock JE, et al In-hospital mortality for surgical repair of congenital heart defects: preliminary observations of variation by hospital caseload Pediatrics 1995 95(3):323 30 7862467
333 Hirshfeld JW, Jr., Ellis SG, Faxon DP Recommendations for the assessment and maintenance of proficiency in coronary interventional procedures: Statement of the American College of Cardiology J Am Coll Cardiol 1998 31(3):722 43 9502660
334 Ryan TJ, Klocke FJ, Reynolds WA Clinical competence in percutaneous transluminal coronary angioplasty. A statement for physicians from the ACP/ACC/AHA Task Force on Clinical Privileges in Cardiology J Am Coll Cardiol 1990 15(7):1469 74 2345226
335 Ritchie JL, Phillips KA, Luft HS Coronary angioplasty. Statewide experience in California Circulation 1993 88(6):2735 43 8252686
336 Shook TL, Sun GW, Burstein S, et al Comparison of percutaneous transluminal coronary angioplasty outcome and hospital costs for low-volume and high-volume operators Am J Cardiol 1996 77(5):331 6 8602558
337 Jollis JG, Peterson ED, DeLong ER, et al The relation between the volume of coronary angioplasty procedures at hospitals treating Medicare beneficiaries and short-term mortality N Engl J Med 1994 331(24):1625 9 7969344
338 Malenka DJ, McGrath PD, Wennberg DE, et al The relationship between operator volume and outcomes after percutaneous coronary interventions in high volume hospitals in 1994- 1996: the northern New England experience. Northern New England Cardiovascular Disease Study Group J Am Coll Cardiol 1999 34(5):1471 80 10551694
339 Menard MK Cesarean delivery rates in the United States. The 1990s Obstet Gynecol Clin North Am 1999 26(2):275 86 10399761
340 Parrish KM, Holt VL, Easterling TR, et al Effect of changes in maternal age, parity, and birth weight distribution on primary cesarean delivery rates JAMA 1994 271(6):443 7 8295319
341 Bethesda: United States Department of Health and Human Services National Institutes of Health; 1981Report No.: DHHS publicaton no. [NIH] 82-2067
342 Elixhauser A, Steiner CA. Most Common Diagnoses and Procedures in U. S. Community Hospitals 1996 Summary HCUP Research Note. ,Agency for Health Care Policy and Research Rockville MD.
343 Vaginal Delivery After a Previous Cesarean Birth. Washington, D. C. The American College of Obstetricians and Gynecologists. 1994 October. Report No.: 143.
344 Goyert GL, Bottoms SF, Treadwell MC, et al The physician factor in cesarean birth rates [see comments] N Engl J Med 1989 320(11):706 9 2922015
345 Berkowitz GS, Fiarman GS, Mojica MA, et al Effect of physician characteristics on the cesarean birth rate [see comments] Am J Obstet Gynecol 1989 161(1):146 9 2750795
346 DeMott RK, Sandmire HF The Green Bay cesarean section study. I. The physician factor as a determinant of cesarean birth rates Am J Obstet Gynecol 1990 162(6):1593 9 discussion 1599 602 2360593
347 Burns LR, Geller SE, Wholey DR The effect of physician factors on the cesarean section decision Med Care 1995 33(4):365 82 7731278
348 Guillemette J, Fraser WD Differences between obstetricians in caesarean section rates and the management of labour Br J Obstet Gynaecol 1992 99(2):105 8 1554658
349 Tussing AD, Wojtowycz MA The cesarean decision in New York State, 1986. Economic and noneconomic aspects Med Care 1992 30(6):529 40 1593918
350 Jessee WF, Nickerson CW, Grant WS Assessing medical practices through PSRO cooperative studies, an evaluation of Cesarean births in nine PSRO areas Med Care 1982 20(1):75 84 7200561
351 Placek PJ, Taffel SM Recent patterns in cesarean delivery in the United States Obstet Gynecol Clin North Am 1988 15(4):607 27 3226670
352 Gould JB, Davey B, Stafford RS Socioeconomic differences in rates of cesarean section [see comments] N Engl J Med 1989 321(4):233 9 2747759
353 Stafford RS Cesarean section use and source of payment: an analysis of California hospital discharge abstracts Am J Public Health 1990 80(3):313 5 2305912 1404683
354 Stafford RS The impact of nonclinical factors on repeat cesarean section [see comments] Jama 1991 265(1):59 63 1984126
355 Haas JS, Udvarhelyi S, Epstein AM The effect of health coverage for uninsured pregnant women on maternal health and the use of cesarean section [see comments] Jama 1993 270(1):61 4 8510298
356 Stafford RS, Sullivan SD, Gardner LB Trends in cesarean section use in California, 1983 to 1990 Am J Obstet Gynecol 1993 168(4):1297 302 8475978
357 Keller EB, Park RE, Bell RM, et al Adjusting cesarean delivery rates for case mix Health Serv Res 1997 43(4):511 528 9327816
358 Aron DC, Harper DL, Shepardson LB, et al Impact of risk-adjusting cesarean delivery rates when reporting hospital performance JAMA 1998 279(24):1968 72 9643860
359 Bailit JL, Dooley SL, Peaceman AN Risk adjustment for interhospital comparison of primary cesarean rates Obstet Gynecol 1999 93(6):1025 30 10362175
360 Glantz JC Cesarean delivery risk adjustment for regional interhospital comparisons American Journal of Obstetrics and Gynecology 1999 181(6):1425 31 10601924
361 Gregory KD, Ramicone E, Chan L, et al Cesarean deliveries for medicaid patients: a comparison in public and private hospitals in Los Angeles county Am J Obstet Gynecol 1999 180(5):1177 84 10329874
362 Anderson GM, Lomas J Determinants of the increasing cesarean birth rate. Ontario data 1979 to 1982 N Engl J Med 1984 311(14):887 92 6472401
363 Henry OA, Gregory KD, Hobel CJ, et al Using ICD-9 codes to identify indications for primary and repeat cesarean sections: agreement with clinical records American Journal of Public Health 1995 85(8 Pt 1):1143 6 7625515 1615835
364 Gifford DS, Morton SC, Fiske M, et al A meta-analysis of infant outcomes after breech delivery Obstet Gynecol 1995 85(6):1047 54 7770253
365 Sachs BP, Kobelin C, Castro MA, et al The risks of lowering the cesarean-delivery rate N Engl J Med 1999 340(1):54 7 9878648
366 Lagrew DC, Jr., Adashek JA Lowering the cesarean section rate in a private hospital: comparison of individual physicians' rates, risk factors, and outcomes Am J Obstet Gynecol 1998 178(6):1207 14 9662303
367 Sandmire HF, DeMott RK The Green Bay cesarean section study. IV. The physician factor as a determinant of cesarean birth rates for the large fetus Am J Obstet Gynecol 1996 174(5):1557 64 9065129
368 Washington, D. C.: National Committee for Quality Assurance;1995
369 Maryland Hospital Association.
370 University Hospital Consortium.
371 Florida Agency for Health Care Administration.
372
373 Michigan Hospital Association.
374
375 Virginia Health Information.
376 CHMIS.
377 HealthGrades.com.
378 Kelly H. Under what circumstances is it advisable to remove the veriform appendix when the abdomen is opened for other reasons. JAMA. 1902;39:1014-1021.
379 O'Malley VP, Finch DR, Powley PH Wound sepsis after cholecystectomy. Influence of incidental appendectomy J Clin Gastroenterol 1986 8(4):435 7 3760520
380 Strom PR, Turkleson ML, Stone HH Safety of incidental appendectomy Am J Surg 1983 145(6):819 22 6859420
381 Ikard RW Prospective analysis of the effect of incidental appendectomy on infection rate after cholecystectomy South Med J 1987 80(3):292 5 3824009
382 Pollock AV, Evans M Wound sepsis after cholecystectomy: effect of incidental appendicectomy Br Med J 1977 1(6052):20 2 831968 1603617
383 Warren JL, Penberthy LT, Addiss DG, et al Appendectomy incidental to cholecystectomy among elderly Medicare beneficiaries Surg Gynecol Obstet 1993 177(3):288 94 8356501
384 Wen SW, Hernandez R, Naylor CD Pitfalls in nonrandomized outcomes studies. The case of incidental appendectomy with open cholecystectomy Jama 1995 274(21):1687 91 7474273
385 Andrew MH, Roty AR, Jr Incidental appendectomy with cholecystectomy: is the increased risk justified? Am Surg 1987 53(10):553 7 3674597
386 Fisher KS, Ross DS Guidelines for therapeutic decision in incidental appendectomy Surg Gynecol Obstet 1990 171(1):95 8 2193415
387 Snyder TE, Selanders JR Incidental appendectomy--yes or no? A retrospective case study and review of the literature Infect Dis Obstet Gynecol 1998 6(1):30 7 9678145 1784768
388 Wolff BG Current status of incidental surgery Dis Colon Rectum 1995 38(4):435 41 7720456
389 Nockerts SR, Detmer DE, Fryback DG Incidental appendectomy in the elderly? No Surgery 1980 88(2):301 6 7394710
390 Neulander EZ, Hawke CK, Soloway MS Incidental appendectomy during radical cystectomy: an interdepartmental survey and review of the literature Urology 2000 56(2):241 4 10925086
391 Hill JA, Miranda AA, Keim SG, et al Value of right-sided cardiac catheterization in patients undergoing left-sided cardiac catheterization for evaluation of coronary artery disease Am J Cardiol 1990 65(9):590 3 2309628
392 Shanes JG, Stein MA, Dierenfeldt BJ, et al The value of routine right heart catheterization in patients undergoing coronary arteriography Am Heart J 1987 113(5):1261 3 3578026
393 Friedman HS Right-heart catheterization in coronary artery disease Angiology 1978 29(12):878 87 742727
394 Barron JT, Ruggie N, Uretz E, et al Findings on routine right heart catheterization in patients with suspected coronary artery disease Am Heart J 1988 115(6):1193 8 3376836
395 Pepine CJ, Allen HD, Bashore TM, et al ACC/AHA guidelines for cardiac catheterization and cardiac catheterization laboratories. American College of Cardiology/American Heart Association Ad Hoc Task Force on Cardiac Catheterization Circulation 1991 84(5):2213 47 1934395
396 Health Care Finiancing Administration's Medicare Quality of Care Report of Surveillance Measures.
397 Hall M, Popovic J. 1998 summary: National Hospital Discharge Survey. Advance Data from Vital and Health Statistics. 2000;316.
398 Malone ML, Bajwa TK, Battiola RJ, et al Variation among cardiologists in the utilization of right heart catheterization at time of coronary angiography [see comments] Cathet Cardiovasc Diagn 1996 37(2):125 30 8808065
399 Health Care Financing Administration.
400 A Pillar of Quality:The Medicare Peer Review Organization/Quality Improvement Organization Program.
401 Bing ML, Abel RL, Lee LJ, et al Medical necessity for right heart catheterization Tex Heart Inst J 1997 24(2):109 13 9205984 325413
402 Fortune GJ, Schiffel F, Jr., Elder S MPCRF: the Right Heart Catheterization Cooperative project Mo Med 1996 93(10):657 61 8942190
403 Gold JA Decreasing the rate of bilateral cardiac catheterization Wis Med J 1995 94(10):569 70 8560915
404 Malach M, Imperato PJ, Nenner RP, et al Impact of an educational program on bilateral heart catheterization practice patterns Am J Med Qual 1998 13(4):213 22 9833334
405 Imperato PJ, Malach M, Nenner RP, et al Concurrent improvements in ambulatory cardiac catheterization practices following inpatient interventions J Ambulatory Care Manage 1999 22(2):1 8 10387582
406 Repeat Cesarean Brith. In. Cesarean Childbirth. Wahington D.C.: US Government Printing Office. 1991:p. 351-74.
407 Phelan JP, Clark SL, Diaz F, et al Vaginal birth after cesarean Am J Obstet Gynecol 1987 157(6):1510 5 3425654
408 Rosen MG, Dickinson JC, Westhoff CL Vaginal birth after cesarean: a meta-analysis of morbidity and mortality Obstet Gynecol 1991 77(3):465 70 1825136
409 Flamm BL, Newman LA, Thomas SJ, et al Vaginal birth after cesarean delivery: results of a 5-year multicenter collaborative study Obstet Gynecol 1990 76(5 Pt 1):750 4 2216218
410 Flamm BL, Goings JR, Liu Y, et al Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study Obstet Gynecol 1994 83(6):927 32 8190433
411 Cowan RK, Kinch RA, Ellis B, et al Trial of labor following cesarean delivery Obstet Gynecol 1994 83(6):933 6 8190434
412 Miller DA, Diaz FG, Paul RH Vaginal birth after cesarean: a 10-year experience Obstet Gynecol 1994 84(2):255 8 8041542
413 Joseph GF, Jr., Stedman CM, Robichaux AG Vaginal birth after cesarean section: the impact of patient resistance to a trial of labor Am J Obstet Gynecol 1991 164(6 Pt 1):1441 4 discussion 1444 7 2048590
414 Kline J, Arias F Analysis of factors determining the selection of repeated cesarean section or trial of labor in patients with histories of prior cesarean delivery J Reprod Med 1993 38(4):289 92 8501737
415 Miller ES, Partezana J, Montgomery RL Vaginal birth after cesarean: a 5-year experience in a family practice residency program J Am Board Fam Pract 1995 8(5):357 60 7484222
416 Roberts RG, Bell HS, Wall EM, et al Trial of labor or repeated cesarean section. The woman's choice Arch Fam Med 1997 6(2):120 5 9075445
417 Al-Mufti R, McCarthy A, Fisk NM Obstetricians' personal choice and mode of delivery [letter] [see comments] Lancet 1996 347(9000):
418 Clark SL, Scott JR, Porter TF, et al Is vaginal birth after cesarean less expensive than repeat cesarean delivery? Am J Obstet Gynecol 2000 182(3):599 602 10739514
419 Jones RO, Nagashima AW, Hartnett-Goodman MM, et al Rupture of low transverse cesarean scars during trial of labor [see comments] Obstet Gynecol 1991 77(6):815 7 2030848
420 Scott JR Mandatory trial of labor after cesarean delivery: an alternative viewpoint [see comments] Obstet Gynecol 1991 77(6):811 4 2030847
421 McMahon MJ, Luther ER, Bowes WA, Jr., et al Comparison of a trial of labor with an elective second cesarean section N Engl J Med 1996 335(10):689 95 8703167
422 Hook B, Kiwi R, Amini SB, et al Neonatal morbidity after elective repeat cesarean section and trial of labor Pediatrics 1997 100(3 Pt 1):348 53 9282704
423 Caughey AB, Shipp TD, Repke JT, et al Trial of labor after cesarean delivery: the effect of previous vaginal delivery Am J Obstet Gynecol 1998 179(4):938 41 9790374
424 Gregory KD, Korst LM, Cane P, et al Vaginal birth after cesarean and uterine rupture rates in California Obstet Gynecol 1999 94(6):985 9 10576187
425 MMWR Morb Mortal Wkly Rep 2000 49(12):245 8 10774544
426 Obara H, Minakami H, Koike T, et al Vaginal birth after cesarean delivery: results in 310 pregnancies J Obstet Gynaecol Res 1998 24(2):129 34 9631601
427 Rageth JC, Juzi C, Grossenbacher H Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions Obstet Gynecol 1999 93(3):332 7 10074973
428 Lancet 1997 349(9055):81 5
429 Green DC, Moore JM, Adams MM, et al Are we underestimating rates of vaginal birth after previous cesarean birth? The validity of delivery methods from birth certificates Am J Epidemiol 1998 147(6):581 6 9521185
430 King DE, Lahiri K Socioeconomic factors and the odds of vaginal birth after cesarean delivery JAMA 1994 272(7):524 9 8046806
431 Pollard JK, Capeless EL Cesarean deliveries at a university hospital: analysis of rates and indications Am J Perinatol 1997 14(5):245 8 9259936
432 Lieberman E, Lang JM, Heffner LJ, et al Assessing the role of case mix in cesarean delivery rates Obstet Gynecol 1998 92(1):1 7 9649082
433 Clark SL, Xu W, Porter TF, et al Institutional influences on the primary cesarean section rate in Utah, 1992 to 1995 Am J Obstet Gynecol 1998 179(4):841 5 9790356
434 Pasternak DP, Pine M, Nolan K, et al Risk-adjusted measurement of primary cesarean sections: reliable assessment of the quality of obstetrical services Qual Manag Health Care 1999 8(1):47 54 10662103
435 Clarke SC, Taffel SM State variation in rates of cesarean and VBAC delivery: 1989 and 1993 Stat Bull Metrop Insur Co 1996 77(1):28 36 8744893
436 Gregory KD, Henry OA, Gellens AJ, et al Repeat cesareans: how many are elective? Obstet Gynecol 1994 84(4):574 8 8090395
437 Keeler EB, Park RE, Bell RM, et al Adjusting cesarean delivery rates for case mix Health Serv Res 1997 32(4):511 28 9327816 1070208
438 Goldman G, Pineault R, Bilodeau H, et al Effects of patient, physician and hospital characteristics on the likelihood of vaginal birth after previous cesarean section in Quebec CMAJ 1990 143(10):1017 24 2224667 1452488
439 Oleske DM, Glandon GL, Giacomelli GJ, et al The cesarean birth rate: influence of hospital teaching status Health Serv Res 1991 26(3):325 37 1869443 1069828
440 Kazandjian VA, Lied TR Cesarean section rates: effects of participation in a performance measurement project Jt Comm J Qual Improv 1998 24(4):187 96 9589331
441 Gregory KD, Hackmeyer P, Gold L, et al Using the continuous quality improvement process to safely lower the cesarean section rate Jt Comm J Qual Improv 1999 25(12):619 29 10605652
442 Bickell NA, Zdeb MS, Applegate MS, et al Effect of external peer review on cesarean delivery rates: a statewide program Obstet Gynecol 1996 87(5 Pt 1):664 7 8677064
443 Joint Commission on Accreditation of HealthCare Organizations.
444 A prospective analysis of 1518 laparoscopic cholecystectomies. NEJM. 1991;324:1073-1078. [pmid: 1826143].
445 Karayiannakis AJ, Makri GG, Mantzioka A, et al Postoperative pulmonary function after laparoscopic and open cholecystectomy Br J Anaesth 1996 77(4):448 52 8942326
446 Berggren U, Gordh T, Grama D, et al Laparoscopic versus open cholecystectomy: hospitalization, sick leave, analgesia and trauma responses [see comments] Br J Surg 1994 81(9):1362 5 7953415
447 Barkun JS, Barkun AN, Sampalis JS, et al Randomised controlled trial of laparoscopic versus mini cholecystectomy. The McGill Gallstone Treatment Group [see comments] Lancet 1992 340(8828):1116 9 1359210
448 Trondsen E, Reiertsen O, Andersen OK, et al Laparoscopic and open cholecystectomy. A prospective, randomized study Eur J Surg 1993 159(4):217 21 8102542
449 McGinn FP, Miles AJ, Uglow M, et al Randomized trial of laparoscopic cholecystectomy and mini- cholecystectomy [see comments] Br J Surg 1995 82(10):1374 7 7489170
450 McMahon AJ, Russell IT, Baxter JN, et al Laparoscopic versus minilaparotomy cholecystectomy: a randomised trial [see comments] Lancet 1994 343(8890):135 8 7904002
451 McMahon AJ, Russell IT, Ramsay G, et al Laparoscopic and minilaparotomy cholecystectomy: a randomized trial comparing postoperative pain and pulmonary function Surgery 1994 115(5):533 9 8178250
452 Steiner CA, Bass EB, Talamini MA, et al Surgical rates and operative mortality for open and laparoscopic cholecystectomy in Maryland N Engl J Med 1994 330(6):403 8 8284007
453 Soper NJ, Barteau JA, Clayman RV, et al Comparison of early postoperative results for laparoscopic versus standard open cholecystectomy Surg Gynecol Obstet 1992 174(2):114 8 1531160
454 JAMA. 1996;269:1018-1024.
455 Feldman MG, Russell JC, Lynch JT, et al Comparison of mortality rates for open and closed cholecystectomy in the elderly: Connecticut statewide survey J Laparoendosc Surg 1994 4(3):165 72 7919503
456 Ferreira MR, Bennett RL, Gilman SC, et al Diffusion of laparoscopic cholecystectomy in the Veterans Affairs health care system, 1991-1995 Eff Clin Pract 1999 2(2):49 55 10538476
457 Majeed AW, Troy G, Nicholl JP, et al Randomised, prospective, single-blind comparison of laparoscopic versus small-incision cholecystectomy [see comments] Lancet 1996 347(9007):989 94 8606612
458 Surg Endosc. 1998;12:191-192.
459 Jatzko GR, Lisborg PH, Pertl AM, et al Multivariate comparison of complications after laparoscopic cholecystectomy and open cholecystectomy Ann Surg 1995 221(4):381 6 7726673 1234587
460 Fletcher DR, Hobbs MS, Tan P, et al Complications of cholecystectomy: risks of the laparoscopic approach and protective effects of operative cholangiography: a population-based study Ann Surg 1999 229(4):449 57 10203075 1191728
461 Matthews BD, Williams GB Laparoscopic cholecystectomy in an academic hospital: evaluation of changes in perioperative outcomes Jsls 1999 3(1):9 17 10323163
462 Holcomb GW, 3rd, Morgan WM, 3rd, Neblett WW, 3rd, et al Laparoscopic cholecystectomy in children: lessons learned from the first 100 patients J Pediatr Surg 1999 34(8):1236 40 10466603
463 Maxwell JG, Tyler BA, Rutledge R, et al Cholecystectomy in patients aged 80 and older Am J Surg 1998 176(6):627 31 9926803
464 Fendrick AM, Escarce JJ, McLane C, et al Hospital adoption of laparoscopic cholecystectomy Med Care 1994 32(10):1058 63 7934272
465 Nenner RP, Imperato PJ, Rosenberg C, et al Increased cholecystectomy rates among Medicare patients after the introduction of laparoscopic cholecystectomy J Community Health 1994 19(6):409 15 7844246
466 Steinle EW, VanderMolen RL, Silbergleit A, et al Impact of laparoscopic cholecystectomy on indications for surgical treatment of gallstones Surg Endosc 1997 11(9):933 5 9294276
467 Shea JA, Berlin JA, Bachwich DR, et al Indications for and outcomes of cholecystectomy: a comparison of the pre and postlaparoscopic eras Ann Surg 1998 227(3):343 50 9527056 1191271
468 Escarce JJ, Chen W, Schwartz JS Falling cholecystectomy thresholds since the introduction of laparoscopic cholecystectomy JAMA 1995 273(20):1581 5 7745770
469 Marshall D, Clark E, Hailey D The impact of laparoscopic cholecystectomy in Canada and Australia Health Policy 1994 26(3):221 30 10133133
470 Lam C, Murray F, Cuschieri A. Increased cholecystectomy rates after the introduction of laparoscopic cholecystectomy in Scotland. Gut. 1996;38:282-284. [pmid: 8801212]. [pmcid: 1383038].
471 Cagir B, Rangraj M, Maffuci L, et al The learning curve for laparoscopic cholecystectomy J Laparoendosc Surg 1994 4(6):419 27 7881146
472 Kane R, Lurie N, Borbas Cea The outcomes of elective laparoscopic and open cholecystectomies J Am Coll Surg 1995 180(136-145).7850045
473 Orlando Rd, Russell JC, Lynch J, et al Laparoscopic cholecystectomy. A statewide experience. The Connecticut Laparoscopic Cholecystectomy Registry Arch Surg 1993 128(5):494 8discussion498 9 8489381
474 Gittelsohn A, Powe NR Small area variations in health care delivery in Maryland Health Serv Res 1995 30(2):295 317 7782218 1070065
475 Leape LL, Hilborne LH, Schwartz JS, et al The appropriateness of coronary artery bypass graft surgery in academic medical centers. Working Group of the Appropriateness Project of the Academic Medical Center Consortium Ann Intern Med 1996 125(1):8 18 8644996
476 Leape LL, Park RE, Bashore TM, et al Effect of variability in the interpretation of coronary angiograms on the appropriateness of use of coronary revascularization procedures American Heart Journal 2000 139(1 Pt 1):106 13 10618570
477 McGlynn EA, Naylor CD, Anderson GM, et al Comparison of the appropriateness of coronary angiography and coronary artery bypass graft surgery between Canada and New York State JAMA 1994 272(12):934 40 8084060
478 Bernstein SJ, Brorsson B, Aberg T, et al Appropriateness of referral of coronary angiography patients in Sweden. SECOR/SBU Project Group Heart 1999 81(5):470 7 10212163 1729044
479 Center for the Evaluative Clinical Sciences at Dartmouth Medical School.
480 Kuh D, Stirling S Socioeconomic variation in admission for diseases of female genital system and breast in a national cohort aged 15-43 BMJ 1995 311(7009):840 3 7580490 2550852
481 Broder MS, Kanouse DE, Mittman BS, et al The appropriateness of recommendations for hysterectomy Obstet Gynecol 2000 95(2):199 205 10674580
482 Barron M, Kazandjian VA Geographic variation in lumbar diskectomy: a protocol for evaluation QRB Qual Rev Bull 1992 18(3):98 107 1603577
483 Milamed DR, Warfield CA, Hedley-Whyte J, et al Laminectomy and the treatment of lower-back pain in Massachusetts Int J Technol Assess Health Care 1993 9(3):426 39 8340207
484 Larequi-Lauber T, Vader JP, Burnand B, et al Appropriateness of indications for surgery of lumbar disc hernia and spinal stenosis Spine 1997 22(2):203 9 9122803
485 Porchet F, Vader JP, Larequi-Lauber T, et al The assessment of appropriate indications for laminectomy J Bone Joint Surg Br 1999 81(2):234 9 10204927
486 Ryan TJ, Antman EM, Brooks NH, et al 1999 update: ACC/AHA guidelines for the management of patients with acute myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Acute Myocardial Infarction) J Am Coll Cardiol 1999 34(3):890 911 10483976
487 Ziskind AA, Lauer MA, Bishop G, et al Assessing the appropriateness of coronary revascularization: the University of Maryland Revascularization Appropriateness Score (RAS) and its comparison to RAND expert panel ratings and American College of Cardiology/American Heart Association guidelines with regard to assigned appropriateness rating and ability to predict outcome Clin Cardiol 1999 22(2):67 76 10068842
488 Hilborne LH, Leape LL, Bernstein SJ, et al The appropriateness of use of percutaneous transluminal coronary angioplasty in New York State Jama 1993 269(6):761 5 8423657
489 Billings J, Zeital L, Lukomnik J, et al. Analysis of variation in hospital admission rates associated with area income in New York City. ,Unpublished Report.
490 Silver MP, Babitz ME, Magill MK Ambulatory care sensitive hospitalization rates in the aged Medicare population in Utah, 1990 to 1994: a rural-urban comparison J Rural Health 1997 13(4):285 94 10177150
491 Millman M, editor. Committee on Monitoring Access to Personal Health Care Services. Washington, D.C.: National Academy Press. 1993.
492 Bindman A, Grumbach K, Osmond D, et al Accuracy of preventable hospitalization rates for measureing access to care in rural communities JGIM 1996 11[Suppl 1]:8725975
493 Giuffrida A, Gravelle H, Roland M. Can we use ambulatory sensitive admission rates as primary care quality indicators? Evidence from England. Abstract Book/Association for Health Services Research. 1998;15:104-5.
494 Connell FA, Blide LA, Hanken MA Clinical correlates of small area variations in population-based admission rates for diabetes Med Care 1984 22(10):939 49 6436591
495 Hrdy SA, Hoppe PM, Bouda DW Nebraska outpatient care quality assessment Nebr Med J 1993 78(2):36 41 8441483
496 Komaromy M, Lurie N, Osmond D, et al Physician practice style and rates of hospitalization for chronic medical conditions Med Care 1996 34(6):594 609 8656725
497 Epstein A The role of the medical market in preventable hospitalizations Abstract Book/Association of Health Services Research 1998 15(316-7).
498 Gill JM, Mainous AG, 3rd The role of provider continuity in preventing hospitalizations Arch Fam Med 1998 7(4):352 7 9682689
499 Falik M, Needleman J, McCall N, et al. Ambulatory care sensitive conditions: hospitalization rates by usual source of care. Abstract Book/Association for Health Services Research. 1998;15:236-7.
500 Gill JM Can hospitalizations be avoided by having a regular source of care? Fam Med 1997 29(3):166 71 9085096
501 Shi L, Samuels ME, Pease M, et al Patient characteristics associated with hospitalizations for ambulatory care sensitive conditions in South Carolina Southern Medical Journal 1999 92(10):989 98 10548172
502 Krakauer H, Jacoby I, Millman M, et al Physician impact on hospital admission and on mortality rates in the Medicare population Health Serv Res 1996 31(2):191 211 8675439 1070113
503 Kaestner R, Racine A, Joyce T Did recent expansions in Medicaid narrow socioeconomic differences in hospitalization rates of infants? Med Care 2000 38(2):195 206 10659693
504 Homan R, Bryce C. Preventable hospitalization rates as a marker for access problems. Abstract Book/Association for Health Services Research. 1997;14:6-7.
505 Taroni F, Repetto F, Louis DZ, et al Variation in hospital use and avoidable patient morbidity J Health Serv Res Policy 1997 2(4):217 22 10182250
506 Weinberg AD, Minaker KL Dehydration. Evaluation and management in older adults. Council on Scientific Affairs, American Medical Association [see comments] Jama 1995 274(19):1552 6 7474224
507 Foster DA, Talsma A, Furumoto-Dawson A, et al Influenza vaccine effectiveness in preventing hospitalization for pneumonia in the elderly Am J Epidemiol 1992 136(3):296 307 1415151
508 MMWR Morb Mortal Wkly Rep 1997 46(39):913 9 9347904
509 Marrie TJ, Lau CY, Wheeler SL, et al A controlled trial of a critical pathway for treatment of community- acquired pneumonia. CAPITAL Study Investigators. Community-Acquired Pneumonia Intervention Trial Assessing Levofloxacin JAMA 2000 283(6):749 55 10683053
510 Braveman P, Schaaf VM, Egerter S, et al Insurance-related differences in the risk of ruptured appendix [see comments] N Engl J Med 1994 331(7):444 9 7880234
511 Bratton SL, Haberkern CM, Waldhausen JH Acute appendicitis risks of complications: age and Medicaid insurance Pediatrics 2000 106(1 Pt 1):75 8 10878152
512 Blumberg MS, Juhn PI Insurance and the risk of ruptured appendix [letter; comment] N Engl J Med 1995 332(6):395 6 discussion 397 8 7824005
513 O'Toole SJ, Karamanoukian HL, Allen JE, et al Insurance-related differences in the presentation of pediatric appendicitis J Pediatr Surg 1996 31(8):1032 4 8863226
514 Gibbons RJ, Chatterjee K, Daley J, et al ACC/AHA/ACP-ASIM guidelines for the management of patients with chronic stable angina: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Management of Patients With Chronic Stable Angina) [published erratum appears in J Am Coll Cardiol 1999 Jul;34(1):314] J Am Coll Cardiol 1999 33(7):2092 197 10362225
515 Braunwald E, Antman EM, Beasley JW, et al ACC/AHA guidelines for the management of patients with unstable angina and non-ST-segment elevation myocardial infarction. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on the Management of Patients With Unstable Angina) J Am Coll Cardiol 2000 36(3):970 1062 10987629
516 Adams, Marano Current estimates from the National Health Interview Survey, 1994 Vital Health Stat 1995 10(94).
517 Agency for Healthcare Research and Quality,.
518 Centers for Disease Control.
519 Ambulatory care vistis to physicians' offices, hospital outpatient departments, and emergency departments: United States, 1996 Vital and Health Statistics 1998 13(134).
520 Expert Panel Report 2: Guidelines for the diagnosis and management of asthma. In: National Institutes of Health pub. no. 97-4051. Bethesda, MD. 1997.
521 Blais L, Ernst P, Boivin JF, et al Inhaled corticosteroids and the prevention of readmission to hospital for asthma Am J Respir Crit Care Med 1998 158(1):126 32 9655718
522 Donahue JG, Weiss ST, Livingston JM, et al Inhaled steroids and the risk of hospitalization for asthma Jama 1997 277(11):887 91 9062326
523 Rosenstreich DL, Eggleston P, Kattan M, et al The role of cockroach allergy and exposure to cockroach allergen in causing morbidity among inner-city children with asthma N Engl J Med 1997 336(19):1356 63 9134876
524 Abbey DE, Petersen F, Mills PK, et al Long-term ambient concentrations of total suspended particulates, ozone, and sulfur dioxide and respiratory symptoms in a nonsmoking population Arch Environ Health 1993 48(1):33 46 8452397
525 Greer JR, Abbey DE, Burchette RJ Asthma related to occupational and ambient air pollutants in nonsmokers J Occup Med 1993 35(9):909 15 8229343
526 Jindal SK, Gupta D, Singh A Indices of morbidity and control of asthma in adult patients exposed to environmental tobacco smoke Chest 1994 106(3):746 9 8082352
527 Chilmonczyk BA, Salmun LM, Megathlin KN, et al Association between exposure to environmental tobacco smoke and exacerbations of asthma in children N Engl J Med 1993 328(23):1665 9 8487825
528 Koenig JQ Air pollution and asthma J Allergy Clin Immunol 1999 104(4 Pt 1):717 22 10518814
529 Abbey DE, Petersen FF, Mills PK, et al Chronic respiratory disease associated with long-term ambient concentrations of sulfates and other air pollutants J Expo Anal Environ Epidemiol 1993 3(Suppl 1):99 115 9857297
530 Koenig JQ, Larson TV, Hanley QS, et al Pulmonary function changes in children associated with fine particulate matter Environ Res 1993 63(1):26 38 8404772
531 Walters S, Griffiths RK, Ayres JG Temporal association between hospital admissions for asthma in Birmingham and ambient levels of sulphur dioxide and smoke Thorax 1994 49(2):133 40 8128402 474324
532 Schwartz J, Slater D, Larson TV, et al Particulate air pollution and hospital emergency room visits for asthma in Seattle Am Rev Respir Dis 1993 147(4):826 31 8466116
533 Cody RP, Weisel CP, Birnbaum G, et al The effect of ozone associated with summertime photochemical smog on the frequency of asthma visits to hospital emergency departments Environ Res 1992 58(2):184 94 1511672
534 Ponka A Asthma and low level air pollution in Helsinki Arch Environ Health 1991 46(5):262 70 1953033
535 Thurston GD, Ito K, Kinney PL, et al A multi-year study of air pollution and respiratory hospital admissions in three New York State metropolitan areas: results for 1988 and 1989 summers J Expo Anal Environ Epidemiol 1992 2(4):429 50 1336418
536 Romieu I, Meneses F, Sienra-Monge JJ, et al Effects of urban air pollutants on emergency visits for childhood asthma in Mexico City Am J Epidemiol 1995 141(6):546 53 7900722
537 Kesten S, Szalai J, Dzyngel B Air quality and the frequency of emergency room visits for asthma Ann Allergy Asthma Immunol 1995 74(3):269 73 7889385
538 White MC, Etzel RA, Wilcox WD, et al Exacerbations of childhood asthma and ozone pollution in Atlanta Environ Res 1994 65(1):56 68 8162885
539 Anderson HR, Ponce de Leon A, Bland JM, et al Air pollution, pollens, and daily admissions for asthma in London 1987- 92 Thorax 1998 53(10):842 8 10193370 1745078
540 Sheppard L, Levy D, Norris G, et al Effects of ambient air pollution on nonelderly asthma hospital admissions in Seattle, Washington, 1987-1994 Epidemiology 1999 10(1):23 30 9888276
541 Blanc PD, Toren K How much adult asthma can be attributed to occupational factors? Am J Med 1999 107(6):580 7 10625027
542 Chan-Yeung M, Malo JL Aetiological agents in occupational asthma Eur Respir J 1994 7(2):346 71 8162990
543 Schenker MB, Gold EB, Lopez RL, et al Asthma mortality in California, 1960-1989. Demographic patterns and occupational associations Am Rev Respir Dis 1993 147(6 Pt 1):1454 60 8503556
544 Von Behren J, Kreutzer R, Smith D Asthma hospitalization trends in California, 1983-1996 J Asthma 1999 36(7):575 82 10524540
545 Lin S, Fitzgerald E, Hwang SA, et al Asthma hospitalization rates and socioeconomic status in New York State (1987-1993) J Asthma 1999 36(3):239 51 10350220
546 MMWR Morb Mortal Wkly Rep 1996 45(17):350 3 8604212
547 Ray NF, Thamer M, Fadillioglu B, et al Race, income, urbanicity, and asthma hospitalization in California: a small area analysis Chest 1998 113(5):1277 84 9596306
548 Blixen CE, Havstad S, Tilley BC, et al A comparison of asthma-related healthcare use between African-Americans and Caucasians belonging to a health maintenance organization (HMO) J Asthma 1999 36(2):195 204 10227271
549 Claudio L, Tulton L, Doucette J, et al Socioeconomic factors and asthma hospitalization rates in New York City J Asthma 1999 36(4):343 50 10386498
550 Gottlieb DJ, Beiser AS, O'Connor GT Poverty, race, and medication use are correlates of asthma hospitalization rates. A small area analysis in Boston Chest 1995 108(1):28 35 7606972
551 Giuffrida A, Gravelle H, Roland M Measuring quality of care with routine data: avoiding confusion between performance indicators and health outcomes Bmj 1999 319(7202):94 8 10398635 28159
552 Carr W, Zeitel L, Weiss K Variations in asthma hospitalizations and deaths in New York City Am J Public Health 1992 82(1):59 65 1536336 1694413
553 Bierman A, Steiner C, Friedman B, et al. Ambulatory care sensitive conditions: a viable indicator of access to quality primary care? [abstract]. 1999.
554 Halterman JS, Aligne CA, Auinger P, et al Inadequate therapy for asthma among children in the United States Pediatrics 2000 105(1 Pt 3):272 6 10617735
555 Murray MD, Stang P, Tierney WM Health care use by inner-city patients with asthma J Clin Epidemiol 1997 50(2):167 74 9120510
556 Lozano P, Connell FA, Koepsell TD Use of health services by African-American children with asthma on Medicaid Jama 1995 274(6):469 73 7629955
557 Bosco LA, Gerstman BB, Tomita DK Variations in the use of medication for the treatment of childhood asthma in the Michigan Medicaid population, 1980 to 1986 Chest 1993 104(6):1727 32 8252952
558 Hartert TV, Windom HH, Peebles RS, et al Inadequate outpatient medical therapy for patients with asthma admitted to two urban hospitals Am J Med 1996 100(4):386 94 8610724
559 Ordonez GA, Phelan PD, Olinsky A, et al Preventable factors in hospital admissions for asthma Arch Dis Child 1998 78(2):143 7 9579156 1717453
560 Homer CJ, Szilagyi P, Rodewald L, et al Does quality of care affect rates of hospitalization for childhood asthma? Pediatrics 1996 98(1):18 23 8668406
561 Lieu TA, Quesenberry CP, Jr., Capra AM, et al Outpatient Management Practices Associated With Reduced Risk of Pediatric Asthma Hospitalization and Emergency Department Visits Pediatrics 1997 100(3):334 41 9282702
562 Sherrill DL, Lebowitz MD, Burrows B Epidemiology of chronic obstructive pulmonary disease Clin Chest Med 1990 11(3):375 87 2205437
563 Sullivan SD, Ramsey SD, Lee TA The economic burden of COPD Chest 2000 117(2 Suppl):5S 9S 10673466
564 Hackner D, Tu G, Weingarten S, et al Guidelines in pulmonary medicine: a 25-year profile Chest 1999 116(4):1046 62 10531173
565 Ferguson GT Recommendations for the management of COPD Chest 2000 117(2 Suppl):23S 8S 10673470
566 Feinleib M, Rosenberg HM, Collins JG, et al Trends in COPD morbidity and mortality in the United States Am Rev Respir Dis 1989 140(3 Pt 2):S9 18 2782766
567 Osborne ML, Vollmer WM, Buist AS Periodicity of asthma, emphysema, and chronic bronchitis in a northwest health maintenance organization Chest 1996 110(6):1458 62 8989061
568 Anthonisen NR, Connett JE, Kiley JP, et al Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV1. The Lung Health Study Jama 1994 272(19):1497 505 7966841
569 Sherrill DL, Enright P, Cline M, et al Rates of decline in lung function among subjects who restart cigarette smoking Chest 1996 109(4):1001 5 8635322
570 Prescott E, Vestbo J Socioeconomic status and chronic obstructive pulmonary disease Thorax 1999 54(8):737 41 10413728 1745556
571 Anderson HR, Spix C, Medina S, et al Air pollution and daily admissions for chronic obstructive pulmonary disease in 6 European cities: results from the APHEA project Eur Respir J 1997 10(5):1064 71 9163648
572 Moolgavkar SH, Luebeck EG, Anderson EL Air pollution and hospital admissions for respiratory causes in Minneapolis-St. Paul and Birmingham Epidemiology 1997 8(4):364 70 9209848
573 Morgan G, Corbett S, Wlodarczyk J Air pollution and hospital admissions in Sydney, Australia, 1990 to 1994 Am J Public Health 1998 88(12):1761 6 9842371 1509034
574 Schwartz J Air pollution and hospital admissions for the elderly in Birmingham, Alabama Am J Epidemiol 1994 139(6):589 98 8172170
575 Voigt T, Bailey M, Abramson M Air pollution in the Latrobe Valley and its impact upon respiratory morbidity Aust N Z J Public Health 1998 22(5):556 61 9744209
576 Spix C, Anderson HR, Schwartz J, et al Short-term effects of air pollution on hospital admissions of respiratory diseases in Europe: a quantitative summary of APHEA study results. Air Pollution and Health: a European Approach Arch Environ Health 1998 53(1):54 64 9570309
577 Schwartz J Air pollution and hospital admissions for respiratory disease Epidemiology 1996 7(1):20 8 8664396
578 Sunyer J, Saez M, Murillo C, et al Air pollution and emergency room admissions for chronic obstructive pulmonary disease: a 5-year study Am J Epidemiol 1993 137(7):701 5 8484361
579 Sunyer J, Anto JM, Murillo C, et al Effects of urban air pollution on emergency room admissions for chronic obstructive pulmonary disease Am J Epidemiol 1991 134(3):277 86 discussion 287 9 1877586
580 Trudeau ME, Solano-McGuire SM Evaluating the quality of COPD care Am J Nurs 1999 99(3):47 50 10091569
581 Ramsey SD Suboptimal medical therapy in COPD: exploring the causes and consequences Chest 2000 117(2 Suppl):33S 7S 10673472
582 Weinberger M, Oddone EZ, Henderson WG Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission N Engl J Med 1996 334(22):1441 7 8618584
583 Washington DC: National Academy Press. 1993.
584 Ricketts T. Ambulatory care sensitive conditions and policy development in the United States and the United Kingdom. Abstract Book/Association for Health Services Research. 1998;15:108-6.
585 Asch SM, Sloss EM, Hogan C, et al Measuring underuse of necessary care among elderly medicare beneficiaries using inpatient and outpatient claims [In Process Citation] Jama 2000 284(18):2325 33 11066182
586 Edep ME, Shah NB, Tateo IM, et al Differences between primary care physicians and cardiologists in management of congestive heart failure: relation to practice guidelines J Am Coll Cardiol 1997 30(2):518 26 9247527
587 Reis SE, Holubkov R, Edmundowicz D, et al Treatment of patients admitted to the hospital with congestive heart failure: specialty-related disparities in practice patterns and outcomes J Am Coll Cardiol 1997 30(3):733 8 9283533
588 Philbin EF, Weil HF, Erb TA, et al Cardiology or primary care for heart failure in the community setting: process of care and clinical outcomes Chest 1999 116(2):346 54 10453861
589 Philbin EF, Andreaou C, Rocco TA, et al Patterns of angiotensin-converting enzyme inhibitor use in congestive heart failure in two community hospitals Am J Cardiol 1996 77(10):832 8 8623735
590 United Kingdom National Health Service.
591 Project to Develop and Evaluate Methods to Promote Ambulatory Care Quality (DEMPAQ).
592 Morris AD, Boyle DI, McMahon AD, et al Adherence to insulin treatment, glycaemic control, and ketoacidosis in insulin-dependent diabetes mellitus. The DARTS/MEMO Collaboration. Diabetes Audit and Research in Tayside Scotland. Medicines Monitoring Unit [see comments] Lancet 1997 350(9090):1505 10 9388398
593 Day JL, Metcalfe J, Johnson P Benefits provided by an integrated education and clinical diabetes centre: a follow-up study Diabet Med 1992 9(9):855 9 1473327
594 Hypoglycemia in the Diabetes Control and Complications Trial The Diabetes Control and Complications Trial Research Group Diabetes 1997 46(2):271 86 9000705
595 Musey VC, Lee JK, Crawford R, et al Diabetes in urban African-Americans. I. Cessation of insulin therapy is the major precipitating cause of diabetic ketoacidosis Diabetes Care 1995 18(4):483 9 7497857
596 Umpierrez GE, Kelly JP, Navarrete JE, et al Hyperglycemic crises in urban blacks Arch Intern Med 1997 157(6):669 75 9080921
597 Thompson CJ, Cummings F, Chalmers J, et al Abnormal insulin treatment behaviour: a major cause of ketoacidosis in the young adult Diabet Med 1995 12(5):429 32 7648807
598 Bagg W, Sathu A, Streat S, et al Diabetic ketoacidosis in adults at Auckland Hospital, 1988-1996 Aust N Z J Med 1998 28(5):604 8 9847948
599 Harris MI. Diabetes in America: epidemiology and scope of the problem. Diabetes Care. 1998;21 Suppl 3:C11-4. [pmid: 9850480].
600 Gaster B, Hirsch IB The effects of improved glycemic control on complications in type 2 diabetes Arch Intern Med 1998 158(2):134 40 9448551
601 Vijan S, Hofer TP, Hayward RA Estimated benefits of glycemic control in microvascular complications in type 2 diabetes [see comments] Ann Intern Med 1997 127(9):788 95 9382399
602 Klein R, Klein BE. Relation of glycemic control to diabetic complications and health outcomes. Diabetes Care. 1998;21 Suppl 3:C39-43. [pmid: 9850488].
603 Klein R, Klein BE, Moss SE Relation of glycemic control to diabetic microvascular complications in diabetes mellitus Ann Intern Med 1996 124(1 Pt 2):90 6 8554220
604 Molyneaux LM, Constantino MI, McGill M, et al Better glycaemic control and risk reduction of diabetic complications in Type 2 diabetes: comparison with the DCCT Diabetes Res Clin Pract 1998 42(2):77 83 9886743
605 Henry RR, Genuth S Forum One: Current recommendations about intensification of metabolic control in non-insulin-dependent diabetes mellitus Ann Intern Med 1996 124(1 Pt 2):175 7 8554214
606 The Diabetes Control and Complications Trial Research Group [see comments] N Engl J Med 1993 329(14):977 86 8366922
607 Retinopathy and nephropathy in patients with type 1 diabetes four years after a trial of intensive therapy The Diabetes Control and Complications Trial/Epidemiology of Diabetes Interventions and Complications Research Group [published erratum appears in N Engl J Med 2000 May 4;342(18):1376] N Engl J Med 2000 342(6):381 9 10666428 2630213
608 Zoorob RJ, Hagen MD Guidelines on the care of diabetic nephropathy, retinopathy and foot disease Am Fam Physician 1997 56(8):2021 8, 2033-4 9390097
609 MMWR Morb Mortal Wkly Rep 1999 48(42):958 61 10553809
610 Hiss RG Barriers to care in non-insulin-dependent diabetes mellitus. The Michigan experience Ann Intern Med 1996 124(1 Pt 2):146 8 8554207
611 National Center for Health Statistics.
612 Newton KM, Wagner EH, Ramsey SD, et al The use of automated data to identify complications and comorbidities of diabetes: a validation study J Clin Epidemiol 1999 52(3):199 207 10210237
613 Mayfield JA, Reiber GE, Sanders LJ, et al Preventive foot care in people with diabetes Diabetes Care 1998 21(12):2161 77 9839111
614 National Diabetes Fact Sheet: National Estimates and General Information on Diabetes in the United States. Atlanta, GA: U.S. Department of Health and Human Services (HHS), CDC,. 1999.
615 Pecoraro RE, Reiber GE, Burgess EM Pathways to diabetic limb amputation. Basis for prevention Diabetes Care 1990 13(5):513 21 2351029
616 Peters AL, Legorreta AP, Ossorio RC, et al Quality of outpatient care provided to diabetic patients. A health maintenance organization experience Diabetes Care 1996 19(6):601 6 8725859
617 Jencks SF, Cuerdon T, Burwen DR, et al Quality of medical care delivered to Medicare beneficiaries: A profile at state and national levels Jama 2000 284(13):1670 6 11015797
618 Asch SM, Sloss EM, Hogan C, et al Measuring underuse of necessary care among elderly Medicare beneficiaries using inpatient and outpatient claims Jama 2000 284(18):2325 33 11066182
619 Weiner JP, Parente ST, Garnick DW, et al Variation in office-based quality. A claims-based profile of care provided to Medicare patients with diabetes Jama 1995 273(19):1503 8 7739076
620 Starfield B, Powe NR, Weiner JR, et al Costs vs quality in different types of primary care settings Jama 1994 272(24):1903 8 7990241
621 Humphrey LL, Palumbo PJ, Butters MA, et al The contribution of non-insulin-dependent diabetes to lower-extremity amputation in the community Arch Intern Med 1994 154(8):885 92 8154951
622 Group TG Epidemiology of lower extremity amputation in centres in Europe, North America and East Asia. The global lower extremity amputation study group Br J Surg 2000 87(3):328 37 10718803
623 Selby JV, Zhang D Risk factors for lower extremity amputation in persons with diabetes Diabetes Care 1995 18(4):509 16 7497861
624 Lavery LA, Ashry HR, van Houtum W, et al Variation in the incidence and proportion of diabetes-related amputations in minorities Diabetes Care 1996 19(1):48 52 8720533
625 Reiber GE, Pecoraro RE, Koepsell TD Risk factors for amputation in patients with diabetes mellitus. A case- control study Ann Intern Med 1992 117(2):97 105 1605439
626 Malone JM, Snyder M, Anderson G, et al Prevention of amputation by diabetic education Am J Surg 1989 158(6):520 3 discussion 523 4 2589581
627 Patout CA, Jr., Birke JA, Horswell R, et al Effectiveness of a comprehensive diabetes lower-extremity amputation prevention program in a predominantly low-income African-American population Diabetes Care 2000 23(9):1339 42 10977029
628 Ollendorf DA, Kotsanos JG, Wishner WJ, et al Potential economic benefits of lower-extremity amputation prevention strategies in diabetes Diabetes Care 1998 21(8):1240 5 9702427
629 Stevens-Simon C, Orleans M Low-birthweight prevention programs: the enigma of failure Birth 1999 26(3):184 91 10655819
630 Hessol NA, Fuentes-Afflick E, Bacchetti P Risk of low birth weight infants among black and white parents Obstet Gynecol 1998 92(5):814 22 9794675
631 O'Campo P, Xue X, Wang MC, et al Neighborhood risk factors for low birthweight in Baltimore: a multilevel analysis Am J Public Health 1997 87(7):1113 8 9240099 1380883
632 David RJ, Collins JW, Jr Differing birth weight among infants of U.S.-born blacks, African-born blacks, and U.S.-born whites [see comments] N Engl J Med 1997 337(17):1209 14 9337381
633 Fuentes-Afflick E, Hessol NA, Perez-Stable EJ Maternal birthplace, ethnicity, and low birth weight in California Arch Pediatr Adolesc Med 1998 152(11):1105 12 9811289
634 Larson EH, Hart LG, Rosenblatt RA Is non-metropolitan residence a risk factor for poor birth outcome in the U.S.? Soc Sci Med 1997 45(2):171 88 9225406
635 McDuffie RS, Jr., Beck A, Bischoff K, et al Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial [see comments] Jama 1996 275(11):847 51 8596222
636 Murray JL, Bernfield M The differential effect of prenatal care on the incidence of low birth weight among blacks and whites in a prepaid health care plan [see comments] N Engl J Med 1988 319(21):1385 91 3185649
637 Asthma mortality and hospitalization among children and young adults-- United States, 1980-1993 MMWR Morb Mortal Wkly Rep 1996 45(17):350 3 8604212
638 McCormick MC, Kass B, Elixhauser A, et al Annual report on access to and utilization of health care for children and youth in the United States--1999 Pediatrics 2000 105(1 Pt 3):219 30 10617727
639 Ali S, Osberg JS Differences in follow-up visits between African American and white Medicaid children hospitalized with asthma J Health Care Poor Underserved 1997 8(1):83 98 9019028
640 McConnochie KM, Russo MJ, McBride JT, et al Socioeconomic variation in asthma hospitalization: excess utilization or greater need? Pediatrics 1999 103(6):10353972
641 Miller JE The effects of race/ethnicity and income on early childhood asthma prevalence and health care use Am J Public Health 2000 90(3):428 30 10705865 1446167
642 Arshad SH, Hide DW Effect of environmental factors on the development of allergic disorders in infancy J Allergy Clin Immunol 1992 90(2):235 41 1500628
643 Frischer T, Kuehr J, Meinert R, et al Maternal smoking in early childhood: a risk factor for bronchial responsiveness to exercise in primary-school children J Pediatr 1992 121(1):17 22 1625083
644 Schmitzberger R, Rhomberg K, Buchele H, et al Effects of air pollution on the respiratory tract of children Pediatr Pulmonol 1993 15(2):68 74 8474787
645 Gortmaker SL, Walker DK, Jacobs FH, et al Parental smoking and the risk of childhood asthma Am J Public Health 1982 72(6):574 9 7072874 1650136
646 Henderson FW, Henry MM, Ivins SS, et al Correlates of recurrent wheezing in school-age children. The Physicians of Raleigh Pediatric Associates Am J Respir Crit Care Med 1995 151(6):1786 93 7767521
647 Soyseth V, Kongerud J, Boe J Postnatal maternal smoking increases the prevalence of asthma but not of bronchial hyperresponsiveness or atopy in their children Chest 1995 107(2):389 94 7842766
648 Martinez FD, Wright AL, Taussig LM, et al Asthma and wheezing in the first six years of life. The Group Health Medical Associates N Engl J Med 1995 332(3):133 8 7800004
649 Agudo A, Bardagi S, Romero PV, et al Exercise-induced airways narrowing and exposure to environmental tobacco smoke in schoolchildren Am J Epidemiol 1994 140(5):409 17 8067333
650 Roorda RJ, Gerritsen J, Van Aalderen WM, et al Risk factors for the persistence of respiratory symptoms in childhood asthma Am Rev Respir Dis 1993 148(6 Pt 1):1490 5 8256889
651 Greineder DK, Loane KC, Parks P A randomized controlled trial of a pediatric asthma outreach program J Allergy Clin Immunol 1999 103(3 Pt 1):436 40 10069877
652 McConnochie KM, Conners GP, Lu E, et al How commonly are children hospitalized for dehydration eligible for care in alternative settings? Archives of Pediatrics and Adolescent Medicine 1999 153(12):1233 41 10591299
653 Burkhart DM Management of acute gastroenteritis in children American Family Physician 1999 60(9):2555 63, 2565-6 10605991
654 Bezerra JA, Stathos TH, Duncan B, et al Treatment of infants with acute diarrhea: what's recommended and what's practiced Pediatrics 1992 90(1 Pt 1):1 4 1614754
655 O'Laughlin E, Notaras E, McCullogh C, et al Home-based management of children hospitalized with acute gastroenteritis J Paediatr Child Health 1995 31(3):189 191 7669377
656 Snyder JD Use and misuse of oral therapy for diarrhea: comparison of US practices with American Academy of Pediatrics recommendations Pediatrics 1991 87(1):28 33 1984614
657 To T, Feldman W, Young W, et al Hospitalization rates of children with gastroenteritis in Ontario Can J Public Health 1996 87(1):62 5 8991748
658 Heart and Stroke Facts:1996 Statistical Supplement. Dallas, TX: American Heart Association. 1996.
659
660 Normand S, CN M, KS F, et al Development and validation of a claims based index for adjusting for risk of mortality: the case of acute myocardial infarction J Clin Epidemiol 1995 48(2):229 243 7869069
661 Meehan TP, Hennen J, Radford MJ, et al Process and outcome of care for acute myocardial infarction among Medicare beneficiaries in Connecticut: a quality improvement demonstration project Ann Intern Med 1995 122(12):928 36 7755229
662 Kuulasmaa K, Tunstall-Pedoe H, Dobson A, et al Estimation of contribution of changes in classic risk factors to trends in coronary-event rates across the WHO MONICA Project populations [see comments] Lancet 2000 355(9205):675 87 10703799
663 Fibrinolytic Therapy Trialists' (FTT) Collaborative Group [published erratum appears in Lancet 1994 Mar 19;343(8899):742] [see comments] Lancet 1994 343(8893):311 22 7905143
664 Gruppo Italiano per lo Studio della Streptochinasi nell'Infarto Miocardico (GISSI) Lancet 1986 1(8478):397 402 2868337
665 Wilcox RG, von der Lippe G, Olsson CG, et al Trial of tissue plasminogen activator for mortality reduction in acute myocardial infarction. Anglo-Scandinavian Study of Early Thrombolysis (ASSET) Lancet 1988 2(8610):525 30 2900919
666 AIMS Trial Study Group Lancet 1990 335(8687):427 31 1968167
667 Roux S, Christeller S, Ludin E Effects of aspirin on coronary reocclusion and recurrent ischemia after thrombolysis: a meta-analysis [see comments] J Am Coll Cardiol 1992 19(3):671 7 1531663
668 Gibbons RJ, Holmes DR, Reeder GS, et al Immediate angioplasty compared with the administration of a thrombolytic agent followed by conservative treatment for myocardial infarction. The Mayo Coronary Care Unit and Catheterization Laboratory Groups [see comments] N Engl J Med 1993 328(10):685 91 8433727
669 Grines CL, Browne KF, Marco J, et al A comparison of immediate angioplasty with thrombolytic therapy for acute myocardial infarction. The Primary Angioplasty in Myocardial Infarction Study Group [see comments] N Engl J Med 1993 328(10):673 9 8433725
670 N Engl J Med 1997 336(23):1621 8 Published erratum appears in N Engl J Med 1997 337(4):28 7 9173270
671 ISIS-4 (Fourth International Study of Infarct Survival) Collaborative Group [see comments] Lancet 1995 345(8951):669 85 7661937
672 Ambrosioni E, Borghi C, Magnani B The effect of the angiotensin-converting-enzyme inhibitor zofenopril on mortality and morbidity after anterior myocardial infarction. The Survival of Myocardial Infarction Long-Term Evaluation (SMILE) Study Investigators [see comments] N Engl J Med 1995 332(2):80 5 7990904
673 Lancet 1995 345(8951):686 7 7885123
674 O'Connor GT, Quinton HB, Traven ND, et al Geographic variation in the treatment of acute myocardial infarction: the Cooperative Cardiovascular Project JAMA 1999 281(7):627 33 10029124
675 Berger AK, Edris DW, Breall JA, et al Resource use and quality of care for Medicare patients with acute myocardial infarction in Maryland and the District of Columbia: analysis of data from the Cooperative Cardiovascular Project Am Heart J 1998 135(2 Pt 1):349 56 9489987
676 Kahn KL, Rogers WH, Rubenstein LV, et al Measuring quality of care with explicit process criteria before and after implementation of the DRG-based prospective payment system JAMA 1990 264(15):1969 73 2120476
677 Allison JJ, Kiefe CI, Weissman NW, et al Relationship of hospital teaching status with quality of care and mortality for Medicare patients with acute MI Jama 2000 284(10):1256 62 10979112
678 Holmboe ES, Meehan TP, Radford MJ, et al Use of critical pathways to improve the care of patients with acute myocardial infarction Am J Med 1999 107(4):324 31 10527033
679 Soumerai SB, McLaughlin TJ, Gurwitz JH, et al Effect of local medical opinion leaders on quality of care for acute myocardial infarction: a randomized controlled trial JAMA 1998 279(17):1358 63 9582043
680 Office of Statewide Health Planning and Development, State of California.
681 Pennsylvania Health Care Cost Containment Council.
682 Smith WM Epidemiology of congestive heart failure Am J Cardiol 1985 55(2):3A 8A 3966408
683 Yusuf S, Thom T, Abbott RD Changes in hypertension treatment and in congestive heart failure mortality in the United States Hypertension 1989 13(5 Suppl):I74 9 2490832
684 Croft JB, Giles WH, Pollard RA, et al Heart failure survival among older adults in the United States: a poor prognosis for an emerging epidemic in the Medicare population [see comments] Arch Intern Med 1999 159(5):505 10 10074960
685 MacIntyre K, Capewell S, Stewart S, et al Evidence of improving prognosis in heart failure: trends in case fatality in 66 547 patients hospitalized between 1986 and 1995 [see comments] Circulation 2000 102(10):1126 31 10973841
686 Goff DC, Jr., Pandey DK, Chan FA, et al Congestive heart failure in the United States: is there more than meets the I(CD code)? The Corpus Christi Heart Project Arch Intern Med 2000 160(2):197 202 10647758
687 Psaty BM, Boineau R, Kuller LH, et al The potential costs of upcoding for heart failure in the United States Am J Cardiol 1999 84(1):108 9, A9 10404865
688 Polanczyk CA, Rohde LE, Dec GW, et al Ten-year trends in hospital care for congestive heart failure: improved outcomes and increased use of resources Arch Intern Med 2000 160(3):325 32 10668834
689 Ghali JK, Cooper R, Ford E Trends in hospitalization rates for heart failure in the United States, 1973-1986. Evidence for increasing population prevalence [see comments] Arch Intern Med 1990 150(4):769 73 2327838
690 Senni M, Tribouilloy CM, Rodeheffer RJ, et al Congestive heart failure in the community: a study of all incident cases in Olmsted County, Minnesota, in 1991 Circulation 1998 98(21):2282 9 9826315
691 Ni H, Hershberger RE Was the decreasing trend in hospital mortality from heart failure attributable to improved hospital care? The Oregon experience, 1991-1995 Am J Manag Care 1999 5(9):1105 15 10621076
692 Selker HP, Griffith JL, D'Agostino RB A time-insensitive predictive instrument for acute hospital mortality due to congestive heart failure: development, testing, and use for comparing hospitals: a multicenter study Med Care 1994 32(10):1040 52 7934270
693 Ho KK, Anderson KM, Kannel WB, et al Survival after the onset of congestive heart failure in Framingham Heart Study subjects [see comments] Circulation 1993 88(1):107 15 8319323
694 Croft JB, Giles WH, Pollard RA, et al National trends in the initial hospitalization for heart failure J Am Geriatr Soc 1997 45(3):270 5 9063270
695 Polanczyk CA, Rohde LE, Philbin EA, et al A new casemix adjustment index for hospital mortality among patients with congestive heart failure Med Care 1998 36(10):1489 99 9794342
696 Mulrow CD, Mulrow JP, Linn WD, et al Relative efficacy of vasodilator therapy in chronic congestive heart failure. Implications of randomized trials Jama 1988 259(23):3422 6 3286914
697 The Large State Peer Review Organization Consortium.Arch Intern Med 1997 157(10):1103 8 9164376
698 Senni M, Rodeheffer RJ, Tribouilloy CM, et al Use of echocardiography in the management of congestive heart failure in the community [see comments] J Am Coll Cardiol 1999 33(1):164 70 9935024
699 Rosenthal GE, Baker DW, Norris DG, et al Relationships between in-hospital and 30-day standardized hospital mortality: implications for profiling hospitals Health Serv Res 2000 34(7):1449 68 10737447 1975659
700 Rockall TA, Logan RF, Devlin HB, et al Variation in outcome after acute upper gastrointestinal haemorrhage. The National Audit of Acute Upper Gastrointestinal Haemorrhage Lancet 1995 346(8971):346 50 7623533
701 Cooper GS, Chak A, Way LE, et al Early endoscopy in upper gastrointestinal hemorrhage: associations with recurrent bleeding, surgery, and length of hospital stay Gastrointest Endosc 1999 49(2):145 52 9925690
702 Longstreth GF Epidemiology and outcome of patients hospitalized with acute lower gastrointestinal hemorrhage: a population-based study Am J Gastroenterol 1997 92(3):419 24 9068461
703 Rockall TA, Logan RF, Devlin HB, et al Selection of patients for early discharge or outpatient care after acute upper gastrointestinal haemorrhage. National Audit of Acute Upper Gastrointestinal Haemorrhage Lancet 1996 347(9009):1138 40 8609747
704 Rockall TA, Logan RF, Devlin HB, et al Incidence of and mortality from acute upper gastrointestinal haemorrhage in the United Kingdom. Steering Committee and members of the National Audit of Acute Upper Gastrointestinal Haemorrhage Bmj 1995 311(6999):222 6 7627034 2550278
705 Hay JA, Lyubashevsky E, Elashoff J, et al Upper gastrointestinal hemorrhage clinical--guideline determining the optimal hospital length of stay Am J Med 1996 100(3):313 22 8629677
706 Cook DJ, Guyatt GH, Salena BJ, et al Endoscopic therapy for acute nonvariceal upper gastrointestinal hemorrhage: a meta-analysis Gastroenterology 1992 102(1):139 48 1530782
707 Forsen L, Sogaard AJ, Meyer HE, et al Survival after hip fracture: short- and long-term excess mortality according to age and gender Osteoporos Int 1999 10(1):73 8 10501783
708 Wolinsky FD, Fitzgerald JF, Stump TE The effect of hip fracture on mortality, hospitalization, and functional status: a prospective study Am J Public Health 1997 87(3):398 403 9096540 1381011
709 Magaziner J, Lydick E, Hawkes W, et al Excess mortality attributable to hip fracture in white women aged 70 years and older Am J Public Health 1997 87(10):1630 6 9357344 1381125
710 Fisher ES, Baron JA, Malenka DJ, et al Hip fracture incidence and mortality in New England Epidemiology 1991 2(2):116 22 1932308
711 Popovic JR, Kozak LJ National hospital discharge survey: annual summary, 1998 [In Process Citation] Vital Health Stat 13 2000(148):1 194
712 Romano P. October 2000.
713 Myers AH, Robinson EG, Van Natta ML, et al Hip fractures among the elderly: factors associated with in-hospital mortality Am J Epidemiol 1991 134(10):1128 37 1746523
714 Todd CJ, Freeman CJ, Camilleri-Ferrante C, et al Differences in mortality after fracture of hip: the east Anglian audit BMJ 1995 310(6984):904 8 7719180 2549290
715 Lavernia CJ Hemiarthroplasty in hip fracture care: effects of surgical volume on short-term outcome J Arthroplasty 1998 13(7):774 8 9802663
716 Riley G, Lubitz J Outcomes of surgery among the Medicare aged: surgical volume and mortality Health Care Financ Rev 1985 7(1):37 47 10317676
717 Boles M. A causal model of hospital volume, structure, and process indicators and surgical outcomes. [PhD Dissertation]. Richmond, VA: Virginia Commonwealth University. 1994.
718 Maerki SC, Luft HS, Hunt SS Selecting categories of patients for regionalization. Implications of the relationship between volume and outcome Med Care 1986 24(2):148 58 3080647
719 Flood AB, Scott WR, Ewy W Does practice make perfect? Part I: The relation between hospital volume and outcomes for selected diagnostic categories Med Care 1984 22(2):98 114 6700280
720 Flood AB, Scott WR, Ewy W Does practice make perfect? Part II: The relation between volume and outcomes and other hospital characteristics Med Care 1984 22(2):115 25 6422168
721 Perez JV, Warwick DJ, Case CP, et al Death after proximal femoral fracture--an autopsy study Injury 1995 26(4):237 40 7649622
722 Handoll HH, Farrar MJ, McBirnie J, et al. Heparin, low molecular weight heparin and physical methods for preventing deep vein thrombosis and pulmonary embolism following surgery for hip fractures. Cochrane Database Syst Rev. 2000;2. [pmid: 10796339].
723 Lancet 2000 355(9212):1295 302 10776741
724 Nettleman MD, Alsip J, Schrader M, et al Predictors of mortality after acute hip fracture J Gen Intern Med 1996 11(12):765 7 9016427
725 Mangano DT, Layug EL, Wallace A, et al Effect of atenolol on mortality and cardiovascular morbidity after noncardiac surgery. Multicenter Study of Perioperative Ischemia Research Group [see comments] [published erratum appears in N Engl J Med 1997 Apr 3;336(14):1039] N Engl J Med 1996 335(23):1713 20 8929262
726 Parker MJ, Urwin SC, Handoll HH, et al. General versus spinal/epidural anaesthesia for surgery for hip fractures in adults. Cochrane Database Syst Rev. 2000;2. [pmid: 11034688].
727 Urwin SC, Parker MJ, Griffiths R General versus regional anaesthesia for hip fracture surgery: a meta- analysis of randomized trials Br J Anaesth 2000 84(4):450 5 10823094
728 Avenell A, Handoll HH. Nutritional supplementation for hip fracture aftercare in the elderly (Cochrane Review). Cochrane Database Syst Rev. 2000;4. [pmid: 11034731].
729 Parker MJ, Pryor GA The timing of surgery for proximal femoral fractures J Bone Joint Surg [Br] 1992 74(2):203 5 1544952
730 O'Hara DA, Duff A, Berlin JA, et al The effect of anesthetic technique on postoperative outcomes in hip fracture repair [see comments] Anesthesiology 2000 92(4):947 57 10754613
731 Holt EM, Evans RA, Hindley CJ, et al 1000 femoral neck fractures: the effect of pre-injury mobility and surgical experience on outcome Injury 1994 25(2):91 5 8138305
732 Lu-Yao GL, Keller RB, Littenberg B, et al Outcomes after displaced fractures of the femoral neck. A meta-analysis of one hundred and six published reports J Bone Joint Surg Am 1994 76(1):15 25 8288658
733 Rogers FB, Shackford SR, Keller MS Early fixation reduces morbidity and mortality in elderly patients with hip fractures from low-impact falls J Trauma 1995 39(2):261 5 7674394
734 Roos LL, Walld RK, Romano PS, et al Short-term mortality after repair of hip fracture. Do Manitoba elderly do worse? Med Care 1996 34(4):310 26 8606556
735 Davis FM, Woolner DF, Frampton C, et al Prospective, multi-centre trial of mortality following general or spinal anaesthesia for hip fracture surgery in the elderly Br J Anaesth 1987 59(9):1080 8 3311100
736 Parker MJ Internal fixation or arthroplasty for displaced subcapital fractures in the elderly? Injury 1992 23(8):521 4 1286902
737 Kahn KL, Keeler EB, Sherwood MJ, et al Comparing outcomes of care before and after implementation of the DRG- based prospective payment system JAMA 1990 264(15):1984 8 2120477
738 Kosecoff J, Kahn KL, Rogers WH, et al Prospective payment system and impairment at discharge. The 'quicker- and-sicker' story revisited JAMA 1990 264(15):1980 3 2214063
739 Palmer RM, Saywell RM, Jr., Zollinger TW, et al The impact of the prospective payment system on the treatment of hip fractures in the elderly [see comments] Arch Intern Med 1989 149(10):2237 41 2802890
740 Fitzgerald JF, Moore PS, Dittus RS The care of elderly patients with hip fracture. Changes since implementation of the prospective payment system [see comments] N Engl J Med 1988 319(21):1392 7 3185650
741 Fitzgerald JF, Fagan LF, Tierney WM, et al Changing patterns of hip fracture care before and after implementation of the prospective payment system Jama 1987 258(2):218 21 3599306
742 Gerety MB, Soderholm-Difatte V, Winograd CH Impact of prospective payment and discharge location on the outcome of hip fracture J Gen Intern Med 1989 4(5):388 91 2552060
743 Hoyert DL, Kochanek KD, Murphy SL Deaths: final data for 1997 Natl Vital Stat Rep 1999 47(19):1 104 10641521
744 Fine MJ, Hanusa BH, Lave JR, et al Comparison of a disease-specific and a generic severity of illness measure for patients with community-acquired pneumonia J Gen Intern Med 1995 10(7):359 68 7472683
745 Fine MJ, Smith MA, Carson CA, et al Prognosis and outcomes of patients with community-acquired pneumonia. A meta-analysis JAMA 1996 275(2):134 41 8531309
746 Hasley PB, Albaum MN, Li YH, et al Do pulmonary radiographic findings at presentation predict mortality in patients with community-acquired pneumonia? Arch Intern Med 1996 156(19):2206 12 8885819
747 Davis RB, Iezzoni LI, Phillips RS, et al Predicting in-hospital mortality. The importance of functional status information Med Care 1995 33(9):906 21 7666705
748 Gleason PP, Meehan TP, Fine JM, et al Associations between initial antimicrobial therapy and medical outcomes for hospitalized elderly patients with pneumonia Arch Intern Med 1999 159(21):2562 72 10573046
749 Dowell SF The best treatment for pneumonia: new clues, but no definitive answers Arch Intern Med 1999 159(21):2511 2 10573039
750 Stahl JE, Barza M, DesJardin J, et al Effect of macrolides as part of initial empiric therapy on length of stay in patients hospitalized with community-acquired pneumonia Arch Intern Med 1999 159(21):2576 80 10573047
751 Meehan TP, Fine MJ, Krumholz HM, et al Quality of care, process, and outcomes in elderly patients with pneumonia JAMA 1997 278(23):2080 4 9403422
752 Whittle J, Lin CJ, Lave JR, et al Relationship of provider characteristics to outcomes, process, and costs of care for community-acquired pneumonia Med Care 1998 36(7):977 87 9674616
753 Niederman MS, Bass JB, Jr., Campbell GD, et al Guidelines for the initial management of adults with community-acquired pneumonia: diagnosis, assessment of severity, and initial antimicrobial therapy. American Thoracic Society. Medical Section of the American Lung Association Am Rev Respir Dis 1993 148(5):1418 26 8239186
754 Bartlett JG, Breiman RF, Mandell LA, et al Community-acquired pneumonia in adults: guidelines for management. The Infectious Diseases Society of America Clin Infect Dis 1998 26(4):811 38 9564457
755 Florida Medical Quality Assurance, Inc.Eval Health Prof 1998 21(4):514 524 10351563
756 Report of Final Mortality Statitistics, 1996. Volume, 47, Number 9/. ,Available via the Internet from http://www.cdc.gov/nchs/products/pubs/pubd/nvsr/47-pre/47-pre.htm#NVSR47_19.
757 Brown RD, Whisnant JP, Sicks JD, et al Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989 Stroke 1996 27(3):373 80 8610298
758 Broderick J, Brott T, Kothari R, et al The Greater Cincinnati/Northern Kentucky Stroke Study: preliminary first-ever and total incidence rates of stroke among blacks Stroke 1998 29(2):415 21 9472883
759 Thorvaldsen P, Asplund K, Kuulasmaa K, et al Stroke incidence, case fatality, and mortality in the WHO MONICA project. World Health Organization Monitoring Trends and Determinants in Cardiovascular Disease [published errata appear in Stroke 1995 Aug;26(8):1504 and 1995 Dec;26(12):2376] Stroke 1995 26(3):361 7 7886707
760 Leibson CL, Naessens JM, Brown RD, et al Accuracy of hospital discharge abstracts for identifying stroke Stroke 1994 25(12):2348 55 7974572
761 Benesch C, Witter DM, Jr., Wilder AL, et al Inaccuracy of the International Classification of Diseases (ICD-9-CM) in identifying the diagnosis of ischemic cerebrovascular disease [published erratum appears in Neurology 1998 Jan;50(1):306] Neurology 1997 49(3):660 4 9305319
762 Goldstein LB Accuracy of ICD-9-CM coding for the identification of patients with acute ischemic stroke: effect of modifier codes Stroke 1998 29(8):1602 4 9707200
763 Rosamond WD, Folsom AR, Chambless LE, et al Stroke incidence and survival among middle-aged adults: 9-year follow- up of the Atherosclerosis Risk in Communities (ARIC) cohort Stroke 1999 30(4):736 43 10187871
764 Lanska DJ, Kryscio R Geographic distribution of hospitalization rates, case fatality, and mortality from stroke in the United States Neurology 1994 44(8):1541 50 8058169
765 Feinberg WM Guidelines for the management of transient ischemic attacks. Ad Hoc Committee on Guidelines for the Management of Transient Ischemic Attacks of the Stroke Council, American Heart Association Heart Dis Stroke 1994 3(5):275 83 7820345
766 Samsa GP, Bian J, Lipscomb J, et al Epidemiology of recurrent cerebral infarction: a medicare claims-based comparison of first and recurrent strokes on 2-year survival and cost Stroke 1999 30(2):338 49 9933269
767 Johnston KC, Connors AF, Jr., Wagner DP, et al A predictive risk model for outcomes of ischemic stroke Stroke 2000 31(2):448 55 10657421
768 Hinchey JA, Furlan AJ, Frank JI, et al Is in-hospital stroke mortality an accurate measure of quality of care? Neurology 1998 50(3):619 25 9521246
769 Horner RD, Sloane RJ, Kahn KL Is use of mechanical ventilation a reasonable proxy indicator for coma among Medicare patients hospitalized for acute stroke? Health Serv Res 1998 32(6):841 59 9460489 1070236
770 Wong KS Risk factors for early death in acute ischemic stroke and intracerebral hemorrhage: A prospective hospital-based study in Asia. Asian Acute Stroke Advisory Panel Stroke 1999 30(11):2326 30 10548666
771 Kalra L, Perez I, Smithard DG, et al Does prior use of aspirin affect outcome in ischemic stroke? Am J Med 2000 108(3):205 9 10723974
772 The National Institute of Neurological Disorders and Stroke rt-PA Stroke Study GroupN Engl J Med 1995 333(24):1581 7 7477192
773 Mohr JP Thrombolytic therapy for ischemic stroke: from clinical trials to clinical practice JAMA 2000 283(9):1189 91 10703782
774 Clark WM, Wissman S, Albers GW, et al Recombinant tissue-type plasminogen activator (Alteplase) for ischemic stroke 3 to 5 hours after symptom onset. The ATLANTIS Study: a randomized controlled trial. Alteplase Thrombolysis for Acute Noninterventional Therapy in Ischemic Stroke JAMA 1999 282(21):2019 26 10591384
775 Smith MA, Doliszny KM, Shahar E, et al Delayed hospital arrival for acute stroke: the Minnesota Stroke Survey Ann Intern Med 1998 129(3):190 6 9696726
776 Kothari R, Jauch E, Broderick J, et al Acute stroke: delays to presentation and emergency department evaluation Ann Emerg Med 1999 33(1):3 8 9867880
777 O'Connor RE, McGraw P, Edelsohn L Thrombolytic therapy for acute ischemic stroke: why the majority of patients remain ineligible for treatment Ann Emerg Med 1999 33(1):9 14 9867881
778 Grotta J Should thrombolytic therapy be the first-line treatment for acute ischemic stroke? t-PA--the best current option for most patients N Engl J Med 1997 337(18):1310 3 9345085
779 Albers GW, Bates VE, Clark WM, et al Intravenous tissue-type plasminogen activator for treatment of acute stroke: the Standard Treatment with Alteplase to Reverse Stroke (STARS) study JAMA 2000 283(9):1145 50 10703776
780 Katzan IL, Furlan AJ, Lloyd LE, et al Use of tissue-type plasminogen activator for acute ischemic stroke: the Cleveland area experience JAMA 2000 283(9):1151 8 10703777
781 He J, Whelton PK, Vu B, et al Aspirin and risk of hemorrhagic stroke: a meta-analysis of randomized controlled trials JAMA 1998 280(22):1930 5 9851479
782 Johnson ES, Lanes SF, Wentworth CE, 3rd, et al A metaregression analysis of the dose-response effect of aspirin on stroke Arch Intern Med 1999 159(11):1248 53 10371234
783 Barnett HJ, Eliasziw M Aspirin benefit remains elusive in primary stroke prevention Arch Neurol 2000 57(3):306 8 10714652
784 Hart RG, Halperin JL, McBride R, et al Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses Arch Neurol 2000 57(3):326 32 10714657
785 CAST (Chinese Acute Stroke Trial) Collaborative Group.Lancet 1997 349(9066):1641 9 9186381
786 International Stroke Trial Collaborative Group.Lancet 1997 349(9065):1569 81 9174558
787 Yusuf S, Anand S, Avezum A, Jr., et al Treatment for acute myocardial infarction. Overview of randomized clinical trials Eur Heart J 1996 17Suppl F:16 29 8960444
788 Stroke Unit Trialists Collaboration.Stroke 1997 28(11):2139 44 9368554
789 Stegmayr B, Asplund K, Hulter-Asberg K, et al Stroke units in their natural habitat: can results of randomized trials be reproduced in routine clinical practice? Riks-Stroke Collaboration Stroke 1999 30(4):709 14 10187866
790 Langhorne P, Williams BO, Gilchrist W, et al Do stroke units save lives? Lancet 1993 342(8868):395 8 8101901
791 Gage BF, Boechler M, Doggette AL, et al Adverse outcomes and predictors of underuse of antithrombotic therapy in medicare beneficiaries with chronic atrial fibrillation Stroke 2000 31(4):822 7 10753982
792 Vanzetto G, Machecourt J, Blendea D, et al Additive value of thallium single-photon emission computed tomography myocardial imaging for prediction of perioperative events in clinically selected high cardiac risk patients having abdominal aortic surgery Am J Cardiol 1996 77(2):143 8 8546081
793 Baron JF, Mundler O, Bertrand M, et al Dipyridamole-thallium scintigraphy and gated radionuclide angiography to assess cardiac risk before abdominal aortic surgery [see comments] N Engl J Med 1994 330(10):663 9 8107716
794 Pilcher DB, Davis JH, Ashikaga T, et al Treatment of abdominal aortic aneurysm in an entire state over 7 1/2 years Am J Surg 1980 139(4):487 94 6892754
795 Poldermans D, Boersma E, Bax JJ, et al The effect of bisoprolol on perioperative mortality and myocardial infarction in high-risk patients undergoing vascular surgery. Dutch Echocardiographic Cardiac Risk Evaluation Applying Stress Echocardiography Study Group [see comments] N Engl J Med 1999 341(24):1789 94 10588963
796 Ghali WA, Ash AS, Hall RE, et al Statewide quality improvement initiatives and mortality after cardiac surgery JAMA 1997 277(5):379 82 9010169
797 Hannan EL, Stone CC, Biddle TL, et al Public release of cardiac surgery outcomes data in New York: what do New York state cardiologists think of it? Am Heart J 1997 134(6):1120 8 9424074
798 Hannan EL, Kilburn H, Jr., O'Donnell JF, et al Adult open heart surgery in New York State. An analysis of risk factors and hospital mortality rates JAMA 1990 264(21):2768 74 2232064
799 New Jersey Department of Health and Senior Services.
800 Higgins TL, Estafanous FG, Loop FD, et al Stratification of morbidity and mortality outcome by preoperative risk factors in coronary artery bypass patients. A clinical severity score Jama 1992 267(17):2344 8 1564774
801 Parsonnet V, Dean D, Bernstein AD A method of uniform stratification of risk for evaluating the results of surgery in acquired adult heart disease Circulation 1989 79(6 Pt 2):I3 12 2720942
802 Ottino G, Bergerone S, Di Leo M, et al Aortocoronary bypass results: a discriminant multivariate analysis of risk factors of operative mortality J Cardiovasc Surg (Torino) 1990 31(1):20 5 2324178
803 Stahle E, Bergstrom R, Holmberg L, et al Risk factors for operative mortality and morbidity in patients undergoing coronary artery bypass surgery for stable angina pectoris Eur Heart J 1991 12(2):162 8 2044549
804 Iyer VS, Russell WJ, Leppard P, et al Mortality and myocardial infarction after coronary artery surgery. A review of 12,003 patients Med J Aust 1993 159(3):166 70 8336616
805 Mathew JP, Parks R, Savino JS, et al Atrial fibrillation following coronary artery bypass graft surgery: predictors, outcomes, and resource utilization. MultiCenter Study of Perioperative Ischemia Research Group Jama 1996 276(4):300 6 8656542
806 Weightman WM, Gibbs NM, Sheminant MR, et al Drug therapy before coronary artery surgery: nitrates are independent predictors of mortality and beta-adrenergic blockers predict survival Anesth Analg 1999 88(2):286 91 9972742
807 Dziuban SW, Jr., McIlduff JB, Miller SJ, et al How a New York cardiac surgery program uses outcomes data Ann Thorac Surg 1994 58(6):1871 6 7979785
808 Rosenthal GE, Hammar PJ, Way LE, et al Using hospital performance data in quality improvement: the Cleveland Health Quality Choice experience Jt Comm J Qual Improv 1998 24(7):347 60 9689568
809 Burack JH, Impellizzeri P, Homel P, et al Public reporting of surgical mortality: a survey of New York State cardiothoracic surgeons Ann Thorac Surg 1999 68(4):1195 200 discussion 1201 2 10543479
810 Peterson ED, DeLong ER, Jollis JG, et al The effects of New York's bypass surgery provider profiling on access to care and patient outcomes in the elderly J Am Coll Cardiol 1998 32(4):993 9 9768723
811 Romano PS, Zach A, Luft HS, et al The California Hospital Outcomes Project: using administrative data to compare hospital performance Jt Comm J Qual Improv 1995 21(12):668 82 8688923
812 Osswald BR, Blackstone EH, Tochtermann U, et al The meaning of early mortality after CABG Eur J Cardiothorac Surg 1999 15(4):401 7 10371112
813 Office of Statewide Health Planning and Development.
814 New York Department of Health.
815 Le Roux P, Elliott J, Newell D, et al Predicting outcome in poor-grade patients with subarachnoid hemorrhage: a retrospective review of 159 aggressively managed patients J Neurosurg 1996 85(1):39 49 8683281
816 Stachniak JB, Layon AJ, Day AL, et al Craniotomy for intracranial aneurysm and subarachnoid hemorrhage. Is course, cost, or outcome affected by age? Stroke 1996 27(2):276 81 8571423
817 Solomon RA, Mayer SA, Tarmey JJ Relationship between the volume of craniotomies for cerebral aneurysm performed at New York state hospitals and in-hospital mortality Stroke 1996 27(1):13 7 8553389
818 Taylor CL, Yuan Z, Selman WR, et al Mortality rates, hospital length of stay, and the cost of treating subarachnoid hemorrhage in older patients: institutional and geographical differences J Neurosurg 1997 86(4):583 8 9120619
819 Lanzino G, Kassell NF, Germanson TP, et al Age and outcome after aneurysmal subarachnoid hemorrhage: why do older patients fare worse? J Neurosurg 1996 85(3):410 8 8751625
820 Whisnant JP, Sacco SE, O'Fallon WM, et al Referral bias in aneurysmal subarachnoid hemorrhage J Neurosurg 1993 78(5):726 32 8468603
821 Kreder HJ, Williams JI, Jaglal S, et al Are complication rates for elective primary total hip arthroplasty in Ontario related to surgeon and hospital volumes? A preliminary investigation Can J Surg 1998 41(6):431 7 9854532
822 Sharrock NE, Cazan MG, Hargett MJ, et al Changes in mortality after total hip and knee arthroplasty over a ten- year period Anesth Analg 1995 80(2):242 8 7818108
823 Dearborn JT, Harris WH Postoperative mortality after total hip arthroplasty. An analysis of deaths after two thousand seven hundred and thirty-six procedures J Bone Joint Surg Am 1998 80(9):1291 4 9759813
824 Whittle J, Steinberg EP, Anderson GF, et al Mortality after elective total hip arthroplasty in elderly Americans. Age, gender, and indication for surgery predict survival Clin Orthop 1993(295):119 26 8403635
825 Seagroatt V, Tan HS, Goldacre M, et al Elective total hip replacement: incidence, emergency readmission rate, and postoperative mortality Bmj 1991 303(6815):1431 5 1773147 1671663
826 Cleves MA, Golden WE Assessment of HCFA's 1992 Medicare hospital information report of mortality following admission for hip arthroplasty Health Serv Res 1996 31(1):39 48 8617608 1070102
827 Wroblewski BM, Siney PD, White R Fatal pulmonary embolism after total hip arthroplasty. Seasonal variation Clin Orthop 1992(276):222 4 1537157
828 Health Care Financing Administration.
829 Bartmus DA, Driscoll DJ, Offord KP, et al The modified Fontan operation for children less than 4 years old J Am Coll Cardiol 1990 15(2):429 35 2299084
830 Knott-Craig CJ, Danielson GK, Schaff HV, et al The modified Fontan operation. An analysis of risk factors for early postoperative death or takedown in 702 consecutive patients from one institution J Thorac Cardiovasc Surg 1995 109(6):1237 43 7776688
831 Fontan F, Fernandez G, Costa F, et al The size of the pulmonary arteries and the results of the Fontan operation J Thorac Cardiovasc Surg 1989 98(5 Pt 1):711 9 discussion 719 24 2811408
832 Cetta F, Feldt RH, O'Leary PW, et al Improved early morbidity and mortality after Fontan operation: the Mayo Clinic experience, 1987 to 1992 J Am Coll Cardiol 1996 28(2):480 6 8800129
833 Iannettoni MD, Bove EL, Mosca RS, et al Improving results with first-stage palliation for hypoplastic left heart syndrome J Thorac Cardiovasc Surg 1994 107(3):934 40 7510352
834 Gelatt M, Hamilton RM, McCrindle BW, et al Arrhythmia and mortality after the Mustard procedure: a 30-year single-center experience J Am Coll Cardiol 1997 29(1):194 201 8996314
835 Gentles TL, Mayer JE, Jr., Gauvreau K, et al Fontan operation in five hundred consecutive patients: factors influencing early and late outcome J Thorac Cardiovasc Surg 1997 114(3):376 91 9305190
836 Kaulitz R, Ziemer G, Luhmer I, et al Modified Fontan operation in functionally univentricular hearts: preoperative risk factors and intermediate results J Thorac Cardiovasc Surg 1996 112(3):658 64 8800153
837 Fontan F, Kirklin JW, Fernandez G, et al Outcome after a &quot;perfect&quot; Fontan operation Circulation 1990 81(5):1520 36 2331765
838 Kern JH, Hayes CJ, Michler RE, et al Survival and risk factor analysis for the Norwood procedure for hypoplastic left heart syndrome Am J Cardiol 1997 80(2):170 4 9230154
839 Vricella LA, Dearani JA, Gundry SR, et al Ultra fast track in elective congenital cardiac surgery Ann Thorac Surg 2000 69(3):865 71 10750774