# List of Acronyms

## List of acronyms and meanings used in the evidence report

AAA | Abdominal aortic aneurysm
ACG | Ambulatory Care Groups
ACSC | Ambulatory care sensitive conditions
ADE | Adverse drug events
ADL | Activities of Daily Living
AHCPR | Agency for Health Care Policy and Research
AHRQ | Agency for Healthcare Research and Quality
AMI | Acute myocardial infarction
APR-DRGs | All Patient Refined - Diagnosis Related Groups (developed by 3M™ Corporation)
CABG | Coronary artery bypass graft
CAD | Coronary artery disease
CCP | Cooperative Cardiovascular Project
CE | Carotid endarterectomy
CHF | Congestive heart failure
CONQUEST | Computerized Needs-oriented Quality Measurement Evaluation System
COPD | Chronic obstructive pulmonary disease
CPI | Consumer Price Index
CSI | Comprehensive Severity Index
C-section | Cesarean section
DEMPAQ | Develop and Evaluate Methods to Promote Ambulatory Care Quality (HCFA)
DNR | Do not resuscitate
DRG | Diagnosis Related Groups, developed by HCFA
DVT | Deep vein thrombosis
EPC | Evidence-Based Practice Center
GI | Gastrointestinal
HCFA | Health Care Financing Administration
HCUP | Healthcare Cost and Utilization Project
HEDIS | The Health Plan Employer Data and Information Set
HP 2000 or 2010 | Healthy People 2000 or 2010, developed by the Dept. of Health and Human Services
ICD-9-CM | The International Classification of Diseases, ninth revision, clinical modification
IRB | Internal review board
IT | Information technology
JCAHO | Joint Commission on Accreditation of Healthcare Organizations
LC | Laparoscopic cholecystectomy
MEDPAC | Medicare Payment Advisory Commission
MeSH | Medical Subject Headings (developed by National Library of Medicine for Medline)
MDC | Major Diagnostic Category
MSA | Metropolitan Statistical Area
MSX | Multivariate Signal Extraction
NCQA | National Committee on Quality Assurance
NIS | Nationwide Inpatient Sample
NLHI | National Library of Healthcare Indicators
OLS | Ordinary Least Squares (regression)
OMD | Optimal minimal distance
ORYX™ | Trademark name used by JCAHO for a set of hospital performance measures
OSHPD | Office of Statewide Health Planning and Development, State of California
PID | Pelvic Inflammatory Disease
PIP-DCG | Principal Inpatient Diagnostic Cost Groups, developed by HCFA
PPV | Positive predictive value
PTCA | Percutaneous transluminal coronary angioplasty
QI | Quality Indicators
RCT | Randomized controlled trial
SAS™ | formerly, Statistical Analysis System (distributed by the SAS Corporation)
SEER | Surveillance, Epidemiology, and End Results
SPSS™ | formerly, Statistical Package for Social Scientists (distributed by the SPSS Corporation)
UB-92 | Uniform Billing form 92, developed by HCFA
UCSF | University of California, San Francisco
UR | Uterine rupture
UTI | Urinary tract infection
VAR | Vector autoregression structure
VBAC | Vaginal birth after cesarean section