# Literature Tables for Utilization and ACSC Indicators

This appendix summarizes the literature reviews for area utilization and ACSC indicators in table format.

Table 1A. Studies of appropriateness of specific procedures. This table summarizes the studies used to identify area utilization indicators.

Tables 2A-6A. These tables summarize studies of ACSC indicators. Table 2A identifies the studies and designs. Table 3A lists the ACS conditions examined in each study. Tables 4A-6A list pediatric avoidable hospitalizations, infant discretionary hospitalizations, and late hospitalization indicators examined by each study.

Table 3A focuses on conditions for which the risk of hospitalization can be reduced, either through better outpatient management of chronic diseases (e.g., asthma, CHF, diabetes) or through more timely diagnosis and effective treatment of acute conditions (e.g., pneumonia, UTI, cellulitis). This is the best validated of the 4 constructs, and is the basis for all of our selected indicators.

Table 4A includes "conditions for which evidence exists that specific ambulatory care modalities reduce hospitalization rates." This category differs from #1 in that it is more sharply focused on defects in ambulatory care, such as a lack of prior outpatient visits or antibiotic prescriptions. There is some overlap between this list and #1 (e.g., asthma, gastroenteritis, DKA, severe ENT infections, PID), although the definitions often differ slightly. Some of these indicators cannot be implemented without linked outpatient claims.

Table 5A focuses on conditions "for which the decision to admit involves a substantial amount of physician judgment...have a wide range in severity and are often managed at home." This concept seems somewhat less relevant to discussions about quality of care.

Table 6A focuses on conditions "whose advanced stages are presumed to have a greater likelihood of reflecting untimely hospital admissions" (because earlier admission would have prevented progression to the advanced stage). This concept relates to the timeliness of hospitalization and the appropriateness of inpatient care, more than to the timeliness and effectiveness of outpatient care.

Table 1A. Studies of appropriateness of specific procedures

Procedure | % inappropriate | % uncertain | Source of population | # of patients evaluated
Carotid Endarterectomy^ 1 ^ | 18% (51/281) overall; neurosurgery 14% vs. non-neurosurgery 21%; varied from 0% to 33% among surgeons (P = 0.07) | 49% (138/281) overall, decreased to 45% after adjusting for benefit of CEA for severe symptomatic disease found in NASCET; 40% neurosurgery vs. 55% non-neurosurgery; varied from 33% to 67% across surgeons (P=.26) | All in Edmonton, Alberta, Canada | 291 cases of CEA performed on 265 patients between April 1994 and Sept 1995, from nine surgeons at four teaching hospitals (2 were tertiary-care centers); excluded patients without angiograms (10)
Carotid Endartectomy^ 24 ^ *follow up to above study | 4% (8/184) | 47% (84/184) | All in Edmonton, Alberta, Canada | 184 patients with CEA between 9/1/96 and 8/31/97 were evaluated after results of previous study, CEA guidelines and notification of possible surveillance were distributed to all surgeons performing CEA in Edmonton
Carotid Endarterectomy^ 2 ^ | Definition A (low risk of stroke/death):~55% Definition B: ~5% Definition C:~5% | Definition A (low risk of stroke/death): ~12% Definition B: ~37% Definition C:~14% | Twelve academic medical centers | 1160 randomly selected patients with CEA from 1988-1990 (with the exception of one hospital which included 1987 data), miscoded charts were excluded
Carotid Endarterectomy^ 3 ^ | 32% overall; varied from 29% to 40% among sites | 32% overall; varied from 29% to 34% among sites | 5 sites of varying utilization for the 3 procedures selected from Medicare claims submitted by physicians in Arkansas, Colorado, Iowa, Mass., Montana, Penn., S. Carolina, and N. Calif. | Random sample of Medicare beneficiaries for each procedure (claims submitted in 1981) at each site (high, average, and low use geographic areas)
Carotid Endarterectomy^ 4 ^ | Varied by county from 0% - 67% | No discussion of equivocal indication | 23 adjacent rural and urban, large and small, counties in one large, populous state | Sampled procedures by Medicare billing codes performed on 600 CEA patients in 1981, aged 65 years and older
Carotid Endarterectomy^ 22 ^ | 3.9% characterized as inappropriate; study considered CEA inappropriate if the case was "uncertain" or "proven inappropriate". | | 1993 Medicare admissions in Georgia w/procedure code for CEA | 1945 CEAs performed on Medicare recipients in GA in 1993
Cataract Surgery^ 5 ^ | 2% (15/723) overall; varied from 0% to 6% by institution | 8% (359/723) overall; varied from 0% to 15% by institution | Ten Academic Medical Centers | 1139 randomly selected until approx. 130 patients at each facility w/cataract surgery in 1990 were obtained; patients receiving other ocular surgery performed at the same time as cataract surgery or with specific ICD-9 CM or CPT-4 were excluded
Cholecystectomy^ 6 ^ | 12% overall; varied from 6%-14% (p=.002) among hospitals | 17% overall; varied from 9%-24% (p=.002) among hospitals | Four Israeli hospitals belonging to the General Sick Fund (provides prepaid healthcare to 76% of Israeli population) | 816 patients identified as having undergone cholecystectomy in 1986; 702 records were located and evaluated; complete clinical info was obtained on 657 patients
Colonoscopy^ 7 ^ | 27.8% (110/553) by ASGE criteria; 31.5% (170/553) by US 94 criteria; 25.6% (138/553) by Swiss 94 criteria | No rating for ASGE; 10.9% (59/553) by US 94 criteria; 11.6% (63/553) by Swiss 94 criteria | Two university-based multi-specialty outpatient clinics in Lausanne and Basel, Switzerland | 553 consecutive patients referred by the outpatient clinics for colonoscopy, aged >15 from January 1995 to September 1995 (Lausanne) and January 1995 to July 1995 (Basel)
Coronary Angiography^ 26 ^ | 7% (1/14) of blacks; 10% (4/41) whites who underwent angiography | 50% (7/14) of blacks; 46.3% (19/41) whites who underwent angiography | Department of Veterans Affairs | 200 (100 white and 100 black) VA inpatients discharged between 1/193 and 12/1/93 with primary dx of cardiovascular disease or chest pain
Coronary Angiography^ 8 ^ | 6% overall; no difference across subgroups | 16% overall; no difference across subgroups | Harvard Community Health Plan (HCHP), Brookline Mass; mixed model HMO | 292 HCHP enrollees with coronary angiography in 1992; stratified into four subgroups
Coronary Angiography^ 9 ^ | 21% overall | 30% overall | Trent region; coronary angiography is done in 3 referral centers and CABG in 2 centers. | random sample of 320 patients with coronary angiography between 2/1/87 and 5/30/88. Exclusions: incomplete records, congenital heart disease, transplant, primary valve disease.
Coronary Angiography^ 3 ^ | 17% overall; varied from 15%-18% among sites | 9% overall; varied from 4%-10% among sites | 5 sites of varying utilization for the 3 procedures selected from Medicare claims submitted by physicians in Arkansas, Colorado, Iowa, Mass., Montana, Penn., S. Carolina, and N. Calif. | Random sample of Medicare beneficiaries for each procedure (claims submitted in 1981) at each site (high, average, and low use geographic areas)
Coronary Angiography^ 4 ^ | Varied by county from 8%-75% | no discussion of equivocal indication | 23 adjacent rural and urban, large and small, counties in one large, populous state | Sampled procedures by Medicare billing codes performed on 600 CA patients in 1981, aged 65 years and older
Coronary Angiography^ 10 ^ | Canadian Criteria Canadian sample: 9.0% (95% CI, 6.6%-11.4%) New York sample: 10.2% (95% CI, 8.5%-11.8%) US Criteria Canadian sample: 5.1% (95% CI, 3.2%-6.9%) New York sample: 4.2% (95% CI, 3.4%-6.9%) | Canadian Criteria Canadian sample: 33.2% (95% CI, 29.2%-37.2%) New York sample: 39.1 (95% CI, 35.1%-43.1%) US Criteria Canadian sample: 18.2% (95% CI, 14.9%-21.5%) New York sample: 20.1% (95% CI, 18.4%-21.8%) | All hospitals performing CA and CABG in Ontario and British Columbia; 15 randomly selected hospitals that provide CA in New York State; 15 randomly selected hospitals that provide CABG in New York State | 553 randomly selected patients in Canada, 1333 randomly selected patients in New York. New York patients had procedures performed in 1990; Canadian patients had procedures performed between 4/89 and 3/90. Cases performed primarily for valve surgery were excluded
Coronary Angiography^ 11 ^ | 4% overall; varied from 0% - 9% among hospitals (NS) | 20% overall; varied from 13%-31% among hospitals (NS) | 15 randomly selected, non federal hospitals in New York State providing coronary angiography | Random sample of 1335 patients undergoing angiography in New York State in 1990, distributed across the 15 hospitals
CABG^ 12 ^ | 6% (5/85), compared to 1/85 identified by the original panel of NY cardiologists | 12% (10/85), compared to 1/85 identified by the original panel of NY cardiologists | A follow-up to the above study was done using a sub-sample of the patients. A panel of Duke University cardiologists reviewed 308 records for appropriateness
CABG^ 13 ^ | 1.6% (95% CI, 0.6% - 2.5%) overall; increased to 1.9% when revised by Consortium surgeons. Varied from 0% to 5% across hospitals (P=0.02) (NS) | 7% (95% CI, 5%-8%) overall; did not vary significantly across hospitals | All 12 Academic Medical Center Consortium hospitals | 1156 patients w/CABG surgery in 1990 w/o previous CABG or concurrent valve replacement surgery, randomly selected consecutively until 100 records were obtained from each facility
CABG^ 14 ^ | 2.4% (95% CI, 2% - 3%) overall; varied from 0% to 5% among hospitals (NS) | 7% (95% CI, 5%-9%) overall; varied from 3% to 15% among hospitals (NS) | 15 randomly selected, non federal hospitals in New York State providing CABG surgery | Random sample of 1338 patients undergoing isolated CABG in NY in 1990; those undergoing another major procedure in conjunction with CABG (55) were excluded; records missing critical data (13) were also excluded
CABG^ 9 ^ | 16% overall | 26% overall | Trent region; coronary angiography is done in 3 referral centers and CABG in 2 centers. | 319 randomly selected patients with CABG between 7/1/87 and 6/31/88. Exclusions: incomplete records, congenital heart disease, transplant, primary valve disease
CABG^ 10 ^ | Canadian Criteria Canadian sample: 3.6% (95% CI, 2.0%-5.1%) New York sample: 5.5% (95% CI, 4.0%-7.1%) US Criteria Canadian sample: 2.5% (95% CI, 1.2%-3.8%) New York sample: 2.4% (95% CI, 1.6%-3.1%) | Canadian Criteria Canadian sample: 11.3% (95% CI, 8.7%-14.0%) New York sample: 9.9% (95% CI, 8.4%-11.4%) US Criteria Canadian sample: 9.0% (95% CI, 6.6%-11.4%) New York sample: 7.0% (95% CI, 5.1%-9.0%) | All hospitals performing CA and CABG in Ontario and British Columbia; 15 randomly selected hospitals that provide CA in New York; 15 randomly selected hospitals that provide CABG in New York | 556 randomly selected CABG patients in Canada, 1336 randomly selected CABG patients in New York. New York patients had procedures performed in 1990; Canadian patients had procedures performed between 4/89 and 3/90. Cases performed primarily for valve surgery were excluded
CABG (referral after Coronary Angiography)^ 16 ^ | 9.7% overall | 12.3% overall | Seven of eight public Swedish heart centers. (perform 92% of all bypass surgeries in Sweden) | Consecutive series of 2767 patients with coronary angiography between 5/94 and 1/95 who were considered for coronary revascularization
CABG^ 15 ^ | RAND criteria: 42% ACC/AHA criteria:17% RAS criteria: 46% | RAND criteria: 17% ACC/AHA criteria:no rating RAS criteria: no rating | An academic medical center cardiac catheterization laboratory and a VA cardiac catheterization lab in Maryland | 153 catheterization patients referred to a either Univ. of Maryland Cardiac Catheterization Lab and/or Baltimore VA Medical Center Cardiac Catheterization Lab with a variety of cardiac diagnoses and treatments between 3/93 and 10/94
PTCA^ 15 ^ | RAND criteria: 22% ACC/AHA criteria: 49% RAS criteria: 35% | RAND criteria: 29% ACC/AHA criteria: no rating RAS criteria: no rating | An academic medical center cardiac catheterization laboratory and a VA cardiac catheterization lab in Maryland | 153 catheterization patients referred to a either Univ. of Maryland Cardiac Catheterization Lab and/or Baltimore VA Medical Center Cardiac Catheterization Lab with a variety of cardiac diagnoses and treatments between 3/93 and 10/94
PTCA (referral after Coronary Angiography)^ 16 ^ | 38.3% overall | 30.0% overall | Seven of eight public Swedish heart centers. (perform 92% of all bypass surgeries in Sweden) | Consecutive series of 2767 patients with coronary angiography between 5/94 and 1/95 who were considered for coronary revascularization
PTCA^ 12 ^ | 12% (11/95), compared to 9/95 identified by the original panel of NY cardiologists | 27% (26/95), compared to 23/95 identified by the original panel of NY cardiologists | A follow-up to reference 11 was done using a sub-sample of the patients. A panel of Duke University cardiologists reviewed 308 records for appropriateness
Diagnostic testing for Coronary Artery Disease^ 17 ^ | 3% (7/215) overall | 39% (42/109) overall | Five urban Los Angeles area hospital emergency departments, 2 public, 1 private NFP, 1 university med. ctr., 1 NFP HMO | 356 patients with chest pain not due to myocardial infarction or history of cardiac disease between Oct 94 and Apr 96. Those not receiving ECG during initial eval were excluded
Hip Joint Replacement^ 25 ^ | 8.3% (86/997) overall; 6.7% - 16.3%. for osteoarthritis, 0% - 25.0% for avascular necrosis, 0% for fracture and revision | 32.4% (334/997) overall; 42.3%-50.0% for osteoarthritis, 0%- 50.0% for avascular necrosis, 9.6%-40.0% for fracture, 3.4%-18.9% for revision | 5 large public hospitals (4 university affiliated, 1 community-based) | 997 patients with osteoarthritis, avascular necrosis, hip fracture, or revision who were undergoing HJR between 12/96 and 12/97
Hip and Knee Joint Replacement^ 21 ^ | High-rate region: 6.1% Low-rate region: 6.4% Rated by subspecialists High-rate region: 11.4% Low-rate region: 11.0% | Not evaluated | 7 high-rate region hospitals: 3 university affiliated, 4 community 8 low-rate region hospitals: 5 university affiliated, 3 community | 371 patients in the high rate region and 565 in the low rate region with surgery performed between 4/1/92 and 3/31/93 without fracture or other indication, and < 60 years old
Hysterectomy^ 18 ^ | 16% overall; varied across plans from 10% to 27% | 25% overall | Seven managed care organizations | Random sample of 642 hysterectomies (non-emergency and non-oncological) between 8/1/89 and 7/31/90, among women enrolled in a health plan 2 years prior to surgery
Hysterectomy^ 23 ^ | 70% (367/497); varied from 45% to 100% across diagnoses indicative of hysterectomy | Not evaluated | Nine capitated medical groups in Southern California | 497 women receiving hysterectomy between 8/93 and 7/95 in one of nine capitated medical groups in S. California
Laminectomy^ 19 ^ | 23% | 29% | One Swiss University hospital | 196 patients with surgical treatment for herniated discs
Lumbar Discectomy and Spinal Stenosis surgery^ 20 ^ | 38% (126/328) | Combined with "appropriate" category | Two university neurosurgery departments | 328 consecutive patients undergoing surgery for Lumbar Disc Hernia of Spinal Stenosis at hosp A from 4/92-10/92 and at hosp B from 5/93-9/93. Patients with neoplasms were excluded
Upper GI Tract endoscopy^ 3 ^ | 17% overall; varied from 15% to 19% among sites | 11% overall; varied from 8% to 14% among sites | 5 sites of varying utilization for the 3 procedures selected from Medicare claims submitted by physicians in Arkansas, Colorado, Iowa, Mass., Montana, Penn., S. Carolina, and N. Calif. | Random sample of Medicare beneficiaries for each procedure (claims submitted in 1981) at each site (high, average, and low use geographic areas)
Upper GI Tract endoscopy^ 4 ^ | Varied by county from 0%-25% | Not evaluated | 23 adjacent rural and urban, large and small, counties in one large, populous state | Sampled procedures by Medicare billing codes performed on 614 UGI patients in 1981, aged 65 years and older

Table 2A. Studies of ACSC indicators

Study | Payer | Level | Validating variables
Begley, 1994 | all | area (city/state) | none
Bierman, 2000 | all | person | income (area, all), Medicaid (asthma, diabetes), race (asthma, diabetes), race (asthma, diabetes)
Billings, 1993 | all | area (zip code) | income, race (diagnosis-specific findings in Billings, 1992)
Billings, 1996 | all and Canadian health system | area (zip code) | Income, national health insurance
Bindman, 1995 | all | area (zip code cluster/MSSA) | self-rated access (all, but strongest for asthma, CHF, DM), income, education, uninsured, Medicaid
Blustein, 1998 | Medicare | person | education, income, usual source of care, race, supplemental Medicaid or other insurance, prior physician visits
Casanova, 1995 | Spanish national health system | person | illiteracy (area), unemployment (area), income (area), school enrollment (area), availability of health center, availability of pediatrician
Casanova, 1996 | Spanish national health system | person | family income, paternal/maternal employment, social class, paternal/maternal education, prior physician visit, pediatrician
Claudio, 1999 | all | area | income, % minority, % children under 18, lack of access to preventative health care, poor housing conditions, environmental exposures, genetic suseptibility
Connell, 1984 | Medicare and Medicaid | hospitalization | reside in nursing home, payment source, quality of care (appropriate diagnostic tests, use of IV insulin)_
Culler, 1998 | Medicare | person | race, education, living alone/with spouse, income, supplemental Medicaid or other insurance, problems obtaining care, health professional shortage area, core SMSA or rural county
Djojonegoro 2000 | all | area (zip code) | income, race (person)
Gadomski, 1998 | Medicaid | person/quarter | enrollment in Maryland Access to Care (Medicaid managed care with gatekeeper), SSI or AFDC recipients, urban residence, race
Gill, 1997 | Medicaid | person | regular source of care, regular care from primary care physician
Gill, 1998 | Medicaid | person | continuity index (function of number of ambulatory visits and unique providers)
Giuffrida, 1999 | English Health Services Area | area | supply of secondary care (physicians, hosp beds), morbidity measures (limiting l.t. illness, permanently sick), socioeconomic characteristics (pop density, unemploy, no central heating, crowded accomodations, no car, new commonwealth, retired living alone, students, social class 1 & 2, pop mobility), year
Kaestner, 2000 | all | hospital-income category -year | income
Krakauer, 1996 | Medicare | area (HCSA) | race/ethnicity, supplemental Medicaid or HMO coverage, urban residence, income, unemployment, active, generalist, med spec, & surg spec MD/pop ratio, generalists/MD, med spec/MD, surg spec/MD
Laditka, 1999 (JWA) | Medicare | area (hospital market area) | income
Laditka, 1999 (JHSP) | Medicaid | area (hospital market area) | Medicaid proportion
McConnochie1997 | all | area (zip code) | inner city or "other urban" residence (person), late prenatal care, maternal education, uninsured, Medicaid, race, unemployment, lack of telephone/automobile, childhood poverty
Millman, 1993 | all | area | income (all except congenital syphilis, immunization/preventable, dental; gastroenteritis O:E<2)
O' Sullivan 1996 | all | area | geographic region, insurance status
Pappas, 1997 | all | person | race, income (area), uninsured, Medicaid)
Parchman, 1994 | all | area, (HSA) | FP-GP/pop ratio, gen IM/pop ratio, gen ped/pop ratio, income
Parchman, 1999 | Medicare | person | primary care shortage area, supplemental Medicaid, income, race, education, marital status
Rohrer, 1997 | all | area | geographic region
Schreiber, 1997 | all | area (zip code) | poverty, race, pop density, primary care MD/pop ratio, health professional shortage area, proximity to hospital
Shi, 1999 | all | person | race, income (area), non-MSA, primary care MD, uninsured, Medicare/Medicaid
Shukla, 1997 | all | person | race (all conditions), insurance type (diabetes, hypertension, asthma), localities
Silver, 1997 | Medicare | area (county) | rural regions of Utah (0/4 anemia, 2/4 asthma, 4/4 cellulitis, 2/4 CHF, ¼ DM, ¾ gastric, 2/4 hypertension, 4/4 pneumonia
Solet, 2000 | all | area | income/ poverty status
Taroni, 1997 | Italian health system | area (local health unit) | low overall hospital use
Weissman, 1992 | all | person | uninsured (0/2 rupt appendix, ½ asthma, 2/2 cellulitis, ½ CHF, 2/2 DM, 2/2 gangrene,½ hypokalemia, ½ immunizable, 2/2 malig. htn. 2/2 pneumonia, ½ pyelo, 2/2 ulcer), Medicaid, race

Table 3A. Studies of ACSC indicators

Study | | Acute Myocardial Infarction | Acute Poliomyelitis | Anemia, Iron deficiency | Anemia, any | Angina | Asthma | Asthma & bronchitis | Cellulitis or abscess | Cellulitis, or other soft tissue infection | Cellulitis, abscess, lymphadenitis | Cellulitis with skin graft | Chest pain | Congestive heart failure | CHF (plus pulmonary edema) | CHF and shock | Congenital syphilis | Convulsions 'A' & 'B' | COPD | Dehydration/volume depletion | Dental conditions | Diabetes A | Diabetes B | Diabetes C | Diabetes w/ketoacidosis or coma | Diabetes, Uncontrolled | Diabetes with complications | Diabetes, all | Epilepsy or grand mal status | Failure to thrive | Gangrene | Gastroenteritis | Gastrointestinal hemorrhage, upper | High risk/complicated delivery | Hypertension | Hypertension, malignant | Hypoglycemia | Hypokalemia | Immunizable conditions | Immunization- related or preventable | Immunization- preventable pneumonia | Invasive cervical cancer | Kidney/UTI | Low infant birth weight | Malignant neoplasm of female breast | Measlres | Mumps | Nutritional Deficiency | Otitis Media | Pelvic Inflammatory Disease | Perforated or Bleeding Ulcer | Pneumonia, bacterial (outpatient treatable) | Pneumonia, bacterial (any) | Pneumonia or pleurisy | Pneumonia, Bronchitis, Bronchiolotis, Pharyngitis | Pneumonia, sinsusitis | Pyelonephritis | Respiriatory infections (including pulmonary TB) | Rheumatic fever | Ruptured appendix | Severe ENT infection | Stroke with hypertension | TB, other | TB, pulmonary
Begley, 1994 | Adult Peds Adult & Peds | X | | | | | X | | | | | | | | X | | | X | X | | | | | | | | X | | X | | | | | | | | X | | | X | | | | | | | | | | | | | | | | X | X** | | | | | X
Bierman, 2000 | Adult Peds Adult & Peds | | | | | | X | | | | | | | | | | | | | | | | | | | X | | | | | | | | | | | | | | | X
Billings, 1993 | Adult Peds Adult & Peds | | | X | | X X | X X | | | | X X | X X | | | X X | | X | X X | X X | X X | X X | X X | X X | X X | | | | | X X | X | | X X | | | X X | | X X | | | X X | | | X X | | | | | X X | | X X | | X X | | | | | | | | | X X | | X X | X X
Billings, 1996 | Adult Peds Adult & Peds | | | X | | X | X | | | | X | X | | | X | | X | X | X | X | X | X | X | X | | | | | X | X | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | | X | X
Bindman, 1995 | Adult Peds Adult & Peds | | | | | | X | | | | | | | | X | | | | X | | | X | X | X | | | | | | | | | | | X
Blustein, 1998 | Adult Peds Adult & Peds | | | | | X | X | | | | X | X | | | X | | | | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | X | | | X | | | | | X | | X | | | | | | | | | | | X | | X | X
Casanova, 1995 | Adult Peds Adult & Peds | | | X | | X | X | | | | X | | | | X | | X | X | X | X | X | X | X | X | | | | | X | X | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | | X | X
Casanova, 1996 | Adult Peds Adult & Peds | | | X | | X | X | | | | X | | | | X | | X | X | X | X | X | X | X | X | | | | | X | X | | X | | | X | | X | | | X | | | X | | | | | X | | | | X | | | | | | | | | X | | X | X
Claudio, 1999 | Adult Peds Adult & Peds | | | | | | X
Connell, 1984 | Adult Peds Adult & Peds | | | | | | | | | | | | | | | | | | | | | | | | | | | X
Culler, 1998 | Adult Peds Adult & Peds | | | | | X | X | | | | X | X | | | X | | | X | X | X | | X | X | X | | | | | X | | | X | | | X | | X | | | | | | X | | | | | | | | | X | | | | | | | | | X
Djojonegoro 2000 | Adult Peds Adult & Peds | | | X | | X | X | | | | | | | | X | | X | X | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | X | X | X
Gadomski, 1998 | Adult Peds Adult & Peds | | | X | | | X | | | | X | | | | | | X | X | | X | | X | X | X | | | | | X | X | | X | | | | | X | | | X | | | X | | | | | X | | | | X | | | | | | | | | X | | X | X
Gill, 1997 | Adult Peds Adult & Peds | | | | | X | X X | | | | X | X | | | X X | | | | X X | X | | X X | X X | X X | | | | | | | | X | | | X X | | X | | | | | | | | | | | | | | | | X | | | | | | | | X
Gill, 1998 | Adult Peds Adult & Peds | | | | | X | X | | | | X | | | | X | | | X | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | | | | | | | | | | | | | | X | | | | | | | | X
Guiffrida, 1999 | Adult Peds Adult & Peds | | | | | | X
Kaestner, 2000 | Adult Peds Adult & Peds | | | | | | | | | | | | | | | | | X | | X | | | | | | | | | | X | | X
Krakauer, 1996 | Adult Peds Adult & Peds | | | | | X | X | | | | X | X | | | X | | | | X | X | | X | X | X | | | | | | | | X | | | X | | X | | | | | | X | | | | | | | | | X
Laditka, 1999 (JWA) | Adult Peds Adult & Peds | | | | | X | X | | | | X | X | | | X | | | X | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | | X | X
Laditka, 1999 (JHSP) | Adult Peds Adult & Peds | | | X | | X X | X X | | | | X X | X X | | | X X | | | X X | X X | X X | X X | X X | X X | X X | | | | | X X | X | | X X | | X | X X | | X X | | | X X | | | X X | | | | | X X | | X X | | X X | | | | | | | | | X X | | X X | X X
McConnochie1997 | Adult Peds Adult & Peds | | | | | | | | | | | | | | | | | X | | X | | | | | | | | | | X | | X
Millman, 1993 | Adult Peds Adult & Peds | | | | | X | X | | | | X | X | | | X | | X | X | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | X | | | X | | | | | | | | | X | | | | | | | | | X
O'Sullivan, 1996 | Adult Peds Adult & Peds | | | X | | X | X | | | | X | X | | | X | | | X | X | X | X | X | X | X | | | | | X | | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | | | X
Pappas, 1997 | Adult Peds Adult & Peds | | | | | | X | | X | | | | | X | | | | | | | | | | | X | | | | | | X | | | | | X | | X | X | | | | | | | | | | | | X | | X | | | | X | | | X
Parchman, 1994 | Adult Peds Adult & Peds | | | | | X | X | | | | | | | | X | | | | | | | X | X | X | | | | | | | | | | X | | | | | | | | | | | | | | | | | | X X
Parchman, 1999 | Adult Peds Adult & Peds | | | | | X | X | | | | X | | | | X | | | X | X | X | | X | X | X | | | | | X | | | X | | | X | | X | | | | | | X | | | | | | | | | X | | | | | | | | | X
Rohrer, 1997 | Adult Peds Adult & Peds | | | | | X | | X | X | | | | X | | | X | | | X | | | | | | | | | X | | | | | | | X | | | | | | | | | | | | | | X | | | | | X | | | | X
Schreiber, 1997 | Adult Peds Adult & Peds | | | X | | X | X | | | | X | X | | | X | | X | X | X | X | X | X | X | X | | | | | X | X | | X | | | X | | X | | | X | | | X | | | | | X | | X | | X | | | | | | | | | X | | X | X
Shi, 1999 | Adult Peds Adult & Peds | | | X | | X X | X X | | | | X X | X X | | | X | | X | X X | X | X X | X X | X X | X X | X X | | | | | X X | X | | X X | | | X | | X | | | X X | | | X X | | | | | X X | | X | | X X | | | | | | | | | X X | | X X | X X
Shukla, 1997 | Adult Peds Adult & Peds | | X | | | | X | | | | | | | | | | | | | | | | | | | X | | | | | | | | | X | | | | | | | X | | X | X | X | X | | | | | | | | | | | | X | | | | | X X*
Silver, 1997 | Adult Peds Adult & Peds | | | | X | | X | | | X | | | | X | | | | | | | | | | | | | | X* | | | | | X | | X# | | | | | | | | | | | | | | | | | | | | X
Solet, 2000 | Adult Peds Adult & Peds | | | | | | X
Taroni, 1997 | Adult Peds Adult & Peds
Weissman, 1992 | Adult Peds Adult & Peds | | | | | | X X | | X X | | | | | X X | | | | | | | | | | | X X | | | | | | X X | | | | | X X | | X X | X X | | | | | | | | | | | | X X | | X X | | | | X X | | | X X

*Removed "diabetes mellitus without mention of complication, not stated as uncontrolled"Includes other respiratory TB (01)

# Added benign hypertension and hypertensive renal failure

** Separate indicators for pregnancy (646.6+590.1) and others (590.1); removed chronic or NOS pyelonephritisIncludes other respiratory TB (012)

Table 4A. Studies of ACSC Indicators- Pediatric Avoidable Hospitalizations

Study | Acute Ottisis Media | Acute pyelonephritis | Asthma | Bronchitis | Burns | Congenital Lower Bowel Obstruction*** | Diabetic ketoacidosis | Gastroenteritis | Hypernatremic*** | Immunizable Diseases | Jaundice*** | Mastoiditis | Nausea and Vomiting | Obstuctive Cardiac Defects*** | PID | Upper Respiratory Infection | UTI | Viral Meningitis | Viral Syndrome | Volume depletion***
Gadomski, 1998 | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X | X

*** Infant readmission within 2 weeks of DOB

Table 5A. Studies of ACSC Indicators-Discretionary Hospitalization of Infants

Study | Croup/Tracheitis | Failure to Thrive | Fever, acute unexplained | Gastroenteritis/ Dehydration | Gastrointestinal disorders, other | Lower Respiratory Illness | Nonspecific signs and symptoms | Seizure w/o intractactable mentioned | UTI | Viral Meningitis
Kaestner, 2000 | X | X | X | X | X | X | X | X | X | X
McConnochie, 1997 | X | X | X | X | X | X | X | X | X | X

Table 6A. Studies of ACSC Indicators- Late Hospitalization

Study | Appendicitis | Diverticular disease | Hernia, External | Peptic Ulcer | Pneumonia, bacterial | Uterine Fibroma
Taroni, 1997 | X | X | X | X | X | X

1 Wong JH, Findlay JM, Surez-Alamazor ME. Regional performance of Carotid Endarterectomy. Stroke. 1997;28:891-898. [pmid: 9158621].
2 Matchar DB, et al Influence of projected complication rates on estimated appropriate use rates for carotid endarterectomy HSR. 1997 32(3):325 342 9240284
3 Chassin MR, et al. Does inappropriate use explain geographic variations in the use of health care services: A study of three procedures. JAMA. 1987;258:2533-2537. [pmid: 3312655].
4 Leape LL, et al. Does inappropriate use explain small -- area variations in the use of health care services?. JAMA. 1990;236:669-672.
5 Tobacman JK, et al. Assessment of appropriateness of cataract surgery at ten academic medical centers in 1990. Ophthalmology. 1996;103:207-215. [pmid: 8594503].
6 Pilpel D, Fraser GM, Kosecoff J, Weitzman S, Brook RH. Regional differences in appropriateness of cholecystectomy prepaid health insurance system. Public Health Rev. 1992/93;20:61-74. [pmid: 1305979].
7 Froehlich F, et al. Performance of panel-based criteria to evaluate the appropriateness of colonoscopy: A prospective study. Gastrointest Endosc. 1998;48:128-36. [pmid: 9717777].
8 Noonan SJ, et al. Relationship of anatomic disease to appropriateness ratings of coronary angiography. Arch Intern Med. 1995;155:1209-1213. [pmid: 7763127].
9 Gray D, Hampton JR, Bernstein SJ, Kosecoff J, Brook RH. Audit of coronary angiography and bypass surgery. Lancet. 1990;335:1317-1320. [pmid: 1971385].
10 McGlynn EA, et al. Comparison of the appropriateness of coronary angiography and coronary artery bypass graft surgery between Canada and New York State. JAMA. 1994;272:934-940. [pmid: 8084060].
11 Bernstein SJ, et al. The appropriateness of use of coronary angiography in New York State. JAMA. 1993;269:766-769. [pmid: 8423658].
12 Leape LL, et al. Effect of variability in the interpretation of coronary angiograms on the appropriateness of use of coronary revascularization procedures. Am Heart J. 2000;139:106-113. [pmid: 10618570].
13 Leape LL, et al. The appropriateness of Coronary Artery Bypass Graft surgery in academic medical centers. Ann Intern Med. 1996;125:8-18. [pmid: 8644996].
14 Leape LL, et al. The appropriateness of use of Coronary Artery Bypass Graft surgery in New York state. JAMA. 1993;269:753-760. [pmid: 8423656].
15 Ziskind AA, Lauer MA, Bishop G, Vogel A. Assessing the appropriateness of coronary revascularization: The University of Maryland Revascularization Appropriateness Score (RAS) and its comparison to RAND expert panel ratings and American College of Cardiology/American Heart Association guidelines with regard to assigned appropriateness rating and ability to predict outcome. Clin Cardiol. 1999;22:67-76. [pmid: 10068842].
16 Bernstein SJ, Brorsson B, Aberg T, Emanuelsson H, Brook RH, Werko L. Appropriateness of referral of coronary angiography patients in Sweden. Heart. 1999;81:470-477. [pmid: 10212163].
17 Carlisle DM, et al. Underuse and overuse of diagnostic testing for coronary artery disease in patients presenting with new-onset chest pain. Am J Med. 1999;106:391-398. [pmid: 10225240].
18 Bernstein SJ, et al. The appropriateness of hysterectomy: A comparison of care in seven health plans. JAMA. 1993;269:2398-2402. [pmid: 8479066].
19 Porchet F, Vader JP, Larequi-Lauber T, Costanza MC, Burnand B, Dubois RW. The assessment of appropriate indications for laminectomy. J Bone Joint Surg [Br]. 1999;81-B:234-239. [pmid: 10204927].
20 Larequi-Lauber T, et al. Appropriateness of indications for surgery of Lumbar Disc Hernia and Spinal Stenosis. Spine. 1997;22:203-209. [pmid: 9122803].
21 Van Walraven C, et al. Appropriateness of primary total hip and knee replacements in regions of Ontario with high and low utilization rates.
22 Karp HR, Flanders WD, Shipp CC, Taylor B, Martin D. Carotid Endarterectomy among Medicare beneficiaries: A statewide evaluation of appropriateness and outcome. Stroke. 1998;29:46-52. [pmid: 9445327].
23 Broder MS, Kanouse DE, Mittman BS, Bernstein SJ. The appropriateness of recommendations for hysterectomy. Obstet Gynecol. 2000;95:199-205. [pmid: 10674580].
24 Wong JH, Lubkey TB, Auarez-Almazor ME, Findlay JM. Improving the appropriateness of Carotid Endarterectomy: Results of a prospective city-wide study. Stoke. 199;30:12-15.
25 Quintana JM, Azkarate J, Goenaga JI, Ar?stegui I, Beldarrain I, Villar JM. Evaluation of the appropriateness of hip joint replacement techniques. Intl J Tech Assessment in Health Care. 2000;16:165-177.
26 Ferguson JA, Adams TA, Weinberger M. Racial differences in cardiac catheterization use and appropriateness. Am J Med Sci. 1998;315:302-306. [pmid: 9587086].

## References

1 Begley, C, Slater CH, Engel MJ, Reynolds TF. Avoidable hospitalization and socio-economic status in Galveston County, Texas. J Comm Health. 1994;19:377-387.
2 Bierman AS, Steiner C, Friedman B, Fillmore CM, Clancy CM. Ambulatory Care Sensitive Conditions: A viable indicator of access to quality primary care. Abstract. Available at http://www.ahsr.org/1999/abstracts/bierman.htm. Accessed: 5/18/00.
3 Billings J, Anderson GM, Newman LS. Recent findings on preventable hospitalizations. Health Affairs. 1996;15:239-249. [pmid: 8854530].
4 Billings J, Zeitel L, Lukomnik J, Carey TS, Blank AE, Newman L. Impact of socioeconomic status on hospital use in New York City. Health Affairs. 1993;Spring:162-173. [pmid: 8509018].
5 Bindman AB, Grumbach K, Osmond D, et al. Preventable hospitalizations and access to health care. JAMA. 1995;274:305-311. [pmid: 7609259].
6 Blustein J, Hanson K, Shea S. Preventable hospitalizations and socioeconomic status. Health Affairs. 1998;17:177-189. [pmid: 9558796].
7 Cassanova C, Colomer C, Starfield B. Pediatric hospitalization due to ambulatory care-sensitive conditions in Valencia (Spain). Intl J Quality in Health Care. 1996;8:51-59.
8 Cassanova C, Starfield B. Hospitalizations of children and access to primary care: A cross-national comparison. Intl J of Health Services. 1995;25:283-294.
9 Claudio L, Tulton L, Doucette J, Landrigan PJ. Socioeconomic factors and asthma hospitalization rates in New York City. J Asthma. 1999;36:343-350. [pmid: 10386498].
10 Connell FA, Blide LA, Hanken MA. Clinical correlates of small area variations in population-based admission rates for diabetes. Med Care. 1984;22:939-949. [pmid: 6436591].
11 Culler SD, Parchman ML, Przybylski M. Factors related to potentially preventable hospitalizations among the elderly. Med Care. 1998;36:804-817. [pmid: 9630122].
12 Djojonegoro BM, Williams AF. Area Income as a predictor of preventable hospitalizations in the Harris County Hospital District, Houston. Tex Med. 2000;96:58-62. [pmid: 10682419].
13 Epstein AJ. The role of the medical market in preventable hospitalizations [abstract]. Abstract Book/Association for Health Services Research. 1998;15:316-7.
14 Gadomski A, Jenkins P, Nichols M Impact of a Medicaid provider and preventive care on pediatric hospitalization Peds 1998 101(3):E 1
15 Gill JM, Mainous AG. The role of provider continuity in preventing hospitalizations. Arch Fam Med. 1998;7:352-357. [pmid: 9682689].
16 Gill JM. Can hospitalizations be avoided by having a regular source of care?. Fam Med. 1997;29:166-71. [pmid: 9085096].
17 Giuffrida A, Gravelle H, Roland M. Measuring quality of care with routine data: avoiding confusion between performance indicators and health outcomes. BMJ. 1999;319:94-98. [pmid: 10398635]. [pmcid: 28159].
18 Halterman, JS, Aligne A, Auinger P, McBride JT, Szilagyi PG. Inadequate therapy for asthma among children in the United States. Peds. 2000;105:272-276.
19 Kaestner R, Racine A, Joyce T. Did recent expansions in Medicaid narrow socioeconomic differences in hospitalizations rates of infants. Med Care. 2000;38:195-206. [pmid: 10659693].
20 Krakauer H, Jacoby I, Millman M, Lukomnik JE. Physician impact on hospital admission and on mortality rates in the Medicare population. HSR. 1996;31:191-211. [pmid: 8675439].
21 Laditka SB, Johnston JM. Preventable hospitalization and avoidable maternity outcomes: Implications for access to health services for Medicaid recipients. J Heath & Social Policy. 1999;11:41-55.
22 Laditka SB, Laditka JN. Geographic variation in preventable hospitalization of Older Women and Men: Implications for access to primary health care. J Women & Aging. 1999;11:43-56. [pmid: 10721688].
23 McConnochie KM, Roghmann KJ, Liptak GS. Socioeconomic variation in discretionary and mandatory hospitalization of infants: An ecologic analysis. Peds. 1997;99:774-784.
24 O'Sullivan MJ, Volicer B. Preventable Hospitalizations: A tool for planning and marketing ambulatory health care services. J Ambulatory Care Manage. 1996;19:84-95. [pmid: 10156660].
25 Ordoñez GA, Phelan PD, Olinsky A, Robertson CF. Preventable factors in hospital admissions for asthma. Arch Dis Child. 1998;78:143-147. [pmid: 9579156].
26 Pappas G, Hadden WC, Kozak LJ, Fisher GF. Potentially avoidable hospitalizations: Inequalities in rates between US socioeconomic groups. Am J Pub Health. 1997;87:811-816. [pmid: 9184511].
27 Parchman ML, Culler S. Primary care physicians and avoidable hospitalization. J Fam Prac. 1994;39:123-128.
28 Parchman ML, Culler SD. Preventable hospitalizations in primary care shortage areas: An analysis of vulnerable Medicare Beneficiaries. Arch Fam Med. 1999;8:487-491. [pmid: 10575386].
29 Rohrer JE, Vaughan M. Monitoring health care system performance in Iowa. Health Srvs Manage Research. 1997;10:107-112.
30 Schreiber S, Zielinski T. The meaning of ambulatory care sensitive admissions: Urban and Rural Perspectives. J Rural Health. 1997;13:276-284. [pmid: 10177149].
31 Shi L, Samuels ME, Pease M, Bailey WP, Corley EH. Patient characteristics associated with hospitalizations for ambulatory care sensitive conditions in South Carolina. S Med J. 1999;92:989-998.
32 Shukla RK, Pestian JP. Small area analysis of ambulatory care sensitive conditions in Virginia [abstract]. Abstract Book/Association for Health Services Research. 1997;14:9-0.
33 Silver MP, Babitz ME, Magill MK. Ambulatory care sensitive rates in the aged Medicare population in Utah, 1990 to 1994: A rural-urban comparison. J Rural Health. >1997;13:285-294. [pmid: 10177150].
34 Solet D, Krieger J, Stout J, Lui L. Childhood asthma hospitalizations - King County, Washington, 1987-1998. CDC MMWR Weekly. www.cdc.gov/mmwr/preview/mmwrthml. 2000;49:929-933. Last accessed 10/19/00.
35 Taroni F, Repetto F, Louis DZ, Moro ML, Yuen EJ, Gonnella JS. Variation in hospital use and avoidable patient morbidity. J Health Services Research and Policy. 1997;2:217-222.
36 Weissman JS, Gatsonix C, Epstein AM. Rates of avoidable hospitalization by insurance status in Massachusetts and Maryland. JAMA. 1992;268:2388-2394. [pmid: 1404795].