# Empirical Evaluation Results Tables

This appendix summarizes the empirical results for each indicator in table format. Indicators are in order according to their unique identifier.

Indicator 1: AAA repair volume
Type: Volume
Definition: Provider level. Number of AAA Procedures Threshold 1: 10/yr, Threshold 2: 32/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 716 | 14 | 16 | 8 | 35 | 47
1996 | 727 | 14 | 16 | 8 | 36 | 46
1997 | 717 | 14 | 16 | 8 | 34 | 52

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 84.19% | 43.11% | 46.09% | 12.57%
1996 | 83.87% | 42.99% | 44.43% | 12.24%
1997 | 84.70% | 41.73% | 46.44% | 11.58%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 86.24% | 81.11%
1996-1997 | 87.03% | 75.86%

Indicator 2: Carotid endarterectomy volume
Type: Volume
Definition: Provider level. Number of Carotid Endarterectomy Procedures Threshold 1: 50/yr, Threshold 2: 101/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 893 | 52 | 60 | 32 | 127 | 158
1996 | 904 | 52 | 60 | 31.5 | 129 | 169
1997 | 884 | 54 | 64 | 32 | 133 | 175

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 76.08% | 50.32% | 35.05% | 16.35%
1996 | 77.77% | 51.03% | 36.61% | 16.70%
1997 | 78.71% | 52.54% | 37.33% | 17.08%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 93.53% | 87.50%
1996-1997 | 89.72% | 87.76%

Indicator 3: CABG volume
Type: Volume
Definition: Provider level. Number of CABG Procedures Threshold 1: 100/yr, Threshold 2: 200/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 304 | 375 | 323 | 280 | 804 | 998
1996 | 307 | 399 | 338 | 293 | 830 | 1095
1997 | 307 | 401 | 345 | 301 | 892 | 1074

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 98.03% | 89.50% | 86.18% | 65.13%
1996 | 98.28% | 90.65% | 87.62% | 67.75%
1997 | 98.30% | 90.71% | 87.95% | 68.08%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 98.85% | 96.94%
1996-1997 | 98.08% | 97.49%

Indicator 4: Esophageal resection volume
Type: Volume
Definition: Provider level. Number of Esophageal Resection Procedures Threshold 1: 6/yr, Threshold 2: 7/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 265 | 2 | 3 | 1 | 4 | 7
1996 | 265 | 2 | 3 | 1 | 4 | 6
1997 | 233 | 2 | 3 | 1 | 5 | 8

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 30.43% | 26.26% | 6.79% | 5.28%
1996 | 39.51% | 34.26% | 8.58% | 6.43%
1997 | 30.85% | 24.47% | 5.15% | 3.43%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 50.00% | 57.14%
1996-1997 | 58.33% | 60.00%

Indicator 5: Pancreatic resection volume
Type: Volume
Definition: Provider level. Number of Pancreatic Resection Procedures Threshold 1: 10/yr, Threshold 2: 11/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 461 | 3 | 5 | 2 | 5 | 8
1996 | 429 | 3 | 4 | 2 | 5 | 10
1997 | 453 | 3 | 5 | 2 | 6 | 8

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 30.22% | 27.96% | 4.77% | 4.12%
1996 | 30.25% | 27.03% | 5.13% | 4.19%
1997 | 31.58% | 31.58% | 4.41% | 4.41%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 72.73% | 73.68%
1996-1997 | 71.43% | 82.35%

Indicator 6: Pediatric heart surgery volume
Type: Volume
Definition: Provider level. Number of Pediatric Heart Surgery Procedures Threshold 1: 100/yr, Threshold 2: 100/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 135 | 52 | 86 | 2 | 145 | 244
1996 | 126 | 53 | 90 | 2.5 | 149 | 245
1997 | 126 | 52 | 91 | 2 | 143 | 263

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | | 72.88% | | 19.26%
1996 | | 75.52% | | 20.63%
1997 | | 74.33% | | 19.05%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | | 84.62%
1996-1997 | | 84.00%

Indicator 7: PTCA volume
Type: Volume
Definition: Provider level. Number of PTCA Procedures Threshold 1: 200/yr, Threshold 2: 400/yr
Procedure volume: | | Number of procedures performed per year
Procedure volume: | # Hosp with >=1 procedures/yr | Mean | Standard deviation | 50^th^ percentile | 90^th^ percentile | 95^th^ percentile
1995 | 354 | 379 | 367 | 292 | 803 | 1066
1996 | 356 | 418 | 400 | 330 | 869 | 1157
1997 | 354 | 447 | 428 | 338 | 934 | 1290

Procedure share: | Share of procedures done at high volume hospitals | | Share of hospitals at high volume
Procedure share: | Threshold 1 | Threshold 2 | Threshold 1 | Threshold 2
1995 | 94.41% | 72.54% | 65.82% | 37.29%
1996 | 95.70% | 77.01% | 68.82% | 42.13%
1997 | 95.38% | 79.06% | 69.21% | 44.63%

Persistence of high volume: | Share of high volume hospitals remaining high volume
Persistence of high volume: | Threshold 1 | Threshold 2
1995-1996 | 97.84% | 98.47%
1996-1997 | 97.88% | 96.53%

Indicator 8: Cesarean section delivery rate
Type: Provider level utilization
Definition: Provider level. Number of cesarean section delivery per 100 deliveries.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.214 | 0.087 | 0.045 | 0.012 | 0.880 | 0.922
Demographics | - | - | 0.045 | 0.012 | 0.882 | 0.925

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.956 | 0.054 | 0.724 | 0.793 | 0.026

Indicator 9: Incidental appendectomy among elderly rate
Type: Provider level utilization
Definition: Provider level. Number of incidental appendectomies per 100 patients age 65 years or older undergoing intra-abdominal surgery.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.027 | 0.035 | 0.019 | 0.015 | 0.554 | 0.670
Demographics | - | - | 0.019 | 0.018 | 0.590 | 0.689
APR-DRG | - | - | 0.019 | 0.014 | 0.554 | 0.673

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.988 | 0.050 | 0.829 | 0.946 | 0.003

Indicator 10: Bi-lateral cardiac catheterization rate
Type: Provider level utilization
Definition: Provider level. Number of bilateral cardiac catheterizations per 100 heart catheterizations.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.193 | 0.200 | 0.163 | 0.147 | 0.944 | 0.963
Demographics | - | - | 0.162 | 0.140 | 0.942 | 0.961
APR-DRG | - | - | 0.161 | 0.144 | 0.943 | 0.962

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.988 | 0.061 | 0.707 | 0.966 | 0.002

Indicator 11: Successful vaginal birth after cesarean section (VBAC) rate
Type: Provider level utilization
Definition: Provider level. Number of successful vaginal deliveries per 100 deliveries in women with previous cesarean section.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.336 | 0.148 | 0.115 | 0.055 | 0.825 | 0.889
Demographics | - | - | 0.117 | 0.057 | 0.831 | 0.895

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.995 | 0.031 | 0.931 | 0.943 | 0.000

Indicator 12: Laparoscopic cholecystectomy rate
Type: Provider level utilization
Definition: Provider level. Number of laparoscopic cholecystectomies per 100 cholecystectomies (open and laparoscopic) performed.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.662 | 0.192 | 0.137 | 0.083 | 0.836 | 0.893
Demographics | - | - | 0.133 | 0.079 | 0.831 | 0.891

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.966 | 0.039 | 0.938 | 0.788 | 0.025

Indicator 13: Coronary artery bypass graft (CABG) rate
Type: Area level utilization
Definition: Area level. Number of CABGs per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001804 | 0.005716 | 0.002508 | 0.002152 | 0.973 | 0.974
Demographics | - | - | 0.002486 | 0.002117 | 0.973 | 0.973

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.6548 | 0.126 | 0.364 | 0.955 | 0.350

Indicator 14: Hysterectomy rate
Type: Area level utilization
Definition: Area level. Number of hysterectomies per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.004194 | 0.003233 | 0.001840 | 0.000940 | 0.933 | 0.935
Demographics | - | - | 0.001881 | 0.000983 | 0.936 | 0.937

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9964 | 0.030 | 0.818 | 0.909 | 0.000

Indicator 15: Laminectomy and/or spinal fusion rate
Type: Area level utilization
Definition: Area level. Number of laminectomies per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001390 | 0.003475 | 0.001328 | 0.001020 | 0.967 | 0.967
Demographics | - | - | 0.001320 | 0.001009 | 0.967 | 0.967

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9333 | 0.063 | 0.318 | 0.955 | 0.074

Indicator 16: Percutaneous transluminal coronary angioplasty (PTCA) rate
Type: Area level utilization
Definition: Area level. Number of PTCAs per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001908 | 0.004556 | 0.002780 | 0.002163 | 0.973 | 0.974
Demographics | - | - | 0.002750 | 0.002120 | 0.973 | 0.973

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.6712 | 0.104 | 0.364 | 0.955 | 0.355

Indicator 17: Dehydration admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for dehydration per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001399 | 0.001032 | 0.000484 | 0.000216 | 0.900 | 0.903
Demographics | - | - | 0.000446 | 0.000184 | 0.885 | 0.889

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9572 | 0.092 | 0.818 | 0.909 | 0.046

Indicator 18: Bacterial pneumonia admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for bacterial pneumonia per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.003956 | 0.002085 | 0.000971 | 0.000343 | 0.932 | 0.933
Demographics | - | - | 0.000948 | 0.000326 | 0.929 | 0.931

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9234 | 0.111 | 0.682 | 0.909 | 0.097

Indicator 19: Urinary infection admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for urinary infection per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001451 | 0.000895 | 0.000395 | 0.000134 | 0.854 | 0.859
Demographics | - | - | 0.000386 | 0.000128 | 0.849 | 0.854

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9143 | 0.115 | 0.682 | 0.909 | 0.088

Indicator 20: Perforated appendix admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for perforated appendix per 100 admissions for appendicitis within an area.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.332740 | 0.144097 | 0.032117 | 0.004604 | 0.308 | 0.436
Demographics | - | - | 0.027529 | 0.003387 | 0.265 | 0.394

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9687 | 0.020 | 0.900 | 0.850 | 0.025

Indicator 21: Angina (without procedure) admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for angina (without procedure) per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001660 | 0.001357 | 0.000639 | 0.000392 | 0.921 | 0.923
Demographics | - | - | 0.000614 | 0.000362 | 0.916 | 0.919

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9677 | 0.106 | 0.636 | 0.909 | 0.032

Indicator 22: Adult asthma admission rate.
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for adult asthma per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001079 | 0.000817 | 0.000443 | 0.000158 | 0.840 | 0.846
Demographics | - | - | 0.000435 | 0.000153 | 0.836 | 0.842

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9879 | 0.038 | 0.864 | 0.955 | 0.000

Indicator 23: Chronic obstructive pulmonary disease (COPD) admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for COPD per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.003240 | 0.002038 | 0.001153 | 0.000646 | 0.950 | 0.950
Demographics | - | - | 0.000986 | 0.000472 | 0.934 | 0.935

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9333 | 0.135 | 0.682 | 0.864 | 0.069

Indicator 24: Congestive heart failure admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for CHF per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.005210 | 0.002865 | 0.001772 | 0.000708 | 0.954 | 0.954
Demographics | - | - | 0.001404 | 0.000444 | 0.930 | 0.932

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.8577 | 0.196 | 0.545 | 0.818 | 0.166

Indicator 25: Diabetes - short term complications admissions rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for diabetes short term complications (uncontrolled diabetes, DKA, hyperosmolarity, and coma) per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000360 | 0.000246 | 0.000092 | 0.000022 | 0.518 | 0.543
Demographics | - | - | 0.000092 | 0.000022 | 0.517 | 0.543

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9951 | 0.006 | 1.000 | 1.000 | 0.005

Indicator 26: Uncontrolled diabetes
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for uncontrolled diabetes per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000347 | 0.000281 | 0.000152 | 0.000078 | 0.735 | 0.751
Demographics | - | - | 0.000147 | 0.000074 | 0.726 | 0.742

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9764 | 0.079 | 0.773 | 0.909 | 0.023

Indicator 27: Diabetes - long-term complications admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for diabetes long-term complications (neurological, circulatory, eye, kidney, NOS), per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000808 | 0.000581 | 0.000265 | 0.000077 | 0.741 | 0.752
Demographics | - | - | 0.000279 | 0.000085 | 0.756 | 0.766

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9264 | 0.124 | 0.727 | 0.909 | 0.083

Indicator 28: Hypertension admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for hypertension per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000371 | 0.000322 | 0.000142 | 0.000066 | 0.716 | 0.728
Demographics | - | - | 0.000138 | 0.000060 | 0.699 | 0.712

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9631 | 0.091 | 0.727 | 1.000 | 0.032

Indicator 29: Lower extremity amputation in diabetics admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for lower extremity amputation and diagnosis code for diabetes per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000305 | 0.000427 | 0.000146 | 0.000064 | 0.706 | 0.722
Demographics | - | - | 0.000137 | 0.000057 | 0.685 | 0.702

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9192 | 0.131 | 0.591 | 0.909 | 0.074

Indicator 30: Low birth weight rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of infants with a birth weight of under 2500 grams per 100 births within area.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.039108 | 0.023135 | 0.011832 | 0.002720 | 0.671 | 0.812
Demographics | - | - | 0.011836 | 0.002722 | 0.671 | 0.812

Minimum bias: | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | NA | NA | NA | NA | NA

Indicator 31: Pediatric asthma admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for asthma in patients age 18 years and younger per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.001541 | 0.001439 | 0.001137 | 0.000514 | 0.853 | 0.858
Demographics | - | - | 0.001129 | 0.000506 | 0.851 | 0.856

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9938 | 0.053 | 1.000 | 0.955 | 0.000

Indicator 32: Pediatric gastroenteritis admission rate
Type: Avoidable hospitalization/ Ambulatory Care Sensitive Condition (ACSC)
Definition: Area level. Number of admissions for gastroenteritis in patients age 18 years and younger per 100,000 population.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.000985 | 0.001012 | 0.000535 | 0.000291 | 0.778 | 0.788
Demographics | - | - | 0.000537 | 0.000293 | 0.778 | 0.788

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.9953 | 0.055 | 0.909 | 1.000 | 0.000

Indicator 33: Acute myocardial infarction (AMI) mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of AMI.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.244 | 0.161 | 0.078 | 0.043 | 0.718 | 0.826
Demographics | - | - | 0.061 | 0.023 | 0.617 | 0.756
APR-DRG | - | - | 0.034 | 0.008 | 0.428 | 0.590

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.747 | 0.324 | 0.363 | 0.673 | 0.290

Indicator 34: Congestive heart failure (CHF) mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of CHF.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.075 | 0.095 | 0.025 | 0.010 | 0.598 | 0.750
Demographics | - | - | 0.021 | 0.007 | 0.505 | 0.696
APR-DRG | - | - | 0.021 | 0.007 | 0.535 | 0.697

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.794 | 0.137 | 0.398 | 0.729 | 0.235

Indicator 35: Gastrointestinal (GI) hemorrhage mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of GI hemorrhage.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.046 | 0.057 | 0.016 | 0.006 | 0.323 | 0.589
Demographics | - | - | 0.013 | 0.003 | 0.224 | 0.607
APR-DRG | - | - | 0.011 | 0.003 | 0.202 | 0.555

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.803 | 0.105 | 0.504 | 0.678 | 0.229

Indicator 36: Hip fracture mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of hip fracture.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.144 | 0.160 | 0.079 | 0.062 | 0.544 | 0.670
Demographics | - | - | 0.072 | 0.048 | 0.476 | 0.635
APR-DRG | - | - | 0.078 | 0.060 | 0.543 | 0.653

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.880 | 0.225 | 0.556 | 0.788 | 0.151

Indicator 37: Pneumonia mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of pneumonia.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.138 | 0.102 | 0.052 | 0.022 | 0.744 | 0.850
Demographics | - | - | 0.045 | 0.015 | 0.675 | 0.822
APR-DRG | - | - | 0.037 | 0.012 | 0.629 | 0.781

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.596 | 0.219 | 0.306 | 0.603 | 0.408

Indicator 38: Acute stroke mortality rate
Type: In-patient mortality
Definition: Provider level. Number of deaths per 100 patients with diagnosis of stroke (not TIA).
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.213 | 0.137 | 0.070 | 0.029 | 0.626 | 0.756
Demographics | - | - | 0.067 | 0.025 | 0.589 | 0.738
APR-DRG | - | - | 0.053 | 0.017 | 0.519 | 0.707

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.803 | 0.131 | 0.638 | 0.629 | 0.244

Indicator 39: Abdominal aortic aneurysm repair mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone AAA repair.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.215 | 0.268 | 0.085 | 0.060 | 0.423 | 0.540
Demographics | - | - | 0.067 | 0.035 | 0.037 | 0.571
APR-DRG | - | - | NA | NA | NA | NA

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.890 | 0.234 | 0.708 | 0.646 | 0.141

Indicator 40: Coronary artery bypass graft (CABG) mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone CABG.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.051 | 0.062 | 0.017 | 0.007 | 0.611 | 0.726
Demographics | - | - | 0.016 | 0.006 | 0.552 | 0.727
APR-DRG | - | - | 0.014 | 0.005 | 0.545 | 0.698

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.743 | 0.152 | 0.414 | 0.655 | 0.301

Indicator 41: Craniotomy mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone craniotomy.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.162 | 0.185 | 0.084 | 0.071 | 0.589 | 0.719
Demographics | - | - | 0.077 | 0.054 | 0.527 | 0.704
APR-DRG | - | - | 0.037 | 0.015 | 0.289 | 0.490

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.786 | 0.338 | 0.296 | 0.611 | 0.274

Indicator 42: Esophageal resection mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone esophageal resection for cancer.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.202 | 0.366 | 0.043 | 0.026 | 0.120 | 0.353
Demographics | - | - | 0.024 | 0.008 | 0.089 | 0.210
APR-DRG | - | - | NA | NA | NA | NA

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.858 | 0.168 | 0.667 | 1.000 | 0.095

Indicator 43: Hip replacement mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone total or partial hip arthroplasty.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.012 | 0.057 | 0.013 | 0.029 | 0.339 | 0.346
Demographics | - | - | 0.012 | 0.021 | 0.202 | 0.218
APR-DRG | - | - | 0.009 | 0.012 | 0.200 | 0.216

Minimum bias: | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.642 | 0.489 | 0.278 | 0.708 | 0.361

Indicator 44: Pancreatic resection mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients having undergone pancreatic resection for cancer.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.154 | 0.313 | 0.079 | 0.084 | 0.315 | 0.359
Demographics | - | - | 0.042 | 0.032 | 0.165 | 0.347
APR-DRG | - | - | NA | NA | NA | NA

Minimum bias (age-sex): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.540 | 0.419 | 0.714 | 0.286 | 0.381

Indicator 45: Pediatric heart surgery mortality rate
Type: Post-procedural mortality
Definition: Provider level. Number of deaths per 100 patients age 18 and under having undergone heart surgery.
Precision: | Provider Level | | Provider Signal
| Mean | Std Dev | Std Dev (1) | Share (2) | Univariate Ratio (3) | MSX R^2^ (4)
Unadjusted | 0.072 | 0.170 | 0.022 | 0.008 | 0.357 | 0.496
Demographics | - | - | 0.017 | 0.005 | 0.263 | 0.430
APR-DRG | - | - | 0.015 | 0.003 | 0.222 | 0.379

Minimum bias (APR-DRG): | Rank Corr. (1) | Absolute Diff (2) | High 10% (3) | Low 10% (4) | Two Decile Diff (5)
MSX | 0.674 | 0.128 | 0.167 | 0.667 | 0.351