# Indicator Definitions

Table of indicator includes complete specification of current HCUP indicators and potential HCUP indicators evaluated in this evidence report.

Indicators are organized by indicator type. Each indicator is numbered with a unique identifier used throughout the report.

The numerator refers to the outcome of interest and the denominator refers to the population at risk.

Some indicators specification are so detailed that the full specifications are included after the table.

## Appendix 6 Indicator Definitions - Potential HCUP Indicators

** indicates current HCUP indicators

Indicator | Numerator | Denominator | #
Volume Outcome
- AAA repair volume | Discharges with ICD-9 codes 38.34, 38.44, or 38.64 in any procedure field and diagnosis of AAA (see below) in any field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable. | 1
- Carotid Endarterectomy volume | Discharges with ICD-9 code 38.12 in any procedure field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable | 2
- CABG volume | Discharges with ICD-9 codes 36.10 - 36.19 in any procedure field. Age 40 years and older. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable | 3
- Esophageal resection volume | Discharges with ICD-9 codes 42.40 - 42.42 in any procedure field and diagnosis code of esophageal cancer in any field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable | 4
- Pancreatic resection volume | Discharges with ICD-9 codes 52.6 or 52.7 in any procedure field and diagnosis code of pancreatic cancer in any field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable | 5
- Pediatric heart surgery volume | Discharges with ICD-9 codes for specified heart surgery (see below) in any field, or for any heart surgery and a diagnosis of hypoplastic left heart syndrome (see below) in any field Age less than 18. See NOTE for additional exclusions Exclude MDC 14 (pregnancy, childbirth, and puerperium). | Not applicable | 6
- PTCA volume | Discharges with ICD-9 codes 36.01, 36.02, 36.05, or 36.06 in any procedure field. Age 40 years and older. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Not applicable | 7
Utilization - provider level
- Cesarean section delivery rate | Number of C-sections per 100 deliveries (see below). | All deliveries (see below) | 8
- Incidental appendectomy among elderly rate | Number of incidental appendectomies per 100 elderly discharges with intra-abdominal procedure (see below). | All non-maternal/non-neonatal discharges age 65 years and older with intra-abdominal procedure in any procedure field (see below). Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 9
- Bi-lateral catheterization rate | Number of simultaneous right and left heart catheterizations per 100 discharges with procedure code of heart catheterization (see below). Exclude valid indications for right sided catheterization (see below) in any diagnosis field. | All non-maternal/non-neonatal discharges with heart catheterization (see below) in any procedure field. Include only coronary artery disease (see below) Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 10
- Successful vaginal birth after cesarean section (VBAC) rate | Number of vaginal births per 100 deliveries with diagnosis of previous C-section (see below). | All deliveries with previous C-section diagnosis in any diagnosis field (see below). | 11
- Laparoscopic cholecystectomy rate | Number of laparoscopic cholecystectomies per 100 discharges with procedure code of cholecystectomy (see below). | All non-maternal/non-neonatal discharges with cholecystectomy (see below) in any procedure field. Include only discharges with uncomplicated cases: cholecystitis and/or cholelithiasis (see below) in any diagnosis field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 12
Utilization - area level
- Coronary artery bypass graft (CABG) rate | Number of CABGs (any procedure field) per 100,000 population (see below). All non-maternal/non-neonatal discharges age 40 years and older. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 40 years and older. | 13
- Hysterectomy rate | Number of hysterectomies (any procedure field) per 100,000 population (see below). All non-maternal/non-neonatal discharges of females age 18 years and older. Exclude discharges with genital cancer or pelvic or lower abdominal trauma (see below) in any diagnosis field. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Female population in MSA or county, age 18 years and older. | 14
- Laminectomy and/or spinal fusion rate | Number of laminectomies and/or spinal fusions (any procedure field) per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 years and older. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 years and older. | 15
- PTCA rate | Number of PTCAs (any procedure field) per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 40 years and older. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 40 years and older. | 16
Ambulatory Care Sensitive Conditions
- Dehydration admission rate | Discharges with ICD-9 principal diagnosis code for hypovolemia per 100,000 population (see below). All non-maternal/non-neonatal discharges of age less than 65*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age less than 65*. * Rate can also be calculated for age 65 and older | 17
- Bacterial pneumonia admission rate | Discharges with ICD-9 principal diagnosis code for bacterial pneumonia per 100,000 population. All non-maternal/non-neonatal discharges of age less than 65*. Exclude discharges with diagnosis code for sickle cell anemia or HB-S disease (see below) in any field. Exclude patients <2 months (8 weeks) of age Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age less than 65*. * Rate can also be calculated for age 65 and older. | 18
- Urinary infection admission rate | Discharges with ICD-9 principal diagnosis code of urinary tract infection per 100,000 population (see below). All non-maternal/non-neonatal discharges of age less than 65*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age less than 65*. * Rate can also be calculated for age 65 and older. | 19
- Perforated appendix admission rate | Discharges with ICD-9 diagnosis code for perforations or abscesses of appendix (see below) in any field per 100 discharges with diagnosis code for appendicitis (see below). Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Number of discharges with diagnosis code for appendicitis in any field in MSA or county. | 20
- Angina admission rate | Discharges with ICD-9 principal diagnosis code for angina (see below) per 100,000 population. All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude discharges with a surgical procedure in any field (01.0-86.99). Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 21
- Adult asthma admission rate | Discharges with ICD-9 principal diagnosis code of asthma per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 22
- Chronic Obstructive Pulmonary Disease admission rate | Discharges with ICD-9 principal diagnosis code for COPD (see below) per 100,000 population. All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 23
- Congestive Heart Failure admission rate | Discharges with ICD-9 principal diagnosis code for CHF (see below) per 100,000 population. All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude discharges with cardiac procedure codes (see below) in any field. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 24
- Diabetes - short-term complications admission rate | Discharges with ICD-9 principal diagnosis code for short-term complications (ketoacidosis, hyperosmolarity, coma) per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 25
- Diabetes - uncontrolled without complications admission rate; MAY BE COMBINED WITH DIABETES SHORT-TERM COMPLICATIONS AS A SINGLE INDICATOR. | Discharges with ICD-9 principal diagnosis code for uncontrolled diabetes, without mention of a short-term or long-term complication, per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 26
- Diabetes - long-term complications admission rate | Discharges with ICD-9 principal diagnosis code for long-term complications (renal, eye, neurological, circulatory, or complications not otherwise specified) per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 27
- Hypertension admission rate | Discharges with ICD-9 principal diagnosis code for hypertension per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude discharges with cardiac procedure codes (see below) in any field. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 28
- Lower extremity amputation in diabetics admission rate | Discharges with ICD-9 procedure code for lower extremity amputation (see below) in any field and diagnosis code of diabetes in any field per 100,000 population (see below). All non-maternal/non-neonatal discharges of age 18 to 64 years old*. Exclude trauma (see below). Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, age 18 to 64 years old*. * Rate can also be calculated for age 65 and older. | 29
- Low birthweight rate | Number of births with ICD-9 diagnosis code for less than 2500 grams per 100 births (see below) in any field. Exclude transfer from other institution. | All births (discharges in MDC 15 - newborns and other neonates) in MSA or county. | 30
- Pediatric asthma admission rate | Discharges with ICD-9 principal diagnosis code of asthma per 100,000 population (see below). All non-maternal/non-neonatal discharges of under age 18. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, under age 18. | 31
- Pediatric gastroenteritis admission rate | Discharges with ICD-9 principal diagnosis code for gastroenteritis per 100,000 population (see below). All non-maternal/non-neonatal discharges of under age 18. Exclude transfer from other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | Population in MSA or county, under age 18. | 32
In-hospital Mortality
- Acute myocardial infarction mortality rate | Number of deaths per 100 discharges with diagnosis code for AMI in any field. | All non-maternal/non-neonatal discharges with diagnosis codes for AMI (see below) in any field, age 18 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 33
- Congestive Heart Failure mortality rate | Number of deaths per 100 discharges with principal diagnosis code for CHF. | All non-maternal/non-neonatal discharges with principal diagnostic code for CHF (see below), age 18 years and older. Exclude discharges with cardiac procedure codes (see below) in any field Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 34
- GI Hemorrhage mortality rate | Number of deaths per 100 discharges with principal diagnosis code for GI hemorrhage. | All non-maternal/non-neonatal discharges with principal diagnostic code for gastrointestinal hemorrhage (see below), age 18 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates | 35
- Hip fracture mortality rate | Number of deaths per 100 discharges with principal diagnosis code for hip fracture. | All non-maternal/non-neonatal discharges with principal diagnostic code for hip fracture (see below), age 18 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 36
- Pneumonia mortality rate | Number of deaths per 100 discharges with principal diagnosis code for pneumonia. | All non-maternal/non-neonatal discharges with principal diagnostic code for pneumonia (see below), age 18 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates | 37
- Stroke mortality rate | Number of deaths per 100 discharges with principal diagnosis code for stroke. | All non-maternal/non-neonatal discharges with principal diagnostic code for stroke (see below), age 18 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates | 38
Post-procedural Mortality
- Abdominal aortic artery repair mortality rate | Number of deaths per 100 discharges with procedure code for AAA repair and diagnosis of AAA in any field. | All non-maternal/non-neonatal discharges with procedure code for AAA repair and diagnosis of AAA (see below) in any field. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 39
- Coronary Artery Bypass Graft mortality rate | Number of deaths per 100 discharges with procedure code for CABG in any field. Age 40 years and older. | All non-maternal/non-neonatal discharges with procedure code for CABG (see below) in any field. Age 40 years and older. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates) | 40
- Craniotomy mortality rate | Number of deaths per 100 discharges with DRG code for craniotomy (DRG 001, Craniotomy Age > 17, Except for Trauma). | All non-maternal/non-neonatal discharges with DRG code for craniotomy (DRG 001 Craniotomy Age > 17, Except for Trauma). Exclude transfers to other institution. | 41
- Esophageal resection mortality rate | Number of deaths per 100 esophageal cancer discharges with procedure code for esophageal resection for in any field. | All non-maternal/non-neonatal esophageal cancer discharges with procedure code for esophageal resection (see below) in any field. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 42
- Hip replacement mortality rate | Number of deaths per 100 discharges with procedure code for partial or full hip replacement in any field. | All non-maternal/non-neonatal discharges with procedure code for partial or full hip replacement. (see below) in any field. Include only discharges with uncomplicated cases: diagnosis or procedure codes for osteoarthrosis of hip. (see below) in any field. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 43
- Pancreatic resection mortality rate | Number of deaths per 100 pancreatic cancer discharges with procedure code for pancreatic resection in any field. | All non-maternal/non-neonatal pancreatic cancer discharges with procedure code for pancreatic resection (see below) in any field. Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium) and MDC 15 (newborns and other neonates). | 44
- Pediatric heart surgery mortality rate | Number of deaths per 100 discharges with procedure code for pediatric heart surgery in any field. | All non-maternal/non-neonatal discharges less than 18 with procedure code for specified heart surgery (see below) in any field, or for any heart surgery and a diagnosis code for hypoplastic left heart syndrome (see below) in any field. See NOTE for additional exclusions Exclude transfers to other institution. Exclude MDC 14 (pregnancy, childbirth, and puerperium). | 45

NOTE (Exclusions for Pediatric Heart Surgery): 1) patients who underwent PDA ligation as a single cardiac procedure (diagnosis code 747.0 and procedure code 38.85); 2) patients with prosthetic closures of atrial septal defects (procedure codes 35.51-52, 35.71) or ventricular septal defects (codes 35.53, 35.72) or atrial septal enlargement (35.41) without concomitant use of cardiopulmonary bypass (code 39.61); 3) patients with PDA closure as single cardiac procedure (procedure code 38.85) with concomitant cardiac catheterization (codes 37.21, 37.22, 37.23, 88.42, 88.43); 4) patients with occlusion of thoracic vessel (procedure code 38.85) without congenital heart defect (diagnosis codes 745.0-747.9).

Indicator | Coding Source
Indicator | Coding Source
- AAA repair volume and mortality rate | CCS Procedure Category #52 Manheim LM, J Vasc Surg 1998; 28:48-58.
- Acute myocardial infarction mortality rate | CCS Diagnosis Category #100
- Adult asthma admission rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 85)
- Angina admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Bacterial pneumonia admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Bi-lateral catheterization rate | Medicare Quality of Care Report of Surveillance Measures (http://www.hcfa.gov/quality/3d.htm#2).
- CABG volume, utilization rate, and mortality rate | CCS Procedure Category #44 (except 36.2, 36.3x)
- Carotid Endarterectomy volume and utilization rate | CCS Procedure Category #51
- Cesarean section delivery rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 82)
- Chronic Obstructive Pulmonary Disease admission rate | CCS Diagnosis Category #127
- Congestive Heart Failure admission rate and mortality rate | CCS Diagnosis Category #108
- Craniotomy mortality rate | DRG 001, "CRANIOTOMY AGE >17 EXCEPT FOR TRAUMA"
- Dehydration admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Diabetes - long-term complications admission rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 86)
- Diabetes - short-term complications admission rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 86)
- Diabetes - uncontrolled without complications admission rate | Healthy People 2010
- Esophageal resection volume and mortality rate | Patti MG, Corvera CU, Glasgow RE, Way LW. A hospital's annual rate of esophagectomy influences the operative mortality rate. J Gastrointest Surg. 1998; 2:186-192. Begg CB, Cramer LD, Hoskins WJ, Brennan MF. Impact of hospital volume on operative mortality for major cancer surgery. JAMA. 1998; 280:1747-1751
- GI Hemorrhage mortality rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 75)
- Hip fracture mortality rate | CCS Diagnosis Category #226
- Hip replacement mortality rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 73)
- Hypertension admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Hysterectomy rate | CCS Procedure Category #124 HCUP-3 QI (AHRQ Pub. No. 98-0035, page 83)
- Incidental appendectomy rate (Utilization #5) | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 82)
- Laminectomy and/or spinal fusion rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 83)
- Laparoscopic cholecystectomy rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 84)
- Low birthweight rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 84)
- Lower extremity amputation in diabetics admission rate | Healthy People 2010
- Pancreatic resection volume and mortality rate | Begg CB, Cramer LD, Hoskins WJ, Brennan MF. Impact of hospital volume on operative mortality for major cancer surgery. JAMA. 1998; 280:1747-1751. Glasgow RE, Mulvihill SJ. Hospital volume influences outcome in patients undergoing pancreatic resection for cancer. West J Med. 1996; 165:294-300. Gordon TA, Bowman HM, Tielsch JM, Bass EB, Burleyson GP, Cameron JL. Statewide regionalization of pancreaticoduodenectomy and its effect on in-hospital mortality. Ann Surg. 1998; 228:71-78. Imperato PJ, Nenner RP, Starr HA, Will TO, Rosenberg CR, Dearie MB. The effects of regionalization on clinical outcomes for a high-risk surgical procedure. Am J Med Qual. 1996; 11: 193-197. Lieberman MD, Kilburn H, Lindsey M, Brennan MF.Relation of perioperative deaths to hospital volume among patients undergoing pancreatic resection for malignancy. Ann Surg. 1995;222:638-645.
- Pediatric asthma admission rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 85)
- Pediatric gastroenteritis admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Pediatric heart surgery volume and mortality rate | Jenkins KJ, et al. Pediatrics 1995; 95: 323-330.
- Perforated appendix admission rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 87)
- Pneumonia mortality rate | CCS Diagnosis Category #122
- PTCA volume and utilization rate | CCS Procedure Category #45
- Stroke mortality rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 85)
- Urinary infection admission rate | Billings et al, "Analysis of Variation in Hospital Admission Rates Associated with Area Income in New York City," (March, 1992)
- Vaginal birth after cesarean section (VBAC) rate | HCUP-3 QI (AHRQ Pub. No. 98-0035, page 82)

Volume
AAA repair volume(QI #1)
AAA repair
ICD-9-CM procedure codes:
3834 | AORTA RESECTION & ANAST
3844 | RESECT ABDM AORTA W REPL
3864 | EXCISION OF AORTA
Include only: AAA
ICD-9-CM diagnosis codes:
4413 | RUPT ABD AORTIC ANEURYSM
4414 | ABDOM AORTIC ANEURYSM
Carotid endarterectomy volume(QI #2)
Carotid endarterectomy
ICD-9-CM procedure codes:
3812 | HEAD & NECK ENDARTER NEC
CABG volume(QI #3)
CABG
ICD-9-CM procedure codes:
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | INT MAM-COR ART BYPASS
3616 | INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
Esophageal resection volume(QI #4)
Esophageal resection
ICD-9-CM procedure codes:
4240 | ESOPHAGECTOMY NOS
4241 | PARTIAL ESOPHAGECTOMY
4242 | TOTAL ESOPHAGECTOMY
Include only: Esophageal cancer:
ICD-9-CM diagnosis codes:
1500 | MAL NEO CERVICAL ESOPHAG
1501 | MAL NEO THORACIC ESOPHAG
1502 | MAL NEO ABDOMIN ESOPHAG
1503 | MAL NEO UPPER 3RD ESOPH
1504 | MAL NEO MIDDLE 3RD ESOPH
1505 | MAL NEO LOWER 3RD ESOPH
1508 | MAL NEO ESOPHAGUS NEC
1509 | MAL NEO ESOPHAGUS NOS
Pancreatic resection volume(QI #5)
Pancreatic resection
ICD-9-CM procedure codes:
526 | TOTAL PANCREATECTOMY
527 | RAD PANCREATICODUODENECT
Include only: Pancreatic cancer
ICD-9-CM diagnosis codes:
1520 | MALIGNANT NEOPL DUODENUM
1561 | MAL NEO EXTRAHEPAT DUCTS
1562 | MAL NEO AMPULLA OF VATER
1570 | MAL NEO PANCREAS HEAD
1571 | MAL NEO PANCREAS BODY
1572 | MAL NEO PANCREAS TAIL
1573 | MAL NEO PANCREATIC DUCT
1574 | MAL NEO ISLET LANGERHANS
1578 | MALIG NEO PANCREAS NEC
1579 | MALIG NEO PANCREAS NOS
Pediatric heart surgery volume(QI #6)
Pediatric heart surgery (#1)
ICD-9-CM procedure codes:
3500 | CLOSED VALVOTOMY NOS
3501 | CLOSED AORTIC VALVOTOMY
3502 | CLOSED MITRAL VALVOTOMY
3503 | CLOSED PULMON VALVOTOMY
3504 | CLOSED TRICUSP VALVOTOMY
3510 | OPEN VALVULOPLASTY NOS
3511 | OPN AORTIC VALVULOPLASTY
3512 | OPN MITRAL VALVULOPLASTY
3513 | OPN PULMON VALVULOPLASTY
3514 | OPN TRICUS VALVULOPLASTY
3520 | REPLACE HEART VALVE NOS
3521 | REPLACE AORT VALV-TISSUE
3522 | REPLACE AORTIC VALVE NEC
3523 | REPLACE MITR VALV-TISSUE
3524 | REPLACE MITRAL VALVE NEC
3525 | REPLACE PULM VALV-TISSUE
3526 | REPLACE PULMON VALVE NEC
3527 | REPLACE TRIC VALV-TISSUE
3528 | REPLACE TRICUSP VALV NEC
3531 | PAPILLARY MUSCLE OPS
3532 | CHORDAE TENDINEAE OPS
3533 | ANNULOPLASTY
3534 | INFUNDIBULECTOMY
3535 | TRABECUL CARNEAE CORD OP
3539 | TISS ADJ TO VALV OPS NEC
3542 | CREATE SEPTAL DEFECT
3550 | PROSTH REP HRT SEPTA NOS
3554 | PROS REP ENDOCAR CUSHION
3560 | GRFT REPAIR HRT SEPT NOS
3561 | GRAFT REPAIR ATRIAL DEF
3562 | GRAFT REPAIR VENTRIC DEF
3563 | GRFT REP ENDOCAR CUSHION
3570 | HEART SEPTA REPAIR NOS
3573 | ENDOCAR CUSHION REP NEC
3581 | TOT REPAIR TETRAL FALLOT
3582 | TOTAL REPAIR OF TAPVC
3583 | TOT REP TRUNCUS ARTERIOS
3584 | TOT COR TRANSPOS GRT VES OCT88-
3591 | INTERAT VEN RETRN TRANSP
3592 | CONDUIT RT VENT-PUL ART
3593 | CONDUIT LEFT VENTR-AORTA
3594 | CONDUIT ARTIUM-PULM ART
3595 | HEART REPAIR REVISION
3598 | OTHER HEART SEPTA OPS
3599 | OTHER OP ON HRT VALVES
3835 | THOR VESSEL RESECT/ANAST
3845 | RESECT THORAC VES W REPL
390 | SYSTEMIC-PULM ART SHUNT
3921 | CAVAL-PULMON ART ANASTOM
3959 | REPAIR OF VESSEL NEC
Pediatric heart surgery (#1A)
ICD-9-CM procedure codes:
3541 | ENLARGE EXISTING SEP DEF#
3551 | PROS REP ATRIAL DEF-OPN#
3552 | PROS REPAIR ATRIA DEF-CL#
3553 | PROST REPAIR VENTRIC DEF#
3571 | ATRIA SEPTA DEF REP NEC#
3572 | VENTR SEPTA DEF REP NEC#
Include only:Cardiopulmonary Bypass
ICD-9-CM procedure code:
3961 | EXTRACORPOREAL CIRCULAT
Pediatric heart surgery (#1B)
ICD-9-CM procedure code:
3885 | OCCLUDE THORACIC VES NEC*
Include only: Congenital heart defect
ICD-9-CM diagnosis codes:
7450 | COMMON TRUNCUS
74510 | COMPL TRANSPOS GREAT VES
74511 | DOUBLE OUTLET RT VENTRIC
74512 | CORRECT TRANSPOS GRT VES
74519 | TRANSPOS GREAT VESS NEC
7452 | TETRALOGY OF FALLOT
7453 | COMMON VENTRICLE
7454 | VENTRICULAR SEPT DEFECT
7455 | SECUNDUM ATRIAL SEPT DEF
74560 | ENDOCARD CUSHION DEF NOS
74561 | OSTIUM PRIMUM DEFECT
74569 | ENDOCARD CUSHION DEF NEC
7457 | COR BILOCULARE
7458 | SEPTAL CLOSURE ANOM NEC
7459 | SEPTAL CLOSURE ANOM NOS
74600 | PULMONARY VALVE ANOM NOS
74601 | CONG PULMON VALV ATRESIA
74602 | CONG PULMON VALVE STENOS
74609 | PULMONARY VALVE ANOM NEC
7461 | CONG TRICUSP ATRES/STEN
7462 | EBSTEIN'S ANOMALY
7463 | CONG AORTA VALV STENOSIS
7464 | CONG AORTA VALV INSUFFIC
7465 | CONGEN MITRAL STENOSIS
7466 | CONG MITRAL INSUFFICIENC
7467 | HYPOPLAS LEFT HEART SYND
74681 | CONG SUBAORTIC STENOSIS
74682 | COR TRIATRIATUM
74683 | INFUNDIB PULMON STENOSIS
74684 | OBSTRUCT HEART ANOM NEC
74685 | CORONARY ARTERY ANOMALY
74686 | CONGENITAL HEART BLOCK
74687 | MALPOSITION OF HEART
74689 | CONG HEART ANOMALY NEC
7469 | CONG HEART ANOMALY NOS
7470 | PATENT DUCTUS ARTERIOSUS
74710 | COARCTATION OF AORTA
74711 | INTERRUPT OF AORTIC ARCH
74720 | CONG ANOM OF AORTA NOS
74721 | ANOMALIES OF AORTIC ARCH
74722 | AORTIC ATRESIA/STENOSIS
74729 | CONG ANOM OF AORTA NEC
7473 | PULMONARY ARTERY ANOM
74740 | GREAT VEIN ANOMALY NOS
74741 | TOT ANOM PULM VEN CONNEC
74742 | PART ANOM PULM VEN CONN
74749 | GREAT VEIN ANOMALY NEC
7475 | UMBILICAL ARTERY ABSENCE
74760 | UNSP PRPHERL VASC ANOMAL
74761 | GSTRONTEST VESL ANOMALY
74762 | RENAL VESSEL ANOMALY
74763 | UPR LIMB VESSEL ANOMALY
74764 | LWR LIMB VESSEL ANOMALY
74769 | OTH SPCF PRPH VSCL ANOML
74781 | CEREBROVASCULAR ANOMALY
74782 | SPINAL VESSEL ANOMALY
74789 | CIRCULATORY ANOMALY NEC
7479 | CIRCULATORY ANOMALY NOS
Or
Exclude (if single procedure): PDA ligation
ICD-9-CM diagnosis code:
7470 | PATENT DUCTUS ARTERIOSUS | Or
Exclude (if single procedure): Cardiac Catheterization
ICD-9-CM procedure codes:
3721 | RT HEART CARDIAC CATH
3722 | LEFT HEART CARDIAC CATH
3723 | RT/LEFT HEART CARD CATH
8842 | CONTRAST AORTOGRAM
8843 | CONTR PULMON ARTERIOGRAM
Pediatric heart surgery (#2)
ICD-9-CM procedure codes:
3500 | CLOSED VALVOTOMY NOS
3501 | CLOSED AORTIC VALVOTOMY
3502 | CLOSED MITRAL VALVOTOMY
3503 | CLOSED PULMON VALVOTOMY
3504 | CLOSED TRICUSP VALVOTOMY
3510 | OPEN VALVULOPLASTY NOS
3511 | OPN AORTIC VALVULOPLASTY
3512 | OPN MITRAL VALVULOPLASTY
3513 | OPN PULMON VALVULOPLASTY
3514 | OPN TRICUS VALVULOPLASTY
3520 | REPLACE HEART VALVE NOS
3521 | REPLACE AORT VALV-TISSUE
3522 | REPLACE AORTIC VALVE NEC
3523 | REPLACE MITR VALV-TISSUE
3524 | REPLACE MITRAL VALVE NEC
3525 | REPLACE PULM VALV-TISSUE
3526 | REPLACE PULMON VALVE NEC
3527 | REPLACE TRIC VALV-TISSUE
3528 | REPLACE TRICUSP VALV NEC
3531 | PAPILLARY MUSCLE OPS
3532 | CHORDAE TENDINEAE OPS
3533 | ANNULOPLASTY
3534 | INFUNDIBULECTOMY
3535 | TRABECUL CARNEAE CORD OP
3539 | TISS ADJ TO VALV OPS NEC
3542 | CREATE SEPTAL DEFECT
3550 | PROSTH REP HRT SEPTA NOS
3554 | PROS REP ENDOCAR CUSHION
3560 | GRFT REPAIR HRT SEPT NOS
3561 | GRAFT REPAIR ATRIAL DEF
3562 | GRAFT REPAIR VENTRIC DEF
3563 | GRFT REP ENDOCAR CUSHION
3570 | HEART SEPTA REPAIR NOS
3573 | ENDOCAR CUSHION REP NEC
3581 | TOT REPAIR TETRAL FALLOT
3582 | TOTAL REPAIR OF TAPVC
3583 | TOT REP TRUNCUS ARTERIOS
3584 | TOT COR TRANSPOS GRT VES
3591 | INTERAT VEN RETRN TRANSP
3592 | CONDUIT RT VENT-PUL ART
3593 | CONDUIT LEFT VENTR-AORTA
3594 | CONDUIT ARTIUM-PULM ART
3595 | HEART REPAIR REVISION
3596 | PERC HEART VALVULOPLASTY
3598 | OTHER HEART SEPTA OPS
3599 | OTHER HEART VALVE OPS
3601 | PTCA-1 VES/ATH W/O AGENT
3602 | PTCA-1 VES/ATH W AGENT
3603 | OPEN CORONRY ANGIOPLASTY
3604 | INTRCORONRY THROMB INFUS
3605 | PTCA-MULTIPLE VESSEL/ATH
3606 | INSERT OF COR ART STENT OCT95-
3609 | REM OF COR ART OBSTR NEC
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | INT MAM-COR ART BYPASS
3616 | INT MAM-COR ART BYPASS
3617 | ABD-CORON ARTERY BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
362 | ARTERIAL IMPLANT REVASC
363 | HEART REVASCULARIZAT NEC -OCT98
3631 | OPEN CHEST TRANS REVASC OCT98-
3632 | OTH TRANSMYO REVASCULAR OCT98-
3639 | OTH HEART REVASCULAR OCT98-
3691 | CORON VESS ANEURYSM REP
3699 | HEART VESSEL OP NEC
370 | PERICARDIOCENTESIS
3710 | INCISION OF HEART NOS
3711 | CARDIOTOMY
3712 | PERICARDIOTOMY
3721 | RT HEART CARDIAC CATH
3722 | LEFT HEART CARDIAC CATH
3723 | RT/LEFT HEART CARD CATH
3724 | PERICARDIAL BIOPSY
3725 | CARDIAC BIOPSY
3726 | CARDIAC ELECTROPHY STIM
3727 | CARDIAC MAPPING
3729 | HRT/PERICAR DX PROC NEC
3731 | PERICARDIECTOMY
3732 | HEART ANEURYSM EXCISION
3733 | EXC/DEST OTH HRT LESION
3734 | CATH ABLATION LES HEART
3735 | PARTIAL VENTRICULECTOMY OCT97-
374 | HEART & PERICARD REPAIR
375 | HEART TRANSPLANTATION
3761 | PULSATION BALLOON IMPLAN
3762 | IMPLANT HRT ASST SYS NEC
3763 | REPLACE HRT ASSIST SYST
3764 | REMOVE HEART ASSIST SYS
3765 | IMP EXT PUL HRT ASST SYS OCT95-
3766 | IMP IMP PUL HRT ASST SYS OCT95-
3767 | IMP CARDIOMYOSTIMUL SYS OCT98-
3770 | INT INSERT PACEMAK LEAD
3771 | INT INSERT LEAD IN VENT
3772 | INT INSER LEAD ATRI-VENT
3773 | INT INSER LEAD IN ATRIUM
3774 | INT OR REPL LEAD EPICAR
3775 | REVISION OF LEAD
3776 | REPL TV ATRI-VENT LEAD
3777 | REMOVAL OF LEAD W/O REPL
3778 | INSER TEMP PACEMAKER SYS
3779 | REVIS OR RELOCATE POCKET
3780 | INT OR REPL PERM PACEMKR
3781 | INT INSERT 1-CHAM, NON
3782 | INT INSERT 1-CHAM, RATE
3783 | INT INSERT DUAL-CHAM DEV
3785 | REPL PACEM W 1-CHAM, NON
3786 | REPL PACEM 1-CHAM, RATE
3787 | REPL PACEM W DUAL-CHAM
3789 | REVISE OR REMOVE PACEMAK
3791 | OPN CHEST CARDIAC MASSAG
3792 | INJECTION INTO HEART
3793 | INJECTION INTO PERICARD
3794 | IMPLT/REPL CARDDEFIB TOT
3795 | IMPLT CARDIODEFIB LEADS
3796 | IMPLT CARDIODEFIB GENATR
3797 | REPL CARDIODEFIB LEADS
3798 | REPL CARDIODEFIB GENRATR
3799 | OTHER HEART/PERICARD OPS
Include only: Hypoplastic left heart syndrome:
ICD-9-CM diagnosis code:
7467 | HYPOPLAS LEFT HEART SYND
PTCA Volume(QI #7)
PTCA
ICD-9-CM procedure codes:
3601 | PTCA-1 VESSEL W/O AGENT
3602 | PTCA-1 VESSEL WITH AGNT
3605 | PTCA-MULTIPLE VESSEL
3606 | INSERT OF COR ART STENT OCT95-
Utilization - Provider level
Cesarean section delivery(QI #8)
Cesarean section deliveries (Outcome of Interest):
DRGs:
370 | Cesarean section w/CC
371 | Cesarean section w/o CC
All deliveries (Population at Risk):
DRGs:
370 | CESAREAN SECTION W CC
371 | CESAREAN SECTION W/O CC
372 | VAGINAL DELIVERY W COMPL
373 | VAG DELIVERY W/O COMPL
374 | VAG DELIV W STERIL OR DC
375 | VAG DELIV W OTH OR PROC
Incidental appendectomy among elderly(QI #9)
Incidental appendectomy (Outcome of Interest):
ICD-9-CM procedure codes:
471 | INCIDENTAL APPENDECTOMY -OCT96
4711 | LAP INCID APPENDECTOMY OCT96-
4719 | OTHER INCID APPENDECTOMY OCT96-
Intra-abdominal procedure (Population at Risk):
DRGs:
146 | RECTAL RESECTION W CC
147 | RECTAL RESECTION W/O CC
148 | MAJ BOWEL PROC W CC
149 | MAJ BOWEL PROC W/0 CC
150 | PERITONEAL ADHES W CC
151 | PERITONEAL ADHES W/O CC
152 | MIN BOWEL PROC W CC
153 | MIN BOWEL PROC W/O CC
154 | UGI PROC AGE >17 W CC
155 | UGI PROC AGE >17 W/O CC
170 | OTH GI OR PROC W CC
171 | OTH GI OR PROC W/O CC
191 | PANC LVR SHNT PRC W CC
192 | PANC LVR SHNT PRC W/O CC
193 | BILIARY PROC W/ CC
194 | BILIARY PROC W/O CC
195 | CHOLE W/ CDE W/ CC
196 | CHOLE W/ CDE W/O CC
197 | CHOLE W/ CC
198 | CHOLE W/O CC
201 | OTH BILIARY/PANC PROC
354 | UTER PROC MALIG W/ CC
355 | UTER PROC MALIG W/O CC
356 | FEMALE REPROD RECONSTR
357 | UTER PROC OVARIAN MALIG
358 | UTER PROC NONMALIG W/ CC
359 | UTER PROC NONMALI W/O CC
365 | OTH FEMAL REPROD PROC
Bilateral cardiac catheterization(QI #10)
Bilateral catheterization (Outcome of interest)
ICD-9-CM procedure code:
3723 | RT/LEFT HEART CARD CATH
Catheterization (Population at risk)
ICD-9-CM procedure codes:
3722 | LEFT HEART CARDIAC CATH
3723 | RT/LEFT HEART CARD CATH
Include only: Coronary artery disease
ICD-9-CM diagnosis codes:
41000 | AMI ANTEROLATERAL,UNSPEC
41001 | AMI ANTEROLATERAL, INIT
41002 | AMI ANTEROLATERAL,SUBSEQ
41010 | AMI ANTERIOR WALL,UNSPEC
41011 | AMI ANTERIOR WALL, INIT
41012 | AMI ANTERIOR WALL,SUBSEQ
41020 | AMI INFEROLATERAL,UNSPEC
41021 | AMI INFEROLATERAL, INIT
41022 | AMI INFEROLATERAL,SUBSEQ
41030 | AMI INFEROPOST, UNSPEC
41031 | AMI INFEROPOST, INITIAL
41032 | AMI INFEROPOST, SUBSEQ
41040 | AMI INFERIOR WALL,UNSPEC
41041 | AMI INFERIOR WALL, INIT
41042 | AMI INFERIOR WALL,SUBSEQ
41050 | AMI LATERAL NEC, UNSPEC
41051 | AMI LATERAL NEC, INITIAL
41052 | AMI LATERAL NEC, SUBSEQ
41060 | TRUE POST INFARCT,UNSPEC
41061 | TRUE POST INFARCT, INIT
41062 | TRUE POST INFARCT,SUBSEQ
41070 | SUBENDO INFARCT, UNSPEC
41071 | SUBENDO INFARCT, INITIAL
41072 | SUBENDO INFARCT, SUBSEQ
41080 | AMI NEC, UNSPECIFIED
41081 | AMI NEC, INITIAL
41082 | AMI NEC, SUBSEQUENT
41090 | AMI NOS, UNSPECIFIED
41091 | AMI NOS, INITIAL
41092 | AMI NOS, SUBSEQUENT
4110 | POST MI SYNDROME
4111 | INTERMED CORONARY SYND
41181 | CORONARY OCCLSN W/O MI
41189 | AC ISCHEMIC HRT DIS NEC
412 | OLD MYOCARDIAL INFARCT
4130 | ANGINA DECUBITUS
4131 | PRINZMETAL ANGINA
4139 | ANGINA PECTORIS NEC/NOS
4140 | CORONARY ATHEROSCLEROSIS -OCT94
41400 | COR ATH UNSP VSL NTV/GFT OCT94-
41401 | CRNRY ATHRSCL NATVE VSSL OCT94-
41402 | CRN ATH ATLG VN BPS GRFT OCT94-
41403 | CRN ATH NONATLG BLG GRFT OCT94-
41404 | COR ATH ARTRY BYPAS GRFT OCT96-
41405 | COR ATH BYPASS GRAFT NOS OCT96-
41410 | ANEURYSM, HEART (WALL)
41411 | CORONARY VESSEL ANEURYSM
41419 | ANEURYSM OF HEART NEC
4148 | CHR ISCHEMIC HRT DIS NEC
4149 | CHR ISCHEMIC HRT DIS NOS
Excludes : Possible indications for right cath
ICD-9-CM diagnosis codes:
3910 | ACUTE RHEUMATIC PERICARD
3911 | ACUTE RHEUMATIC ENDOCARD
3912 | AC RHEUMATIC MYOCARDITIS
3918 | AC RHEUMAT HRT DIS NEC
3919 | AC RHEUMAT HRT DIS NOS
3920 | RHEUM CHOREA W HRT INVOL
3929 | RHEUMATIC CHOREA NOS
393 | CHR RHEUMATIC PERICARD
3940 | MITRAL STENOSIS
3941 | RHEUMATIC MITRAL INSUFF
3942 | MITRAL STENOSIS W INSUFF
3949 | MITRAL VALVE DIS NEC/NOS
3960 | MITRAL/AORTIC STENOSIS
3961 | MITRAL STENOS/AORT INSUF
3962 | MITRAL INSUF/AORT STENOS
3963 | MITRAL/AORTIC VAL INSUFF
3968 | MITR/AORTIC MULT INVOLV
3969 | MITRAL/AORTIC V DIS NOS
3970 | TRICUSPID VALVE DISEASE
3971 | RHEUM PULMON VALVE DIS
3979 | RHEUM ENDOCARDITIS NOS
3980 | RHEUMATIC MYOCARDITIS
39890 | RHEUMATIC HEART DIS NOS
39891 | RHEUMATIC HEART FAILURE
39899 | RHEUMATIC HEART DIS NEC
40200 | MAL HYPERTEN HRT DIS NOS
40201 | MAL HYPERT HRT DIS W CHF
40210 | BEN HYPERTEN HRT DIS NOS
40211 | BENIGN HYP HRT DIS W CHF
40290 | HYPERTENSIVE HRT DIS NOS
40291 | HYPERTEN HEART DIS W CHF
4150 | ACUTE COR PULMONALE
4151 | PULMON EMBOLISM/INFARCT -OCT95
41511 | IATROGEN PULM EMB/INFARC OCT95-
41519 | PULM EMBOL/INFARCT NEC OCT95-
4160 | PRIM PULM HYPERTENSION
4161 | KYPHOSCOLIOTIC HEART DIS
4168 | CHR PULMON HEART DIS NEC
4169 | CHR PULMON HEART DIS NOS
4170 | ARTERIOVEN FISTU PUL VES
4171 | PULMON ARTERY ANEURYSM
4178 | PULMON CIRCULAT DIS NEC
4179 | PULMON CIRCULAT DIS NOS
4242 | NONRHEUM TRICUSP VAL DIS
4243 | PULMONARY VALVE DISORDER
7450 | COMMON TRUNCUS
74510 | COMPL TRANSPOS GREAT VES
74511 | DOUBLE OUTLET RT VENTRIC
74512 | CORRECT TRANSPOS GRT VES
74519 | TRANSPOS GREAT VESS NEC
7452 | TETRALOGY OF FALLOT
7453 | COMMON VENTRICLE
7454 | VENTRICULAR SEPT DEFECT
7455 | SECUNDUM ATRIAL SEPT DEF
74560 | ENDOCARD CUSHION DEF NOS
74561 | OSTIUM PRIMUM DEFECT
74569 | ENDOCARD CUSHION DEF NEC
7457 | COR BILOCULARE
7458 | SEPTAL CLOSURE ANOM NEC
7459 | SEPTAL CLOSURE ANOM NOS
74600 | PULMONARY VALVE ANOM NOS
74601 | CONG PULMON VALV ATRESIA
74602 | CONG PULMON VALVE STENOS
74609 | PULMONARY VALVE ANOM NEC
7461 | CONG TRICUSP ATRES/STEN
7462 | EBSTEIN'S ANOMALY
7463 | CONG AORTA VALV STENOSIS
7464 | CONG AORTA VALV INSUFFIC
7465 | CONGEN MITRAL STENOSIS
7466 | CONG MITRAL INSUFFICIENC
7467 | HYPOPLAS LEFT HEART SYND
74681 | CONG SUBAORTIC STENOSIS
74682 | COR TRIATRIATUM
74683 | INFUNDIB PULMON STENOSIS
74684 | OBSTRUCT HEART ANOM NEC
74685 | CORONARY ARTERY ANOMALY
74686 | CONGENITAL HEART BLOCK
74687 | MALPOSITION OF HEART
74689 | CONG HEART ANOMALY NEC
7469 | CONG HEART ANOMALY NOS
7470 | PATENT DUCTUS ARTERIOSUS
74710 | COARCTATION OF AORTA
74711 | INTERRUPT OF AORTIC ARCH
74720 | CONG ANOM OF AORTA NOS
74721 | ANOMALIES OF AORTIC ARCH
74722 | AORTIC ATRESIA/STENOSIS
74729 | CONG ANOM OF AORTA NEC
7473 | PULMONARY ARTERY ANOM
74740 | GREAT VEIN ANOMALY NOS
74741 | TOT ANOM PULM VEN CONNEC
74742 | PART ANOM PULM VEN CONN
74749 | GREAT VEIN ANOMALY NEC
7475 | UMBILICAL ARTERY ABSENCE
74760 | UNSP PRPHERL VASC ANOMAL
74761 | GSTRONTEST VESL ANOMALY
74762 | RENAL VESSEL ANOMALY
74763 | UPR LIMB VESSEL ANOMALY
74764 | LWR LIMB VESSEL ANOMALY
74769 | OTH SPCF PRPH VSCL ANOML
74781 | CEREBROVASCULAR ANOMALY
74782 | SPINAL VESSEL ANOMALY
74789 | CIRCULATORY ANOMALY NEC
7479 | CIRCULATORY ANOMALY NOS
Successful vaginal birth after cesarean section (VBAC) (QI #11)
Vaginal deliveries (Outcome of Interest):
DRGs:
372 | VAGINAL DELIVERY W/ CC
373 | VAGINAL DELIVERY W/O CC
374 | VAGINAL DELIVERY W/ STERILIZATION OR D&C
375 | VAGINAL DELIVERY W/ OTHER O.R. PROCEDURE
All deliveries (Population at Risk):
DRGs:
370 | CESAREAN SECTION W CC
371 | CESAREAN SECTION W/O CC
372 | VAGINAL DELIVERY W COMPL
373 | VAG DELIVERY W/O COMPL
374 | VAG DELIV W STERIL OR DC
375 | VAG DELIV W OTH OR PROC
Previous C-section (Population at Risk):
ICD-9-CM diagnosis codes:
65420 | PREV C-SECT NOS-UNSPEC
65421 | PREV C-SECT NOS-DELIVER
65423 | PREV C-SECT NOS-ANTEPART
Laparoscopic cholecystectomy rate(QI #12)
Laparoscopic cholecystectomy (Outcome of Interest):
ICD-9-CM Procedure Code:
5123 | LAPAROSCOPIC CHOLE
Cholecystectomy (Population at Risk):
ICD-9-CM Procedure Codes:
5122 | CHOLECYSTECTOMY
5123 | LAPAROSCOPIC CHOLE
Include Only: Uncomplicated cholecystitis and/or cholelithiasis:
ICD-9-CM diagnosis Codes:
57400 | CHOLELITH W/ AC CHOLECYS
57401 | CHOLELITH W/ AC CHOLECYS
57410 | CHOLELITH W CHOLECYS NEC
57411 | CHOLELITH W CHOLECYS NEC
57420 | CHOLELITH NOS W/O OBSTRUC
57421 | CHOLELITH NOS W/ OBSTRUC
5750 | ACUTE CHOLECYSTITIS
5751 | CHOLECYSTITIS NEC -OCT96
57510 | CHOLECYSTITIS NOS OCT96-
57511 | CHRONIC CHOLECYSTITIS OCT96-
57512 | ACUTE & CHR CHOLECYSTITIS OCT96-
Utilization - Area level
CABG rate(QI #13)
CABG
ICD-9-CM procedure codes:
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | 1 INT MAM-COR ART BYPASS
3616 | 2 INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
Hysterectomy rate(QI #14)
Hysterectomy
ICD-9-CM Procedure Codes:
683 | SUBTOT ABD HYSTERECTOMY
684 | TOTAL ABD HYSTERECTOMY
685 | VAGINAL HYSTERECTOMY -OCT96
6851 | LAP AST VAG HYSTERECTOMY OCT96-
6859 | OTHER VAG HYSTERECTOMY OCT96-
686 | RADICAL ABD HYSTERECTOMY
687 | RADICAL VAG HYSTERECTOMY
689 | OTHER/UNSP HYSTERECTOMY
Exclude: Female genital cancer:
ICD-9-CM Diagnosis Codes:
179 | MALIG NEOPL UTERUS NOS
1800 | MALIG NEO ENDOCERVIX
1801 | MALIG NEO EXOCERVIX
1808 | MALIG NEO CERVIX NEC
1809 | MAL NEO CERVIX UTERI NOS
181 | MALIGNANT NEOPL PLACENTA
1820 | MALIG NEO CORPUS UTERI
1821 | MAL NEO UTERINE ISTHMUS
1828 | MAL NEO BODY UTERUS NEC
1830 | MALIGN NEOPL OVARY
1832 | MAL NEO FALLOPIAN TUBE
1833 | MAL NEO BROAD LIGAMENT
1834 | MALIG NEO PARAMETRIUM
1835 | MAL NEO ROUND LIGAMENT
1838 | MAL NEO ADNEXA NEC
1839 | MAL NEO ADNEXA NOS
1840 | MALIGN NEOPL VAGINA
1841 | MAL NEO LABIA MAJORA
1842 | MAL NEO LABIA MINORA
1843 | MALIGN NEOPL CLITORIS
1844 | MALIGN NEOPL VULVA NOS
1848 | MAL NEO FEMALE GENIT NEC
1849 | MAL NEO FEMALE GENIT NOS
2331 | CA IN SITU CERVIX UTERI
2332 | CA IN SITU UTERUS NEC
2333 | CA IN SITU FEM GEN NEC
2360 | UNCERT BEHAV NEO UTERUS
2361 | UNC BEHAV NEO PLACENTA
2362 | UNC BEHAV NEO OVARY
2363 | UNC BEHAV NEO FEMALE NEC
Exclude: Pelvic or lower abdominal trauma:
ICD-9-CM Diagnosis Codes:
8674 | UTERUS INJURY-CLOSED
8675 | UTERUS INJURY-OPEN
8676 | PELVIC ORGAN INJ NEC-CL
8677 | PELVIC ORGAN INJ NEC-OPN
8678 | PELVIC ORGAN INJ NOS-CL
8679 | PELVIC ORGAN INJ NOS-OPN
86800 | INTRA-ABDOM INJ NOS-CLOS
86803 | PERITONEUM INJURY-CLOSED
86804 | RETROPERITONEUM INJ-CL
86809 | INTRA-ABDOM INJ NEC-CLOS
86810 | INTRA-ABDOM INJ NOS-OPEN
86813 | PERITONEUM INJURY-OPEN
86814 | RETROPERITONEUM INJ-OPEN
86819 | INTRA-ABDOM INJ NEC-OPEN
8690 | INTERNAL INJ NOS-CLOSED
8691 | INTERNAL INJURY NOS-OPEN
8796 | OPEN WOUND OF TRUNK NEC
8797 | OPEN WND TRUNK NEC-COMPL
8798 | OPEN WOUND SITE NOS
8799 | OPN WOUND SITE NOS-COMPL
9060 | LT EFF OPN WND HEAD/TRNK
9081 | LATE EFF INT INJ ABDOMEN
9082 | LATE EFF INT INJURY NEC
9391 | FOREIGN BODY UTERUS
9474 | BURN OF VAGINA & UTERUS
Laminectomy and/or spinal fusion rate(QI #15)
Laminectomy and/or spinal fusion:
ICD-9-CM Procedure Codes:
0302 | REOPEN LAMINECTOMY SITE
0309 | SPINAL CANAL EXPLOR NEC
8050 | EXC/DEST INTVRT DISC NOS
8051 | EXCISION INTERVERT DISC
8059 | OTH EXC/DEST INTVRT DISC
8100 | SPINAL FUSION NOS
8101 | ATLAS-AXIS FUSION
8102 | OTH CERV FUSION, ANTER
8103 | OTH CERV FUSION, POSTER
8104 | DORSAL FUSION, ANTERIOR
8105 | DORSAL FUSION, POSTERIOR
8106 | LUMBAR FUSION, ANTERIOR
8107 | LUMBAR FUSION, LATERAL
8108 | LUMBAR FUSION, POSTERIOR
8109 | REFUSION OF SPINE
PTCA rate(QI #16)
PTCA
ICD-9-CM procedure codes:
3601 | PTCA-1 VESSEL W/O AGENT
3602 | PTCA-1 VESSEL WITH AGNT
3605 | PTCA-MULTIPLE VESSEL
3606 | INSERT OF COR ART STENT
ACSC Area rates
Dehydration rate(QI #17)
Dehydration
ICD-9-CM diagnosis code:
2765 | HYPOVOLEMIA
Bacterial pneumonia rate(QI #18)
Bacterial pneumonia
ICD-9-CM diagnosis codes:
481 | PNEUMOCOCCAL PNEUMONIA
4822 | H.INFLUENZAE PNEUMONIA
48230 | STREP PNEUMONIA UNSPEC
48231 | GRP A STREP PNEUMONIA
48232 | GRP B STREP PNEUMONIA
48239 | OTH STREP PNEUMONIA
4829 | BACTERIAL PNEUMONIA NOS
4830 | MYCOPLASMA PNEUMONIA
4831 | CHLAMYDIA PNEUMONIA OCT96-
4838 | OTH SPEC ORG PNEUMONIA
485 | BRONCOPNEUMONIA ORG NOS
486 | PNEUMONIA, ORGANISM NOS
Exclude: Sickle cell anemia, HB disease
ICD-9-CM diagnosis codes:
28260 | SICKLE-CELL ANEMIA NOS
28261 | HB-S DISEASE W/O CRISIS
28262 | HB-S DISEASE WITH CRISIS
28263 | SICKLE-CELL/HB-C DISEASE
28269 | SICKLE-CELL ANEMIA NEC
Urinary infection rate(QI #19)
Urinary infection
ICD-9-CM diagnosis codes:
59000 | CHR PYELONEPHRITIS NOS
59001 | CHR PYELONEPH W MED NECR
59010 | AC PYELONEPHRITIS NOS
59011 | AC PYELONEPHR W MED NECR
5902 | RENAL/PERIRENAL ABSCESS
5903 | PYELOURETERITIS CYSTICA
59080 | PYELONEPHRITIS NOS
59081 | PYELONEPHRIT IN OTH DIS
5909 | INFECTION OF KIDNEY NOS
5950 | AC CYSTITIS
5959 | CYSTITIS NOS
5990 | URIN TRACT INFECTION NOS
Perforated appendix rate(QI #20)
Perforated appendix (outcome of interest)
ICD-9-CM diagnosis codes:
5400 | AC APPEND W PERITONITIS
5401 | ABSCESS OF APPENDIX
Appendicitis (population at risk)
ICD-9-CM diagnosis codes:
5400 | AC APPEND W PERITONITIS
5401 | ABSCESS OF APPENDIX
5409 | ACUTE APPENDICITIS NOS
541 | APPENDICITIS NOS
Angina (w/o procedure) rate(QI #21)
Angina
ICD-9-CM diagnosis codes:
4111 | INTERMED CORONARY SYND
41181 | CORONARY OCCLSN W/O MI
41189 | AC ISCHEMIC HRT DIS NEC
4130 | ANGINA DECUBITUS
4131 | PRINZMETAL ANGINA
4139 | ANGINA PECTORIS NEC/NOS
Exclude: All procedures: 01.0-86.99)
Adult asthma rate(QI #22)
Adult asthma
ICD-9-CM diagnosis codes:
49300 | EXT ASTHMA W/O STAT ASTH
49301 | EXT ASTHMA W STATUS ASTH
49302 | EXT ASTHMA W STATUS ACEX OCT00-
49310 | INT ASTHMA W/O STAT ASTH
49311 | INT ASTHMA W STATUS ASTH
49312 | INT ASTHMA W STATUS ACEX OCT00-
49320 | CH OB ASTH W/O STAT ASTH
49321 | CH OB ASTHMA W STAT ASTH
49322 | CH OB ASTHMA W STAT ACEX OCT00-
49390 | ASTHMA W/O STATUS ASTHM
49391 | ASTHMA W STATUS ASTHMAT
49392 | ASTHMA W STATUS AC EXAC OCT00-
COPD rate(QI #23)
COPD
ICD-9-CM diagnosis codes:
4660 | AC BRONCHITIS*
490 | BRONCHITIS NOS*
4910 | SIMPLE CHR BRONCHITIS
4911 | MUCOPURUL CHR BRONCHITIS
49120 | OBS CHR BRNC W/O ACT EXA
49121 | OBS CHR BRNC W ACT EXA
4918 | CHRONIC BRONCHITIS NEC
4919 | CHRONIC BRONCHITIS NOS
4920 | EMPHYSEMATOUS BLEB
4928 | EMPHYSEMA NEC
494 | BRONCHIECTASIS -OCT00
4940 | BRONCHIECTAS W/O AC EXAC OCT00-
4941 | BRONCHIECTASIS W AC EXAC OCT00-
496 | CHR AIRWAY OBSTRUCT NEC
* Qualifies only if accompanied by secondary diagnosis of 491.xx, 492.x, 494, or 496 (i.e., any other code on this list).
Congestive heart failure rate(QI #24)
CHF
ICD-9-CM diagnosis codes:
39891 | RHEUMATIC HEART FAILURE
40201 | MAL HYPERT HRT DIS W CHF
40211 | BENIGN HYP HRT DIS W CHF
40291 | HYPERTEN HEART DIS W CHF
40401 | MAL HYPER HRT/REN W CHF
40403 | MAL HYP HRT/REN W CHF&RF
40411 | BEN HYPER HRT/REN W CHF
40413 | BEN HYP HRT/REN W CHF&RF
40491 | HYPER HRT/REN NOS W CHF
40493 | HYP HT/REN NOS W CHF&RF
4280 | CONGESTIVE HEART FAILURE
4281 | LEFT HEART FAILURE
4289 | HEART FAILURE NOS
Exclude: Cardiac procedures:
ICD-9-CM procedure codes:
3601 | PTCA-1 VESSEL W/O AGENT
3602 | PTCA-1 VESSEL WITH AGNT
3605 | PTCA-MULTIPLE VESSEL
3606 | INSERT CORONARY ART STENT OCT95-
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | 1 INT MAM-COR ART BYPASS
3616 | 2 INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
375 | HEART TRANSPLANTATION
3770 | INT INSERT PACEMAK LEAD
3771 | INT INSERT LEAD IN VENT
3772 | INT INSER LEAD ATRI-VENT
3773 | INT INSER LEAD IN ATRIUM
3774 | INT OR REPL LEAD EPICAR
3775 | REVISION OF LEAD
3776 | REPL TV ATRI-VENT LEAD
3777 | REMOVAL OF LEAD W/O REPL
3778 | INSER TEMP PACEMAKER SYS
3779 | REVIS OR RELOCATE POCKET
Diabetes - short-term complications rate(QI #25)
Diabetes with short-term complications
ICD-9-CM Diagnosis Codes:
25010 | DM KETO T2, DM CONT
25011 | DM KETO T1, DM CONT
25012 | DM KETO T2, DM UNCONT
25013 | DM KETO T1, DM UNCONT
25020 | DM W/ HYPROSM T2, DM CONT
25021 | DM W/ HYPROSM T1, DM CONT
25022 | DM W/ HYPROSM T2, DM UNCNT
25023 | DM W/ HYPROSM T1, DM UNCNT
25030 | DM COMA NEC TYP II, DM CNT
25031 | DM COMA NEC T1, DM CONT
25032 | DM COMA NEC T2, DM UNCONT
25033 | DM COMA NEC T1, DM UNCONT
Diabetes - uncontrolled (without short-term or long-term complications) admission rate (QI #26)
Uncontrolled diabetes
ICD-9-CM Diagnosis Codes:
25002 | DM, T2, UNCONT
25003 | DM, T1, UNCONT
Diabetes - long-term complications rate(QI #27)
Diabetes with long term-complications
ICD-9-CM Diagnosis Codes:
25040 | DM RENAL COMP T2 CONT
25041 | DM RENAL COMP T1 CONT
25042 | DM RENAL COMP T2 UNCNT
25043 | DM RENAL COMP T1 UNCNT
25050 | DM EYE COMP T2 CONT
25051 | DM EYE COMP T1 CONT
25052 | DM EYE COMP T2 UNCNT
25053 | DM EYE COMP T1 UNCNT
25060 | DM NEURO COMP T2 CONT
25061 | DM NEURO COMP T1 CONT
25062 | DM NEURO COMP T2 UNCNT
25063 | DM NEURO COMP T1 UNCNT
25070 | DM CIRCU DIS T2 CONT
25071 | DM CIRCU DIS T1 CONT
25072 | DM CIRCU DIS T2 UNCNT
25073 | DM CIRCU DIS T1 UNCNT
25080 | DM W COMP NEC T2 CONT
25081 | DM W COMP NEC T1 CONT
25082 | DM W COMP NEC T2 UNCNT
25083 | DM W COMP NEC T1 UNCNT
25090 | DM W COMPL NOS T2 CONT
25091 | DM W COMPL NOS T1 CONT
25092 | DM W COMPL NOS T2 UNCNT
25093 | DM W COMPL NOS T1 UNCNT>
Hypertension rate(QI #28)
Hypertension
ICD-9-CM diagnosis codes:
4010 | MALIGNANT HYPERTENSION
4019 | HYPERTENSION NOS
40200 | MAL HYPERTEN HRT DIS W/OUT CHF
40210 | BEN HYPERTEN HRT DIS W/OUT CHF
40290 | HYPERTENSIVE HRT DIS W/OUT CHF
40300 | MAL HYPERT HRT DIS W/OUT RF
40310 | BENIGN HYP HRT DIS W/OUT RF
40390 | HYPERTEN HEART DIS W/OUT RF
40400 | MAL HYPER HRT/REN W/OUT CHF/RF
40410 | BEN HYPER HRT/REN W/OUT CHF/RF
40490 | HYPER HRT/REN NOS W/OUT CHF/RF
Exclude: Cardiac procedures:
ICD-9-CM procedure codes:
3601 | PTCA-1 VESSEL W/O AGENT
3602 | PTCA-1 VESSEL WITH AGNT
3605 | PTCA-MULTIPLE VESSEL-
3606 | INSERT CORONARY ART STENT OCT95-
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | 1 INT MAM-COR ART BYPASS
3616 | 2 INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
375 | HEART TRANSPLANTATION
3770 | INT INSERT PACEMAK LEAD
3771 | INT INSERT LEAD IN VENT
3772 | INT INSER LEAD ATRI-VENT
3773 | INT INSER LEAD IN ATRIUM
3774 | INT OR REPL LEAD EPICAR
3775 | REVISION OF LEAD
3776 | REPL TV ATRI-VENT LEAD
3777 | REMOVAL OF LEAD W/O REPL
3778 | INSER TEMP PACEMAKER SYS
3779 | REVIS OR RELOCATE POCKET
Lower extremity amputation rate(QI #29)
Lower extremity amputation
ICD-9-CM procedure codes:
8410 | LOWER LIMB AMPUTAT NOS
8411 | TOE AMPUTATION
8412 | AMPUTATION THROUGH FOOT
8413 | DISARTICULATION OF ANKLE
8414 | AMPUTAT THROUGH MALLEOLI
8415 | BELOW KNEE AMPUTAT NEC
8416 | DISARTICULATION OF KNEE
8417 | ABOVE KNEE AMPUTATION
8418 | DISARTICULATION OF HIP
8419 | HINDQUARTER AMPUTATION
Include only: Diabetes
ICD-9-CM diagnosis codes:
25000 | DMII WO CMP NT ST UNCNTR
25001 | DMI WO CMP NT ST UNCNTRL
25002 | DMII WO CMP UNCNTRLD
25003 | DMI WO CMP UNCNTRLD
25010 | DMII KETO NT ST UNCNTRLD
25011 | DMI KETO NT ST UNCNTRLD
25012 | DMII KETOACD UNCONTROLD
25013 | DMI KETOACD UNCONTROLD
25020 | DMII HPRSM NT ST UNCNTRL
25021 | DMI HPRSM NT ST UNCNTRLD
25022 | DMII HPROSMLR UNCONTROLD
25023 | DMI HPROSMLR UNCONTROLD
25030 | DMII O CM NT ST UNCNTRLD
25031 | DMI O CM NT ST UNCNTRLD
25032 | DMII OTH COMA UNCONTROLD
25033 | DMI OTH COMA UNCONTROLD
25040 | DMII RENL NT ST UNCNTRLD
25041 | DMI RENL NT ST UNCNTRLD
25042 | DMII RENAL UNCNTRLD
25043 | DMI RENAL UNCNTRLD
25050 | DMII OPHTH NT ST UNCNTRL
25051 | DMI OPHTH NT ST UNCNTRLD
25052 | DMII OPHTH UNCNTRLD
25053 | DMI OPHTH UNCNTRLD
25060 | DMII NEURO NT ST UNCNTRL
25061 | DMI NEURO NT ST UNCNTRLD
25062 | DMII NEURO UNCNTRLD
25063 | DMI NEURO UNCNTRLD
25070 | DMII CIRC NT ST UNCNTRLD
25071 | DMI CIRC NT ST UNCNTRLD
25072 | DMII CIRC UNCNTRLD
25073 | DMI CIRC UNCNTRLD
25080 | DMII OTH NT ST UNCNTRLD
25081 | DMI OTH NT ST UNCNTRLD
25082 | DMII OTH UNCNTRLD
25083 | DMI OTH UNCNTRLD
25090 | DMII UNSPF NT ST UNCNTRL
25091 | DMI UNSPF NT ST UNCNTRLD
25092 | DMII UNSPF UNCNTRLD
25093 | DMI UNSPF UNCNTRLD
Exclude: Trauma
ICD-9-CM diagnosis codes:
8950 | AMPUTATION TOE
8951 | AMPUTATION TOE-COMPLICAT
8960 | AMPUTATION FOOT, UNILAT
8961 | AMPUT FOOT, UNILAT-COMPL
8962 | AMPUTATION FOOT, BILAT
8963 | AMPUTAT FOOT, BILAT-COMP
8970 | AMPUT BELOW KNEE, UNILAT
8971 | AMPUTAT BK, UNILAT-COMPL
8972 | AMPUT ABOVE KNEE, UNILAT
8973 | AMPUT ABV KN, UNIL-COMPL
8974 | AMPUTAT LEG, UNILAT NOS
8975 | AMPUT LEG, UNIL NOS-COMP
8976 | AMPUTATION LEG, BILAT
8977 | AMPUTAT LEG, BILAT-COMPL
Low birthweight rate(QI #30)
Low birthweight (Outcome of interest)
ICD-9-CM diagnosis codes:
76400 | LIGHT-FOR-DATES WTNOS
76401 | LIGHT-FOR-DATES <500G
76402 | LT-FOR-DATES 500-749G
76403 | LT-FOR-DATES 750-999G
76404 | LT-FOR-DATES 1000-1249G
76405 | LT-FOR-DATES 1250-1499G
76406 | LT-FOR-DATES 1500-1749G
76407 | LT-FOR-DATES 1750-1999G
76408 | LT-FOR-DATES 2000-2499G
76410 | LT-FOR-DATE W/MAL WTNOS
76411 | LT-FOR-DATE W/MAL <500G
76412 | LT-DATE W/MAL 500-749G
76413 | LT-DATE W/MAL 750-999G
76414 | LT-DATE W/MAL 1000-1249G
76415 | LT-DATE W/MAL 1250-1499G
76416 | LT-DATE W/MAL 1500-1749G
76417 | LT-DATE W/MAL 1750-1999G
76418 | LT-DATE W/MAL 2000-2499G
76420 | FETAL MALNUTRITION WTNOS
76421 | FETAL MALNUTRITION <500G
76422 | FETAL MALNUTR 500-749G
76423 | FETAL MAL 750-999G
76424 | FETAL MAL 1000-1249G
76425 | FETAL MAL 1250-1499G
76426 | FETAL MAL 1500-1749G
76427 | FETAL MALNUTR 1750-1999G
76428 | FETAL MALNUTR 2000-2499G
76490 | FET GROWTH RETARD WTNOS
76491 | FET GROWTH RETARD <500G
76492 | FET GROWTH RET 500-749G
76493 | FET GROWTH RET 750-999G
76494 | FET GRWTH RET 1000-1249G
76495 | FET GRWTH RET 1250-1499G
76496 | FET GRWTH RET 1500-1749G
76497 | FET GRWTH RET 1750-1999G
76498 | FET GRWTH RET 2000-2499G
76500 | EXTREME IMMATUR WTNOS
76501 | EXTREME IMMATUR <500G
76502 | EXTREME IMMATUR 500-749G
76503 | EXTREME IMMATUR 750-999G
76504 | EXTREME IMMAT 1000-1249G
76505 | EXTREME IMMAT 1250-1499G
76506 | EXTREME IMMAT 1500-1749G
76507 | EXTREME IMMAT 1750-1999G
76508 | EXTREME IMMAT 2000-2499G
76510 | PRETERM INFANT NEC WTNOS
76511 | PRETERM NEC <500G
76512 | PRETERM NEC 500-749G
76513 | PRETERM NEC 750-999G
76514 | PRETERM NEC 1000-1249G
76515 | PRETERM NEC 1250-1499G
76516 | PRETERM NEC 1500-1749G
76517 | PRETERM NEC 1750-1999G
76518 | PRETERM NEC 2000-2499G
All births (pouulation at risk)
DRG Codes:
DRGs:
370 | CESAREAN SECTION W CC
371 | CESAREAN SECTION W/O CC
372 | VAGINAL DELIVERY W COMPL
373 | VAG DELIVERY W/O COMPL
374 | VAG DELIV W STERIL OR DC
375 | VAG DELIV W OTH OR PROC
Pediatric asthma rate(QI #31)
Pediatric asthma
ICD-9-CM diagnosis codes:
49300 | EXT ASTHMA W/O STAT ASTH
49301 | EXT ASTHMA W STATUS ASTH
49302 | EXT ASTHMA W STATUS ACEX OCT00-
49310 | INT ASTHMA W/O STAT ASTH
49311 | INT ASTHMA W STATUS ASTH
49312 | INT ASTHMA W STATUS ACEX OCT00-
49320 | CH OB ASTH W/O STAT ASTH
49321 | CH OB ASTHMA W STAT ASTH
49322 | CH OB ASTHMA W STAT ACEX OCT00-
49390 | ASTHMA W/O STATUS ASTHM
49391 | ASTHMA W STATUS ASTHMAT
49392 | ASTHMA W STATUS AC EXAC OCT00-
Pediatric Gastroenteritis rate(QI #32)
Pediatric gastroenteritis
ICD-9-CM diagnosis codes:
00861 | ROTAVIRUS ENTERITIS
00862 | ADENOVIRUS ENTERITIS
00863 | NORWALK ENTERITIS
00864 | OTHER SRV ENTERITIS
00865 | CALICIVIRUS ENTERITIS
00866 | ASTROVIRUS ENTERITIS
00867 | ENTEROVIRUS ENTERITIS NEC
00869 | ENTERITIS NOS
0088 | VIRAL ENTERITIS NOS
0090 | INFECTIOUS ENTERITIS NOS
0091 | ENTERITIS OF INFECT ORIG
0092 | INFECTIOUS DIARRHEA
0093 | DIARRHEA, PRESUM INFECTIOUS
5589 | NONINF GASTROENTERIT NEC
Mortality
AMI mortality (QI #33)
AMI
ICD-9-CM diagnosis codes:
41001 | AMI ANTEROLATERAL, INIT
41011 | AMI ANTERIOR WALL, INIT
41021 | AMI INFEROLATERAL, INIT
41031 | AMI INFEROPOST, INITIAL
41041 | AMI INFERIOR WALL, INIT
41051 | AMI LATERAL NEC, INITIAL
41061 | TRUE POST INFARCT, INIT
41071 | SUBENDO INFARCT, INITIAL
41081 | AMI NEC, INITIAL
41091 | AMI NOS, INITIAL
Congestive heart failure mortality (QI #34)
CHF
ICD-9-CM diagnosis codes:
39891 | RHEUMATIC HEART FAILURE
40201 | MAL HYPERT HRT DIS W CHF
40211 | BENIGN HYP HRT DIS W CHF
40291 | HYPERTEN HEART DIS W CHF
40401 | MAL HYPER HRT/REN W CHF
40403 | MAL HYP HRT/REN W CHF&RF
40411 | BEN HYPER HRT/REN W CHF
40413 | BEN HYP HRT/REN W CHF&RF
40491 | HYPER HRT/REN NOS W CHF
40493 | HYP HT/REN NOS W CHF&RF
4280 | CONGESTIVE HEART FAILURE
4281 | LEFT HEART FAILURE
4289 | HEART FAILURE NOS
Exclude: Cardiac procedures:
ICD-9-CM procedure codes:
3601 | PTCA-1 VESSEL W/O AGENT
3602 | PTCA-1 VESSEL WITH AGNT
3607 | PTCA-MULTIPLE VESSEL
3608 | INSERT CORONARY ART STENT OCT95-
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | 1 INT MAM-COR ART BYPASS
3616 | 2 INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
375 | HEART TRANSPLANTATION
3770 | INT INSERT PACEMAK LEAD
3771 | INT INSERT LEAD IN VENT
3772 | INT INSER LEAD ATRI-VENT
3773 | INT INSER LEAD IN ATRIUM
3774 | INT OR REPL LEAD EPICAR
3775 | REVISION OF LEAD
3776 | REPL TV ATRI-VENT LEAD
3777 | REMOVAL OF LEAD W/O REPL
3778 | INSER TEMP PACEMAKER SYS
3779 | REVIS OR RELOCATE POCKET
GI Hemorrhage mortality(QI #35)
GI Hemorrhage
ICD-9-CM diagnosis codes:
4560 | ESOPH VARICES W HEM
5307 | GASTROESOPH LACER W HEM
53082 | ESOPHAGEAL HEM
53100 | AC STOMACH ULCER W HEM
53101 | AC STOMAC ULC W HEM-OBST
53120 | AC STOMAC ULC W HEM/PERF
53121 | AC STOM ULC HEM/PERF-OBS
53140 | CHR STOMACH ULC W HEM
53141 | CHR STOM ULC W HEM-OBSTR
53160 | CHR STOMACH ULC HEM/PERF
53161 | CHR STOM ULC HEM/PERF-OB
53200 | AC DUODENAL ULCER W HEM
53201 | AC DUODEN ULC W HEM-OBST
53220 | AC DUODEN ULC W HEM/PERF
53221 | AC DUOD ULC HEM/PERF-OBS
53240 | CHR DUODEN ULCER W HEM
53241 | CHR DUODEN ULC HEM-OBSTR
53260 | CHR DUODEN ULC HEM/PERF
53261 | CHR DUOD ULC HEM/PERF-OB
53300 | AC PEPTIC ULCER W HEMORR
53301 | AC PEPTIC ULC W HEM-OBST
53320 | AC PEPTIC ULC W HEM/PERF
53321 | AC PEPT ULC HEM/PERF-OBS
53340 | CHR PEPTIC ULCER W HEM
53341 | CHR PEPTIC ULC W HEM-OBS
53360 | CHR PEPT ULC W HEM/PERF
53361 | CHR PEPT ULC HEM/PERF-OB
53400 | AC MARGINAL ULCER W HEM
53401 | AC MARGIN ULC W HEM-OBST
53420 | AC MARGIN ULC W HEM/PERF
53421 | AC MARG ULC HEM/PERF-OBS
53440 | CHR MARGINAL ULCER W HEM
53441 | CHR MARGIN ULC W HEM-OBS
53460 | CHR MARGIN ULC HEM/PERF
53461 | CHR MARG ULC HEM/PERF-OB
53501 | ACUTE GASTRITIS W HMRHG
53511 | ATRPH GASTRITIS W HMRHG
53521 | GSTR MCSL HYPRT W HMRG
53531 | ALCHL GSTRITIS W HMRHG
53541 | OTH SPF GASTRT W HMRHG
53551 | GSTRDDNTS NOS W HMRHG
53561 | DUODENITIS W HMRHG
53783 | ANGIODYS STOM DUOD W HEM
56202 | DIVERTICULOS SM INT W HEM
56203 | DIVERTICULIT SM INT W HEM
56212 | DIVERTICULOS COLON W HEM
56213 | DIVERTICULIT COLON W HEM
5693 | HEMORRHAGE RECT/ANUS
56985 | ANGIODYS INTEST W HEM
5780 | HEMATEMESIS
5781 | BLOOD IN STOOL
5789 | GASTROINTEST HEMORR NOS
Hip fracture mortality(QI #36)
Hip fracture
ICD-9-CM diagnosis codes:
82000 | FX FEMUR INTRCAPS NOS-CL
82001 | FX UP FEMUR EPIPHY-CLOS
82002 | FX FEMUR, MIDCERVIC-CLOS
82003 | FX BASE FEMORAL NCK-CLOS
82009 | FX FEMUR INTRCAPS NEC-CL
82010 | FX FEMUR INTRCAP NOS-OPN
82011 | FX UP FEMUR EPIPHY-OPEN
82012 | FX FEMUR, MIDCERVIC-OPEN
82013 | FX BASE FEMORAL NCK-OPEN
82019 | FX FEMUR INTRCAP NEC-OPN
82020 | TROCHANTERIC FX NOS-CLOS
82021 | INTERTROCHANTERIC FX-CL
82022 | SUBTROCHANTERIC FX-CLOSE
82030 | TROCHANTERIC FX NOS-OPEN
82031 | INTERTROCHANTERIC FX-OPN
82032 | SUBTROCHANTERIC FX-OPEN
8208 | FX NECK OF FEMUR NOS-CL
8209 | FX NECK OF FEMUR NOS-OPN
Pneumonia mortality(QI #37)
Pneumonia
ICD-9-CM diagnosis codes:
00322 | SALMONELLA PNEUMONIA
0212 | PULMONARY TULAREMIA
0391 | PULMONARY ACTINOMYCOSIS
0521 | VARICELLA PNEUMONITIS
0551 | POSTMEASLES PNEUMONIA
0730 | ORNITHOSIS PNEUMONIA
1124 | CANDIDIASIS OF LUNG
1140 | PRIMARY COCCIDIOIDOMYCOS
1144 | CHRONIC PULMON COCCIDIOIDOMYCOSIS
1145 | UNSPEC PULMON COCCIDIOIDOMYCOSIS
11505 | HISTOPLASM CAPS PNEUMON
11515 | HISTOPLASM DUB PNEUMONIA
11595 | HISTOPLASMOSIS PNEUMONIA
1304 | TOXOPLASMA PNEUMONITIS
1363 | PNEUMOCYSTOSIS
4800 | ADENOVIRAL PNEUMONIA
4801 | RESP SYNCYT VIRAL PNEUM
4802 | PARINFLUENZA VIRAL PNEUM
4808 | VIRAL PNEUMONIA NEC
4809 | VIRAL PNEUMONIA NOS
481 | PNEUMOCOCCAL PNEUMONIA
4820 | K. PNEUMONIAE PNEUMONIA
4821 | PSEUDOMONAL PNEUMONIA
4822 | H.INFLUENZAE PNEUMONIA
48230 | STREP PNEUMONIA UNSPEC
48231 | GRP A STREP PNEUMONIA
48232 | GRP B STREP PNEUMONIA
48239 | OTH STREP PNEUMONIA
4824 | STAPHYLOCOCCAL PNEUMONIA
48240 | STAPH PNEUMONIA UNSP OCT98-
48241 | STAPH AUREUS PNEUMON OCT98-
48249 | STAPH PNEUMON OTH OCT98-
48281 | ANAEROBIC PNEUMONIA
48282 | E COLI PNEUMONIA
48283 | OTH GRAM NEG PNEUMONIA
48284 | LEGIONNAIRES DX OCT97-
48289 | BACT PNEUMONIA NEC
4829 | BACTERIAL PNEUMONIA NOS
4830 | MYCOPLASMA PNEUMONIA
4831 | CHLAMYDIA PNEUMONIA OCT96-
4838 | OTH SPEC ORG PNEUMONIA
4841 | PNEUM W CYTOMEG INCL DIS
4843 | PNEUMONIA IN WHOOP COUGH
4845 | PNEUMONIA IN ANTHRAX
4846 | PNEUM IN ASPERGILLOSIS
4847 | PNEUM IN OTH SYS MYCOSES
4848 | PNEUM IN INFECT DIS NEC
485 | BRONCOPNEUMONIA ORG NOS
486 | PNEUMONIA, ORGANISM NOS
5070 | PNEUMONITIS, ASP FOOD VOMIT
5100 | EMPYEMA W FISTULA
5109 | EMPYEMA W/O FISTULA
5110 | PLEURISY W EFF, BACT NOT TB
5130 | ABSCESS OF LUNG
Stroke mortality(QI #38)
Stroke
ICD-9-CM diagnosis codes:
430 | SUBARACHNOID HEMORRHAGE
431 | INTRACEREBRAL HEMORRHAGE
4320 | NONTRAUM EXTRADURAL HEM
4321 | SUBDURAL HEMORRHAGE
4329 | INTRACRANIAL HEMORR NOS
43301 | BASI ART OCCL W/ INFARCT
43311 | CAROTD OCCL W/ INFRCT
43321 | VERTB ART OCCL W/ INFRCT
43331 | MULT PRECER OCCL W/ INFRCT
43381 | PRECER OCCL NEC W/ INFRCT
43391 | PRECER OCCL NOS W/ INFRCT
43401 | CERE THROMBOSIS W/ INFRCT
43411 | CERE EMBOLISM W/ INFRCT
43491 | CEREB OCCL NOS W/ INFRCT
436 | CVA
AAA repair mortality(QI #39)
AAA repair
ICD-9-CM procedure codes:
3834 | AORTA RESECTION & ANAST
3844 | RESECT ABDM AORTA W REPL
3864 | EXCISION OF AORTA
Include only: AAA
ICD-9-CM diagnosis codes:
4413 | RUPT ABD AORTIC ANEURYSM
4414 | ABDOM AORTIC ANEURYSM
CABG Mortality(QI #40)
CABG
ICD-9-CM procedure codes:
3610 | AORTOCORONARY BYPASS NOS
3611 | AORTOCOR BYPAS-1 COR ART
3612 | AORTOCOR BYPAS-2 COR ART
3613 | AORTOCOR BYPAS-3 COR ART
3614 | AORTCOR BYPAS-4+ COR ART
3615 | INT MAM-COR ART BYPASS
3616 | INT MAM-COR ART BYPASS
3617 | ABD-CORON ART BYPASS OCT96-
3619 | HRT REVAS BYPS ANAS NEC
Esophageal resection Mortality (QI #42)
Esophageal resection
ICD-9-CM procedure code:
4240 | ESOPHAGECTOMY NOS
4241 | PARTIAL ESOPHAGECTOMY
4242 | TOTAL ESOPHAGECTOMY
Include only: Esophageal cancer:
ICD-9-CM diagnosis codes:
1500 | MAL NEO CERVICAL ESOPHAG
1501 | MAL NEO THORACIC ESOPHAG
1502 | MAL NEO ABDOMIN ESOPHAG
1503 | MAL NEO UPPER 3RD ESOPH
1504 | MAL NEO MIDDLE 3RD ESOPH
1505 | MAL NEO LOWER 3RD ESOPH
1508 | MAL NEO ESOPHAGUS NEC
1509 | MAL NEO ESOPHAGUS NOS
Hip Replacement Mortality(QI #43)
Hip Replacement
ICD-9-CM procedure Codes:
8151 | TOTAL HIP REPLACEMENT
8152 | PARTIAL HIP REPLACEMENT
8153 | REVISION HIP REPLACEMENT
Include only: Osteoarthrosis:
ICD-9-CM diagnosis Codes:
71500 | GENL OSTEOARTHROSIS NOS
71509 | GENL OSTEOARTHROSIS MULT
71510 | LOC PRIM OSTEOART_UNSPEC
71515 | LOC PRIM OSTEOART_PELVIS
71518 | LOC PRIM OSTEOARTHR NEC
71520 | LOC 2ND OSTEOARTH_UNSPEC
71525 | LOC 2ND OSTEOARTH_PELVIS
71528 | LOC 2ND OSTEOARTHROS NEC
71530 | LOC OSTEOARTH NOS_UNSPEC
71535 | LOC OSTEOARTH NOS_PELVIS
71538 | LOC OSTEOAR NOS_SITE NEC
71580 | OSTEOARTHROSIS_MULT SITE
71589 | OSTEOARTHROSIS_MULT SITE
71590 | OSTEOARTHROS NOS_UNSPEC
71595 | OSTEOARTHROS NOS_PELVIS
71598 | OSTEOARTHRO NOS_OTH SITE
71650 | POLYARTHRITIS NOS UNSPEC
71655 | POLYARTHRITIS NOS PELVIS
71658 | POLYARTHRITIS NOS NEC
71659 | POLYARTHRITIS NOS MULT SITE
71660 | MONOARTHRITIS NOS UNSPEC
71665 | MONOARTHRITIS NOS PELVIS
71668 | MONOARTHRITIS NOS NEC
71669 | MONOARTHRITIS NOS MULT SITE
71690 | ARTHROPATHY NOS UNSPEC
71695 | ARTHROPATHY NOS PELVIS
71698 | ARTHROPATHY NOS NEC
71699 | ARTHROPATHY NOS MULT SITE
Pancreatic resection mortality(QI #44)
Pancreatic resection
ICD-9-CM procedure codes:
526 | TOTAL PANCREATECTOMY
527 | RAD PANCREATICODUODENECT
Include only: Pancreatic cancer
ICD-9-CM diagnosis codes:
1520 | MALIGNANT NEOPL DUODENUM
1561 | MAL NEO EXTRAHEPAT DUCTS
1562 | MAL NEO AMPULLA OF VATER
1570 | MAL NEO PANCREAS HEAD
1571 | MAL NEO PANCREAS BODY
1572 | MAL NEO PANCREAS TAIL
1573 | MAL NEO PANCREATIC DUCT
1574 | MAL NEO ISLET LANGERHANS
1578 | MALIG NEO PANCREAS NEC
1579 | MALIG NEO PANCREAS NOS
Pediatric heart surgery mortality(QI #45)
See pediatric heart surgery volume