# Contact List for Phone Interviews

List of researchers, consultants, end users, hospital associations and other groups contacted and interviewed by phone for background information on quality measurement relevant to HCUP QI Refinement Project.

## Appendix 2. List of Individuals Interviewed for Background Information

Consultants

- Mark Blumberg
- Vice President
- TruRisk

- Bill Mohlenbroch
- Vice Chairman
- Iameter

- Michael Pine
- President
- Michael Pine and Associates

Federal Agency

- Dicta Abel-Steinberg
- Project Officer
- HCFA

- Marge Keyes
- CONQUEST Director
- Agency for Healthcare Research and Policy

Health Plans

- Charles Cutler
- Chief Medical Officer
- American Association of Health Plans

Hospital Associations

- Michael Boyson
- Director, Data Services and Research
- Colorado Health and Hospital Association

- Barbara Brooks
- Manager, Maryland Quality Indicators Project
- Healthcare Association of New York State

- Joanna Jiang
- Senior Researcher
- Healthcare Association of New York State

- Don Nielson
- Vice President for Quality
- American Hospital Association

- Bruce Spurlock
- Senior Vice President
- California Healthcare Association

International

- Martin McKee
- London School of Hygiene & Tropical Medicine

Private Accreditors

- Jared Loeb
- Sharon Sprenger
- JCAHO

- Peggy O'Kane
- Executive Director
- National Committee on Quality Assurance

- David Lansky
- President
- Foundation for Accountability (FACCT)

Private Data Group

- Susan Forbes
- President and CEO
- Hawaii Health Information Corporation

- Flossie Wolf
- Director of Policy and Legislative Affairs
- Pennsylvania Health Care Cost Containment Council

Professional Organizations

- David Bergman
- Professor of Pediatric Medicine
- American Academy of Pediatrics
- Stanford University

- Jeff Rideout
- Vice President of Quality
- UCSF-Stanford Healthcare

Provider Organizations

- David Blumenthal
- Professor
- Partners Health Care

- Denise Love
- National Association of Health Data Organizations
- University of Utah School of Medicine

- Jim Mortimer
- President
- Midwest Business Group on Health

- Catherine Kunkel
- National Business Coalition on Health

- Arnie Milstein, M.D.
- Medical Director
- Pacific Business Group on Health
- William M. Mercer

State Data Groups

- Jay Buechner, Ph.D.
- Chief, Office of Health Statistics
- Rhode Island Dept. of Health

- Katherine Ganz, M.D., MSH
- Director
- Health Policy Commission, New Mexico

- Michael Lundberg
- Executive Director
- Virginia Health Information

Other

- Diane Weber
- Director, Quality Management
- University Hospital Consortium

- Shirley Girouard
- Vice President
- National Association for Children's Health and Research Institutions

- Tracy Miller
- United Hospital Fund of New York