# Peer Reviewers

Quality experts reviewed this report and provided their suggestions to the authors. The initial report, released May 26, 2000, was reviewed and revised. The revised report, released November 30, 2000, was also reviewed and revised by a second set of reviewers. Each group of peer reviewers is listed in this appendix.

## List of Peer Reviewers for Initial Draft (5/26/00) and Their Affiliations

- Edward E. Bartlett, Ph.D.
- George Washington UniversityWashington, D.C.

- Mark S. Blumberg, M.D.
- TruRiskOakland, CA

- H. Joanna Jiang, Ph.D.
- Healthcare Association of New York StateRensselaer, NY

- Denise Love, Ph.D.
- National Association of Health DataOrganizationsSalt Lake City, Utah

- Harold S. Luft, Ph.D.
- Institute for Health Policy StudiesUniversity of California, San FranciscoSan Francisco, CA

- Jim Pearse, M.Sc
- NSW HealthNorth Sydney, Australia

- Elaine J. Power, MPP
- National Quality ForumWashington, DC

- Elizabeth M. Sloss, Ph.D.
- RAND CorporationArlington, Virginia

## List of Peer Reviewers for Revised Draft (11/30/00) and Their Affiliations

- Tim Carey, M.D., MPH
- Cecil G. Sheps Center for Health ServicesResearchChapel Hill, NC

- Camille Clifford, B.A.
- New Mexico Health Policy CommissionNew Mexico

- Ethan Halm, M.D., MPH
- Mt. Sinai School of MedicineNew York, NY

- Christine Kovner, Ph.D.
- New York UniversityNew York, NY

- Jarod Loeb, Ph.D.
- Joint Commission on Accreditation ofHealthcare OrganizationsOakbrook Terrace, IL

- Harold S. Luft, Ph.D.
- Institute for Health Policy StudiesUniversity of California, San FranciscoSan Francisco, CA

- Michael Pine, M.D.
- Michael Pine and Associates, Inc.Chicago, IL

- Elaine J. Power, MPP
- National Quality ForumWashington, DC

- Steven Shortell, Ph.D.
- University of California at BerkeleyBerkeley, CA

- Sharon L. Sprenger, RHIA, CPHQ, MPA
- Joint Commission on Accreditation ofHealthcare OrganizationsOakbrook Terrace, IL

- Elizabeth M. Sloss, Ph.D.
- RAND CorporationArlington, Virginia