# Appendixes

APPENDIX 1 Peer Reviewers

APPENDIX 2 Contact List for Phone Interviews

APPENDIX 3 List of Abstracted Articles

APPENDIX 4 Data Collection Instruments

APPENDIX 5 Inventory of Indicators

APPENDIX 6 Indicator Definitions

APPENDIX 7 Empirical Evaluation Results Tables

APPENDIX 8 Literature Tables for Utilization and ACSC Indicators

APPENDIX 9 List of Acronyms