# References

Accardo PJ, Tomazic T, Morrow J, et al. Minor malformations, hyperactivity, and learning disabilities. Am J Dis Child. Oct. 1991;145(10):1184-7. [pmid: 1928014].
Achenbach TM. Integrative guide for the 1991 CBCL/4-18, YRS and TRF profiles. Burlington, VT. University of Vermont Department of Psychiatry. 1991a.
Achenbach TM. Manual for the child behavior checklist/4-18 and 1991 profile. Burlington, VT. University of Vermont Department of Psychiatry. 1991b.
Achenbach TM. Manual for the teachers report form and 1991 profile. Burlington, VT. University of Vermont Department of Psychiatry. 1991c.
Achenbach TM. The Child Behavior Profile: I. Boys aged 6–11. J Consult Clin Psychol. 1978;46:478-88. [pmid: 670491].
Achenbach TM, Edelbrock CS. Behavioral problems and competencies reported by parents of normal and disturbed children aged four through sixteen. Mono Soc Res Child Dev. 1981;46(1, Serial188):1-82.
Altepeter TS, Breen MJ. Situational variation in problem behavior at home and school in attention deficit disorder with hyperactivity: a factor analytic study. J Child Psychol Psychiatry. May. 1992;33(4):741-8. [pmid: 1376326].
Altepeter TS, Breen MJ. The Home Situations Questionnaire (HSQ) and the School Situations Questionnaire (SSQ): normative data and an evaluation of psychometric properties. J Psychoeducational Assessment. 1989;7:312-22.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC. American Psychiatric Association. 1980.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. revised. Washington, DC. American Psychiatric Association. 1987.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Washington, DC. American Psychiatric Association. 1994.
Atkins MS, Pelham WE, Licht MH. A comparison of objective classroom measures and teacher ratings of Attention Deficit Disorder. J Abnorm Child Psychol. 1985;13(1):155-67. [pmid: 3973249].
August GJ, Garfinkel BD. Behavioral and cognitive subtypes of ADHD. J Am Acad Child Adolesc Psychiatry. Sep. 1989;28(5):739-48. [pmid: 2793802].
August GJ, Ostrander R, Bloomquist MJ. Attention deficit hyperactivity disorder: an epidemiological screening method. Am J Orthopsychiatry. Jul. 1992;62(3):387-96. [pmid: 1497104].
August GJ, Realmuto GM, MacDonald AW, et al. Prevalence of ADHD and comorbid disorders among elementary school children screened for disruptive behavior. J Abnorm Child Psychol. 1996;24(5):571-95. [pmid: 8956085].
Barkley RA. A critique of current diagnostic criteria for attention deficit hyperactivity disorder: clinical and research applications. J Dev Behav Pediatr. Dec. 1990;11(6):343-52. [pmid: 2289969].
Barkley RA, DuPaul GJ, McMurray MB. Comprehensive evaluation of attention deficit disorder with and without hyperactivity as defined by research criteria. J Consult Clin Psychol. 1990;58(6):775-89. [pmid: 2292627].
Barkley RA, Grodzinsky GM. Are tests of frontal lobe functions useful in the diagnosis of attention deficit disorders?. Clin Neuropsychologist. Jun. 1994;8(2):121-39.
Barlow PJ. A pilot study on the metal levels in the hair of hyperactive children. Med Hypotheses. 1983;11:309-18. [pmid: 6645998].
Biederman J, Faraone SV, Doyle A, et al. Convergence of the Child Behavior Checklist with structured interview-based psychiatric diagnoses of ADHD children with and without comorbidity. J Child Psychol Psychiatry. Oct. 1993;34(7):1241-51. [pmid: 8245144].
Bird HR, Canino G, Rubio-Stipec M, et al. Estimates of the prevalence of childhood maladjustment in a community survey in Puerto Rico. Arch Gen Psychiatry. Dec. 1988;45:1120-6. [pmid: 3264147].
Boyle MH, Offord DR, Racine Y, et al. Evaluation of the Diagnostic Interview for Children and Adolescents for use in general population samples. J Abnorm Child Psychol. 1993;21(6):663-81. [pmid: 8126319].
Breen MJ. Cognitive and behavioral differences in ADHD boys and girls. J Child Psychol Psychiatry. 1989;30(5):711-6. [pmid: 2793958].
Breen MJ, Altepeter TS. Factor structures of the Home Situations Questionnaire and the School Situations Questionnaire. J Pediatr Psychol. 1991;16(1):59-67. [pmid: 2010877].
Breen MJ, Altepeter TS. Situational variability in boys and girls identified as ADHD. J Clin Psychol. Jul. 1990;46(4):486-90. [pmid: 2212053].
Brown RT, Madan-Swain A, Baldwin K. Gender differences in a clinic-referred sample of attention-deficit-disordered children. Child Psychiatry Hum Dev. 1991;22(2):111-28. [pmid: 1800023].
Brunshaw JM, Szatmari P. The agreement between behaviour checklists and structured psychiatric interviews for children. Can J Psychiatry. Aug. 1988;33(6):474-81. [pmid: 3196999].
Burks HF. Burks behavior rating scales [manual]. Los Angeles. Western Psychological Services. 1996:32. 38.
Buras O. Mental Measurements Yearbook (MMY). 9th ed. New Brunswick, NJ. Rutgers University Press. 1998.
Cacabelos R, Albarran M, Dieguez C, et al. GRF-induced GH response in attention-deficit hyperactivity disorder. Methods Find Exp Clin Pharmacol. Jan–Feb;. 1990;12(1):79. 85. [pmid: 2107369].
Carter CS, Krener P, Chaderjian M, et al. Abnormal processing of irrelevant information in attention deficit hyperactivity disorder. Psychiatry Res. Jan 31. 1995a;56(1):59-70. [pmid: 7792343].
Castellanos FX, Giedd JN, Marsh WL, et al. Quantitative brain magnetic resonance imaging in attention-deficit hyperactivity disorder. Arch Gen Psychiatry. Jul. 1996;53(7):607-16. [pmid: 8660127].
Chen WJ, Faraone SV, Biederman J, et al. Diagnostic accuracy of the child behavior checklist scales for attention-deficit hyperactivity disorder: a receiver-operating characteristic analysis. J Consult Clin Psychol. Oct. 1994;62(5):1017-25. [pmid: 7806710].
Cohen P, Cohen J, Kasen S, et al. An epidemiological study of disorders in late childhood and adolescence: I. Age- and gender-specific prevalence. J Child Psychol Psychiatry. 1993;34(6):851-67. [pmid: 8408371].
Cohen ML, Kelly PC, Atkinson AW. Parent, teacher, child: a trilateral approach to attention deficit disorder. AJDC. 1989;143:1229-1233. [pmid: 2801667].
Conners CK. Conners’ rating scales manual: Conners’ teacher rating scale: Conners’ parent rating scale: instruments for use with children and adolescents. Toronto, North Tonawanda, NY. Multi-Health Systems, Inc. 1990:41.
Conners CK. CRS–R, Conners’ rating scales–revised: instruments for use with children and adolescents. Toronto, North Tonawanda, NY. Multi-Health Systems, Inc. 1997:94. 134.
Cook EH, Stein MA, Ellison T, et al. Attention deficit hyperactivity disorder and whole-blood serotonin levels: effects of comorbidity. Psychiatry Res. 1995;57:13-20. [pmid: 7568555].
Costello EJ, Angold A, Burns BJ, et al. The Great Smokey Mountains study of youth: goals, design, methods, and the prevalence of DSM-III-R disorders. Arch Gen Psychiatry. Dec. 1996;53:1129-36. [pmid: 8956679].
Costello EJ, Costello AJ, Edelbrock C, et al. Psychiatric disorders in pediatric primary care. Arch Gen Psychiatry. 1988;45:1107-16. [pmid: 3264146].
Costello EJ, Edelbrock C, Costello AJ, et al. Psychopathology in pediatric primary care: the new hidden morbidity. Pediatrics. 1988. September;82(3, 2):415-24. [pmid: 3405677].
Dykman RA, Ackerman PT. Attention deficit disorder and specific reading disability: separate but often overlapping disorders. J Learn Disabil. Feb. 1991;24(2):96-103. [pmid: 2010680].
Edelbrock C, Costello AJ. Convergence between statistically derived behavior problem syndromes and child psychiatric diagnoses. J Abnorm Child Psychol. Apr. 1988;16(2):219-31. [pmid: 3385085].
Elia J, Gulotta C, Rose SR, et al. Thyroid function and attention-deficit hyperactivity disorder [see comments]. J Am Acad Child Adolesc Psychiatry. Feb. 1994;33(2):169-72. [pmid: 8150787].
Epstein MA, Shaywitz SE, Shaywitz BA, et al. The boundaries of attention deficit disorder. J Learn Disabil. 1991;24(2):78-86. [pmid: 2010678].
Faraone SV, Biederman J, Mennin D, et al. A prospective four-year follow-up study of children at risk for ADHD: psychiatric, neurological, and social outcome. J Am Acad Child Adolesc Psychiatry. November. 1996;35(11:):1449-59. [pmid: 8936911].
Filipek PA, Semrud-Clikeman M, Steingard RJ, et al. Volumetric MRI analysis comparing subjects having attention-deficit hyperactivity disorder with normal controls. Neurology. 1997;48:589-601. [pmid: 9065532].
Fischer M, Newby RF, Gordon M. Who are the false negatives on continuous performance tests?. J Clin Child Psychol. Dec. 1995;24(4):427-33.
Gillberg C, Carlstrom G, Rasmussen P, et al. Perceptual, motor and attentional deficits in seven-year-old children. Neurological screening aspects. Acta Paediatr Scand. Jan. 1983;72(1):119-24. [pmid: 6858674].
Gittelman R, Eskenazi B. Lead and hyperactivity revisited. An investigation of nondisadvantaged children. Arch Gen Psychiatry. Aug. 1983;40(8):827-33. [pmid: 6683492].
Goyette CH, Conners CK, Ulrich RF. Normative data on Revised Conners Parent and Teacher Rating Scales. J Abnorm Child Psychol. 1978;6(2):221-36. [pmid: 670589].
Grant ML, Ilai D, Nussbaum NL, Bigler ED. The relationship between continuous performance tasks and neuropsychological tests in children with attention-deficit hyperactivity disorder. Percept Mot Skills. Apr. 1990;70(2):435-45. [pmid: 2342842].
Halperin JM, Newcorn JH, Matier K, et al. Discriminant validity of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1038-43. [pmid: 8407749].
Harcherik DF, Cohen DJ, Ort S, et al. Computed tomographic brain scanning in four neuropsychiatric disorders of childhood. Am J Psychiatry. Jun. 1985;142(6):731-4. [pmid: 3859227].
Hasselblad V. Meta-analysis of multi-treatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Hasselblad V, Hedges LV. Meta-analysis of screening and diagnostic tests. Psychol Bull. 1995;117:167-78. [pmid: 7870860].
Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA. Academic Press. 1985.
Holcomb PJ, Ackerman PT, Dykman RA. Cognitive event-related brain potentials in children with attention and reading deficits. Psychophysiology. 1985;22(6):656-67. [pmid: 4089092].
Hole K, Lingjaerde O, Morkrid L, et al. Attention deficit disorders: a study of peptide-containing urinary complexes. J Dev Behav Pediatr. Aug. 1988;9(4):205-12. [pmid: 3216000].
Horn WF, Wagner AE, Ialongo N. Sex differences in school-aged children with pervasive attention deficit hyperactivity disorder. J Abnorm Child Psychol. 1989;17(1):109-124. [pmid: 2926019].
Hynd GW, Hern KL, Novey ES, et al. Attention deficit-hyperactivity disorder and asymmetry of the caudate nucleus. J Child Neurol. Oct. 1993;8(4):339-47. [pmid: 8228029].
Hynd GW, Semrud-Clikeman M, Lorys AR, et al. Brain morphology in developmental dyslexia and attention deficit disorder/hyperactivity. Arch Neurol. Aug. 1990;47(8):919-26. [pmid: 2375699].
Hynd GW, Semrud-Clikeman M, Lorys AR, et al. Corpus callosum morphology in attention deficit-hyperactivity disorder: morphometric analysis of MRI. J Learn Disabil. 1991(A);24(3):141-6. [pmid: 2026955].
Jellinek MS, Murphy JM, Robinson J, et al. Pediatric symptom checklist: screening school-age children for psychosocial dysfunction. J Pediatr. 1988;112:201-9. [pmid: 3339501].
Jensen JB, Burke N, Garfinkel BD. Depression and symptoms of attention deficit disorder with hyperactivity. J Am Acad Child Adolesc Psychiatry. Nov. 1988;27(6):742-7. [pmid: 3198561].
Jensen PS, Shervette RE, Xenakis SN, et al. Anxiety and depressive disorders in attention deficit disorder with hyperactivity: New findings. Am J Psychiatry. Aug. 1993;150(8):1203-9. [pmid: 8328565].
Kahn CA, Kelly PC, Walker WO Jr. Lead screening in children with attention deficit hyperactivity disorder and developmental delay. Clin Pediatr (Phila). Sep. 1995;34(9):498-501. [pmid: 7586924].
King C, Young RD. Attentional deficits with and without hyperactivity: teacher and peer perceptions. J Abnorm Child Psychol. Dec. 1982;10(4):483-95. [pmid: 7161440].
Krug SE, editor. Psychware Sourcebook. 4th edition. Champaign, IN. Metritech. 1993.
Kuehne C, Kehle TJ, McMahon W. Differences between children with attention deficit disorder, children with specific learning disabilities, and normal children. J Sch Psychol. Sum. 1987;25(2):161-6.
Kuperman S, Johnson B, Arndt S, et al. Quantitative EEG differences in a nonclinical sample of children with ADHD and undifferentiated ADD. J Am Acad Child Adolesc Psychiatry. Aug. 1996;35(8):1009-17. [pmid: 8755797].
Lahat E, Avital E, Barr J, et al. BAEP studies in children with attention deficit disorder. Dev Med Child Neurol. Feb. 1995;37(2):119-23. [pmid: 7851667].
LaHoste GJ, Swanson JM, Wigal SB, et al. Dopamine D4 receptor gene polymorphism is associated with attention deficit hyperactivity disorder. Mol Psychiatry. 1996;1:121-4. [pmid: 9118321].
Lambert N, Hartsough C, Sandoval J. Manual for the children’s attention and adjustment survey. Circle Pines, MN. American Guidance Services, Inc. 1990:37.
Lindgren S, Wolraich M, Stromquist A, et al. Diagnosis of attention deficit hyperactivity disorder by primary care physicians. Paper presented at the Mental Health Services for Children and Adolescents in Primary Care Settings: A Research Conference. New Haven, CT. 1989.
Loge DV, Staton D, Beatty WW. Performance of children with ADHD on tests sensitive to frontal lobe dysfunction. J Am Acad Child Adolesc Psychiatry. 1990;29(4):540-5. [pmid: 2387788].
Luk SL, Leung PW. Conners’ Teacher Rating Scale--a validity study in Hong Kong. J Child Psychol Psychiatry. Sep. 1989;30(5):785-93. [pmid: 2793964].
Lyoo IK, Noam GG, Lee CK, et al. The corpus callosum and lateral ventricles in children with attention-deficit hyperactivity disorder: a brain magnetic resonance imaging study. Biol Psychiatry. 1996;40:1060-3. [pmid: 8915567].
Matsuura M, Okubo Y, Toru M, et al. A cross-national EEG study of children with emotional and behavioral problems: a WHO collaborative study in the Western Pacific Region. Biol Psychiatry. Jul. 1–15. 1993;34:1-2. 59. 65. [pmid: 8396991].
McCarney SB. The attention deficit disorders evaluation scale. 2nd ed. [home version technical manual]. Columbia, MO. Hawthorne Educational Services, Inc. 1995a:11-12. 17.
McCarney SB. The attention deficit disorders evaluation scale. 2nd ed. [school version technical manual]. Columbia, MO. Hawthorne Educational Services, Inc. 1995b:12. 14. 18.
McConaughy SH, Achenbach TM. Comorbidity of empirically based syndromes in matched general population and clinical samples. J Child Psychol Psychiatry. 1994;35(6):1141-57. [pmid: 7995848].
Naglieri JA, LeBuffe PA, Pfeiffer SI. Devereux scales of mental disorders [manual]. San Antonio. Harcourt Brace & Co. 1994:70. 79.
Newcorn JH, Halperin JM, Healey JM, et al. Are ADDH and ADHD the same or different?. J Am Acad Child Adolesc Psychiatry. Sep. 1989;28(5):734-8. [pmid: 2793801].
Newcorn JH, Halperin JM, Schwartz S, et al. Parent and teacher ratings of attention-deficit hyperactivity disorder symptoms: implications for case identification. J Dev Behav Pediatr. Apr. 1994;15(2):86-91. [pmid: 8034772].
Newton JE, Oglesby DM, Ackerman PT, et al. Visual slow brain potentials in children with attention deficit disorder. Integr Physiol Behav Sci. Jan–Mar. 1994;29(1):39-54. [pmid: 8018551].
Nussbaum NL, Grant ML, Roman MJ, et al. Attention deficit disorder and the mediating effect of age on academic and behavioral variables. J Dev Behav Pediatr. Feb. 1990;11(1):22-6. [pmid: 2303554].
Pelham WE Jr, Gnagy EM, Greenslade KE, et al. Teacher ratings of DSM-III-R symptoms for the disruptive behavior disorders. J Am Acad Child Adolesc Psychiatry. Mar. 1992;31(2):210-8. [pmid: 1564021].
Pliszka SR, Maas JW, Javors MA, et al. Urinary catecholamines in attention-deficit hyperactivity disorder with and without comorbid anxiety. J Am Acad Child Adolesc Psychiatry. Oct. 1994;33(8):1165-73. [pmid: 7982867].
Reeves JC, Werry JS, Elkind GS, et al. Attention deficit, conduct, oppositional, and anxiety disorders in children: II. Clinical characteristics. J Am Acad Child Adolesc Psychiatry. Mar. 1987;26(2):144-55. [pmid: 3584010].
Reynolds CR, Kamphaus RW. BASC, Behavioral assessment system for children [manual]. Circle Pines, MN. American Guidance Services, Inc. 105. 1992:102-106. 125. 150.
Robaey P, Breton F, Dugas M, et al. An event-related potential study of controlled and automatic processes in 6–8-year-old boys with attention deficit hyperactivity disorder. Electroencephalogr Clin Neurophysiol. May. 1992;82(5):330-40. [pmid: 1374702].
Robins PM. A comparison of behavioral and attentional functioning in children diagnosed as hyperactive or learning-disabled. J Abnorm Child Psychol. 1992;20(1):65-82. [pmid: 1548395].
Satin MS, Winsberg BG, Monetti CH, et al. A general population screen for attention deficit disorder with hyperactivity. J Am Acad Child Psychiatry. Nov. 1985;24(6):756-64. [pmid: 4067144].
Satterfield JH, Schell AM, Nicholas TW, et al. Ontogeny of selective attention effects on event-related potentials in attention-deficit hyperactivity disorder and normal boys. Biol Psychiatry. Nov 15. 1990;28(10):879-903. [pmid: 2268691].
Seidel WT, Joschko M. Assessment of attention in children. Clin Neuropsychologist. Jan. 1991;5(1):53-66.
Semrud-Clikeman M, Filipek PA, Biederman J, et al. Attention-deficit hyperactivity disorder: magnetic resonance imaging morphometric analysis of the corpus callosum. J Am Acad Child Adolesc Psychiatry. Jul–Aug. 1994;33(6):875-81. [pmid: 8083145].
Shaffer D, Fisher P, Dulcan MK, et al. The NIMH diagnostic interview schedule for children version 2.3 (DISC 2.3): description, acceptability, prevalence rates, and performance in the MECA study. J Am Acad Child Adolesc Psychiatry. 1996;35(7):865-77. [pmid: 8768346].
Shaywitz SE, Schnell C, Shaywitz BA, et al. Yale Children’s Inventory (YCI): an instrument to assess children with attentional deficits and learning disabilities. I. Scale development and psychometric properties. J Abnorm Child Psychol. 1986;14(3):347-64. [pmid: 3760344].
Shaywitz BA, Shaywitz SE, Byrne T, et al. Attention deficit disorder: quantitative analysis of CT. Neurology. Nov. 1983;33(11):1500-3. [pmid: 6685244].
Shaywitz SE, Shaywitz BA, Schnell C, et al. Concurrent and predictive validity of the Yale Children’s Inventory: an instrument to assess children with attentional deficits and learning disabilities. Pediatrics. Apr. 1988;81(4):562-71. [pmid: 3353191].
Shekim WO, Cantwell DP, Kashani J, et al. Dimensional and categorical approaches to the diagnosis of attention deficit disorder in children. J Am Acad Child Psychiatry. Sep. 1986;25(5):653-8. [pmid: 3760414].
Shekim WO, Kashani J, Beck N, et al. The prevalence of attention deficit disorders in a rural midwestern community sample of nine-year-old children. J Am Acad Child Psychiatry. Nov. 1985;24(6):765-70. [pmid: 4067145].
Silva PA, Hughes P, Williams S, et al. Blood lead, intelligence, reading attainment, and behaviour in eleven year old children in Dunedin, New Zealand. J Child Psychol Psychiatry. 1988;29(1):43-52. [pmid: 3350882].
Silverthorn P, Frick PJ, Kuper K, et al. Attention deficit hyperactivity disorder and sex: a test of two etiological models to explain the male predominance. J Clin Child Psychol. 1996;25(1):52-9.
Spencer T, Biederman J, Wilens T, et al. ADHD and thyroid abnormalities: a research note. J Child Psychol Psychiatry. Jul. 1995;36(5):879-85. [pmid: 7559851].
Stanford LD, Hynd GW. Congruence of behavioral symptomatology in children with ADD/H, ADD/WO, and learning disabilities. J Learn Disabil. 1994;27(4):243-53. [pmid: 8051505].
Stein MA, Weiss RE, Refetoff S. Neurocognitive characteristics of individuals with resistance to thyroid hormone: comparisons with individuals with attention-deficit hyperactivity disorder. J Dev Behav Pediatr. Dec. 1995;16(6):406-11. [pmid: 8746549].
Steingard R, Biederman J, Doyle A, et al. Psychiatric comorbidity in attention deficit disorder: impact on the interpretation of Child Behavior Checklist results. J Am Acad Child Adolesc Psychiatry. May. 1992;31(3):449-54. [pmid: 1592776].
Tarnowski KJ, Prinz RJ, Nay SM. Comparative analysis of attentional deficits in hyperactive and learning-disabled children. J Abnorm Psychol. Nov. 1986;95(4):341-5. [pmid: 3805496].
Thomson GOB, Raab GM, Hepburn WS, et al. Blood-lead levels and children’s behaviour—results from the Edinburgh lead study. J Child Psychol Psychiatry. 1989;30(4):515-28. [pmid: 2768355].
Trommer BL, Hoeppner JA, Lorber R, et al. The go-no-go paradigm in attention deficit disorder. Ann Neurol. Nov. 1988b;24(5):610-4. [pmid: 3202613].
Tuthill RW. Hair lead levels related to children’s classroom attention-deficit behavior. Arch Environ Health. May–Jun. 1996;51(3):214-20. [pmid: 8687242].
Ullmann RK, Sleator EK, Sprague RL. A change of mind: the Conners abbreviated rating scales reconsidered. J Abnorm Child Psychol. 1985;13(4):553-65. [pmid: 4078186].
Ullmann RK, Sleator EK, Sprague RL, et al. ACTeRS Teacher and parent forms manual. Champaign, IL. MeriTech, Inc. 14. 1997:9-15.
U.S. Department of Health and Human Services, Public Health Service, Health Care Financing Administration. International Classification of Diseases (ICD), 9th revision, Clinical Modification. Fifth edition. DHHS Pub. No. (PHS) 94-1260. 1994.
Valdizan JR, Andreu AC. Test of repeated operations and logistic regression as to the efficacy of brain mapping. Clin Electroencephalogr. Apr. 1993;24(2):89-92. [pmid: 8500254].
Vitiello B, Stoff D, Atkins M, et al. Soft neurological signs and impulsivity in children. J Dev Behav Pediatr. Jun. 1990;11(3):112-5. [pmid: 2365831].
Warren RP, Odell JD, Warren WL, et al. Is decreased blood plasma concentration of the complement C4B protein associated with attention-deficit hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. Aug. 1995;34(8):1009-14. [pmid: 7665439].
Weiss RE, Stein MA, Trommer B, et al. Attention-deficit hyperactivity disorder and thyroid function. J Pediatr. Oct. 1993;123(4):539-45. [pmid: 8410504].
Wolraich ML, Hannah JN, Baumgaertel A, et al. Examination of DSM-IV criteria for attention deficit/hyperactivity disorder in a county-wide sample. J Dev Behav Pediatr. 1998;19(3):162-8. [pmid: 9648041].
Wolraich ML, Hannah JN, Pinnock TY, et al. Comparison of diagnostic criteria for attention-deficit hyperactivity disorder in a county-wide sample. J Am Acad Child Adolesc Psychiatry. Mar. 1996;35(3):319-24. [pmid: 8714320].
Zelko FA. Comparison of parent-completed behavior rating scales: differentiating boys with ADD from psychiatric and normal controls. J Dev Behav Pediatr. Feb. 1991;12(1):31-7. [pmid: 2016400].