# Methodology

This evidence report used a systematic methodology for gathering and analyzing evidence comprising design of the topic and questions, database searches, literature retrieval and review, data abstraction, data entry, and statistical analysis. The selected topics—prevalence and diagnostic screening of ADHD—were defined as clearly as possible. Specific questions about prevalence and diagnostic screening were chosen through a joint effort involving the Agency for Health Care Policy and Research (AHCPR), the American Academy of Pediatrics (AAP), and Technical Resources International, Inc. (TRI). Certain parameters further refined the questions, providing clear and manageable limits to the information that would be gathered and synthesized as evidence. These parameters, called inclusion and exclusion criteria, were then used to select studies that best provided the information needed to answer the report’s questions. Those questions, as well as the inclusion and exclusion criteria, are presented below.

## Questions

1. What percentage of the U.S. general population aged 6 to 12 years has ADHD? Of those with ADHD, what percentage has one or more of the following comorbidities: learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder?
2. What percentage of children aged 6 to 12 years presenting at pediatricians’ or family physicians’ offices in the United States meets diagnostic criteria for ADHD? Of those with ADHD, what percentage has one or more of the following comorbidities: learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder?
3. What are the accuracy (i.e., sensitivity, specificity, positive predictive value) and reliability (i.e., inter/intra-rater agreement) of behavioral rating screening tests for ADHD compared with a reference standard (DSM or ICD-9)?
4. What is the prevalence of abnormal findings on selected medical screening tests commonly recommended as standard components of an evaluation of a child with suspected ADHD?

## Inclusion and Exclusion Criteria

The scope of evidence included in this report was defined according to the following categories of inclusion and exclusion criteria: definition of ADHD and comorbid conditions; demographics of the population studied; type of setting; specific behavioral screening tests considered, with outcomes of interest; specific medical screening tests considered, with outcomes of interest; and criteria for admissible evidence. These categories are specified below and illustrated in Table 1.

Table 1 Inclusion and Exclusion Criteria for the Evidence Report

Inclusion Criteria | Exclusion Criteria
Definition of ADHD/Comorbidities
ADHD with symptoms as listed in DSM-III, DSM-III-R, DSM-IV, and ICD (all editions) Comorbid conditions: learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder Combinations of the 5 listed comorbid conditions allowed in Questions 1 and 2 (prevalence questions) | Criteria other than DSM and ICD Comorbid conditions other than the 5 listed Combinations of the 5 comorbid conditions listed in Questions 3 and 4 (assessment questions)
Patient Population
Boys and girls Ages 6–12 years Representative population North American studies for Questions 1 and 2 (prevalence questions) Any countries for Questions 3 and 4 (assessment questions) | Adults Preschoolers (ages 2–5) Adolescents (ages 13–18) Referral populations (for prevalence estimates) Children with moderate to severe mental retardation (IQ<55) Children with pervasive developmental disorders and/or severe psychiatric disorders Any studies outside North America for Questions 1 and 2 (prevalence questions)
Setting/Provider Population
All settings allowed for Questions 3 and 4 (assessment questions) Limited settings for Questions 1 and 2 (prevalence questions): General population (Question 1) Community School surveys Primary care setting (Question 2) Pediatrician’s office Physicians in family or general practice | Prevalence studies from: Mental health facilities or referral clinics Schools for developmentally disabled students
Behavioral Screening Tests for ADHD
Selected Behavior Checklists/Rating Scales (parent, teacher report forms only) ADHD-Specific Checklists ADD-H: Comprehensive Teacher Rating Scale (ACTeRS) Attention Deficit Disorders Evaluation Scale (ADDES) Barkley Questionnaires (HSQ, SSQ, ADHDR) Children’s Attention and Adjustment Survey (CAAS) ADHD-Specific Conners Rating Scales (CATQ, CAPQ, CPRS:R-ADHD, DSM) SNAP Checklist (SNAP) Vanderbilt AD/HD Diagnostic Teacher Rating Scale (VADTRS) | Behavioral screening tests other than those listed under Inclusion Criteria to the left (others to be identified; if sufficient number of studies of additional tests are available, decision will be made whether to extract and analyze data from those tests) Versions of the behavior checklists/rating scales designed for “youth self-report” Tests for comorbid conditions (e.g., tests for learning disabilities or speech disorders)
Broad-Band Checklists Behavior Assessment System for Children (BASC) Burk’s Behavior Rating Scales, Grades 1–9 (BBRS) Child Behavior Checklists (CBCL) Broad-Band Conners Rating Scales (CPRS, CTRS) Devereaux Scales of Mental Disorders (DSMD) Ontario Child Health Study Scales (OCHS) Pediatric Symptom Checklist (PSC) Yale Children’s Inventory (YCI)
Outcomes of Interest for Behavioral Screening Tests (Question 3)
Accuracy for ADHD (for ADHD-targeted checklists only) Sensitivity Specificity Positive predictive value Accuracy for referral population (for broad-band checklists only) Effect size for discriminating referred from nonreferred samples | Treatment outcomes Accuracy and reliability of tests for comorbid conditions
Medical Screening Tests for ADHD (Question 4)
Selected Medical and Neurological Screening Tests: Electroencephalography (EEG) Lead concentration level Thyroid hormone level Imaging tests Continuous performance tests Hearing and vision screening Neuroloaical screenina tests | Medical or neurological screening tests other than those listed under Inclusion Criteria to the left Medical or neurological screening tests not commonly recommended as standard components of an evaluation of a child with suspected ADHD
Outcomes of Interest for Medical Screening Tests (Question 4)
Prevalence of abnormal findings | Accuracy and reliability of tests
Criteria for Admissible Evidence/Bibliographic Database Boundaries
Data from published studies Literature published 1980–1997 English language | Non-peer-reviewed Non-English language literature Data from unpublished studies Nondiagnostic outcomes (e.g., treatment)

### Definition of ADHD and Comorbid Conditions

Studies were included if the diagnosis of ADHD was based on criteria listed in one of the following diagnostic reference standards: the Diagnostic and Statistical Manual of Mental Disorders, 3rd Edition (DSM-III), 3rd Edition-Revised (DSM-III-R), or 4th Edition (DSM-IV) (American Psychiatric Association, 1980, 1987, 1994), or the International Classification of Diseases (ICD), all editions (U.S. Department of Health and Human Services, 1994). Data were abstracted on five of the most common conditions known to occur with ADHD: learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder. Combinations of ADHD with these disorders were included for the prevalence data, but not for behavior rating scale or medical screening test data.

### Demographics of Population Studied

Patient populations were limited to boys and girls 6 to 12 years of age. Prevalence data were restricted to studies conducted in North America. Data on the performance of behavioral and medical screening tests were not subject to geographic limitation.

### Setting

Only studies using general, unselected populations in communities or schools or pediatric/family practice clinics were used to address the prevalence questions appropriately. Studies were excluded if the prevalence data were obtained in a mental health facility or referral clinic or a school for developmentally disabled students. Data on the performance of screening tests could come from studies conducted in any setting.

### Behavior Rating Scales

The behavior rating scales evaluated in this study were selected after careful investigation of currently available instruments. Several sources provided this information: catalogs ordered from the major publishers of psychological and psychiatric measurement products, Internet searches, reviews of published expert opinion on diagnosis of ADHD in the primary care setting, all editions published since 1970 of the Mental Measurements Yearbook (MMY, a set of professional reviews of psychological assessment products) (Buros, 1998), and the Psychware Sourcebook (a reference guide to computerized psychological assessment products) (Krug, 1993). Published sources of expert opinion were as follows: Altepeter and Breen (1992); August and Garfinkel (1989); August, Ostrander, and Bloomquist (1992); Biederman, Faraone, Doyle, et al. (1993); Breen (1989); Breen and Altepeter (1990); Brunshaw and Szatmari (1988); Chen, Faraone, Biederman, et al. (1994); Cohen, Kelly, and Atkinson (1989); Dykman and Ackerman (1991); Edelbrock and Costello (1988); Epstein, Shaywitz, Shaywitz, et al. (1991); Faraone, Biederman, Mennin, et al. (1996); Halperin, Newcom, Matier, et al. (1993); Hom, Wagner, and Ialongo (1989); Jensen, Burke, and Garfinkel (1988); Jensen, Shervette, Xenakis, et al. (1993); King and Young (1982); Kuehne, Kehle, and McMahon (1987); Luk and Leung (1989); Newcom, Halperin, Healey, et al. (1989); Nussbaum, Grant, Roman, et al. (1990); Reeves, Werry, Elkind, et al. (1987); Satin, Winsberg, Monetti, et al. (1985); Shaywitz, Shaywitz, Schnell, et al. (1988); Shekim, Cantwell, Kashani, et al. (1986); Silverthorn, Frick, Kuper, et al. (1996); Steingard, Biederman, Doyle, et al. (1992); Tarnowski, Prinz, and Nay (1986); Zelko (1991). Selected scales can be easily administered and scored. They have at least a parent version, norms, and subscales designed to measure symptoms of ADHD. Scales that did not have standardized norms or had major flaws identified by reviewers in the MMY were excluded. The resulting list was presented to AHCPR and to AAP for review. AAP members requested inclusion of two additional scales: the Pediatric Symptom Checklist and the Yale Children’s Inventory.

Two types of scales were examined for this report: “ADHD-specific,” designed to target ADHD symptoms only, and “broad-band,” designed to screen for various symptoms, including the symptoms found in ADHD patients. These scales are listed below.

### ADHD-Specific Scales

- ADD-H: Comprehensive Teacher Rating Scale (ACTeRS)
- Attention Deficit Disorders Evaluation Scale (ADDES)
- Barkley Questionnaires:
  - - Home Situations Questionnaire (HSQ)
  - - School Situations Questionnaire (SSQ)
  - - ADHD Rating Scale (ADHDR)
- Children’s Attention and Adjustment Survey (CAAS)
- SNAP Checklist (SNAP)
- Vanderbilt ADIHD Diagnostic Teacher Rating Scale (VADTRS)

### Broad-Band Checklists

- Behavior Assessment System for Children (BASC)
- Burks’ Behavior Rating Scales (BBRS)
- Child Behavior Checklists (CBCL)
- Conners Rating Scales (CRS)
- Devereaux Scales of Mental Disorders (DSMD)
- Pediatric Symptom Checklist (PSC)
- Ontario Child Health Study Scales (OCHS)
- Yale Children’s Inventory (YCI)

Several versions exist for many of these scales, including original and revised versions and parent and teacher report forms. All versions of each scale were included for data abstraction, except the youth self-report forms, because these are designed primarily for adolescents or for children with at least 5th-grade reading levels.

Data of Interest for Behavior Rating Scales. The type of data sought to answer Question 3, “What are the accuracy and reliability of behavioral rating screening tests for ADHD?,” differed according to the type of rating scale being evaluated. For the ADHD-specific checklists, data of interest were each scale’s sensitivity, specificity, validity, and reliability for diagnostic screening of ADHD with and without comorbid conditions. For the broad-band checklists, data of interest were the sensitivity, specificity, validity, and reliability for screening clinical from nonclinical populations. Treatment outcomes were excluded.

### Medical Screening Tests

Medical screening tests evaluated in this report were selected by members of an AAP subcommittee and are commonly used in evaluating a child with suspected ADHD. The evaluated tests were electroencephalography, blood lead level testing, thyroid hormone testing, hearing and vision screening, imaging tests, neurological screening, and continuous performance tests (CPTs).

Data of Interest for Medical Screening Tests. The type of data sought through evaluating the medical tests was the yield of each test for ADHD, or prevalence of abnormal findings among children diagnosed with ADHD at least through DSM criteria, with one exception. Data sought for evaluation of continuous performance tests included the same sort of data gathered for ADHD-specific checklists: each test’s sensitivity and specificity for diagnostic screening of ADHD.

Evidence was deemed admissible if the study from which it came was designed soundly. Sound design was defined according to the following elements: representative study population, comparable control group (not necessarily matched), and adequate description of demographic information. Given the design of these studies, one cannot rule out their possible role in detecting conditions that might mimic ADHD.

## Literature Search and Scope

Several literature search strategies were used: traditional database searches on MEDLINE and PsycINFO; review of reference lists in review articles, research study articles, and a guideline on ADHD obtained from the American Academy of Child and Adolescent Psychiatry; hand-searching of recent journal publications; request to AAP members for suggested citations; and purchase of a database of bibliographies on studies that used or evaluated the Child Behavior Checklist behavior rating scale.

The AAP identified 556 citations published between 1992 and 1996 in a preliminary database search. This search was used as a guide and quality check on subsequent searches. The subsequent searches, outlined in detail in Table 2, were conducted on MEDLINE and PsycINFO databases within the following parameters: studies must have been peer-reviewed and published in English between 1980 and 1997.

Table 2 Literature Searches

Search # | Database Searched | Years of Publication | Search Terms | Yield
1 | MEDLINE | 1980–1996 | Attention deficit disorder with hyperactivity, and Child | 2489
| MEDLINE | 1980–1996 | Attention deficit disorder with hyperactivity, and Child, and Diagnosis | 966
2 | PsycINFO | 1967–1996 | Attention deficit disorder, or Hyperkinesis, and Diagnosis | 286
3 | MEDLINE | 1980–1997 | Attention deficit disorder with hyperactivity, and Child, and Psychometrics, or Diagnosis, or Specificity, and/or Sensitivity | 1229
| PsycINFO | 1967–1997 | School age children, and Attention deficit disorder, or Hyperkinesis, and Testing, or Diagnosis | 109
4 | MEDLINE | 1980–1997 | Attention deficit disorder with hyperactivity, and Prevalence, or Epidemiology, and Child | 224
| PsycINFO | 1967–1997 | Attention deficit disorder, or Hyperkinesis, and Epidemiology | 46
5 | MEDLINE | 1980–1997
| PsycINFO | 1967–1997 | (Each behavior rating scale by name) | 177
6 | MEDLINE | 1980–1997 | Attention deficit disorder with hyperactivity, or Behavioral symptoms, and Lead, or Lead poisoning, or Hyperthyroidism, or Hypothyroidism, or Thyroid function tests, or Electroencephalography, or Diagnostic imaging | 268

Abstracts of more than 4,000 identified citations were reviewed independently by a subject specialist and a physician. Each chose citations of articles to retrieve; differences in choices were discussed and resolved. Subsequently, 356 articles were ordered for retrieval from libraries.

Review of retrieved articles’ bibliographies, Internet searches, and review of a bibliographic database obtained on the Child Behavior Checklist resulted in retrieval of an additional 151 articles. In addition, published manuals were obtained for each of 10 behavior rating scales. Published manuals were not available for the Pediatric Symptom Checklist and the Yale Children’s Inventory.

The subject specialist and physician independently read each of the retrieved articles and manuals and completed the appropriate forms (a listing of retrieved articles and manuals is provided in the reference list). If an article or manual was accepted based on the inclusion and exclusion criteria, the Article Overview Form was completed (Attachment A). The Article Overview Form characterized the type of information in the article or manual, including types of children studied, presence of a control group, setting, diagnostic reference standard used, and type of test, if applicable. If it was not accepted, the Article Overview Form’s cover sheet, the Accept/Reject page only, was completed (Attachment A). This cover sheet identified the country in which the study was conducted, the topic addressed (prevalence, behavior checklists, or medical tests), and the reason for rejection of the article or manual.

A resulting 87 articles and 10 manuals were selected for data abstraction, yielding a total of 97 accepted sources. The search strategy was restricted to MEDLINE. However, several additional studies that met eligibility criteria but were not yet listed in MEDLINE were identified by experts and included in the analysis. For studies of medical screening tests only, the inclusion criteria were revised after initial review of the literature, to better represent how these tests are used in clinical practice. Because medical tests are often done to rule out underlying medical problems before a diagnosis of ADHD is made, the requirement that studies employ one of the diagnostic reference standards to diagnose ADHD cases was dropped. This resulted in the inclusion of 4 studies examining the association between lead levels and behavior (Barlow, 1983; Silva, Hughes, Williams, et al., 1988; Thomson, Raab, Hepburn, et al. 1989; Gittleman and Eskenazi, 1983), studies that had originally been excluded because they employed only behavioral screening tests to identify children with abnormal behavior.

## Data Abstraction Methodology

The accepted articles/manuals were each abstracted twice, using the Data Abstraction Form (Attachment A). Trained personnel abstracted each article, while the subject specialist independently abstracted each article. The resulting sets of abstractions (2 abstractions per article) were compared, with differences discussed and resolved.

The abstracted data were entered into a FoxPro database. During and after data entry, quality checks were performed on every entry to ensure accuracy of the abstraction and entry processes. Data were then tabulated systematically, per topic, for further quality checks and facilitation of statistical analyses.