# Introduction

Attention-deficit/hyperactivity disorder (ADHD), one of the most common behavioral disorders, is distinguished by symptoms of inattention, hyperactivity, and impulsivity. With recent increased public awareness of the disorder, pediatricians and health care providers in general are reporting increases in referral rates of children with suspected ADHD. A plethora of rating scales and medical tests are available, with mixed expert opinion on their individual usefulness. Evidence is needed on the usefulness, or yield, of the various methods available for evaluation and diagnosis of ADHD, to enable the pediatrician and other health care providers to make confident choices. Careful investigation and thorough discussion of the biological, epidemiological, diagnostic, and treatment issues surrounding ADHD led to the rationale for developing an evidence-based report on this disorder and for the specific topics the report would address—prevalence and diagnostic screening of ADHD.