# Conclusions

## Question 1

This report first sought evidence on the percentage of children, aged 6 to 12 years, in the U.S. general population who meet diagnostic criteria for ADHD. Of children with ADHD, percentages having one or more co-occurring disorders—learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder—were ascertained.

In the general, unscreened, school-age U.S. population, prevalence of ADHD ranged from 4 to 12 percent in studies using the DSM-III or DSM-III-R classification scheme. A multiple logistic regression analysis with random effects yielded results suggesting that gender, diagnostic tool, and setting are significant factors in the prevalence of ADHD, but that age is not significant. A study using the DSM-IV classification scheme demonstrated a prevalence of about 7 percent when impairment is considered in the diagnosis and of 16 percent when impairment is not considered. Higher rates of ADHD were found in boys than in girls for all types of ADHD, with the inattentive type most common.

In the general, unscreened, school-age population, prevalence of ADHD co-occurring with other disorders—oppositional defiant disorder, conduct disorder, anxiety disorder, depressive disorder, and learning disability—was estimated to be high, based on results of four studies. Of children diagnosed with ADHD, approximately 35 percent also qualified for a diagnosis of oppositional defiant disorder, 28 percent qualified for a diagnosis of conduct disorder, 26 percent qualified for a diagnosis of anxiety disorder, and 18 percent also had a depressive disorder. Learning disabilities in children with ADHD are estimated at a 12 percent prevalence.

Prevalence of ADHD in the screened school-age population was estimated at about 4 percent.

## Question 2

The report next reviewed evidence on the percentage of children aged 6 to 12 years presenting at pediatricians’ or family physicians’ offices in the United States meeting diagnostic criteria for ADHD. Of those with ADHD, percentages were determined for those having one or more of the following comorbidities: learning disabilities, depression, anxiety, conduct disorder, and oppositional defiant disorder.

Two studies yielded information on prevalence of ADHD and comorbid ADHD diagnosed in a pediatric clinic setting. One study found that approximately 5 percent of children seen in a pediatric setting were diagnosed with ADHD and the other found fewer than 2 percent diagnosed with ADHD. Coexistence of ADHD with other disorders in children seen by a pediatrician was found in the first study to be 59 percent and in the other to range from 8 to 20 percent, depending on the comorbid condition and whether the informant was the parent or the child. These different results could not be explained, but the higher rates are consistent with rates found in general population studies.

## Question 3

The evidence was assessed on accuracy (i.e., sensitivity, specificity, positive predictive value) and reliability (i.e., inter/intra-rater agreement) of behavioral rating screening tests for ADHD compared with a reference standard (DSM or ICD-9).

Among ADHD-specific checklists, the 1997 revision of the Conners Rating Scale contained two highly effective indices for discriminating between children with ADHD and normal controls. The new ADHD Index and DSM-IV Symptoms Scale each were able to distinguish children with ADHD from normal controls 94 percent of the time. On the other hand, the Barkley School Situations Questionnaire was weak, with less than 86 percent effectiveness. Only one study provided data for these two tests and thus interpretations of effectiveness must be made with caution.

Hyperactivity subscales of the SNAP Checklist and the Conners Rating Scale were strong in their ability to discriminate between children with ADHD and normal controls. The only hyperactivity subscale to perform poorly was from the ACTeRS Checklist.

The inattention and impulsivity subscales of the SNAP Checklist discriminated well between children with ADHD and normal controls, with effectiveness of greater than 97 percent. The ACTeRS Checklist performed poorly.

Unfortunately, the available studies of broad-band checklists could not be used to derive conclusions regarding the effectiveness of the scales in distinguishing children with significant problems from children without significant problems.

## Question 4

The evidence was assessed on prevalence of abnormal findings on selected medical screening tests commonly recommended as components of an evaluation of a child with suspected ADHD. Studies of tests for lead levels, abnormal thyroid function, morphologic differences in brain structures, EEG abnormalities (e.g., signs of seizure activity), and neurological characteristics were reviewed for this report. The studies sought to determine whether these tests were useful in detecting conditions that are associated with ADHD.

The ability of any of these tests to demonstrate a relationship to ADHD was not established. Significant lead levels were not found useful as a general tool for ADHD diagnosis. Studies describing the relationship of elevated lead levels and ADHD differed in their results. Overall, lead is not thought to be a major cause of ADHD, a conclusion strengthened by the fact that ADHD prevalence appears to be increasing, whereas lead levels in the population appear to be decreasing. Not one study discovered a relationship between abnormal thyroid levels and ADHD. Overall, the prevalence of any thyroid disorder in children with ADHD appeared to be the same as, or only slightly above, the prevalence of thyroid disorder in normal children. The evidence does not support the use of tests of thyroid function to screen for ADHD. Researchers are studying the relationship between a thyroid disorder called “Generalized Resistance to Thyroid Hormone” (GRTH) and ADHD and hope it will shed light on the etiology of ADHD.

Study results varied in regard to significant differences on brain computer tomographic (CT) or computed axial tomographic (CAT) scans between children with ADHD and normal controls. Two studies showed no significant differences, but several others noted abnormalities in children with ADHD, including differences in size, in asymmetries, or in the shape or volume of the ventricles. In all cases, the structures in the children with ADHD were smaller than those of the normal control subjects. A better understanding of ADHD is likely to evolve from work currently being done with imaging. At the present time, however, the evidence is sparse and diverse, and none of the imaging procedures are supported by research as useful screening or diagnostic tools for ADHD. No studies discovered any serious EEG abnormalities in children with ADHD. However, many found significant differences in brain wave activity between children with ADHD and normal controls. Overall, however, there was a lack of sufficient evidence of EEG patterns typically found in children with ADHD. Therefore, evidence did not support routine use of the EEG as a screening tool for ADHD. Finally, no studies found a significant correlation between neurological anomalies and ADHD.

This report reviewed the small number of studies of miscellaneous other tests to measure neurotransmitters, hormones, and proteins, including serotonin levels, plasma protein levels, peptide-containing urinary fractions, response to growth hormone releasing factor, dopamine receptors, and epinephrine levels. Trends or correlations between these measurements and ADHD could not be determined.

Finally, results on continuous performance tests and their subtests indicated poor prediction of ADHD. These tests would not serve as useful screening tools for ADHD.