# Bibliography

Abikoff H, Courtney M, Pelham WE Jr, et al. Teachers’ ratings of disruptive behaviors: the influence of halo effects. J Abnorm Child Psychol. 1993;21(5):519-33. [pmid: 8294651].
Abikoff H, Klein RG. Attention-deficit hyperactivity and conduct disorder: comorbidity and implications for treatment. J Consult Clin Psychol. 1992;60(6):881-92. [pmid: 1360990].
Accardo PJ, Blondis TA, Whitman BY. Disorders of attention and activity level in a referral population. Pediatrics. 1990;85(3 Pt 2):426-31. [pmid: 2304804].
Accardo PJ, Tomazic T, Morrow J, et al. Minor malformations, hyperactivity, and learning disabilities. Am J Dis Child. 1991;145(10):1184-7. [pmid: 1928014].
Achenbach TM. Integrative guide for the 1991 CBCL/4-18, YRS and TRF profiles. Burlington, VT. University of Vermont Department of Psychiatry. 1991a.
Achenbach TM. Manual for the child behavior checklist/4-18 and 1991 profile. Burlington, VT. University of Vermont Department of Psychiatry. 1991b.
Achenbach TM. Manual for the teachers report form and 1991 profile. Burlington, VT. University of Vermont Department of Psychiatry. 1991c.
Achenbach TM. The Child Behavior Profile: I. Boys aged 6–11. J Consult Clin Psychol. 1978;46:478-88. [pmid: 670491].
Achenbach TM, Edelbrock CS. Behavioral problems and competencies reported by parents of normal and disturbed children aged four through sixteen. Mono Soc Res Child Dev. 1981;46(1, Serial188):1-82.
Achenbach TM, Edelbrock CS. The child behavior profile: II. Boys aged 12–16 and girls aged 6–11 and 12–16. J Consult Clin Psychol. 1979;47(2):223-33. [pmid: 469068].
Achenbach TM, Howell CT, McConaughy SH, et al. Six-year predictors of problems in a national sample: III. Transitions to young adult syndromes. J Am Acad Child Adolesc Psychiatry. 1995a;34(5):658-9. [pmid: 7775361].
Achenbach TM, Howell CT, McConaughy SH, et al. Six-year predictors of problems in a national sample of children and youth: II. Signs of disturbance. J Am Acad Child Adolesc Psychiatry. 1995b;34(4):488-98. [pmid: 7751263].
Ackerman PT, Dykman RA, Oglesby DM, et al. EEG power spectra of children with dyslexia, slow learners, and normally reading children with ADD during verbal processing. J Learn Disabil. 1994;27(10):619-30. [pmid: 7844478].
Adams RM, Macy DJ, Kocsis JJ, et al. Attention deficit disorder with hyperactivity: normative data for Conners behavior rating scale. Tex Med. 1984;80(9):58-61. [pmid: 6484868].
Adesman AR. The Attention Deficit Disorders Evaluation Scale. J Dev Behav Pediatr. 1991;12(1):65-6. [pmid: 2016406].
Altepeter TS, Breen MJ. Situational variation in problem behavior at home and school in attention deficit disorder with hyperactivity: a factor analytic study. J Child Psychol Psychiatry. 1992;33(4):741-8. [pmid: 1376326].
Altepeter TS, Breen MJ. The Home Situations Questionnaire (HSQ) and the School Situations Questionnaire (SSQ): normative data and an evaluation of psychometric properties. J Psychoeducational Assessment. 1989;7:312-22.
American Academy of Child and Adolescent Psychiatry. Practice parameters for the psychiatric assessment of children and adolescents. J Am Acad Child Adolesc Psychiatry. 1995;34(10):1386-402. [pmid: 7592276].
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. Washington, DC. American Psychiatric Association. 1980.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 3rd ed. revised. Washington, DC. American Psychiatric Association. 1987.
American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Washington, DC. American Psychiatric Association. 1994.
Anastopolous AD, Spisto MA, Maher MC. The wisc-iii freedom from distractibility factor: its utility in identifying children with attention deficit hyperactivity disorder. Psychol Assess. 1994;6(4):368-71.
Anderson BW. Comorbidity of attention deficit hyperactivity disorder and other disorders [letter; comment]. Am J Psychiatry. 1992;149(1):148-9. discussion 149. [pmid: 1728179].
Anderson JC, Williams S, McGee R, et al. DSM-III disorders in preadolescent children. Prevalence in a large sample from the general population. Arch Gen Psychiatry. 1987;44(1):69-76. [pmid: 2432848].
Angold A, Costello EJ. Depressive comorbidity in children and adolescents: empirical, theoretical, and methodological issues. Am J Psychiatry. 1993;150(12):1779-91. [pmid: 8238631].
Angold A, Costello EJ. Toward establishing an empirical basis for the diagnosis of oppositional defiant disorder. J Am Acad Child Adolesc Psychiatry. 1996;35(9):1205-12. [pmid: 8824064].
Arcia E, Roberts JE. Otitis media in early childhood and its association with sustained attention in structured situations. J Dev Behav Pediatr. 1993;14(3):181-3. [pmid: 8340473].
Arnold LE. Sex differences in ADHD: conference summary. J Abnorm Child Psychol. 1996;24(5):555-69. [pmid: 8956084].
Atkins MS, Pelham WE, Licht MH. The development and validation of objective classroom measures for conduct and attention deficit disorders. Adv Behav Assess Child Fam. 1988;4:3-31.
Atkins MS, Pelham WE, Licht MH. The differential validity of teacher ratings of inattention/overactivity and aggression. J Abnorm Child Psychol. 1989;17(4):423-35. [pmid: 2794255].
Atkins MS, Pelham WE, Licht MH. A comparison of objective classroom measures and teacher ratings of Attention Deficit Disorder. J Abnorm Child Psychol. 1985;13(1):155-67. [pmid: 3973249].
Atkins MS, Stoff DM. Instrumental and hostile aggression in childhood disruptive behavior disorders. J Abnorm Child Psychol. 1993;21(2):165-78. [pmid: 8491930].
Auerbach JG, Lerner Y. Syndromes derived from the Child Behavior Checklist for clinically referred Israeli boys aged 6–11: a research note. J Child Psychol Psychiatry. 1991;32(6):1017-24. [pmid: 1744189].
August GJ, Garfinkel BD. Behavioral and cognitive subtypes of ADHD. JAm Acad Child Adolesc Psychiatry. 1989;28(5):739-48. [pmid: 2793802].
August GJ, Ostrander R, Bloomquist MJ. Attention deficit hyperactivity disorder: an epidemiological screening method. Am J Orthopsychiatry. 1992;62(3):387-96. [pmid: 1497104].
August GJ, Realmuto GM, MacDonald AW, et al. Prevalence of ADHD and comorbid disorders among elementary school children screened for disruptive behavior. J Abnorm Child Psychol. 1996;24(5):571-95. [pmid: 8956085].
August GJ, Stewart MA. Is there a syndrome of pure hyperactivity?. Br J Psychiatry. 1982;140:305-11. [pmid: 7093599].
Aylward GP, Verhulst SJ, Bell S. Individual and combined effects of attention deficits and learning disabilities on computerized ADHD assessment. J Psychoeduc Assess. 1990;8(4):497-508.
Barbaresi WJ. Primary-care approach to the diagnosis and management of attention-deficit hyperactivity disorder. Mayo Clin Proc. 1996;71(5):463-71. [pmid: 8628026].
Barkley RA. A critique of current diagnostic criteria for attention deficit hyperactivity disorder: clinical and research applications. J Dev Behav Pediatr. Dec. 1990;11(6):343-52. [pmid: 2289969].
Barkley RA. The ecological validity of laboratory and analogue assessment methods of ADHD symptoms. J Abnorm Child Psychol. 1991;19(2):149-78. [pmid: 2056161].
Barkley RA, DuPaul GJ, McMurray MB. Comprehensive evaluation of attention deficit disorder with and without hyperactivity as defined by research criteria. J Consult Clin Psychol. 1990;58(6):775-89. [pmid: 2292627].
Barkley RA, Grodzinsky GM. Are tests of frontal lobe functions useful in the diagnosis of attention deficit disorders?. Clin Neuropsychologist. 1994;8(2):121-39.
Barkley RA, Grodzinsky G, DuPaul GJ. Frontal lobe functions in attention deficit disorder with and without hyperactivity: a review and research report. J Abnorm Child Psychol. 1992;20(2):163-88. [pmid: 1593025].
Barlow PJ. A pilot study on the metal levels in the hair of hyperactive children. Med Hypotheses. 1983;11:309-18. [pmid: 6645998].
Bartell SS, Solanto MV. Usefulness of the Rorschach inkblot test in assessment of attention deficit hyperactivity disorder. Percept Mot Skills. 1995;80(2):531-41. [pmid: 7675586].
Bauermeister JJ, Alegria M, Bird HR, et al. Are attentional-hyperactivity deficits unidimensional or multidimensional syndromes? Empirical findings from a community survey. 37th Annual Meeting of the American Academy of Child and Adolescent Psychiatry. 1990. Chicago, IL. J Am Acad Child Adolesc Psychiatry. 1992;31(3):423-31.
Bauermeister JJ, Berrios V, Jimenez AL, et al. Some issues and instruments for the assessment of attention-deficit hyperactivity disorder in Puerto Rican children. J Clin Child Psychol. 1990;19(1):9-16.
Bedi GC, Halperin JM, Sharma V. Investigation of modality-specific distractibility in children. Int J Neurosci. 1994;74(1–4):79-85. [pmid: 7928117].
Bell RQ. Four new research approaches to socialization: an evaluation of their advantages and disadvantages. J Abnorm Child Psychol. 1981;9(3):341-5. [pmid: 7320351].
Bellak L. Comorbidity of attention deficit hyperactivity disorder and other disorders. Am J Psychiatry. 1992;149(1):147-8. [pmid: 1728175].
Bhatara VS, Kummer M, McMillin JM, et al. ADHD and the thyroid [letter]. J Am Acad Child Adolesc Psychiatry. 1994;33(7):1057-8. [pmid: 7961345].
Bhatia MS, Nigam VR, Bohra N, et al. Attention deficit disorder with hyperactivity among paediatric outpatients. J Child Pyschol Psychiatry. 1991;32(2):297-306.
Biederman J, Faraone S, Mick E, et al. Child behavior checklist findings further support comorbidity between ADHD and major depression in a referred sample. J Am Acad Child Adolesc Psychiatry. 1996;35(6):734-42. [pmid: 8682754].
Biederman J, Faraone S, Mick E, et al. Attention-deficit hyperactivity disorder and juvenile mania: an overlooked comorbidity?. J Am Acad Child Adolesc Psychiatry. 1996;35(8):997-1008. [pmid: 8755796].
Biederman J, Faraone S, Milberger S, et al. Predictors of persistence and remission of ADHD into adolescence: results from a four-year prospective follow-up study. JAm Acad Child Adolesc Psychiatry. 1996a;35(3):343-51. [pmid: 8714323].
Biederman J, Faraone S, Milberger S, et al. A prospective 4-year follow-up study of attention-deficit hyperactivity and related disorders. Arch Gen Psychiatry. 1996b;53(5):437-46. [pmid: 8624187].
Biederman J, Faraone SV, Chen WJ. Social Adjustment Inventory for Children and Adolescents: concurrent validity in ADHD children. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1059-64. [pmid: 8407752].
Biederman J, Faraone SV, Doyle A, et al. Convergence of the Child Behavior Checklist with structured interview-based psychiatric diagnoses of ADHD children with and without comorbidity. J Child Psychol Psychiatry. 1993;34(7):1241-51. [pmid: 8245144].
Biederman J, Faraone SV, Keenan K, et al. Further evidence for family-genetic risk factors in attention deficit hyperactivity disorder. Patterns of comorbidity in probands and relatives psychiatrically and pediatrically referred samples. Arch Gen Psychiatry. 1992;49(9):728-38. [pmid: 1514878].
Biederman J, Faraone SV, Keenan K, et al. Evidence of familial association between attention deficit disorder and major affective disorders. Arch Gen Psychiatry. 1991;48(7):633-42. [pmid: 2069494].
Biederman J, Faraone SV, Mick E, et al. High risk for attention deficit hyperactivity disorder among children of parents with childhood onset of the disorder: a pilot study. Am J Psychiatry. 1995;152(3):431-5. [pmid: 7864271].
Biederman J, Faraone SV, Milberger S, et al. Diagnoses of attention-deficit hyperactivity disorder from parent reports predict diagnoses based on teacher reports. J Am Acad Child Adolesc Psychiatry. 1993;32(2):315-7. [pmid: 8444759].
Biederman J, Faraone SV, Milberger S, et al. Is childhood oppositional defiant disorder a precursor to adolescent conduct disorder? Findings from a four-year follow-up study of children with ADHD. J Am Acad Child Adolesc Psychiatry. 1996c;35(9):1193-204. [pmid: 8824063].
Biederman J, Keenan K, Faraone SV. Parent-based diagnosis of attention deficit disorder predicts a diagnosis based on teacher report [published erratum appears in J Am Acad Child Adolesc Psychiatry 1991;30(2):337]. J Am Acad Child Adolesc Psychiatry. 1990;29(5):698-701. [pmid: 2228921].
Biederman J, Milberger S, Faraone SV, et al. Associations between childhood asthma and ADHD: issues of psychiatric comorbidity and familiality. J Am Acad Child Adolesc Psychiatry. 1994;33(6):842-8. [pmid: 8083141].
Biederman J, Milberger S, Faraone SV, et al. Family-environment risk factors for attention-deficit hyperactivity disorder. A test of Rutter’s indicators of adversity. Arch Gen Psychiatry. 1995;52(6):464-70. [pmid: 7771916].
Biederman J, Milberger S, Faraone SV, et al. No confirmation of Geschwind’s hypothesis of associations between reading disability, immune disorders, and motor preference in ADHD. J Abnorm Child Psychol. 1995;23(5):545-52. [pmid: 8568078].
Biederman J, Munir K, Knee D, et al. High rate of affective disorders in probands with attention deficit disorder and in their relatives: a controlled family study. Am J Psychiatry. 1987;144(3):330-3. [pmid: 3826433].
Biederman J, Newcorn J, Sprich S. Comorbidity of attention deficit hyperactivity disorder with conduct, depressive, anxiety, and other disorders [see comments]. Am J Psychiatry. 1991;148(5):564-77. [pmid: 2018156].
Biederman J, Rosenbaum JF, Hirshfeld DR, et al. Psychiatric correlates of behavioral inhibition in young children of parents with and without psychiatric disorders. Arch Gen Psychiatry. 1990;47(1):21-6. [pmid: 2294852].
Biederman J, Santangelo SL, Faraone SV, et al. Clinical correlates of enuresis in ADHD and non-ADHD children. J Child Psychol Psychiatry. 1995;36(5):865-77. [pmid: 7559850].
Biederman J, Wozniak J, Kiely K, et al. CBCL clinical scales discriminate prepubertal children with structured interview-derived diagnosis of mania from those with ADHD. J Am Acad Child Adolesc Psychiatry. 1995;34(4):464-71. [pmid: 7751260].
Bird HR. Epidemiology of childhood disorders in a cross-cultural context. J Child PsychoI Psychiatry. 1996;37(1):35-49.
Bird HR, Canino G, Rubio-Stipec M, et al. Estimates of the prevalence of childhood maladjustment in a community survey in Puerto Rico. Arch Gen Psychiatry. 1988;45:1120-6. [pmid: 3264147].
Bird HR, Gould MS, Staghezza BM. Patterns of diagnostic comorbidity in a community sample of children aged 9 through 16 years. J Am Acad Child Adolesc Psychiatry. 1993;32(2):361-8. [pmid: 8444766].
Blondis TA, Accardo PJ, Snow JH. Measures of attention deficit. Part I: Questionnaires. Clin Pediatr. 1989;28(5):222-8.
Bohline DS. Intellectual and affective characteristics of attention deficit disordered children. J Learn Disabil. 1985;18(10):604-8. [pmid: 4086939].
Bowers TG, Risser MG, Suchanec JF, et al. A developmental index using the Wechsler Intelligence Scale for Children: implications for the diagnosis and nature of ADHD. J Learn Disabil. 1992;25(3):179-85. [pmid: 1602225].
Boyle MH, Offord DR, Hoffman HG, et al. Ontario Child Health Study: I. Methodology. Arch Gen Psychiatry. 1987;44:826-31. [pmid: 3632257].
Boyle MH, Offord DR, Racine Y, et al. Evaluation of the revised Ontario Child Health Study scales. J Child Psychol Psychiatry. 1993a;34(2):189-213. [pmid: 8444992].
Boyle MH, Offord DR, Racine Y, et al. Evaluation of the original Ontario Child Health Study scales. Can J Psychiatry. 1993b;38(6):397-405. [pmid: 8402433].
Boyle MH, Offord DR, Racine Y, et al. Evaluation of the Diagnostic Interview for Children and Adolescents for use in general population samples. J Abnorm Child Psychol. 1993c;21(6):663-81. [pmid: 8126319].
Boyle MH, Offord DR, Racine Y, et al. Identifying thresholds for classifying childhood psychiatric disorder: issues and prospects. JAm Acad Child Adolesc Psychiatry. 1996;35(11):1440-8. [pmid: 8936910].
Brandenburg NA, Friedman RM, Silver SE. The epidemiology of childhood psychiatric disorders: prevalence findings from recent studies. J Am Acad Child Adolesc Psychiatry. 1990;29(1):76-83. [pmid: 2295582].
Brandon KA, Kehle TJ, Jenson WR, et al. Regression, practice, and expectation effects on the Revised Conners Teacher Rating Scale. J Psychoeduc Assess. 1990;8:456-66.
Breen MJ. Cognitive and behavioral differences in ADHD boys and girls. J Child Psychol Psychiatry. 1989;30(5):711-6. [pmid: 2793958].
Breen MJ, Altepeter TS. Factor structures of the Home Situations Questionnaire and the School Situations Questionnaire. J Pediatr Psychol. 1991;16(1):59-67. [pmid: 2010877].
Breen MJ, Altepeter TS. Situational variability in boys and girls identified as ADHD. J Clin Psychol. 1990;46(4):486-90. [pmid: 2212053].
Brent DA. Psychiatric assessment of the school age child. Pediatr Ann. 1985;14(5):371-2. [pmid: 4000740].
Brito GN, Pinto RC, Lins MF. A behavioral assessment scale for attention deficit disorder in Brazilian children based on DSM-IIIR criteria. J Abnorm Child Psychol. 1995;23(4):509-20. [pmid: 7560559].
Broad J, Burke J, Byford SR, et al. Clinical application of the Children’s Action Tendency Scale. Psychol Rep. 1986;59:71-4. [pmid: 3737819].
Brown RT. Teacher ratings and the assessment of attention deficit disordered children. J Learn Disabil. 1986;19(2):95-100. [pmid: 3950521].
Brown RT, Madan-Swain A, Baldwin K. Gender differences in a clinic-referred sample of attention-deficit-disordered children. Child Psychiatry Hum Dev. 1991;22(2):111-28. [pmid: 1800023].
Brunshaw JM, Szatmari P. The agreement between behaviour checklists and structured psychiatric interviews for children. Can J Psychiatry. 1988;33(6):474-81. [pmid: 3196999].
Burke J, Broad J, Byford SR, et al. Use of the Burks’ Behavior Rating Scale with a referred population. Psychol Rep. 1983;53:491-6. [pmid: 6647695].
Burks HF. Burks behavior rating scales [manual]. Los Angeles. Western Psychological Services. 1996:32. 38.
Buros O. Mental Measurements Yearbook (MMY). 9th ed. New Brunswick, NJ. Rutgers University Press. 1998.
Butler SF, Arredondo DE, McCloskey V. Affective comorbidity in children and adolescents with attention deficit hyperactivity disorder. Ann Clin Psychiatry. 1995;7(2):51-5. [pmid: 8556093].
Cacabelos R, Albarran M, Dieguez C, et al. GRF-induced GH response in attention-deficit hyperactivity disorder. Methods Find Exp Clin Pharmacol. 1990;12(1):79-85. [pmid: 2107369].
Camp JA, Bialer I, Sverd J, et al. Clinical usefulness of the NIMH physical and neurological examination for soft signs. Am J Psychiatry. 1978;135(3):362-4. [pmid: 204204].
Campbell SB. Behavior problems in preschool children: a review of recent research. J Child Psychol Psychiatry. 1995;36(1):113-49. [pmid: 7714027].
Canadian Paediatric Society. Hyperactivity in children. Mental Health Committee, Canadian Paediatric Society. Can Med Assoc J. 1988;139(3):211-2. [pmid: 3395935].
Cantwell DP. Attention deficit disorder: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry. 1996;35(8):978-87. [pmid: 8755794].
Cantwell DP. Classification of child and adolescent psychopathology. J Child Psychol Psychiatry. 1996;37(1):3-12. [pmid: 8655656].
Cantwell DP, Baker L. Association between attention deficit-hyperactivity disorder and learning disorders. J Learn Disabil. 1991;24(2):88-95. [pmid: 2010679].
Caparulo BK, Cohen DJ, Rothman SL, et al. Computed tomographic brain scanning in children with developmental neuropsychiatric disorders. J Am Acad Child Psychiatry. 1981;20(2):338-57. [pmid: 6167604].
Caplan R, Guthrie D, Komo S. Blink rate in children with attention-deficit-hyperactivity disorder. Biol Psychiatry. 1996;15;39(12):1032-8.
Carey WB, McDevitt SC, Baker D. Differentiating minimal brain dysfunction and temperament. Ann Prog Child Psychiatry Child Devel. 1980:265-70.
Carter CS, Krener P, Chaderjian M, et al. Abnormal processing of irrelevant information in attention deficit hyperactivity disorder. Psychiatry Res. 1995a;56(1):59-70. [pmid: 7792343].
Carter CS, Krener P, Chaderjian M, et al. Asymmetrical visual-spatial attentional performance in ADHD: evidence for a right hemispheric deficit. Biol Psychiatry. 1995b;37(11):789-97. [pmid: 7647163].
Castellanos FX, Elia J, Kruesi MJ, et al. Cerebrospinal fluid monoamine metabolites in boys with attention-deficit hyperactivity disorder. Psychiatry Res. 1994;52(3):305-16. [pmid: 7527565].
Castellanos FX, Giedd JN, Eckburg P, et al. Quantitative morphology of the caudate nucleus in attention deficit hyperactivity disorder. Am J Psychiatry. 1994;151(12):1791-6. [pmid: 7977887].
Castellanos FX, Giedd JN, Hamburger SD, et al. Brain morphometry in Tourette’s syndrome: the influence of comorbid attention deficit/hyperactivity disorder. Neurology. 1996;47:1581-3. [pmid: 8960751].
Castellanos FX, Giedd JN, Marsh WL, et al. Quantitative brain magnetic resonance imaging in attention-deficit hyperactivity disorder. Arch Gen Psychiatry. 1996;53(7):607-16. [pmid: 8660127].
Chen WJ, Faraone SV, Biederman J, et al. Diagnostic accuracy of the child behavior checklist scales for attention-deficit hyperactivity disorder: a receiver-operating characteristic analysis. J Consult Clin Psychol. 1994;62(5):1017-25. [pmid: 7806710].
Christie D, De Witt RA, Kaltenbach P, et al. Hyperactivity in children: evidence for differences between parents’ and teachers’ perceptions of predominant features. Psychol Rep. 1984;54(3):771-4. [pmid: 6473593].
Cohen M. The Revised Conners Parent Rating Scale: factor structure replication with a diversified clinical sample. J Abnorm Child Psychol. 1988;16(2):187-96. [pmid: 3385082].
Cohen M, Becker MG, Campbell R. Relationships among four methods of assessment of children with attention deficit-hyperactivity disorder. J Sch Psychol. 1990;28(3):189-202.
Cohen P, Cohen J, Brook J. An epidemiological study of disorders in late childhood and adolescence--II. Persistence of disorders. J Child Psychol Psychiatry. 1993;34(6):869-77. [pmid: 8408372].
Cohen P, Cohen J, Kasen S, et al. An epidemiological study of disorders in late childhood and adolescence: I. Age- and gender-specific prevalence. J Child Psychol Psychiatry. 1993;34(6):851-67. [pmid: 8408371].
Cohen M, DuRant RH, Cook C. The Conners Teacher Rating Scale: effects of age, sex, and race with special education children. Psych Sch. 1988;25:195-202.
Cohen NJ, Gotlieb H, Kershner J, et al. Concurrent validity of the internalizing and externalizing profile patterns of the Achenbach Child Behavior Checklist. J Consult Clin Psychol. 1985;53(5):724-8. [pmid: 4056190].
Cohen ML, Kelly PC, Atkinson AW. Parent, teacher, child: a trilateral approach to attention deficit disorder. Am J Dis Child. 1989;143:1229-33. [pmid: 2801667].
Cohen MJ, Riccio CA, Gonzalez JJ. Methodological differences in the diagnosis of attention-deficit hyperactivity disorder: impact on prevalence. Annual Convention of the National Association of School Psychologists. 1992. Nashville, TN. J Emotion Behav Disord. 1994;2(1):31-8.
Compas BE, Davis GE, Forsythe CJ, et al. Assessment of major and daily stressful events during adolescence: the Adolescent Perceived Events Scale. J Consult Clin Psychol. 1987;55(4):534-41. [pmid: 3624609].
Conger AJ, Conger JC, Wallander J, et al. A generalizability study of the Conners’ Teacher Rating Scales-Revised. Educ Psychol Meas. 1983;43:1019-31.
Conners CK. Conners’ rating scales manual: Conners’ teacher rating scale: Conners’ parent rating scale: instruments for use with children and adolescents. Toronto, North Tonawanda, NY. Multi-Health Systems, Inc. 1990:41.
Conners CK. CRS–R, Conners’ rating scales-revised: instruments for use with children and adolescents. Toronto, North Tonawanda, NY. Multi-Health Systems, Inc. 1997:94. 134.
Conners CK. The computerized continuous performance test. Psychopharmacol Bull. 1985;21:891-2. [pmid: 4089110].
Conners CK, Kronsberg S. Measuring activity level in children. Psychopharmacol Bull. 1985;21(4):893-7. [pmid: 4089111].
Cook EH, Stein MA, Ellison T, et al. Attention deficit hyperactivity disorder and whole-blood serotonin levels: effects of comorbidity. Psychiatry Res. 1995;57:13-20. [pmid: 7568555].
Copeland L, Wolraich M, Lindgren S, et al. Pediatricians’ reported practices in the assessment and treatment of attention deficit disorders. J Dev Behav Pediatr. 1987;8(4):191-7. [pmid: 3611359].
Corkum PV, Siegel LS. Is the Continuous Performance Task a valuable research tool for use with children with Attention-Deficit-Hyperactivity Disorder?. J Child Psychol Psychiatry. 1993;34(7):1217-39. [pmid: 8245143].
Costello EJ. Child psychiatric disorders and their correlates: A primary care pediatric sample. J Am Acad Child Adolesc Psychiatry. 1989;28(6):851-5. [pmid: 2808254].
Costello EJ, Angold A, Burns BJ, et al. The Great Smokey Mountains study of youth: goals, design, methods, and the prevalence of DSM-III-R disorders. Arch Gen Psychiatry. Dec. 1996;53:1129-36. [pmid: 8956679].
Costello EJ, Burns BJ, Costello AJ, et al. Service utilization and psychiatric diagnosis in pediatric primary care: the role of the gatekeeper. Pediatrics. 1988;82(3 Pt 2):435-41. [pmid: 3405679].
Costello EJ, Costello AJ, Edelbrock C, et al. Psychiatric disorders in pediatric primary care. Arch Gen Psychiatry. 1988;45:1107-16. [pmid: 3264146].
Costello EJ, Edelbrock C, Costello AJ, et al. Psychopathology in pediatric primary care: the new hidden morbidity. Pediatrics. 1988;82(3, Pt 2):415-24. [pmid: 3405677].
Costello EJ, Loeber R, Stouthamer-Loeber M. Pervasive and situational hyperactivity--confounding effect of informant: a research note. J Child Psychol Psychiatry. 1991;32(2):367-76. [pmid: 2033114].
Cotugno AJ. Personality attributes of attention deficit hyperactivity disorder (ADHD) using the Rorschach Inkblot Test. J Clin Psychol. 1995;51(4):554-62. [pmid: 7593679].
Curtis PA, Schmidt LL. A Spanish translation of the Revised Behavior Problem Checklist. Child Welfare. 1993;72(5):453-60. [pmid: 8404249].
Dalby JT. Taxonomic separation of attention deficit disorders and developmental reading disorders. Contemp Educ Psychol. 1985;10(3):228-34.
Daugherty TK, Quay HC, Ramos L. Response perseveration, inhibitory control, and central dopaminergic activity in childhood behavior disorders. J Genet Psychol. 1993;154(2):177-88. [pmid: 8366330].
David OJ, Hoffman SP, Clark J, et al. The relationship of hyperactivity to moderately elevated lead levels. Arch Environ Health. 1983;38(6):341-6. [pmid: 6667034].
de Jong PF. Validity of the Amsterdam Child Behavior Checklist: a short rating scale for children. Psychol Rep. 1995;77(3 Pt 2):1139-44. [pmid: 8643775].
de Mesquita PB, Gilliam WS. Differential diagnosis of childhood depression: using comorbidity and symptom overlap to generate multiple hypotheses. Child Psychiatry Hum Dev. 1994;24(3):157-72. [pmid: 8174393].
deHaas PA, Young RD. Attention styles of hyperactive and normal girls. J Abnorm Child Psychol. 1984;12(4):531-46. [pmid: 6491060].
Deuel RK. Minimal brain dysfunction, hyperkinesis, learning disabilities, attention deficit disorder. J Pediatr. 1981;98(6):912-5. [pmid: 7229792].
Diamond JM, Deane FP. Conners Teachers’s Questionnaire: effects and implications of frequent administration. J Clin Child Psychol. 1990;19(3):202-4.
Dulcan MK. Attention deficit disorder: evaluation and treatment. Pediatr Ann. 1985;14(5):383-5. [pmid: 2860631].
Dulcan MK. Comprehensive treatment of children and adolescents with attention deficit disorders: the state of the art. Clin Psychol Rev. 1986;6:539-69.
Dulcan JK, Costello EJ, Costello AJ, et al. The pediatrician as gatekeeper to mental health care for children: do parents’ concerns open the gate?. J Am Acad Child Adolesc Psychiatry. 1990;29(3):453-8. [pmid: 2347844].
DuPaul GJ. Parent and teacher ratings of ADHD symptoms: psychometric properties in a community-based sample. J Clin Child Psychol. 1991;20(3):245-53.
DuPaul GJ, Anastopoulos AD, Shelton TL, et al. Multimethod assessment of attention-deficit hyperactivity disorder: the diagnostic utility of clinic-based tests. J Clin Child Psychol. 1992;21(4):394-402.
DuPaul GJ, Barkley RA. Situational variability of attention problems: psychometric properties of the Revised Home and School Situations Questionnaire. J Clin Child Psychol. 1992;21(2):178-88.
Dykman RA, Ackerman PT. Attention deficit disorder and specific reading disability: separate but often overlapping disorders. J Learn Disabil. 1991;24(2):96-103. [pmid: 2010680].
Eberle AJ. Hyperactivity and Graves’ disease [letter]. J Am Acad Child Adolesc Psychiatry. 1995;34(8):973. [pmid: 7665452].
Edelbrock C. Behavioral ratings of children diagnosed for attention deficit disorder. Psychiatr Ann. 1986;16(1):36-40.
Edelbrock C, Costello AJ. Convergence between statistically derived behavior problem syndromes and child psychiatric diagnoses. J Abnorm Child Psychol. 1988;16(2):219-31. [pmid: 3385085].
Edelbrock C, Costello AJ, Kessler MD. Empirical corroboration of attention deficit disorder. J Am Acad Child Psychiatry. 1984;23(3):285-90. [pmid: 6736493].
Edelbrock C, Greenbaum R, Conover NC. Reliability and concurrent relations between the teacher version of the Child Behavior Profile and the Conners Revised Teacher Rating Scale. J Abnorm Child Psychol. 1985;13(2):295-303. [pmid: 4008757].
Edelbrock C, Rancurello MD. Childhood hyperactivity: an overview of rating scales and their applications. Clin Psychol Rev. 1985;5:429-45.
Edwards MC, Schulz EG, Long N. The role of the family in the assessment of attention deficit hyperactivity disorder. Clin Psychol Rev. 1995;15:375-94.
Eisert DC, Sturner RA, Mabe PA. Questionnaires in behavioral pediatrics: guidelines for selection and use. J Dev Behav Pediatr. 1991;12(1):42-50. [pmid: 2016402].
Elia J, Gulotta C, Rose SR, et al. Thyroid function and attention-deficit hyperactivity disorder [see comments]. J Am Acad Child Adolesc Psychiatry. 1994;33(2):169-72. [pmid: 8150787].
Elliot SN, Busse RT, Gresham FM. Behavior rating scales: issues of use and development. Sch Psychol Rev. 1993;22(2):313-21.
Epkins CC. Parent ratings of children’s depression, anxiety, and aggression: a cross-sample analysis of agreement and differences with child and teacher ratings. J Clin Psychol. 1996;52(6):599-608. [pmid: 8912102].
Epstein MA, Shaywitz SE, Shaywitz BA, et al. The boundaries of attention deficit disorder. J Learn Disabil. 1991;24(2):78-86. [pmid: 2010678].
Epstein MH, Nieminen GS. Reliability of the Conners Abbreviated Teacher Rating Scale across raters and across time: use with learning disabled students. Sch Psychol Rev. 1983;12(4):457-9.
Erford BT. Analysis of the Conners’ Teacher Rating Scale-28 (CTRS-28). Assessment. 1996:27-36.
Ernst M, Liebenauer LL, King AC, et al. Reduced brain metabolism in hyperactive girls. J Am Acad Child Adolesc Psychiatry. 1994;33(6):858-68. [pmid: 8083143].
Esser G, Schmidt MH, Woerner W. Epidemiology and course of psychiatric disorders in school-age children--results of a longitudinal study. J Child Psychol Psychiatry. 1990;31(2):243-63. [pmid: 2312652].
Faraone SV, Biederman J. Genetics of attention-deficit hyperactivity disorder. Child Adolesc Psychiatr Clin North Am. 1994;3(2):285-301.
Faraone SV, Biederman J, Lehman BK, et al. Evidence for the independent familial transmission of attention deficit hyperactivity disorder and learning disabilities: results from a family genetic study. Am J Psychiatry. 1993a;150(6):891-5. [pmid: 8494064].
Faraone SV, Biederman J, Lehman BK, et al. Intellectual performance and school failure in children with attention deficit hyperactivity disorder and in their siblings. J Abnorm Psychol. 1993b;102(4):616-23. [pmid: 8282932].
Faraone SV, Biederman J, Mennin D, et al. A prospective four-year follow-up study of children at risk for ADHD: Psychiatric, neurological, and social outcome. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1449-59. [pmid: 8936911].
Faraone SV, Biederman J, Milberger S. How reliable are maternal reports of their children’s psychopathology? One-year recall of psychiatric diagnoses of ADHD children. J Am Acad Child Adolesc Psychiatry. 1995;34(8):1001-8. [pmid: 7665438].
Faraone SV, Biederman J, Sprich-Buckminster S, et al. Efficiency of diagnostic criteria for attention deficit disorder: toward an empirical approach to designing and validating diagnostic algorithms. J Am Acad Child Adolesc Psychiatry. 1993;32(1):166-74. [pmid: 7679093].
Fergusson DM, Horwood LJ. Predictive validity of categorically and dimensionally scored measures of disruptive childhood behaviors. J Am Acad Child Adolesc Psychiatry. 1995;34(4):477-85. [pmid: 7751262].
Fergusson DM, Horwood LJ. The structure, stability and correlations of the trait components of conduct disorder, attention deficit and anxiety/withdrawal reports. J Child Psychol Psychiatry. 1993;34(5):749-66. [pmid: 8340443].
Fergusson DM, Horwood LJ, Lloyd M. Confirmatory factor models of attention deficit and conduct disorder. J Child Psychol Psychiatry. 1991;32(2):257-74. [pmid: 2033107].
Filipek PA, Semrud-Clikeman M, Steingard RJ, et al. Volumetric MRI analysis comparing subjects having attention-deficit hyperactivity disorder with normal controls. Neurology. 1997;48:589-601. [pmid: 9065532].
Fischer M, Barkley RA, Fletcher KE, et al. The stability of dimensions of behavior in ADHD and normal children over an 8-year followup. J Abnorm Child Psychol. 1993;21(3):315-37. [pmid: 8335766].
Fischer M, Newby RF, Gordon M. Who are the false negatives on continuous performance tests?. J Clin Child Psychol. 1995;24(4):427-33.
Flanagan DP, Alfonso VC, Primavera LH, et al. Convergent validity of the BASC and SSRS: implications for social skills assessment. Psych Sch. 1996;33:13-23.
Flanagan R. A review of the Behavior Assessment System for Children (BASC): assessment consistent with the requirements of the Individuals with Disabilities Education Act (IDEA). J Sch Psychol. 1995;33(2):177-86.
Flannery KA, Liederman J. Is there really a syndrome involving the co-occurrence of neurodevelopmental disorder talent, non-right handedness and immune disorder among children?. Cortex. 1995;31(3):503-15. [pmid: 8536478].
Fletcher JM, Morris RD, Francis DJ. Methodological issues in the classification of attention-related disorders. J Learn Disabil. 1991;24(2):72-7. [pmid: 2010677].
Fombonne E. The Chartres Study: I. Prevalence of psychiatric disorders among French school-age children. Br J Psychiatry. 1994;164(1):69-79. [pmid: 8137112].
Forbes GB. The personality inventory for children and hyperactivity: clinical utility and generalizability problems. J Pediatr Psychol. 1985;10(2):141-9. [pmid: 4020600].
Frank Y, Ben-Nun Y. Toward a clinical subgrouping of hyperactive and nonhyperactive attention deficit disorder. Results of a comprehensive neurological and neuropsychological assessment. Am J Dis Child. 1988;142(2):153-5. [pmid: 3341314].
Frankel F, Hanna GL, Cantwell DP, et al. Cluster analysis of child behavior checklists of 6 to 11-year-old males with varying degrees of behavior disorders. Child Psychiatry Hum Dev. 1992;23(2):69-85. [pmid: 1490398].
Frick PJ, Kamphaus RW, Lahey BB, et al. Academic underachievement and the disruptive behavior disorders. J Consult Clin Psychol. 1991;59(2):289-94. [Erratum appears in J Consult Clin Psychol 1995;63(2):220.]. [pmid: 2030190].
Fristad MA, Weller EB, Weller RA. The Mania Rating Scale: can it be used in children? A preliminary report. J Am Acad Child Adolesc Psychiatry. 1992;31(2):252-7. [Erratum appears in J Am Acad Child Adolesc Psychiatry 1992;31(5):1001.]. [pmid: 1564026].
Gabel S, Schmitz S, Fulker DW. Comorbidity in hyperactive children: issues related to selection bias, gender, severity, and internalizing symptoms. Child Psychiatr Hum Dev. 1996;27(1):15-28.
Gallucci F, Bird HR, Berardi C, et al. Symptoms of attention-deficit hyperactivity disorder in an Italian school sample: findings of a pilot study. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1051-8. [pmid: 8407751].
Garfinkel BD, Amrami KK. A perspective on the attention-deficit disorders. Hosp Community Psychiatry. 1992;43(5):445-6. 448. [pmid: 1587505].
Gascon GG, Johnson R, Burd L. Central auditory processing and attention deficit disorders. J Child Neurol. 1986;1(1):27-33. [pmid: 3598105].
Giedd JN, Castellanos FX, Casey BJ, et al. Quantitative morphology of the corpus callosum in attention deficit hyperactivity disorder [see comments]. Am J Psychiatry. 1994;151(5):665-9. [pmid: 8166306].
Gilger JW, Pennington BF, DeFries JC. A twin study of the etiology of comorbidity: attention-deficit hyperactivity disorder and dyslexia. J Am Acad Child Adolesc Psychiatry. 1992;31(2):343-8. [pmid: 1564037].
Gillberg C, Carlstrom G, Rasmussen P, et al. Perceptual, motor and attentional deficits in seven-year-old children. Neurological screening aspects. Acta Paediatr Scand. 1983;72(1):119-24. [pmid: 6858674].
Gillberg C, Matousek M, Petersen I, et al. Perceptual, motor and attentional deficits in seven-year-old children. Electroencephalographic aspects. Acta Paedopsychiatr. 1984;50(5):243-53. [pmid: 6393700].
Gillberg C, Rasmussen P. Perceptual, motor and attentional deficits in six-year-old children: screening procedure in pre-school. Acta Paediatr. 1982;71:21-9.
Gillberg C, Rasmussen P, Carlstrom G, et al. Perceptual, motor and attentional deficits in six-year-old children: epidemiological aspects. J Child Psychol Psychiatry. 1982;23(2):131-44. [pmid: 7082448].
Gittelman R, Eskenazi B. Lead and hyperactivity revisited. An investigation of nondisadvantaged children. Arch Gen Psychiatry. 1983;40(8):827-33. [pmid: 6683492].
Glod CA, Teicher MH. Relationship between early abuse, posttraumatic stress disorder, and activity levels in prepubertal children. J Am Acad Child Adolesc Psychiatry. 1996;35(10):1384-93. [pmid: 8885593].
Glow RA, Glow PH, Rump EE. The stability of child behavior disorders: a one year test-retest study of Adelaide versions of the Conners Teacher and Parent Rating Scales. J Abnorm Child Psychol. 1982;10(1):33-60. [pmid: 7108055].
Golden GS. Role of attention deficit hyperactivity disorder in learning disabilities. Semin Neurol. 1991;11(1):35-41. [pmid: 2034916].
Goldman J, Sorensen E, Ward M. Brief child assessment battery to assist with treatment planning and program evaluation. Community Ment Health J. 1995;31(5):437-48. [pmid: 8556851].
Golinko BE. Hyperactivity: operationalization of traits using a structured behavioral interview: a pilot study. J Pediatr Psychol. 1978;3(1):35-44.
Gomez R, Sanson AV. Effects of experimenter and mother presence on the attentional performance and activity of hyperactive boys. J Abnorm Child Psychol. 1994;22(5):517-29. [pmid: 7822626].
Goodyear P, Hynd GW. Attention-deficit disorder with (ADD/H) and without (ADD/WO) hyperactivity: behavioral and neuropsychological differentiation. J Clin Child Psychol. 1992;21(3):273-305.
Gordon M, Mettelman BB. The assessment of attention: I. Standardization and reliability of a behavior-based measure. J Clin Psychol. 1988;44(5):682-90. [pmid: 3192705].
Goyette CH, Conners CK, Ulrich RF. Normative data on Revised Conners Parent and Teacher Rating Scales. J Abnorm Child Psychol. 1978;6(2):221-36. [pmid: 670589].
Grant ML, Ilai D, Nussbaum NL, et al. The relationship between continuous performance tasks and neuropsychological tests in children with attention-deficit hyperactivity disorder. Percept Mot Skills. 1990;70(2):435-45. [pmid: 2342842].
Greenbaum PE, Dedrick RF, Friedman RM, et al. National adolescent and child treatment study (NACTS): outcomes for children with serious emotional and behavioral disturbance. J Emotion Behav Disord. 1996;4(3):130-46.
Greenberg LM, Waldman ID. Developmental normative data on the test of variables of attention (T.O.V.A.). J Child Psychol Psychiatry. 1993;34(6):1019-30. [pmid: 8408366].
Gross-Tsur V, Shalev RS, Manor O, et al. Developmental right-hemisphere syndrome: clinical spectrum of the nonverbal learning disability. J Learn Disabil. 1995;28(2):80-6. [pmid: 7884301].
Hadders-Algra M, Touwen BC. Minor neurological dysfunction is more closely related to learning difficulties than to behavioral problems. J Learn Disabil. 1992;25(10):649-57. [pmid: 1460386].
Halperin JM. The clinical assessment of attention. Int J Neurosci. 1991;58(3–4):171-82. [pmid: 1365040].
Halperin JM, Matier K, Bedi G, et al. Specificity of inattention, impulsivity, and hyperactivity to the diagnosis of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1992;31(2):190-6. [pmid: 1564018].
Halperin JM, Newcorn JH, Matier K, et al. Discriminant validity of attention-deficit hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1038-43. [pmid: 8407749].
Halperin JM, Newcorn JH, Sharma V, et al. Inattentive and noninattentive ADHD children: do they constitute a unitary group?. J Abnorm Child Psychol. 1990;18(4):437-49. [pmid: 2246434].
Halperin JM, Sharma V, Siever LJ, et al. Serotonergic function in aggressive and nonaggressive boys with attention deficit hyperactivity disorder. Am J Psychiatry. 1994;151(2):243-8. [pmid: 8296897].
Halperin JM, Wolf LE, Pascualvaca DM, et al. Differential assessment of attention and impulsivity in children. J Am Acad Child Adolesc Psychiatry. 1988;27(3):326-9. [pmid: 3379014].
Harcherik D, Cohen DJ, Ort S, et al. Computed tomographic brain scanning in four neuropsychiatric disorders of childhood. Am J Psychiatry. 1985;142(6):731-4. [pmid: 3859227].
Hare WA, Inverso MJ, Yolton RL. Neuropathology of the hyperkinetic child. J Am Optom Assoc. 1980;51(1):27-30. [pmid: 7410770].
Hart EL, Lahey BB, Loeber R, Hanson KS. Criterion validity of informants in the diagnosis of disruptive behavior disorders in children: a preliminary study. J Consult Clin Psychol. 1994;62(2):410-4. [pmid: 8201081].
Hartsough CS, Lambert NM. Medical factors in hyperactive and normal children: prenatal, developmental, and health history findings. Am J Orthopsychiatry. 1985;55(2):190-201. [pmid: 4039534].
Hasselblad V. Meta-analysis of multi-treatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Hasselblad V, Hedges LV. Meta-analysis of screening and diagnostic tests. Psychol Bull. 1995;117:167-78. [pmid: 7870860].
Hauser P, Zametkin AJ, Martinez P, et al. ADHD and the thyroid controversy [letter]. J Am Acad Child Adolesc Psychiatry. 1994;33(5):756-8. [pmid: 8056740].
Hauser P, Zametkin AJ, Martinez P, et al. Attention deficit-hyperactivity disorder in people with generalized resistance to thyroid hormone [see comments]. N Engl J Med. 1993;328(14):997-1001. [pmid: 8450877].
Hechtman L. Genetic and neurobiological aspects of attention deficit hyperactive disorder: a review. J Psychiatr Neurosci. 1994;19(3):193-201.
Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA. Academic Press. 1985.
Hicks MR, Johansson CB, Heinze AM, et al. Teacher and parent checklist ratings with learning-disabled, hyperactive, and emotionally disturbed children. J Pediatr Psychol. 1981;6(1):43-60. [pmid: 7252714].
Hill JC, Schoener EP. Age-dependent decline of attention deficit hyperactivity disorder. Am J Psychiatry. 1996;153(9):1143-6. [pmid: 8780416].
Hodges K, Saunders WB, Kashani J, et al. Internal consistency of DSM-III diagnoses using the symptom scales of the Child Assessment Schedule. J Am Acad Child Adolesc Psychiatry. 1990;29(4):635-41. [pmid: 2387800].
Holborow P, Berry P. A multinational, cross-cultural perspective on hyperactivity. Am J Orthopsychiatry. 1986;56(2):320-2. [pmid: 3706510].
Holborow PL, Berry PS. Hyperactivity and learning difficulties. J Learn Disabil. 1986;19(7):426-31. [pmid: 3746127].
Holcomb PJ, Ackerman PT, Dykman RA. Cognitive event-related brain potentials in children with attention and reading deficits. Psychophysiology. 1985;22(6):656-67. [pmid: 4089092].
Hole K, Lingjaerde O, Morkrid L, et al. Attention deficit disorders: a study of peptide-containing urinary complexes. J Dev Behav Pediatr. 1988;9(4):205-12. [pmid: 3216000].
Homatidis S, Konstantareas MM. Assessment of hyperactivity: isolating measures of high discriminant ability. J Consult Clin Psychol. 1981;49(4):533-41. [pmid: 7264035].
Horn WF, Wagner AE, Ialongo N. Sex differences in school-aged children with pervasive attention deficit hyperactivity disorder. J Abnorm Child Psychol. 1989;17(1):109-24. [pmid: 2926019].
Hoza B, Pelham WE, Milich R, et al. The self-perceptions and attributions of attention deficit hyperactivity disordered and nonreferred boys. J Abnorm Child Psychol. 1993;21(3):271-86. [pmid: 8335764].
Huessy HR. Comorbidity of attention deficit hyperactivity disorder and other disorders [letter]. Am J Psychiatry. 1992;149(1):148. discussion 149. [pmid: 1728177].
Hynd GW, Hern KL, Novey ES, et al. Attention deficit-hyperactivity disorder and asymmetry of the caudate nucleus. J Child Neurol. 1993;8(4):339-47. [pmid: 8228029].
Hynd GW, Nieves N, Conner RT, et al. Attention deficit disorder with and without hyperactivity: reaction time and speed of cognitive processing. J Learn Disabil. 1989;9(22):573-80. [pmid: 2809410].
Hynd GW, Semrud-Clikeman M, Lorys AR, et al. Brain morphology in developmental dyslexia and attention deficit disorder/hyperactivity. Arch Neurol. 1990;47(8):919-26. [pmid: 2375699].
Hynd GW, Semrud-Clikeman M, Lorys AR, et al. Corpus callosum morphology in attention deficit-hyperactivity disorder: morphometric analysis of MRI. J Learn Disabil. 1991(A);24(3):141-6. [pmid: 2026955].
Jellinek MS, Murphy JM. The recognition of psychosocial disorders in pediatric office practice: the current status of the Pediatric Symptom Checklist. Dev Behav Pediatr. 1990;11(5):273-8.
Jellinek MS, Murphy JM, Burns BJ. Brief psychosocial screening in outpatient pediatric practice. J Pediatr. 1986;109:371-8. [pmid: 3734977].
Jellinek MS, Murphy JM, Robinson J, et al. Pediatric symptom checklist: screening school-age children for psychosocial dysfunction. J Pediatr. 1988;112:201-9. [pmid: 3339501].
Jensen JB, Burke N, Garfinkel BD. Depression and symptoms of attention deficit disorder with hyperactivity. J Am Acad Child Adolesc Psychiatry. 1988;27(6):742-7. [pmid: 3198561].
Jensen PS, Koretz D, Locke BZ, et al. Child and adolescent psychopathology research: problems and prospects for the 1990s. J Abnorm Child Psychol. 1993;21(5):551-80. [pmid: 7507503].
Jensen PS, Salzberg AD, Richters JE, et al. Scales, diagnoses, and child psychopathology: I. CBCL and DISC relationships. J Am Acad Child Adolesc Psychiatry. 1993;32(2):397-406. [pmid: 8444770].
Jensen PS, Shervette RE, Xenakis SN, et al. Anxiety and depressive disorders in attention deficit disorder with hyperactivity: new findings. Am J Psychiatry. 1993;150(8):1203-9. [pmid: 8328565].
Jensen PS, Traylor J, Xenakis SN, et al. Child psychopathology rating scales and interrater agreement: I. Parents’ gender and psychiatric symptoms. J Am Acad Child Adolesc Psychiatry. 1988;27(4):442-50. [pmid: 3182600].
Jensen PS, Watanabe HK, Richters JE, et al. Scales, diagnoses, and child psychopathology: II. Comparing the CBCL and the DISC against external validators. J Abnorm Child Psychol. 1996;24(2):151-68. [pmid: 8743242].
Jensen PS, Xenakis SN, Davis H, et al. Child psychopathology rating scales and interrater agreement: II. Child and family characteristics. J Am Acad Child Adolesc Psychiatry. 1988;27(4):451-61. [pmid: 3182601].
Kahn CA, Kelly PC, Walker WO Jr. Lead screening in children with attention deficit hyperactivity disorder and developmental delay. Clin Pediatr. 1995;34(9):498-501.
Kamphaus RW, Frick PJ, Lahey BB. Methodological issues and learning disabilities diagnosis in clinical populations. J Learn Disabil. 1991;24(10):613-8. [Errata appear in J Learn Disabil 1992;25(7):429 and 1992;25(8):543.]. [pmid: 1783868].
Kanbayashi Y, Nakata Y, Fujii K, et al. ADHD-related behavior among non-referred children: parents’ ratings of DSM-III-R symptoms. Child Psychiatry Hum Dev. 1994;25(1):13-29. [pmid: 7805432].
Kaneko M, Hoshino Y, Hashimoto S, et al. Hypothalamic-pituitary-adrenal axis function in children with attention-deficit hyperactivity disorder. J Autism Dev Disord. 1993;23(1):59-65. [pmid: 8463202].
Kataria S, Hall CW, Wong MM, et al. Learning styles of LD and NLD ADHD children. J Clin Psychol. 1992;48(3):371-8. [pmid: 1602028].
Kelly DP, Aylward GP. Attention deficits in school-aged children and adolescents. Current issues and practice. Pediatr Clin North Am. 1992;39(3):487-512. [pmid: 1574355].
Kemp SL, Kirk U. An investigation of frontal executive dysfunction in attention deficit disorder subgroups. Ann N Y Acad Sci. 1993;682:363-5. [pmid: 8323137].
King C, Young RD. Attentional deficits with and without hyperactivity: teacher and peer perceptions. J Abnorm Child Psychol. 1982;10(4):483-95. [pmid: 7161440].
Klee SH, Garfinkel BD. The computerized continuous performance task: a new measure of inattention. J Abnorm Child Psychol. 1983;11(4):487-95. [pmid: 6689172].
Klorman R. Cognitive event-related potentials in attention deficit disorder. J Learn Disabil. 1991;24(3):130-40. [pmid: 2026954].
Kobak KA. Computer-administered symptom rating scales. Psychiatr Serv. 1996;47(4):367-9. [pmid: 8689365].
Kobak KA, Greist JH, Jefferson JW, et al. Computer-administered clinical rating scales: a review. Psychopharmacology. 1996;127:291-301. [pmid: 8923563].
Kolko DJ. Daily ratings on a child psychiatric unit: psychometric evaluation of the child behavior rating form. J Am Acad Child Adolesc Psychiatry. 1988;27(1):126-32. [Erratum appears in J Am Acad Child Adolesc Psychiatry 1989;28(1):144.]. [pmid: 3343197].
Koriath U, Gualtieri T, Van Bourgondien ME, et al. Construct validity of clinical diagnosis in pediatric psychiatry: relationship among measures. J Am Acad Child Psychiatry. 1985;24(4):429-36. [pmid: 4019970].
Korkman M, Hilakivi-Clarke LA, Autti-Ramo I, et al. Cognitive impairments at two years of age after prenatal alcohol exposure or perinatal asphyxia. Neuropediatrics. 1994;25(2):101-5. [pmid: 8072673].
Korkman M, Peltomaa K. A pattern of test findings predicting attention problems at school. J Abnorm Child Psychol. 1991;19(4):451-67. [pmid: 1721930].
Korkman M, Pesonen AE. A comparison of neuropsychological test profiles of children with attention deficit-hyperactivity disorder and/or learning disorder. J Learn Disabil. 1994;27(6):383-92. [pmid: 8051511].
Krug SE, editor. Psychware Sourcebook. 4th edition. Champaign, IN. Metritech. 1993.
Kuehne C, Kehle TJ, McMahon W. Differences between children with attention deficit disorder, children with specific learning disabilities, and normal children. J Sch Psychol. 1987;25(2):161-6.
Kuperman S, Johnson B, Arndt S, et al. Quantitative EEG differences in a nonclinical sample of children with ADHD and undifferentiated ADD. J Am Acad Child Adolesc Psychiatry. 1996;35(8):1009-17. [pmid: 8755797].
Kupietz SS. Sustained attention in normal and in reading-disabled youngsters with and without ADDH. J Abnorm Child Psychol. 1990;18(4):357-72. [pmid: 2246429].
Lahat E, Avital E, Barr J, et al. BAEP studies in children with attention deficit disorder. Dev Med Child Neurol. 1995;37(2):119-23. [pmid: 7851667].
Lahey BB, Green KD, Forehand R. On the independence of ratings of hyperactivity, conduct problems, and attention deficits in children: a multiple regression analysis. J Consult Clin Psychol. 1980;48(5):566-74. [pmid: 7410655].
Lahey BB, Loeber R, Stouthamer-Loeber M, et al. Comparison of DSM-III and DSM-III-R diagnoses for prepubertal children: changes in prevalence and validity. J Am Acad Child Adolesc Psychiatry. 1990;29(4):620-6. [pmid: 2387798].
Lahey BB, Pelham WE, Schaughency EA, et al. Dimensions and types of attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1988;27(3):330-5. [pmid: 3379015].
Lahey BB, Schaughency EA, Frame CL, et al. Teacher ratings of attention problems in children experimentally classified as exhibiting attention deficit disorder with and without hyperactivity. J Am Acad Child Psychiatry. 1985;24(5):613-6. [pmid: 4045062].
Lahey BB, Schaughency EA, Hynd GW, et al. Attention deficit disorder with and without hyperactivity: comparison of behavioral characteristics of clinic-referred children. J Am Acad Child Adolesc Psychiatry. 1987;26(5):718-23. [pmid: 3667501].
LaHoste GJ, Swanson JM, Wigal SB, et al. Dopamine D4 receptor gene polymorphism is associated with attention deficit hyperactivity disorder. Mol Psychiatry. 1996;1:121-4. [pmid: 9118321].
Lam CM, Beale IL. Relationship between the delay task and rating scale measures of inattention and hyperactivity. J Abnorm Child Psychol. 1989;17(6):625-31. [pmid: 2607054].
Lambert NM, Hartsough CS. Contribution of predispositional factors to the diagnosis of hyperactivity. Am J Orthopsychiatry. 1984;54(1):97-109. [pmid: 6703027].
Lambert NM, Hartsough CS. The measurement of attention deficit disorder with behavior ratings of parents. Am J Orthopsychiatry. 1987;57(3):361-70. [pmid: 3618734].
Lambert N, Hartsough C, Sandoval J. Manual for the children’s attention and adjustment survey. Circle Pines, MN. American Guidance Services, Inc. 1990:37.
Lambert NM, Hartsough CS, Sassone D, et al. Persistence of hyperactivity symptoms from childhood to adolescence and associated outcomes. Am J Orthopsychiatry. 1987;57(1):22-32. [pmid: 3826314].
Lambert NM, Sandoval J, Sassone D. Prevalence of hyperactivity in elementary school children as a function of social system definers. Am J Orthopsychiatry. 1978;48(3):446-63. [pmid: 307912].
Landau S, Milich R, Widiger TA. Conditional probabilities of child interview symptoms in the diagnosis of attention deficit disorder. J Child Psychol Psychiatry. 1991;32(3):501-13. [pmid: 2061369].
Landman GB, McCrindle B. Pediatric management of nonpervasively “hyperactive” children. Clin Pediatr. 1986;25(12):600-4.
Last CG, Hersen M, Kazdin A, et al. Anxiety disorders in children and their families. Arch Gen Psychiatry. 1991;48(10):928-34. [pmid: 1929763].
Leaf PJ, Alegria M, Cohen P, et al. Mental health service use in the community and schools: Results from the four-community MECA study. JAm Acad Child Adolesc Psychiatry. 1996;35(7):889-97. [pmid: 8768348].
Leo RJ, Khin NA, Cohen GN. ADHD and thyroid dysfunction [letter]. JAm Acad Child Adolesc Psychiatry. 1996;35(12):1572-3. [pmid: 8973061].
Leung PW, Connolly KJ. Attentional difficulties in hyperactive and conduct-disordered children: a processing deficit. J Child Psychol Psychiatry. 1994;35(7):1229-45. [pmid: 7806607].
Leung PW, Connolly KJ. Distractibility in hyperactive and conduct-disordered children. J Child Psychol Psychiatry. 1996;37(3):305-12. [pmid: 8707913].
Leung PW, Luk SL, Ho TP, et al. The diagnosis and prevalence of hyperactivity in Chinese schoolboys. Br J Psychiatry. 1996;168(4):486-96. [pmid: 8730946].
Levine MD. The high prevalence-low severity developmental disorders of schoolchildren. Adv Pediatr. 1982;29:529-54.
Levine MI. Psychiatric problems of children: the pediatrician in diagnosis and treatment. Pediatric Ann. 1995;14(5):359-68.
Levinson HN. The diagnostic value of cerebellar-vestibular tests in detecting learning disabilities, dyslexia, and attention deficit disorder. Percept Mot Skills. 1990;71(1):67-82. [pmid: 2235277].
Leviton A, Bellinger D, Allred E. The Boston Teacher Questionnaire. 3. A reassessment [see comments]. J Child Neurol. 1993;8(1):64-72. [pmid: 8445173].
Leviton A, Guild-Wilson M, Neff RK, et al. The Boston Teacher Questionnaire. 1. Definition of syndromes [see comments]. J Child Neurol. 1993;8(1):43-53. [pmid: 8445171].
Levy F, Hay D, McLaughlin M, et al. Twin sibling differences in parental reports of ADHD, speech, reading and behaviour problems. J Child Psychol Psychiatry. 1996;37(5):569-78. [pmid: 8807437].
Levy F, Hobbes G. The diagnosis of attention deficit disorder (hyperkinesis) in children. J Am Acad Child Psychiatry. 1981;20(2):376-84. [pmid: 7264109].
Levy F, Ward PB. Neurometrics, dynamic brain imaging and attention deficit hyperactivity disorder. J Paediatr Child Health. 1995;31:279-83. [pmid: 7576882].
Li X, Su L, Townes BD, et al. Diagnosis of attention deficit disorder with hyperactivity in Chinese boys. J Am Acad Child Adolesc Psychiatry. 1989;28(4):497-500. [pmid: 2768142].
Lindgren S, Wolraich M, Stromquist A, et al. Diagnosis of attention deficit hyperactivity disorder by primary care physicians. Paper presented at the Mental Health Services for Children and Adolescents in Primary Care Settings: A Research Conference. New Haven, CT. 1989.
Livingston RL, Dykman RA, Ackerman PT. The frequency and significance of additional self-reported psychiatric diagnoses in children with attention deficit disorder. J Abnorm Child Psychol. 1990;18(5):465-78. [pmid: 2266220].
Loeber R, Green S, Keenan K, et al. Which boys will fare worse? Early predictors of the onset of conduct disorder in a six-year longitudinal study. J Am Acad Child Adolesc Psychiatry. 1995;34(4):499-509. [pmid: 7751264].
Loeber R, Green SM, Lahey BB, et al. Differences and similarities between children, mothers, and teachers as informants on disruptive child behavior. J Abnorm Child Psychol. 1991;19(1):75-95. [pmid: 2030249].
Loge DV, Staton D, Beatty WW. Performance of children with ADHD on tests sensitive to frontal lobe dysfunction. J Am Acad Child Adolesc Psychiatry. 1990;29(4):540-5. [pmid: 2387788].
Loney J, Milich R. Hyperactivity, inattention, and aggression in clinical practice. Adv Dev Behav Pediatr. 1982;3:113-47.
Lovejoy MC, Rasmussen NH. The validity of vigilance tasks in differential diagnosis of children referred for attention and learning problems. J Abnorm Child Psychol. 1990;18(6):671-81. [pmid: 2074345].
Lubar JF. Discourse on the development of EEG diagnostics and biofeedback for attention-deficit/hyperactivity disorders. Biofeedback Self Regul. 1991;16(3):201-25. [pmid: 1932259].
Lubow RE, Josman ZE. Latent inhibition deficits in hyperactive children. J Child Psychol Psychiatry. 1993;34(6):959-73. [pmid: 8408378].
Lufi D, Cohen A, Parish-Plass J. Identifying attention deficit hyperactive disorder with the WISC-R and the Stroop color and word test. Psychol Sch. Jan. 1990;27(1):28-34.
Luk SL, Leung PW. Conners’ Teacher Rating Scale--a validity study in Hong Kong. J Child Psychol Psychiatry. 1989;30(5):785-93. [pmid: 2793964].
Luk SL, Leung PWL, Lee PLM. Conners’ Teacher Rating Scale in Chinese children in Hong Kong. J Child Psychol Psychiatry. 1988;29(2):165-74. [pmid: 3372613].
Lyoo IK, Noam GG, Lee CK, et al. The corpus callosum and lateral ventricles in children with attention-deficit hyperactivity disorder: a brain magnetic resonance imaging study. Biol Psychiatry. 1996;40:1060-3. [pmid: 8915567].
MacDonald VM, Achenbach TM. Attention problems versus conduct problems as six-year predictors of problem scores in a national sample. J Am Acad Child Adolesc Psychiatry. 1996;35(9):1237-46. [pmid: 8824067].
Mann CA, Lubar JF, Zimmerman AW, et al. Quantitative analysis of EEG in boys with attention-deficit-hyperactivity disorder: controlled study with clinical implications. Pediatr Neurol. 1992;8(1):30-6. [pmid: 1558573].
Mann EM, Ikeda Y, Mueller CW, et al. Cross-cultural differences in rating hyperactive-disruptive behaviors in children [see comments]. Am J Psychiatry. 1992;149(11):1539-42. [pmid: 1415822].
Mantzicopoulos PY, Morrison D. A comparison of boys and girls with attention problems: kindergarten through second grade. Am J Orthopsychiatry. 1994;64(4):522-33. [pmid: 7847568].
Margalit M. Cultural differences in the hyperactive syndrome rated in the Conners Abbreviated Scale. J Learn Disabil. 981;14(6):330-1.
Margalit M. Diagnostic application of the Conners abbreviated symptom questionnaire. J Clin Child Psychol. 1983;12(3):355-7.
Martin CS, Earleywine M, Blackson TC, et al. Aggressivity, inattention, hyperactivity, and impulsivity in boys at high and low risk for substance abuse. J Abnorm Child Psychol. 1994;22(2):177-203. [pmid: 8064028].
Matsuura M, Okubo Y, Toru M, et al. A cross-national EEG study of children with emotional and behavioral problems: a WHO collaborative study in the Western Pacific Region. Biol Psychiatry. 1993;34(1–2):59-65. [pmid: 8373939].
Mattison RE, Bagnato SJ, Strickler E. Diagnostic importance of combined parent and teacher ratings on the Revised Behavior Problem Checklist. J Abnorm Child Psychol. 1987;15(4):617-28. [pmid: 3437095].
McArdle P, O’Brien G, Kolvin I. Hyperactivity: prevalence and relationship with conduct disorder. J Child Psychol Psychiatry. 1995;36(2):279-303. [pmid: 7759591].
McCarney SB. The attention deficit disorders evaluation scale. 2nd ed. [home version technical manual]. Columbia, MO. Hawthorne Educational Services, Inc. 1995a:11-12. 17.
McCamey SB. The attention deficit disorders evaluation scale. 2nd ed. [school version technical manual]. Columbia, MO. Hawthorne Educational Services, Inc. 1995b:12. 14. 18.
McClellan JM, Rubert MP, Reichler RJ, et al. Attention deficit disorder in children at risk for anxiety and depression. J Am Acad Child Adolesc Psychiatry. 1990;29(4):534-9. [pmid: 2387787].
McClure FD, Gordon M. Performance of disturbed hyperactive and nonhyperactive children on an objective measure of hyperactivity. J Abnorm Child Psychol. 1984;12(4):561-71. [pmid: 6491062].
McConaughy SH, Achenbach TM. Comorbidity of empirically based syndromes in matched general population and clinical samples. J Child Psychol Psychiatry. 1994;35(6):1141-57. [pmid: 7995848].
McDermott PA. A nationwide study of developmental and gender prevalence for psychopathology in childhood and adolescence. J Abnorm Child Psychol. 1996;24(1):53-66. [pmid: 8833028].
McDermott PA. National standardization of uniform multisituational measures of child and adolescent behavior pathology. Psychol Assess. 1993;5(4):413-24.
McGee R, Birkbeck J, Silva PA. Physical development of hyperactive boys. Dev Med Child Neurol. 1985;27(3):364-8. [pmid: 4018430].
McGee R, Stanton WR, Sears MR. Allergic disorders and attention deficit disorder in children. J Abnorm Child Psychol. 1993;21(1):79-88. [pmid: 8463506].
McGee R, Williams S, Anderson J, et al. Hyperactivity and serum and hair zinc levels in 11-year-old children from the general population. Biol Psychiatry. 1990;28:165-8. [pmid: 2378920].
McGee R, Williams S, Silva PA. A comparison of girls and boys with teacher-identified problems of attention. J Am Acad Child Adolesc Psychiatry. 1987;26(5):711-7. [pmid: 3667500].
McGee R, Williams S, Silva PA. Factor structure and correlates of ratings of inattention, hyperactivity, and antisocial behavior in a large sample of 9-year-old children from the general population. J Consult Clin Psychol. 1985;53(4):480-90. [pmid: 4031203].
McIntosh DE, Mulkins RS, Dean RS. Utilization of maternal perinatal risk indicators in the differential diagnosis of ADHD and UADD children. Int J Neurosci. 1995;81(1–2):35-46. [pmid: 7775071].
Meller WH, Yates WR. Hyperactivity in children: changing diagnostic criteria. Am Fam Physician. 1988;37(3):129-32. [pmid: 3348114].
Merenda PF. BASC: Behavior Assessment System for Children. Measurement Eval Counsel Devel. 1996;28:229-32.
Merry SN, Andrews LK. Psychiatric status of sexually abused children 12 months after disclosure of abuse. JAm Acad Child Adolesc Psychiatry. 1994;33(7):939-44. [pmid: 7961348].
Mick E, Biederman J, Faraone SV. Is season of birth a risk factor for attention-deficit hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1470-6. [pmid: 8936913].
Milberger S, Biederman J, Faraone SV, et al. Attention deficit hyperactivity disorder and comorbid disorders: issues of overlapping symptoms. Am J Psychiatry. 1995;152(12):1793-9. [pmid: 8526248].
Milich R, Landau S. Teacher ratings of inattention/overactivity and aggression: cross-validation with classroom observations. J Clin Child Psychol. 1988;17(1):92-7.
Milich R, Pelham WE, Hinshaw SP. Issues in the diagnosis of attention deficit disorder: a cautionary note on the Gordon Diagnostic System. Psychopharmacol Bull. 1986;22(4):1101-4. [pmid: 3809377].
Milich R, Roberts MA, Loney J, et al. Differentiating practice effects and statistical regression on the Conners Hyperkinesis Index. J Abnorm Child Psychol. 1980;8(4):549-52. [pmid: 7462532].
Milich R, Widiger TA, Landau S. Differential diagnosis of attention deficit and conduct disorders using conditional probabilities. Special issue: eating disorders. J Consult Clin Psychol. 1987;55(5):762-7. [pmid: 3454788].
Minder B, Das-Smaal EA, Brand EF, et al. Exposure to lead and specific attentional problems in schoolchildren. J Learn Disabil. 1994;27(6):393-9. [pmid: 7519655].
Mintz LI, Collins BE. Qualitative influence on the perception of movement: an experimental study. J Abnorm Child Psychol. 1985;13(1):143-53. [pmid: 3973248].
Mirsky AF, Anthony BJ, Duncan CC, et al. Analysis of the elements of attention: a neuropsychological approach. Neuropsychol Rev. 1991;2(2):109-45. [pmid: 1844706].
Mitchell WG, Chavez JM, Baker SA, et al. Reaction time, impulsivity, and attention in hyperactive children and controls: a video game technique. J Child Neurol. 1990;5(3):195-204. [pmid: 2398235].
Morgan AE, Hynd GW, Riccio CA, et al. Validity of DSM-IV ADHD predominantly inattentive and combined types: relationship to previous DSM diagnoses/subtype differences. J Am Acad Child Adolesc Psychiatry. 1996;35(3):325-33. [pmid: 8714321].
Moser SE, Kallail KJ. Attention-deficit hyperactivity disorder: management by family physicians. Arch Fam Med. 1995;4:241-4. [pmid: 7881606].
Mulhern S, Dworkin PH, Bernstein B. Do parental concerns predict a diagnosis of attention-deficit hyperactivity disorder?. J Dev Behav Pediatr. 1994;15(5):348-52. [pmid: 7868703].
Munoz-Millan RJ, Casteel CR. Attention-deficit hyperactivity disorder: recent literature. Hosp Community Psychiatry. 1989;40(7):699-707. [pmid: 2673976].
Murphy JM, Reede J, Jellinek MS, et al. Screening for psychosocial dysfunction in inner-city children: further validation of the Pediatric Symptom Checklist. J Am Acad Child Adolesc Psychiatry. 1992;31(6):1105-11. [pmid: 1429413].
Murphy-Berman V, Rosell J. Measuring children’s attention span: a microcomputer assessment technique. J Educ Res. 1986;80(1):23-28.
Naglieri JA, Flanagan DP. A psychometric review of behavior-rating scales. Compreh Mental Health Care. 1992;2(3):225-39.
Naglieri JA, Gottling SH. Use of the Teacher Report Form and the Devereux Behavior Rating Scale-School Form with learning disordered/emotionally disordered students. J Clin Child Psychol. 1995;24(1):71-6.
Naglieri JA, LeBuffe PA, Pfeiffer SI. Devereux scales of mental disorders [manual]. San Antonio. Harcourt Brace & Co. 1994:70. 79.
National Institute of Mental Health. NIMH Research Conference. Research recommendations for anxiety disorders and ADHD. JAm Acad Child Adolesc Psychiatry. 1993;32(5):1099-101.
Newcorn JH, Halperin JM. Comorbidity among disruptive behavior disorders. Child Adolesc Psychiatr Clin North Am. 1994;3(2):227-52.
Newcorn JH, Halperin JM, Healey JM, et al. Are ADDH and ADHD the same or different?. J Am Acad Child Adolesc Psychiatry. 1989;28(5):734-8. [pmid: 2793801].
Newcorn JH, Halperin JM, Schwartz S, et al. Parent and teacher ratings of attention-deficit hyperactivity disorder symptoms: implications for case identification. J Dev Behav Pediatr. 1994;15(2):86-91. [pmid: 8034772].
Newton JE, Oglesby DM, Ackerman PT, et al. Visual slow brain potentials in children with attention deficit disorder. Integr Physiol Behav Sci. 1994;29(1):39-54. [pmid: 8018551].
Nussbaum NL, Grant ML, Roman MJ, et al. Attention deficit disorder and the mediating effect of age on academic and behavioral variables. J Dev Behav Pediatr. 1990;11(1):22-6. [pmid: 2303554].
O’Brien JD, Halperin JM, Newcorn JH, et al. Psychometric differentiation of conduct disorder and attention deficit disorder with hyperactivity. J Dev Behav Pediatr. 1992;13(4):274-7. [pmid: 1506466].
O’Connell KL. Attention deficit hyperactivity disorder. Pediatr Nurs. 1996;22(1):30-3. [pmid: 8700622].
Oades RD, Dittmann-Balcar A, Schepker R, et al. Auditory event-related potentials (ERPs) and mismatch negativity (MMN) in healthy children and those with attention-deficit or Tourette/tic symptoms. Biol Psychol. 1996;12;43(2):163-85.
Offord DR. Child psychiatric disorders: prevalence and perspectives. Psychiatr Clin North Am. 1985;8(4):637-52. [pmid: 3878505].
Offord DR, Boyle MH, Szatmari P, et al. Ontario child health study: II. Six-month prevalence of disorder and rates of service utilization. Arch Gen Psychiatry. 1987;44:832-6. [pmid: 3498458].
Palfrey JS, Levine MD, Walker DK, et al. The emergence of attention deficits in early childhood: a prospective study. J Dev Behav Pediatr. 1985;6(6):339-48. [pmid: 4077993].
Pantle ML, Ebner DL, Hynan LS. The Rorschach and the assessment of impulsivity. J Clin Psychol. 1994;50(4):633-8. [pmid: 7983214].
Pauls DL, Leckman JF, Cohen DJ. Familial relationship between Gilles de la Tourette’s syndrome, attention deficit disorder, learning disabilities, speech disorders, and stuttering. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1044-50. [pmid: 8407750].
Pearson DA, Aman MG. Ratings of hyperactivity and developmental indices: should clinicians correct for developmental level?. J Autism Dev Disord. 1994;24(4):395-411. [pmid: 7525533].
Pelham WE Jr, Gnagy EM, Greenslade KE, et al. Teacher ratings of DSM-III-R symptoms for the disruptive behavior disorders. J Am Acad Child Adolesc Psychiatry. 1992;31(2):210-8. [Erratum appears in J Am Acad Child Adolesc Psychiatry 1992;31(6): 1177.]. [pmid: 1564021].
Pelham WE, Milich R, Murphy DA, et al. Normative data on the Iowa Conners teacher rating scale. J Clin Child Psychol. 1989;18(3):259-62.
Pennington BF, Ozonoff S. Executive functions and developmental psychopathology. J Child Psychol Psychiatry. 1996;37(1):51-87. [pmid: 8655658].
Perrin S, Last CG. Do childhood anxiety measures measure anxiety?. J Abnorm Child Psychol. 1992;20(6):567-78. [pmid: 1487597].
Phelps L. Discriminative validity of the WRAML with ADHD and LD children. Psychol Sch. 1996;33(1):5-12.
Pinto LP, Tryon WW. Activity measurements support dimensional assessment. Behav Modif. 1996;20(3):243-58. [pmid: 8768507].
Pisecco S, Baker DB, Silva PA, et al. Behavioral distinctions in children with reading disabilities and/or ADHD. J Am Acad Child Adolesc Psychiatry. 1996;35(11):1477-84. [pmid: 8936914].
Pliszka SR. Comorbidity of attention-deficit hyperactivity disorder and overanxious disorder. J Am Acad Child Adolesc Psychiatry. 1992;31(2):197-203. [pmid: 1564019].
Pliszka SR, Maas JW, Javors MA, et al. Urinary catecholamines in attention-deficit hyperactivity disorder with and without comorbid anxiety. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1165-73. [pmid: 7982867].
Plomin R, Foch JJ. Hyperactivity and pediatrician diagnoses, parental ratings, specific cognitive abilities, and laboratory measures. J Abnorm Child Psychol. 1981;9(1):55-64. [pmid: 7217538].
Power TJ. Contextual factors in vigilance testing of children with ADHD. J Abnorm Child Psychol. 1992;20(6):579-93. [pmid: 1487598].
Power TJ, Ikeda MJ. Commentary: the clinical utility of behavior rating scales: comments on the diagnostic assessment of ADHD. J Sch Psychol. 1996;34(4):379-85.
Prendergast M, Taylor E, Rapoport JL, et al. The diagnosis of childhood hyperactivity. A U.S.-U.K. cross-national study of DSM-III and ICD-9. J Child Psychol Psychiatry. 1988;29(3):289-300. [pmid: 3417805].
Rao GP. Developmental dyslexia and hyperkinetic behaviour syndrome. Indian J Pediatr. 1981;48(392):323-6. [pmid: 7319599].
Rapport MD, DuPaul GJ, Stoner G, et al. Comparing classroom and clinic measures of attention deficit disorder: differential, idiosyncratic, and dose-response effects of methylphenidate. J Consult Clin Psychol. 1986;54(3):334-41. [pmid: 3522683].
Reatig N. Bibliography on rating and assessment instruments for attention deficit disorder (ADD) (years covered: 1976–1984). Psychopharmacol Bull. 1985;21:929-30. [pmid: 3911251].
Reeves JC, Werry JS, Elkind GS, et al. Attention deficit, conduct, oppositional, and anxiety disorders in children: II. Clinical characteristics. J Am Acad Child Adolesc Psychiatry. 1987;26(2):144-55. [pmid: 3584010].
Reid R, Maag JW. How many fidgets in a pretty much: a critique of behavior rating scales for identifying students with ADHD. J Sch Psychol. 1994;32(4):339-54.
Reiff MI, Banez GA, Culbert TP. Children who have attentional disorders: diagnosis and evaluation. Pediatr Rev. 1993;14(12):455-65. [pmid: 8115282].
Reynolds CR, Kamphaus RW. BASC, behavioral assessment system for children [manual]. Circle Pines, MN. American Guidance Services, Inc. 105. 1992:102-106. 125. 150.
Riccio CA, Cohen MJ, Hynd GW, et al. Validity of the Auditory Continuous Performance Test in differentiating central processing auditory disorders with and without ADHD. J Learn Disabil. 1996;29(5):561-6. [pmid: 8870525].
Richters JE, Arnold LE, Jensen PS, et al. NIMH collaborative multisite multimodal treatment study of children with ADHD: I. Background and rationale. J Am Acad Adolesc Psychiatry. 1995;34(8):987-1000.
Robaey P, Breton F, Dugas M, et al. An event-related potential study of controlled and automatic processes in 6–8-year-old boys with attention deficit hyperactivity disorder. Electroencephalogr Clin Neurophysiol. 1992;82(5):330-40. [pmid: 1374702].
Robins PM. A comparison of behavioral and attentional functioning in children diagnosed as hyperactive or learning-disabled. J Abnorm Child Psychol. 1992;20(1):65-82. [pmid: 1548395].
Rogeness GA, Maas JW, Javors MA, et al. Attention deficit disorder symptoms and urine catecholamines. Psychiatry Res. 1989;27(3):241-51. [pmid: 2469096].
Rosenberg LA, Harris JC, Singer HS. Relationship of the Child Behavior Checklist to an independent measure of psychopathology. Psychol Rep. 1984;54:427-30. [pmid: 6588402].
Ross RG, Hommer D, Breiger D, et al. Eye movement task related to frontal lobe functioning in children with attention deficit disorder. J Am Acad Child Adolesc Psychiatry. 1994;33(6):869-74. [pmid: 8083144].
Rovet J, Alvarez M. Thyroid hormone and attention in school-age children with congenital hypothyroidism. J Child Psychol Psychiatry. 1996;37(5):579-85. [pmid: 8807438].
Rubio-Stipek M, Shrout PE, Canino G, et al. Empirically defined symptom scales using the DISC 2.3. J Abnorm Child Psychol. 1996;24(1):67-83. [pmid: 8833029].
Russo MF, Beidel DC. Comorbidity of childhood anxiety and externalizing disorders: prevalence, associated characteristics, and validation issues. Clin Psychol Rev. 1994;14(3):199-221.
Rutter M, Sandberg S. Epidemiology of child psychiatric disorder: methodological issues and some substantive findings. Child Psychiatry Hum Dev. 1985;15(4):209-33. [pmid: 3899538].
Safer DJ, Zito JM, Fine EM. Increased methylphenidate usage for attention deficit disorder in the 1990s. Pediatrics. 1996;98(6 Pt 1):1084-8. [pmid: 8951257].
Sandberg S. Hyperkinetic or attention deficit disorder. Br J Psychiatry. 1996;169(1):10-7. [pmid: 8818362].
Sandberg ST, Wieselberg M, Shaffer D. Hyperkinetic and conduct problem children in a primary school population: some epidemiological considerations. J Child Psychol Psychiatry. 1980;21:293-311. [pmid: 7419639].
Sandler AD, Hooper SR, Watson TE, et al. Talkative children: verbal fluency as a marker for problematic peer relationships in clinic-referred children with attention deficits. Percept Mot Skills. 1993;76:943-51. [pmid: 8321611].
Sandoval J, Echandia A. Behavior assessment system for children. J Sch Psychol. 1994;32(4):419-25.
Sanson A, Smart D, Prior M, et al. Precursors of hyperactivity and aggression. J Am Acad Child Adolesc Psychiatry. 1993;32(6):1207-16. [pmid: 8282666].
Satin MS, Winsberg BG, Monetti CH, et al. A general population screen for attention deficit disorder with hyperactivity. J Am Acad Child Psychiatry. 1985;24(6):756-64. [pmid: 4067144].
Satterfield JH, Schell AM, Nicholas TW, et al. Ontogeny of selective attention effects on event-related potentials in attention-deficit hyperactivity disorder and normal boys. Biol Psychiatry. 1990;28(10):879-903. [pmid: 2268691].
Scerbo AS, Kolko DJ. Salivary testosterone and cortisol in disruptive children: relationship to aggressive, hyperactive, and internalizing behaviors [see comments]. J Am Acad Child Adolesc Psychiatry. 1994;33(8):1174-84. [pmid: 7982868].
Schachar R. Childhood hyperactivity. J Child Psychol Psychiatry. 1991;32(1):155-91. [pmid: 2037644].
Schachar R, Sandberg S, Rutter M. Agreement between teachers’ ratings and observations of hyperactivity, inattentiveness, and defiance. J Abnorm Child Psychol. 1986;14(2):331-45. [pmid: 3722627].
Schachar R, Tannock R. Test of four hypotheses for the comorbidity of attention-deficit hyperactivity disorder and conduct disorder. J Am Acad Child Adolesc Psychiatry. 1995;34(5):639-48. [pmid: 7775359].
Schechter MD, Timmons GD. Objectively measured hyperactivity. I. Comparison with normal controls. J Clin Pharmacol. 1985;25(4):269-75. [pmid: 4008671].
Schroeder SR, Milar C, Wool R, et al. Multiple measurement, transsituational diagnosis, and the concept of generalized overactivity. J Pediatr Psychol. 1980;5(4):365-75. [pmid: 7463265].
Schwab-Stone M, Fallon T, Briggs M, et al. Reliability of diagnostic reporting for children aged 6–11 years: a test-retest study of the Diagnostic Interview Schedule for Children-Revised. Am J Psychiatry. 1994;151(7):1048-54. [pmid: 8010363].
Schwab-Stone M, Fisher P, Piacentini J, et al. The Diagnostic Interview Schedule for Children-Revised Version (DISC-R). II. Test-retest reliability. J Am Acad Child Adolesc Psychiatry. 1993;32(3):651-7. [pmid: 8496129].
Schwab-Stone ME, Shaffer D, Dulcan MK, et al. Criterion validity of the NIMH diagnostic interview schedule for children version 2.3 (DISC-2.3). J Am Acad Child Adolesc Psychiatry. 1996;35(7):878-88. [pmid: 8768347].
Searight HR, Nahlik JE, Campbell DC. Attention-deficit/hyperactivity disorder: assessment, diagnosis, and management. J Fam Pract. 1995;40(3):270-9. [pmid: 7876785].
Seidel WT, Joschko M. Assessment of attention in children. Clin Neuropsychologist. 1991;5(1):53-66.
Seidel WT, Joschko M. Evidence of difficulties in sustained attention in children with ADDH. J Abnorm Child Psychol. 1990;18(2):217-29. [pmid: 2348033].
Semrud-Clikeman M, Biederman J, Sprich-Buckminster S, et al. Comorbidity between ADDH and learning disability: a review and report in a clinically referred sample. J Am Acad Child Adolesc Psychiatry. 1992;31(3):439-48. [pmid: 1592775].
Semrud-Clikeman M, Filipek PA, Biederman J, et al. Attention-deficit hyperactivity disorder: magnetic resonance imaging morphometric analysis of the corpus callosum. J Am Acad Child Adolesc Psychiatry. 1994;33(6):875-81. [pmid: 8083145].
Semrud-Clikeman M, Hynd GW, Lorys AR, et al. Differential diagnosis of children with ADHD and ADHD/with co-occurring conduct disorder. Sch Psychol Intl. 1993;14(4):361-70.
Shaffer D, Fisher P, Dulcan MK, et al. The NIMH diagnostic interview schedule for children version 2.3 (DISC 2.3): description, acceptability, prevalence rates, and performance in the MECA study. J Am Acad Child Adolesc Psychiatry. 1996;35(7):865-77. [pmid: 8768346].
Shapiro SK, Garfinkel HD. The occurrence of behavior disorders in children: the interdependence of attention deficit disorder and conduct disorder. J Am Acad Child Psychiatry. 1986;25(6):809-19. [pmid: 3491846].
Sharma V, Halperin JH, Newcorn JN, et al. The dimension of focussed attention: relationship to behavior and cognitive functioning in children. Percept Mot Skills. 1991;72(3,1):787-93. [pmid: 1891315].
Shaywitz SE, Schnell C, Shaywitz BA, et al. Yale Children’s Inventory (YCI): an instrument to assess children with attentional deficits and learning disabilities. I. Scale development and psychometric properties. J Abnorm Child Psychol. 1986;14(3):347-64. [pmid: 3760344].
Shaywitz SE, Shaywitz BA. Attention deficit disorder: current perspectives. Pediatr Neurol. 1987;3(3):129-35. [pmid: 3334012].
Shaywitz BA, Shaywitz SE, Byrne T, et al. Attention deficit disorder: quantitative analysis of CT. Neurology. Nov. 1983;33(11):1500-3. [pmid: 6685244].
Shaywitz SE, Shaywitz BA, Schnell C, et al. Concurrent and predictive validity of the Yale Children’s Inventory: an instrument to assess children with attentional deficits and learning disabilities. Pediatrics. 1988;81(4):562-71. [pmid: 3353191].
Shekim WO, Cantwell DP, Kashani J, et al. Dimensional and categorical approaches to the diagnosis of attention deficit disorder in children. J Am Acad Child Psychiatry. 1986;25(5):653-8. [pmid: 3760414].
Shekim WO, Kashani J, Beck N, et al. The prevalence of attention deficit disorders in a rural midwestern community sample of nine-year-old children. J Am Acad Child Psychiatry. 1985;24(6):765-70. [pmid: 4067145].
Shekim WO, Sinclair E, Glaser R, et al. Norepinephrine and dopamine metabolites and educational variables in boys with attention deficit disorder and hyperactivity. J Child Neurol. 1987;2(1):50-6. [pmid: 3624828].
Shue KL, Douglas VI. Attention deficit hyperactivity disorder and the frontal lobe syndrome. Brain Cogn. 1992;20(1):104-24. [pmid: 1389116].
Silva PA, Hughes P, Williams S, et al. Blood lead, intelligence, reading attainment, and behaviour in eleven year old children in Dunedin, New Zealand. J Child Psychol Psychiatry. 1988;29(1):43-52. [pmid: 3350882].
Silverthorn P, Frick PJ, Kuper K, et al. Attention deficit hyperactivity disorder and sex: a test of two etiological models to explain the male predominance. J Clin Child Psychol. 1996;25(1):52-9.
Sinclair E, Alexson J. Creating diagnostic related groups: a manageable way to deal with DSM-III. Am J Orthopsychiatry. 1985;55(3):426-33. [pmid: 3927742].
Sleator EK, Ullmann RK. Can the physician diagnose hyperactivity in the office?. Pediatrics. 1981;67(1):13-7. [pmid: 7243422].
Solanto MV, Lewitter M. The delayed response task for ADD children. Psychopharmacol Bull. 1987;23(2):283-5. [pmid: 3615776].
Soltys SM, Kashani JH, Dandoy AC, et al. Comorbidity for disruptive behavior disorders in psychiatrically hospitalized children. Child Psychiatry Hum Dev. 1992;23(2):87-98. [pmid: 1490399].
Sonuga-Barke EJ, Houlberg K, Hall M. When is “impulsiveness” not impulsive? The case of hyperactive children’s cognitive style. J Child Psychol Psychiatry. 1994;35(7):1247-53. [pmid: 7806608].
Sonuga-Barke EJ, Lamparelli M, Stevenson J, et al. Behaviour problems and pre-school intellectual attainment: the associations of hyperactivity and conduct problems. J Child Psychol Psychiatry. 1994;35(5):949-60. [pmid: 7962250].
Spencer T, Biederman J, Wilens T, et al. ADHD and thyroid abnormalities: a research note. J Child Psychol Psychiatry. 1995;36(5):879-85. [pmid: 7559851].
Spiel G. Is there a possibility of differentiating between children with minimal cerebral dysfunction by means of computer-assisted automatic EEG analysis?. Adv Biol Psychiatry. 1987;16:171-7.
Sprich-Buckminster S, Biederman J, Milberger S, et al. Are perinatal complications relevant to the manifestation of ADD? Issues of comorbidity and familiality [see comments]. J Am Acad Child Adolesc Psychiatry. 1993;32(5):1032-7. [pmid: 8407748].
Stanford LD, Hynd GW. Congruence of behavioral symptomatology in children with ADD/H, ADD/WO, and learning disabilities. J Learn Disabil. 1994;27(4):243-53. [pmid: 8051505].
Stein MA, O’Donnell JP. Classification of children’s behavior problems: clinical and quantitative approaches. J Abnorm Child Psychol. 1985;13(2):269-79. [pmid: 3159774].
Stein MA, Weiss RE, Refetoff S. Neurocognitive characteristics of individuals with resistance to thyroid hormone: comparisons with individuals with attention-deficit hyperactivity disorder. J Dev Behav Pediatr. 1995;16(6):406-11. [pmid: 8746549].
Steingard R, Biederman J, Doyle A, et al. Psychiatric comorbidity in attention deficit disorder: impact on the interpretation of Child Behavior Checklist results. J Am Acad Child Adolesc Psychiatry. 1992;31(3):449-54. [pmid: 1592776].
Steinhausen HC, Gobel D. Convergence of parent checklists and child psychiatric diagnoses. J Abnorm Child Psychol. 1987;15(1):147-51. [pmid: 3571736].
Stevenson J, Pennington BF, Gilger JW, et al. Hyperactivity and spelling disability: testing for shared genetic aetiology. J Child Psychol Psychiatry. 1993;34(7):1137-52. [pmid: 8245138].
Stoff DM, Pasatiempo AP, Yeung JH, et al. Test-retest reliability of the prolactin and cortisol responses to D,L-fenfluramine challenge in disruptive behavior disorders. Psychiatry Res. 1992;42(1):65-72. [pmid: 1603882].
Strayhorn JM. The case of the uncertain prescriber. J Am Acad Child Adolesc Psychiatry. 1995;34(2):253-4. [pmid: 7896659].
Streissguth AP, Barr HM, Sampson PD, et al. Prenatal alcohol and offspring development: the first fourteen years. Drug Alcohol Depend. 1994;36(2):89-99. [pmid: 7851285].
Sunder TR. Commentary: attention deficit-hyperactivity disorder: reductio ad absurdum. J Child Neurol. 1992;7(4):454-8.
Szatmari P, Boyle M, Offord DR. ADDH and conduct disorder: degree of diagnostic overlap and differences among correlates. J Am Acad Child Adolesc Psychiatry. 1989;28(6):865-72. [pmid: 2478519].
Tarnowski KJ, Prinz RJ, Nay SM. Comparative analysis of attentional deficits in hyperactive and learning-disabled children. J Abnorm Psychol. 1986;95(4):341-5. [pmid: 3805496].
Taylor E, Everitt B, Thorley G, et al. Conduct disorder and hyperactivity: II. A cluster analytic approach to the identification of a behavioural syndrome. Br J Psychiatry. 1986;149:768-77. [pmid: 3790876].
Taylor E, Sandberg S. Hyperactive behavior in English schoolchildren: a questionnaire survey. J Abnorm Child Psychol. 1984;12(1):143-55. [pmid: 6715689].
Taylor E, Schachar R, Thorley G, et al. Conduct disorder and hyperactivity: I. Separation of hyperactivity and antisocial conduct in British child psychiatric patients. Br J Psychiatry. 1986;149:760-7. [pmid: 3790875].
Teicher MH, Ito Y, Glod CA, et al. Objective measurement of hyperactivity and attentional problems in ADHD. J Am Acad Child Adolesc Psychiatry. 1996;35(3):334-42. [pmid: 8714322].
Tharinger DJ, Laurent J, Best LR. Classification of children referred for emotional and behavioral problems: a comparison of PL 94–142 SED criteria, DSM III, and the CBCL system. J Sch Psychol. 1986;24(2):111-21.
Thompson JS, Ross RJ, Horwitz SJ. The role of computed axial tomography in the study of the child with minimal brain dysfunction. J Learn Disabil. 1980;13(6):334-7. [pmid: 7410957].
Thompson RJ Jr, Curry JF. A construct validity study of the Missouri Children’s Behavior Checklist with developmentally disabled children. J Clin Psychol. 1983;39(5):691-5. [pmid: 6195195].
Thompson RW, Nichols GT. Correlations between scores on a continuous performance test and parents’ ratings of attention problems and impulsivity in children. Psychol Rep. 1992;70(3 Pt 1):739-42. [pmid: 1620764].
Thomson GOB, Raab GM, Hepburn WS, et al. Blood-lead levels and children’s behaviour—results from the Edinburgh lead study. J Child Psychol Psychiatry. 1989;30(4):515-28. [pmid: 2768355].
Treiber FA, Mabe PA. Child and parent perceptions of children’s psychopathology in psychiatric outpatient children. J Abnorm Child Psychol. 1987;15(1):115-24. [pmid: 3571734].
Trites RL, Blouin AG, Laprade K. Factor analysis of the Conners Teacher Rating Scale based on a large normative sample. J Consult Clin Psychol. 1982;50(5):615-23. [pmid: 7142537].
Trites RL, Laprade K. Evidence for an independent syndrome of hyperactivity. J Child Psychol Psychiatry. 1983;24(4):573-86. [pmid: 6630330].
Trommer BL, Hoeppner JB, Lorber R, et al. Pitfalls in the use of a continuous performance test as a diagnostic tool in attention deficit disorder [see comments]. J Dev Behav Pediatr. 1988a;9(6):339-45. [pmid: 3220953].
Trommer BL, Hoeppner JA, Lorber R, et al. The go-no-go paradigm in attention deficit disorder. Ann Neurol. 1988b;24(5):610-4. [pmid: 3202613].
Tryon WW. The role of motor excess and instrumented activity measurement in attention deficit hyperactivity disorder. Behav Modif. 1993;17(4):371-406. [pmid: 8216180].
Tuthill RW. Hair lead levels related to children’s classroom attention-deficit behavior. Arch Environ Health. 1996;51:214-20. [pmid: 8687242].
Ucles P, Lorente S. Electrophysiologic measures of delayed maturation in attention-deficit hyperactivity disorder. J Child Neurol. 1996;11(2):155-6. [pmid: 8881992].
Ullmann RK, Sleator EK, Sprague RL. A new rating scale for diagnosis and monitoring of ADD children. Psychopharmacol Bull. 1984a;20(1):160-4. [pmid: 6718641].
Ullmann RK, Sleator EK, Sprague RL. ADD children: who is referred from the schools?. Psychopharmacol Bull. 1984b;20(2):308-12. [pmid: 6728995].
Ullmann RK, Sleator EK, Sprague RL. A change of mind: the Conners abbreviated rating scales reconsidered. J Abnorm Child Psychol. 1985;13(4):553-65. [pmid: 4078186].
Ullmann RK, Sleator EK, Sprague RL. MeriTech Staff. ACTeRS Teacher and parent forms manual. Champaign, IL. MeriTech, Inc. 14. 1997:9-15.
U.S. Department of Health and Human Services, Public Health Service, Health Care Financing Administration. International Classification of Diseases (ICD), 9th revision, Clinical Modification. Fifth edition. DHHS Pub. No. (PHS) 94-1260. 1994.
Valdizan JR, Andreu AC. Test of repeated operations and logistic regression as to the efficacy of brain mapping. Clin Electroencephalogr. 1993;24(2):89-92. [pmid: 8500254].
van der Meere J, Shalev R, Borger N, et al. Sustained attention, activation and MPH in ADHD: a research note. J Child Psychol Psychiatry. 1995;36(4):697-703. [pmid: 7650092].
Verhulst FC, Koot HM, Van der Ende J. Differential predictive value of parents’ and teachers’ reports of children’s problem behaviors: a longitudinal study. J Abnorm Child Psychol. 1994;22(S):531-46. [pmid: 7822627].
Verhulst FC, van der Ende J. “Comorbidity” in an epidemiological sample: a longitudinal perspective”. J Child Psychol Psychiatry. 1993;34(5):767-83. [pmid: 8340444].
Vitiello B, Stoff D, Atkins M, et al. Soft neurological signs and impulsivity in children. J Dev Behav Pediatr. 1990;11(3):112-5. [pmid: 2365831].
Waldman ID, Lilienfeld SO. Diagnostic efficiency of symptoms for oppositional defiant disorder and attention-deficit hyperactivity disorder. J Consult Clin Psychol. 1991;59(5):732-8. [pmid: 1955607].
Waldrop RD. Selection of patients for management of attention deficit hyperactivity disorder in a private practice setting. Clin Pediatr (Phila). 1994;33(2):83-7. [pmid: 8200161].
Wallbrown FH. Shedd’s formulations concerning the hyperkinetic syndrome--an empirical test of selected features. Percept Mot Skills. 1978;46:809-10. [pmid: 673636].
Warren RP, Odell JD, Warren WL, et al. Is decreased blood plasma concentration of the complement C4B protein associated with attention-deficit hyperactivity disorder?. J Am Acad Child Adolesc Psychiatry. 1995;34(8):1009-14. [pmid: 7665439].
Weinberg WA, Emslie GJ. Attention deficit hyperactivity disorder: the differential diagnosis. J Child Neurol. 1991;6(Suppl):S23-S36. [pmid: 2002214].
Weiss RE, Stein MA, Trommer B, et al. Attention-deficit hyperactivity disorder and thyroid function. J Pediatr. 1993;123(4):539-45. [pmid: 8410504].
Werry JS, Elkind GS, Reeves JC. Attention deficit, conduct, oppositional, and anxiety disorders in children: III. Laboratory differences. J Abnorm Child Psychol. 1987;15(3):409-28. [pmid: 3668087].
Werry JS, Hawthorne D. Conners Teacher Questionnaire--norms and validity. Aust N Z J Psychiatry. 1976;10:257-62. [pmid: 1071004].
Werry JS, Scaletti R, Mills F. Sensory integration and teacher-judged learning problems: a controlled intervention trial. J Paediatr Child Health. 1990;26(1):31-5. [pmid: 2184874].
Weyandt LL, Willis WG. Executive functions in school-aged children: potential efficacy of tasks in discriminating clinical groups. Devel Neuropsychol. 1994;10(1):27-38.
Whalen CK, Henker B, Hinshaw SP, et al. Externalizing behavior disorders, situational generality, and the Type A behavior pattern. Child Dev. 1989;60:1453-62. [pmid: 2692983].
Wilson JM, Kiessling LS. What is measured by the Conners’ Teacher Behavior Rating Scale? Replication of factor analysis. J Dev Behav Pediatr. 1988;9(5):271-8. [pmid: 3225322].
Wilson MJ, Bullock LM. Psychometric characteristics of behavior rating scales: definitions, problems, and solutions. Behav Disorders. 1989;14(3):186-200.
Wolraich ML, Feurer ID, Hannah JH, et al. Obtaining systematic teacher report of disruptive behavior disorders utilizing DSM-IV. Nashville, TN. Vanderbilt University.
Wolraich ML, Hannah JN, Baumgaertel A, et al. Examination of DSM-IV criteria for attention deficit/hyperactivity disorder in a county-wide sample. J Dev Behav Pediatr. 1998;19(3):162-8. [pmid: 9648041].
Wolraich ML, Hannah JN, Pinnock TY, et al. Comparison of diagnostic criteria for attention-deficit hyperactivity disorder in a county-wide sample. J Am Acad Child Adolesc Psychiatry. 1996;35(3):319-24. [pmid: 8714320].
Wong CK, Lau JT. Psychiatric morbidity in a Chinese primary school in Hong Kong. Aust NZ J Psychiatry. 1992;26(3):459-66.
Wozniak J, Biederman J, Kiely K, et al. Mania-like symptoms suggestive of childhood-onset bipolar disorder in clinically referred children. J Am Acad Child Adolesc Psychiatry. 1995;34(7):867-76. [pmid: 7649957].
Wright D, Edelbrock C, Reed ML. Convergent and discriminant validity of the Burks Behavior Rating Scales. J Psychoeduc Assess. 1983;1:253-60.
Yapa P, Haque MS. Use of the international classification of diseases-10, (ICD 10) to recognise pervasively hyperactive children in a child-guidance clinic: feasibility and validity. Eur Arch Psychiatry Clin Neurosci. 1991;240(3):138-43. [pmid: 1827597].
Yellin AM, Greenberg LM. Attention-deficit disorder: monitored data-based assessment and treatment. Minn Med. 1981;64(8):487-90. [pmid: 7290045].
Zahn TP, Kruesi MJ. Autonomic activity in boys with disruptive behavior disorders. Psychophysiology. 1993;30(6):605-14. [pmid: 8248452].
Zahner GE, Jacobs JH, Freeman DH Jr, et al. Rural-urban child psychopathology in a northeastern U.S. state: 1986–1989. J Am Acad Child Adolesc Psychiatry. 1993;32(2):378-87. [pmid: 8444768].
Zelko FA. Comparison of parent-completed behavior rating scales: differentiating boys with ADD from psychiatric and normal controls. J Dev Behav Pediatr. 1991;12(1):31-7. [pmid: 2016400].
Zentall SS, Barack RS. Rating scales for hyperactivity: concurrent validity, reliability, and decisions to label for the Conners and Davids Abbreviated Scales. J Abnorm Child Psychol. 1979;7(2):179-90. [pmid: 469111].
Zentall SS, Zentall TR. Hyperactivity ratings: statistical regression provides an insufficient explanation of practice effects. J Pediatr Psychol. 1986;11(3):393-6. [pmid: 3772683].
Zohar AH, Ratzoni G, Pauls DL, et al. An epidemiological study of obsessive-compulsive disorder and related disorders in Israeli adolescents. J Am Acad Child Adolesc Psychiatry. 1992;31(6):1057-61. [pmid: 1429405].