# References

Ad Hoc Committee on the Classification of Headache, National Institute of Neurological Diseases and Blindness. Classification of headache. JAMA. 1962;179:717-8.
Belgrade MJ, Ling LJ, Schleevogt MB, Ettinger MG, Ruiz E. Comparison of single-dose meperidine, butorphanol, and dihydroergotamine in the treatment of vascular headache. Neurology. 1989;39(4):590-2. [pmid: 2648190].
Bell R, Montoya D, Shuaib A, Lee MA. A comparative trial of three agents in the treatment of acute migraine headache. Ann Emerg Med. 1990;19(10):1079-82. [pmid: 2221511].
Callaham M, Raskin N. A controlled study of dihydroergotamine in the treatment of acute migraine headache. Headache. 1986;26(4):168-71. [pmid: 3519528].
Cameron JD, Lane PL, Speechley M. Intravenous chlorpromazine vs intravenous metoclopramide in acute migraine headache. Acad Emerg Med. 1995;2(7):597-602. [pmid: 8521205].
Celentano DD, Stewart WF, Lipton RB, Reed ML. Medication use and disability among migraineurs: a national probability sample survey. Headache. 1992;32(5):223-8. [pmid: 1628958].
Chappell AS, Bay JM, Botzum GD, Cohen ML. Zatosetron, a 5-HT3 receptor antagonist in a multicenter trial for acute migraine. Neuropharmacology. 1994;33(3–4):509-13. [pmid: 7984290].
Clouse JC, Osterhaus JT. Healthcare resource use and costs associated with migraine in a managed healthcare setting. Ann Pharmacother. 1994;28(5):659-64. [pmid: 8069007].
Cochrane Controlled Trials Register (CCTR) [computer program]. The Cochrane Library, CD-ROM for Windows (IBM-PC) version. London. BMJ Publishing Group. 1997.
Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. L Erlbaum Associates. 1988.
Coppola M, Yealy DM, Leibold RA. Randomized, placebo-controlled evaluation of prochlorperazine versus metoclopramide for emergency department treatment of migraine headache. Ann Emerg Med. 1995;26(5):541-6. [pmid: 7486359].
Davis CP, Torre PR, Williams C, Gray C, Barrett K, Krucke G, Peake D, Bass B Jr. Ketorolac versus meperidine-plus-promethazine treatment of migraine headache: evaluations by patients. Am J Emerg Med. 1995;13(2):146-50. [pmid: 7893296].
Del Bene E, Poggioni M, Garagiola U, Maresca V. Intramuscular treatment of migraine attacks using diclofenac sodium: a crossover clinical trial. J Int Med Res. 1987;15(1):44-8. [pmid: 3545942].
Diamond S, Freitag FG. Analgesic efficacy and safety of TNB in the acute treatment of migraine. Clin Pharmacol Ther. 1990;47(2):135.
Diamond S, Freitag FG, Diamond ML, Urban G. Transnasal butorphanol in the treatment of migraine headache pain. Headache Quarterly. 1992;3(2):164-171.
Diamond S, Freitag FG, Gallagher RM, Chu G, Mosnaim AD. The analgesic efficacy of transnasal butorphanol (TNB) in the acute treatment of migraine. Cephalalgia. 1989;9(Suppl 10):357.
Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ. 1994;309(6964):1286-91. [pmid: 7718048].
Duarte C, Dunaway F, Turner L, Aldag J, Frederick R. Ketorolac versus meperidine and hydroxyzine in the treatment of acute migraine headache: a randomized, prospective, double-blind trial. Ann Emerg Med. 1992;21(9):1116-21. [pmid: 1514724].
Edmeads J, Findlay H, Tugwell P, Pryse-Phillips W, Nelson RF, Murray TJ. Impact of migraine and tension-type headache on life-style, consulting behaviour, and medication use: a Canadian population survey. Can J Neurol Sci. 1993;20(2):131-7. [pmid: 8334575].
Elenbaas RM, Iacono CD, Koellner KJ, Pribble JP, Gratton M, Racz G, Evens RP. Dose effectiveness and safety of butorphanol in acute migraine headache. Pharmacotherapy. 1991;11(1):56-63. [pmid: 2020612].
Ellis GL, Delaney J, DeHart DA, Owens A. The efficacy of metoclopramide in the treatment of migraine headache. Ann Emerg Med. 1993;22(2):191-5. [pmid: 8427430].
Fleiss JL. Statistical methods for rates and proportions. 2. New York. John Wiley & Sons, Inc. 1981.
Freitag FG. The acute treatment of migraine with transnasal butorphanol (TNB). Headache Quarterly. 1993;4(Suppl 3):22-28.
Harden RN, Gracely RH, Carter T, Warner G. The placebo effect in acute headache management: ketorolac, meperidine, and saline in the emergency department. Headache. 1996;36(6):352-6. [pmid: 8707552].
Headache Classification Committee of the International Headache Society. Classification and diagnostic criteria for headache disorders, cranial neuralgias and facial pain. Cephalalgia. 1988;8(Suppl 7):1-96.
International Headache Society Committee on Clinical Trials in Migraine. Guidelines for controlled trials of drugs in migraine. 1. Cephalalgia. 1991;11(1):1-12.
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Jones EB, Gonzalez ER, Boggs JG, Grillo JA, Elswick RK Jr. Safety and efficacy of rectal prochlorperazine for the treatment of migraine in the emergency department. Ann Emerg Med. 1994;24(2):237-41. [pmid: 8037389].
Jones J, Pack S, Chun E. Intramuscular prochlorperazine versus metoclopramide as single-agent therapy for the treatment of acute migraine headache. Am J Emerg Med. 1996;14(3):262-4. [pmid: 8639197].
Jones J, Sklar D, Dougherty J, White W. Randomized double-blind trial of intravenous prochlorperazine for the treatment of acute headache. JAMA. 1989;261(8):1174-6. [pmid: 2915441].
Karachalios GN, Fotiadou A, Chrisikos N, Karabetsos A, Kehagioglou K. Treatment of acute migraine attack with diclofenac sodium: a double-blind study. Headache. 1992;32(2):98-100. [pmid: 1551795].
Keele KD. The pain chart. Lancet. 1948;2:6-8. [pmid: 18871952].
Klapper J, Stanton J. The emergency treatment of acute migraine headache; a comparison of intravenous dihydroergotamine, dexamethasone, and placebo. Cephalalgia. 1991;11(Suppl 11):159-160.
Klapper JA, Stanton J. Current emergency treatment of severe migraine headaches. Headache. 1993;33(10):560-2. [pmid: 8294195].
Kozubski W. Metamizole and hydrocortisone for the interruption of a migraine attack--preliminary study. Headache Quarterly. 1992;3(3):326-8.
Lane PL, McLellan BA, Baggoley CJ. Comparative efficacy of chlorpromazine and meperidine with dimenhydrinate in migraine headache. Ann Emerg Med. 1989;18(4):360-5. [pmid: 2705667].
Larkin GL, Prescott JE. A randomized, double-blind, comparative study of the efficacy of ketorolac tromethamine versus meperidine in the treatment of severe migraine. Ann Emerg Med. 1992;21(8):919-24. [pmid: 1497157].
Linet MS, Stewart WF, Celentano DD, Ziegler D, Sprecher M. An epidemiologic study of headache among adolescents and young adults. JAMA. 1989;261(15):2211-6. [pmid: 2926969].
Littman GS, Walker BR, Schneider BE. Reassessment of verbal and visual analog ratings in analgesic studies. Clin Pharmacol Ther. 1985;38(1):16-23. [pmid: 3891192].
Maizels M, Scott B, Cohen W, Chen W. Intranasal lidocaine for treatment of migraine: a randomized, double-blind, controlled trial. JAMA. 1996;276(4):319-21. [pmid: 8656545].
McEwen JI, O’Connor HM, Dinsdale HB. Treatment of migraine with intramuscular chlorpromazine. Ann Emerg Med. 1987a;16(7):758-63. [pmid: 3592329].
McEwen J, O’Connor H, Dinsdale H. Treating migraine with chlorpromazine. Nurses Drug Alert. 1987b;11(11):87.
Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Controlled Clin Trials. 1995;16(1):62-73. [pmid: 7743790].
Osterhaus JT, Gutterman DL, Plachetka JR. Healthcare resource and lost labour costs of migraine headache in the US. Pharmacoeconomics. 1992;2(1):67-76. [pmid: 10146980].
Reutens DC, Fatovich DM, Stewart-Wynne EG, Prentice DA. Is intravenous lidocaine clinically effective in acute migraine?. Cephalalgia. 1991;11(6):245-7. [pmid: 1790567].
Rowat BM, Merrill CF, Davis A, South V. A double-blind comparison of granisetron and placebo for the treatment of acute migraine in the emergency department. Cephalalgia. 1991;11(5):207-13. [pmid: 1663423].
Sacks W. The use of an isopyrine-phenylbutazone compound in migraine. S Afr Med J. 1980;58(11):444-6. [pmid: 6996149].
Scherl ER, Wilson JF. Comparison of dihydroergotamine with metoclopramide versus meperidine with promethazine in the treatment of acute migraine. Headache. 1995;35(5):256-9. [pmid: 7775186].
Scott J, Huskisson EC. Graphic representation of pain. Pain. 1976;2(2):175-84. [pmid: 1026900].
Shrestha M, Singh R, Moreden J, Hayes JE. Ketorolac vs chlorpromazine in the treatment of acute migraine without aura. A prospective, randomized, double-blind trial. Arch Intern Med. 1996;156(15):1725-8. [pmid: 8694672].
Stewart WF, Shechter A, Lipton RB. Migraine heterogeneity. Disability, pain intensity, and attack frequency and duration. Neurology. 1994;44(6 Suppl 4):S24-39. [pmid: 8008223].
Stewart WF, Shechter A, Rasmussen BK. Migraine prevalence. A review of population-based studies. Neurology. 1994;44(6 Suppl 4):S17-23. [pmid: 8008222].
Stiell IG, Dufour DG, Moher D, Yen M, Beilby WJ, Smith NA. Methotrimeprazine versus meperidine and dimenhydrinate in the treatment of severe migraine: a randomized, controlled trial. Ann Emerg Med. 1991;20(11):1201-5. [pmid: 1952306].
Tek DS, McClellan DS, Olshaker JS, Allen CL, Arthur DC. A prospective, double-blind study of metoclopramide hydrochloride for the control of migraine in the emergency department. Ann Emerg Med. 1990;19(10):1083-7. [pmid: 2221512].
Tek D, Mellon M. The effectiveness of nalbuphine and hydroxyzine for the emergency treatment of severe headache. Ann Emerg Med. 1987;16(3):308-13. [pmid: 3544982].
Tfelt-Hansen P, Jensen K, Vendsborg P, Lauritzen M, Olesen J. Chlormezanone in the treatment of migraine attacks: a double blind comparison with diazepam and placebo. Cephalalgia. 1982;2(4):205-10. [pmid: 6760981].
Tfelt-Hansen P, Olesen J, Aebelholt-Krabbe A, Melgaard B, Veilis B. A double blind study of metoclopramide in the treatment of migraine attacks. J Neurol Neurosurg Psychiatry. 1980;43(4):369-71. [pmid: 7373338].
Thomas SH, Stone CK, Ray VG, Whitley TW. Intravenous versus rectal prochlorperazine in the treatment of benign vascular or tension headache: a randomized, prospective, double-blind trial. Ann Emerg Med. 1994;24(5):923-7. [pmid: 7978566].
Wallenstein SL, Heidrich G 3d, Kaiko R, Houde RW. Clinical evaluation of mild analgesics: the measurement of clinical pain. Br J Clin Pharmacol. Oct. 1980;10(Suppl 2):319S-327S. [pmid: 7437271].
Winner P, Dalessio D, Mathew N, Sadowsky C, Turkewitz LJ, Sheftell F, Silberstein SD, Solomon S. Concomitant administration of antiemetics is not necessary with intramuscular dihydroergotamine. Am J Emerg Med. 1994;12(2):138-41. [pmid: 8161382].
Winner P, Ricalde O, Leforce B, Saper J, Margul B. A double-blind study of subcutaneous dihydroergotamine vs. subcutaneous sumatriptan in the treatment of acute migraine. Arch Neurol. 1996;53(2):180-184. [pmid: 8639069].