# Executive Summary

## BACKGROUND

Migraine is a common and disabling health problem among adult Americans. Surveys from the U.S. and elsewhere suggest that 6% of men and 15%–17% of women experience migraine headaches. These headaches result in significant disability and work loss; estimated aggregate indirect costs to employers in the U.S. for reduced productivity due to migraine range from 6.5 to 17 billion dollars annually. Even these measurements fall short of demonstrating the full impact of migraine on the individual and society, since they fail to account for the substantial effect of migraine on other aspects of life.

Acute episodes of migraine are ordinarily treated by patients themselves with prescription or over-the-counter drugs. But concern about the possible cause of a particularly severe attack or the failure of ordinary treatment strategies sometimes leads patients to seek urgent medical care for an acute attack. The annual rate of emergency department use among migraineurs has been estimated to be between 3% and 48%.

The parenteral drugs (intravenous, intramuscular, and subcutaneous) available in the emergency department (ED) and in other clinical settings for the treatment of migraine offer several theoretical advantages over the (usually oral) formulations used by patients for self-treatment. Parenterally administered drugs may offer improved speed of onset of relief and, along with rectal formulations, can be used when severe nausea or vomiting preclude the use of oral medication. Anecdotal evidence, however, suggests that migraine is frequently inadequately treated in the emergency or urgent care setting. Analgesic treatment may be delayed because of diagnostic uncertainty while patients undergo evaluation. Opiates, in particular, may not be used because of regulatory constraints and additional concerns about addiction, dependency, tolerance, respiratory depression, and other side effects. More generally, effective treatments may not be used because many clinicians may not be familiar with the full range of alternative effective therapies for acute migraine.

A variety of parenteral agents have been tested in a controlled manner for the treatment of acute migraine headache and associated symptoms. Some of these agents are frequently used to treat other conditions (e.g., NSAIDs and opiates); others are used exclusively or almost exclusively for migraine (e.g., dihydroergotamine). This report summarizes the evidence for the efficacy and safety of all these agents.

## SCOPE OF REPORT

The objective of this Technical Review is to provide a comprehensive review and analysis of published reports of randomized controlled trials (RCTs) and other prospective, comparative clinical trials of parenteral drug treatments for the acute, episodic treatment of migraine. The report is restricted to trials of treatments delivered by a parenteral route (i.e., intravenous [IV], intramuscular [IM], or subcutaneous [SC]). Studies of oral (PO), intranasal (IN), rectal (PR), and some subcutaneous treatments (those delivered with an autoinjector designed for self-administration) are covered in a companion report on self-administered drug treatments for acute migraine. The present report is also limited to agents that have been studied specifically among populations of patients with migraine. As a result, some drugs used by health care providers to treat migraine may not be represented.

## METHODOLOGY

The literature review addressed the question “What are the effects on headache pain and the tolerability of parenterally administered. drug treatments for acute migraine headache compared to placebo, alternative drug treatments, and. non-drug therapies?”

To be considered for this review, studies were required to be prospective, controlled trials of parenteral drug treatments aimed at the relief of symptoms of individual episodes of headache in patients with migraine. Although the use of a specific set of diagnostic criteria (e.g., those developed by the Ad Hoc Committee on the Classification of Headache and the Headache Classification Committee of the International Headache Society) was not required, diagnoses were required to be based on at least some of the distinctive features of migraine, e.g., nausea/vomiting, severe head pain, throbbing character, unilateral location, phono/photophobia, or aura.

Studies were included only if allocation to treatment groups was randomized or pseudo-randomized (based on some non-random process unrelated to the treatment selection or expected response); concurrent cohort comparisons or other subexperimental designs were excluded. Control groups could comprise placebo, no intervention, usual care, or a specified alternative drug or non-drug treatment.

Relevant controlled trials were identified by searching MEDLINE (January 1966 through December 1996) using the MeSH term “headache” (exploded) and a published strategy for identifying randomized controlled trials. Additional search strategies included computerized bibliographical searching of PsycINFO and CINAHL databases; retrospective and prospective hand-searching of the journals Headache, Cephalalgia, and Headache Quarterly; searching the reference lists of review articles and included studies; searching books related to headache; and consulting experts in the field. We also searched a database of randomized trials in pain relief which is now part of the Cochrane Controlled Trials Register.

Studies identified by the literature search were screened for further review based on criteria focusing on patient population, intervention, study design, and type of outcome data reported.

Studies passing the initial screen were reviewed for methodological quality based on the following considerations: the use of random allocation; description of an adequate method of concealment of allocation; the use of double-blinding; description of an adequate method of blinding; and a description of drop-outs sufficient to determine the number of patients in each treatment group entering and completing the trial. Each trial could score between 0 and 5 points, with higher scores indicating higher quality in the conduct or reporting of the trial.

Efficacy and adverse events data were abstracted from the original reports onto specially designed forms. We collected trial data on short-term symptomatic outcomes related to head pain (severity/intensity, relief, and duration), other symptoms (nausea, vomiting, photophobia, phonophobia), functional status (disability), and quality of life. We did not consider physiological or other measures not directly relevant to the patients’ symptomatic experience.

We required that outcome data be obtained directly from the patient, not judged by the treating clinician or study personnel. We required that data be recorded at or near the time of symptoms. We chose to analyze l-hour data whenever they were reported. If 1-hour data were not reported, we chose the measurement closest to one hour. In comparisons between parenteral and orally administered drugs, we reported results from later timepoints, if available, since the 1-hour results could favor parenteral treatments. Also, we reported 24-hour outcomes whenever they were available to capture any information provided on headache recurrence.

Among outcomes related to headache pain, we generally preferred those that measured headache relief or change in headache intensity, since these are more comparable among patients with different baseline pain intensity scores. If these outcomes were not available, we analyzed data on post-treatment headache intensity. If no headache relief or pain intensity data were reported, then we used data on functional disability or headache duration as a proxy.

For outcomes measured on a dichotomous scale (success/failure), we required that the threshold for distinguishing between success and failure be clinically significant; for example, we interpreted a 50% or more decrease in severity or a reduction from moderate-severe to mild-none (two of the most common definitions) as meeting this criterion. Some studies also reported results for a more stringent criterion, complete resolution of symptoms. We did not consider a reduction in severity from mild to none as meeting our criterion.

Dichotomous outcomes meeting our definition. of a clinically significant threshold were reported as proportions (or response rates for each treatment) which may be directly compared (difference in proportions). We also used these proportions to calculate odds ratios.

When outcome data were provided on an ordinal scale (e.g., for headache relief: none, mild, moderate, near complete, complete), we selected a threshold based on the definition for improvement (discussed above) and converted these data into a dichotomous outcome. When categorical data could not be split into dichotomous outcomes meeting our a priori definition and no continuous data were reported, we assigned a numeric score to each category and analyzed the results as continuous data.

When outcomes were reported on a continuous scale (e.g., a visual analog pain scale) and variance estimates were also available, we calculated an effect size, or standardized mean difference.

When several efficacy estimates were available from comparable trials for a given treatment comparison, we tested these for homogeneity and combined them using an inverse variance weighted method to yield a meta-analytic summary estimate.

The incidence of adverse events was recorded and the proportion of patients experiencing adverse events calculated for each treatment group, whenever possible. The difference between rates of adverse events was calculated along with a 95% confidence interval for the difference. A 95% confidence interval (CI) that excludes zero suggests that the rates are significantly different between groups. The identity and rates of specific adverse events reported were summarized for each study.

## SUMMARY OF FINDINGS

The evidence supporting different agents or classes of agents varies in quantity and quality. This section summarizes the results of our analysis.

### Antinauseants

Several different rectally and parenterally administered drugs commonly referred to as antinauseants have been studied in controlled trials for the treatment of acute migraine. Our analysis included fourteen trials involving the following agents: metoclopramide, three phenothiazines.(chlorpromazine, methotrimeprazine, and prochlorperazine), and two 5HT_3_-antagonists (granisetron and zatosetron).

Only limited clinical conclusions can be drawn from the trials we reviewed due to their small sample sizes. The principal findings were these:

Prochlorperazine by intravenous, intramuscular, and rectal routes significantly relieved headache pain in three small, placebo-controlled studies.

Metoclopramide by intravenous administration was shown to be effective compared to placebo in two of three trials. A single, small study suggested that it was also superior to oral ibuprofen. Intramuscular metoclopramide was no better than placebo at providing headache relief in one trial. Another trial comparing intramuscular and rectal metoclopramide with placebo found a trend toward significance for the two metoclopramide formulations, considered together. Overall, these data suggest that metoclopramide provides effective relief of headache.

Chlorpromazine has less support from controlled trials for efficacy in acute migraine. A single, small trial of intramuscular chlorpromazine was not able to establish its superiority to placebo. Individual trials found no significant differences between chlorpromazine (IV) and DHE (IV) for complete relief at 60 minutes, or between chlorpromazine (IV) and ketorolac (IM) for pain relief over 2 hours. One trial each supported the superiority of chlorpromazine (IV) over meperidine (IV) and lidocaine (IV); however, neither of these comparator agents has been shown to be effective for acute migraine.

Single small trials of granisetron and zatosetron did not demonstrate significant differences with placebo. In the only trial of methotrimeprazine (IM), no significant difference was found between it and meperidine (IM).

Different antinauseants were directly compared in three trials. Two studies found prochlorperazine (in both IV and IM forms) performed significantly better than metoclopramide (in the corresponding form). One showed no significant differences between chlorpromazine (IV) and metoclopramide (IV).

The antinauseants share the common adverse event of drowsiness or sedation. Because of this, these agents do not return patients quickly to normal functioning, even though the studies reviewed in this report demonstrated that some of them have a beneficial effect on headache severity. Some alternative interventions (e.g., meperidine) share this problem, but others (e.g., sumatriptan, DHE, and ketorolac) do not. Acute dystonic reactions and akathisia, two well-known complications of the phenothiazine derivatives, were rarely reported.

### Opiate analgesics

Ten controlled trials of parenteral opiate analgesics for the treatment of acute migraine were included in our analysis. The main findings of the review were as follows:

No placebo-controlled studies of butorphanol were identified. Intramuscular butorphanol was tested in a small dose-ranging study which showed that 2- and 3-mg doses were more effective than a 1-mg dose. Another small trial comparing intramuscular butorphanol 2 mg with DHE + metoclopramide found no significant differences between the two interventions for 30-minute pain outcomes.

Intravenous meperidine was compared with intravenous chlorpromazine in a single trial which showed that chlorpromazine was significantly better at reducing headache. Another, slightly larger trial found no significant differences between intramuscular meperidine and the antinauseant methotrimeprazine (IM) for headache relief at 1 hour. Of three studies comparing intramuscular meperidine and intramuscular ketorolac, one suggested that meperidine was superior in improving clinical disability at 60 minutes; however, this study used a lower dose of ketorolac than did the other two trials (30 mg vs. 60 mg), both of which failed to confirm a difference in favor of meperidine. A summary odds ratio from these three trials was inconclusive. Intramuscular meperidine was significantly less effective than intravenous DHE at relieving headache pain at 30 and 60 minutes in two of the three small trials comparing these drugs. The third trial found no significant difference between the two treatments, but used a low dose of DHE (0.5 mg vs. the usual 1 mg). These results fail to demonstrate the efficacy of meperidine for the treatment of acute migraine.

A single trial found that methadone was significantly better than placebo at relieving head pain over 2 hours.

No clear differences in analgesic efficacy were demonstrated when the opiate analgesics were directly compared (butorphanol [IM] vs. meperidine [IM]; methadone [IM] vs. butorphanol [IN]).

Adverse events were similar for all the opiate analgesics discussed above and included sedation, nausea, and dizziness. The short-term trials considered in this report did not address the risks associated with frequent or prolonged use of opiate analgesics, such as rebound headache, tolerance, and dependence.

### NSAIDs and other non-opiate analgesics

Several oral non-steroidal anti-inflammatory drugs (NSAIDs) have been shown in numerous placebo-controlled and comparative RCTs to be effective for the acute treatment of migraine. A few agents from this class have in recent years been approved for intramuscular administration and tested among patients with migraine. Our analysis included seven trials involving intramuscular acetaminophen, diclofenac sodium, ketorolac, and metamizole sodium. The principal findings were:

Diclofenac was effective in a single, small placebo comparison and a similar trial in which the control group received small dose of acetaminophen.

There were no placebo-controlled trials of ketorolac for the acute treatment of migraine, but the drug has been compared to chlorpromazine(IV) and meperidine (IM) for this indication. The single trial of ketorolac vs. chlorpromazine was inconclusive due to its small sample size. Of three studies comparing ketorolac and meperidine, one suggested that meperidine was superior in improving clinical disability at 60 minutes; however, this study used a lower dose of ketorolac than did the other two trials (30 mg vs. 60 mg), both of which failed to confirm a difference in favor of meperidine. A summary odds ratio from these three trials was inconclusive.

Adverse events from the parenteral NSAIDs examined in this report were infrequent. The well-known complications of repeated or prolonged use of NSAIDs (gastric irritation or ulceration and renal impairment) were not observed and probably would not be expected with the sort of short-term, occasional use examined in the included trials.

### Dihydroergotamine (DHE)

Dihydroergotamine (DHE) is a semi-synthetic ergot alkaloid, which is commercially available in the U.S. as a parenteral preparation (D.H.E.-45®, Sandoz Pharmaceuticals) suitable for intravenous, intramuscular, or subcutaneous administration. In recent years, the drug has been tested as a possible alternative to agents (particularly opiate analgesics) commonly used to treat acute migraine in an emergency or urgent care setting. Our analysis included seven trials of parenteral DHE (either IV or SC). The main findings were these:

The two placebo-controlled trials described in this report do not clearly establish whether intravenous DHE is effective or ineffective for the treatment of acute migraine. Both were small trials. One found that DHE + metoclopramide was significantly better than placebo at returning patients to normal functioning within 30 minutes, but our analysis did not confirm this result. The other failed to find a significant difference in headache severity at 60 minutes between DHE and placebo groups, but used a relatively low dose of DHE (0.75 mg vs. the more usual 1 mg) and did not control for pre-treatment headache severity.

Perhaps the strongest evidence supporting DHE is the single large trial comparing subcutaneous DHE with subcutaneous sumatriptan, a treatment whose efficacy is firmly supported by multiple large RCTs (see the report on self-administered drug treatments for acute migraine). Though this trial showed that sumatriptan was significantly better than DHE at providing headache relief at 1 hour (78% of patients vs. 57%) and 2 hours (85% vs. 73%), it found that there was no significant difference between the two treatments at later timepoints (3, 4, and 24 hours). The trial also demonstrated that sumatriptan was associated with a significantly higher headache recurrence rate (45% of patients vs. 18%). Thus, though DHE appears to provide relief from headache pain less quickly than sumatriptan, it may lead to superior outcomes over a 24-hour period for a large proportion of patients.

Two of three small trials comparing intravenous DHE with intramuscular meperidine suggest that DHE was significantly better at relieving headache pain at 30 and 60 minutes. The third trial found no significant difference between the two treatments, but used a low dose of DBE (0.5 mg vs. l mg).

Individual small trials of intravenous DHE vs. butorphanol (IM), chlorpromazine (IV), lidocaine (IV), and dexamethasone (IV) provided very limited information.

Nausea and vomiting were the most common adverse events associated with DHE. Because of the nausea associated with DHE, parenteral antinauseants are routinely used with it as adjunctive symptomatic treatments. Some of these antinauseants (particularly metoclopramide and prochlorperazine) have been shown to be effective on their own in treating acute migraine. The largely uncontrolled use of antinauseants in the trials reviewed in this report confounds the assessment of the efficacy of DHE: is the beneficial effect the result of DHE or the antinauseant administered along with it? Only one trial controlled adequately for this possible confounder, and it was too small to confirm or exclude a clinically important effect of DHE.

### Miscellaneous agents

The literature review identified six trials involving agents which did not fall into any of the drug classes reviewed above (lidocaine, dexamethasone, hydrocortisone, diazepam, and chlormezanone). The main findings from a review of these trial were:

There is little evidence to suggest that intravenous lidocaine is effective for the treatment of acute migraine. Lidocaine demonstrated little benefit over placebo in one small study which failed to exclude clinically significant benefit or harm. In another, slightly larger trial lidocaine was significantly less effective than intravenous chlorpromazine and no more effective than intravenous DHE (though the trial did not rule out the possibility that lidocaine is better than DHE).

One placebo-controlled trial suggested that intranasal lidocaine is effective in relieving headache pain quickly (within 15 minutes). The durability of the effect was not directly measured, but the investigators reported that 42% of patients initially achieving relief with lidocaine experienced a recurrence of headache of a moderate or severe intensity within 24 hours. Intranasal lidocaine also produced pronounced local adverse events.

The two small, low-quality studies identified by the literature review provided little data from which to draw any conclusions about the efficacy or safety of dexamethasone or hydrocortisone for the treatment of acute migraine.

A single, moderately large trial suggested that neither diazepam nor chlormezanone significantly enhanced the anti-migraine effects of a combination of intramuscular metoclopramide and oral acetaminophen.

## FUTURE RESEARCH NEEDS

Further research is required into the safety and efficacy of currently available parenteral drugs if the short-term treatment of acute migraine attacks with these agents is to be optimized. The following recommendations may be made:

Further study of the parenteral agents reviewed in this report:

- (1) More placebo-controlled trials of these agents need to be conducted.
- (2) Larger comparative trials need to be conducted to establish equivalence among alternative active treatments or to determine the superiority of one treatment over another.
- (3) Because some antinauseants (e.g., prochlorperazine and metoclopramide) appear to be effective against migraine when used alone, their uncontrolled use as adjunctive therapies has confounded the assessment of the efficacy of some other treatments, most notably dihydroergotamine (DHE). Future trials of DHE and other agents should be designed to avoid this source of bias.
- (4) Sumatriptan, by virtue of the large number of consistent studies demonstrating its efficacy, has become the gold standard for self-treatment of acute migraine (see the report on self-administered drug treatments for acute migraine). It has not, however, been extensively studied in the emergency department setting. Such trials should be conducted, and future studies of parenteral drug treatments for migraine should compare these agents to sumatriptan and should be large enough to demonstrate equivalence or lack thereof.

Conduct and reporting of trials:

- (5) Future trials should use common scales for measuring pain outcomes, if possible.
- (6) Pain relief should be measured at several different times post-intervention (e.g., 30 minutes, and 1, 2, 4 and 24 hours), especially when the agents being compared have different speeds of onset.
- (7) The list of clinically relevant outcomes measured should be expanded in future trials to include 24-hour headache outcomes (including rates of headache recurrence) and data on functional status and quality of life. Comprehensive cost data should also be collected and reported.
- (8) Future studies should carefully consider and report on (a) symptomatic drug treatments taken by patients before they present for treatment, (b) the duration of the attack prior to treatment, and (c) the use of migraine preventive medication by study participants when describing the patient population, reporting results, and designing treatment protocols. The use of non-pharmacological treatments (relaxation, biofeedback, etc.) should also be described.
- (9) The diagnosis of migraine -- even when made according to specific criteria such as the International Headache Society (IHS) criteria for migraine with aura and migraine without aura -- encompasses a wide range of symptomatology. Researchers should be as precise as possible in describing any operational inclusion or exclusion criteria they employ in addition to headache diagnosis, such as headache frequency,. severity, and chronicity.
- (10) Adverse events should be reported for all patients taking study medication, whether or not they completed the trial. The number of patients experiencing adverse events in each treatment group should be reported, and the specific adverse events reported should be described.

New directions for research:

- (11) Treatment protocols should be devised and tested to achieve the dual goals of rapid and durable relief of headache by combining agents that differ in speed of onset and duration of response. For example, a fast-acting agent like intranasal lidocaine might be effectively combined with the slower-, but longer-acting DHE.
- (12) Recurrent migraine sufferers often know “what works for them,” and this may be valuable information for the clinician treating an acute episode. Controlled trials should be conducted to evaluate the effectiveness and best means of using a history of previously effective treatments (drug and non-drug) to guide the choice of an acute treatment in such a situation.
- (13) In many cases, the patient presenting to an emergency department or urgent care setting for acute migraine treatment represents a failure of self-management or preventive strategies. Future studies might identify migraine patients who are high utilizers of emergency services, examine their self-management and preventive strategies, and test various ways of improving them.