# Data collection form

Data Abstraction Form

First Author (last name):_______________

Ver 5.19.95

Pro-Cite no.:__________

Reviewer ____________

Todays date: ___/___/___

EXCLUDE Why?

Are most or all of the patients in this study in the pediatric age group (0–17)?

No

Yes -> STOP

State the inclusion criteria (headache diagnoses first)

Headache diagnosis: Migraine Tension-type Cluster mixed

other_________

Diagnostic criteria: IHS Ad hoc other none/NS

State the exclusion criteria (headache diagnoses first)

Patient enrollment site (circle all that apply)

Primary Care Clinic General Neurology Clinic Headache Clinic Not Stated

Emergency Clinic Pain Clinic Psychology clinic Other_____________

Design:

Unclear

Single-period parallel-group

Crossover

Matched pair (or paired)

For Cross-over design only-> Was there a significant carry-over effect? Yes No Not Stated

If “yes” then abstract “period one” data only as if the trial used a parallel group design.

Instrument to measure bias in pain research reports (Jadad) | | Response | Score
1 | Was the study described as randomized (this includes the use of words such as randomly, random and randomization)? | Yes No | 1 0
la | If the method of generating the randomization sequence was described, was it adequate (table of random numbers, computer-generated, coin tossing, etc.) or inadequate (alternating, date of birth, hospital number, etc.)? | Not described/NA Adequate Inadequate | 0 1 −1
2 | Was the study described as double-blind? | Yes No | 1 0
2a | If the method of blinding was described, was it adequate (identical placebo, active placebo, etc.) or inadequate (comparison of tablet vs. injection with no double dummy)? | Not described/NA Adequate Inadequate | 0 1 −1
3 | Was there a description of withdrawals and drop-outs? | Yes No | 1 0

Describe the elements of the study design common to all groups (eg, 4 wk lead in, 12 wk treatment period)
Brief description of intervention | Details (including dose, duration, timing, etc.)
Intervention 1 (placebo or control or wait-list)
Intervention 2
Intervention 3
Intervention 4

Patient characteristics (overall: if figures are given by treatment groups, then calculate weighted average)

Age _____ ± _____ or _____ (_____ to _____)

mean ± std dev median and (lower to upper) range

Female (%) _____

Chronicity of H/A d/o (x̄, years) ______

HA frequency (#HA/mo) ______

Patient characteristics describe: pre-treatment (trial entry) post-treatment (completion)

Adverse Event Frequency (%) | Overall | Intervention 1 | Intervention 2 | Intervention 3 | Intervention 4
Total entered study, n
Total completed study, n
Dropouts 2°S/E, (%)
Dropouts, total, (%)

Outcome measure Primary or secondary | Def”n (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

BEFORE/Period 1/single-period parallel-group design | Gp1 | Gp2 | Gp3 | Gp4
Sample size
Mean
SD/VAR/SEM (circle one)
AFTER/Period 2
Sample size
Mean
SD/VAR/SEM (circle one)
BEFORE/AFTER comparisons
Mean
SD/VAR/SEM of difference (circle one)
Test statistic for diff
Degrees of freedom for test statistic
p-value of test statistic
Name of test statistic (e.g.; t, F, etc.)
BETWEEN GROUP COMPARISONS
Mean
SD/VAR/SEM of difference (circle one)
Test statistic for diff
Degrees of freedom for test statistic
p-value of test statistic
Name of test statistic (e.g.; t, F, etc.)
| F statistic | d.f. | p-value
OVERALL COMPARISON/ANOVA

Outcome measure Primary or secondary | Def”n (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

| Outcomes (fill in dichotomous outcomes, categories, or ranges for groups as column headers) | | | | | Totals
| worst | | | | best
Treatments | N(%) | N(%) | N(%) | N(%) | N(%) | N (100%)
A
B
C
D

Outcome measure Primary or secondary | Def”n (e.g. from 2 or 3 to 0 or 1) | How measured? (e.g. 4 pt scale) | When assessed? (2 hrs, 2 mo) | When were sx recorded? (daily, etc)

| worst | | | | best | Totals
Treatments | N(%) | N(%) | N(%) | N(%) | N(%) | N (100%)
A
B
C
D