# MEDLINE search strategy

Efficacy of headache treatments
MEDLINE database search strategy
1 | randomized controlled trials/
2 | random allocation/
3 | double-blind method/
4 | single-blind method/
5 | randomized controlled trial.pt.
6 | 1 or 2 or 3 or 4 or 5
7 | animal/
8 | human/
9 | 7 and 8
10 | 7 not 9
11 | 6 not 10
12 | clinical trial.pt.
13 | exp clinical trials/
14 | (clin$ adj trial$).tw.
15 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
16 | placebos/
17 | placebo$.tw.
18 | random$.tw
19 | research design/
20 | 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21 | 20 not 10
22 | comparative-study/
23 | exp evaluation studies/
24 | follow-up studies/
25 | prospective-studies/
26 | (control$ or prospectiv$ or volunteer$).tw.
27 | 22 or 23 or 24 or 25 or 26
28 | 27 not 10
29 | 21 not 11
30 | 28 not (21 or 11)
31 | exp headache/
32 | 11 and 31
33 | 29 and 31
34 | 30 and 31