# Technical Review

## Introduction

### Background

Migraine is a common and disabling health problem among adult Americans. Surveys from the US and elsewhere suggest that 6% of men and 15%–17% of women experience migraine headaches (Stewart, Shechter, and Rasmussen, 1994). These headaches result in significant disability and work loss; estimated aggregate indirect costs to employers in the US for reduced productivity due to migraine range from $6.5 billion to $17 billion annually (Osterhaus, Gutterman, and Plachetka, 1992).

Patterns of medical care for the treatment of migraine are highly variable. A substantial proportion of migraineurs never consult a physician about their headaches. Among those who do seek medical attention, many do not continue with the course of treatment prescribed by their physician (Edmeads, Findlay, Tugwell, et al., 1993), citing the availability of nonprescription medications and negative side effects associated with prescription medications among the reasons for self-treatment.

Preventive drug treatments are used by a small percentage of migraineurs −3% to 5% of patients in various studies (Clarke, MacMillan, Sondhi, et al., 1996; Edmeads, Findlay, Tugwell, et al., 1993; Rasmussen, Jensen, and Olesen, 1992). It is not known whether patients in these studies had never been offered preventive therapy or had tried it and found it ineffective or intolerable.

The pathophysiology of migraine is poorly understood, but recent advances in neuroimaging, neurobiology, genetics, and pharmacology have resulted in a changing view of migraine pathogenesis, from one favoring vascular and muscle tone as primary causes to one involving a primary neuronal event producing secondary vascular changes. There continues to be controversy among headache researchers and clinicians over whether tension-type headache and migraine are part of a single spectrum of headache disorders or different conditions with distinct etiologies. The diagnostic distinction between the two types of headache is, however, generally assumed in clinical trials, most of which have focused on one or the other diagnosis.

A substantial body of high-quality evidence exists describing the effectiveness of various drugs for the prevention of episodes of migraine. Synthesis and dissemination of this information may help correct the underuse or misuse of preventive drug treatment strategies for migraine headache.

### Objectives and Organization of the Report

The objective of this evidence report is to provide a comprehensive review and analysis of published reports of randomized controlled trials (RCTs) and other prospective, comparative clinical trials of self-administered drug treatments for the prevention of migraine headaches. The present report does not cover all drugs that may be used for the treatment of acute migraine, but only those that have been studied in controlled trials among a population of migraineurs. These include (in alphabetical order): alpha-2 agonists (clonidine, guanfacine); anticonvulsants (divalproex sodium, sodium valproate, carbamazepine, clonazepam, gabapentin); antidepressants (amitriptyline, clomipramine, femoxetine, fluoxetine, fluvoxamine, mianserin, opipramol); beta-blockers (propranolol, metoprolol, acebutolol, alprenolol, atenolol, bisoprolol, nadolol, oxprenolol, pindolol, practolol, timolol); calcium antagonists (cyclandelate, flunarizine, nicardipine, nifedipine, nimodipine, verapamil); ergots (dihydroergotamine [DHE], dihydroergokryptine [DEK], ergotamine, and the combination agent Cafergot comp.®), methysergide; nonsteroidal anti-inflammatory drugs (NSAIDs) (aspirin, fenoprofen, flurbiprofen, indobufen, indomethacin, ketoprofen, lornoxicam, mefenamic acid, naproxen, naproxen sodium, tolfenamic acid); other serotoninergic drugs (pizotifen, lisuride, oxitriptan, iprazochrome, tropisetron); and other treatments (hormonal preparations [estradiol, mixed estradiol/progestogen oral contraceptives, flumedroxone] and the herbal remedy feverfew). We identified a small number of trials of other miscellaneous agents, but chose not to review these because the drugs involved have been studied in only a few trials (in most cases, only one), are not widely available, and/or have been shown to be ineffective. Appendix A provides a complete list of these trials. Several drugs for which there is a large body of evidence are unavailable in the US, including flunarizine, pizotifen, and lisuride.

The report is organized into chapters according to classes or categories of drugs: alpha-2 agonists, anticonvulsants, antidepressants, beta-blockers, calcium antagonists, ergots, methysergide, NSAIDs, other serotoninergic drugs, and other treatments.

The text of the report in each chapter briefly describes the studies identified by the literature review, summarizes the evidence for efficacy and the data on adverse events, and draws conclusions. In the sections on efficacy, we first review placebo-controlled trials, then studies comparing different dosages of the same agent, then trials comparing agents within the same class, and finally trials comparing the agents under consideration with drugs outside the class or with nondrug therapies.

Evidence Table 1 summarizes the studies included in the analysis, describing in a standardized way the aims and design of each study, characteristics of the patient population, headache diagnostic criteria used, inclusion and exclusion criteria, interventions, treatment protocol, data collected, outcomes measured, and results. Evidence Tables 2 through 11 summarize the evidence for the efficacy of each class of drugs in standard terms, including measures of efficacy (odds ratios or effect sizes) or tests of statistical significance. The results of meta-analyses of multiple studies are also reported in these tables, wherever it was possible to perform such meta-analyses. Evidence Table 12 summarizes the available data from each study on the occurrence of adverse events, in aggregate, and the incidence of specific adverse events.

A description of future research needs and a list of references are provided at the end of the entire report.

## Methodology

### Topic Questions

The topic questions addressed in the literature review were:

1. What is the effect on headache pain and/or headache frequency of drug treatments taken to prevent migraine headache compared with placebo, alternative drug treatments, and non-drug therapies?
2. What is the tolerability of drug treatments taken to prevent migraine headache compared to placebo, alternative drug treatments, and non-drug therapies?

### Criteria for Considering Studies

To be considered for this review, studies were required to be prospective, controlled trials of self-administered drug treatments taken regularly and intended to prevent the occurrence of episodes of headache in patients with migraine. Studies were included only if allocation to treatment groups was randomized or pseudo-randomized (based on some nonrandom process unrelated to the treatment selection or expected response); concurrent cohort comparisons or other nonexperimental designs were excluded. Control groups could comprise placebo, no intervention, usual care, or a specified alternative drug or non-drug treatment.

### Search Strategy

Relevant controlled trials were identified by MEDLINE searches using the MeSH term “headache” (exploded) and the search strategy for identifying randomized controlled trials described by Dickersin, Scherer, and Lefebvre (1994) (see Appendix B). The MEDLINE searches included literature indexed from January 1966 through December 1996. Additional search strategies included computerized bibliographical searching of PsycINFO and CINAHL databases; retrospective and prospective hand-searching of the journals Headache, Cephalalgia, and Headache Quarterly from the inception of each (1961, 1981, and 1990, respectively); searching the reference lists of review articles and included studies; searching books related to headache; and consulting experts in the field. We also searched a database of randomized trials in pain relief which is now part of the Cochrane Controlled Trials Register (1997).

### Results of Search

Searches of all sources retrieved a total of 6,660 articles (including 352 review articles) on the diagnosis, treatment, and cost of chronic headache (migraine, tension-type, and other types of primary headache). Of these, 2,106 were judged to merit scrutinizing the complete article. Of the articles reviewed, 1,085 concerned the treatment of chronic headache (rather than diagnosis or cost), and 492 of these articles included at least one preventive drug treatment arm. Of the 492 preventive drug treatment articles reviewed, 283 met all the criteria for consideration in the evidence report (i.e., they were controlled trials conducted on a nonpediatric population of patients with migraine).

### Initial Screening and Data Abstraction

Studies identified by the literature search were screened for further review based on criteria focusing on patient population, intervention, study design, and type of outcome data reported. The screen was performed by research nurses specially trained in the application of these criteria; we found excellent inter-rater reliability (kappa =0.95; 95% confidence interval [CI]: 0.73 to 1.0) among the three screeners following training and in subsequent periodic monitoring during the screening process.

The initial screen was based on the criteria for considering studies for the review and was implemented as lists of keywords that described specific examples to include or exclude. For example, for “patient type,” the general rule was that we would accept studies of adults with headache syndromes. This rule was supplemented with lists of appropriate and inappropriate keywords such as the following: headache not otherwise specified, migraine, tension-type headache, tension headache, etc. Excluded were keywords such as “post-lumbar puncture headache.” In response to reviewers’ questions, the criteria were updated periodically throughout the selection process, based on titles and abstracts actually reviewed. The list of screening criteria is several pages long. Because these criteria applied to the overall headache project and not expressly to this report, they are not included here.

Studies passing the initial screen were reviewed for methodological quality (see below). Efficacy and adverse events data were abstracted from the original reports onto specially designed forms (see Appendix C) by the same research nurses who performed the initial screen. During the data abstraction process, the source of extracted data was indicated on the original published report using a highlighter and handwritten notes. The annotated published report was paired with the data abstraction form, and these were kept together during the remainder of the data management and analysis process. When statistical analyses were performed, key data elements were verified on the original report.

### Evaluation of Methodological Quality of Individual Trials

We assessed the internal validity of individual trials using a scale devised by Jadad, Moore, Carroll, et al. (1996) (Exhibit 1). This scale evaluates methodological quality based on the following considerations: the use of random allocation; description of an adequate method of concealment of allocation; the use of double-blinding; description of an adequate method of blinding; and a description of dropouts sufficient to determine the number of patients in each treatment group entering and completing the trial. These criteria were applied during data abstraction using a standardized form with written definitions (see Appendix C and below). Each trial could score between 0. and 5 points, with higher scores indicating higher quality in the conduct or reporting of the trial.

Exhibit 1 Instrument to measure the likelihood of bias in pain research reports

| Question | Response | Score
1 | Was the study described as randomized (this includes the use of words such as randomly, random and randomization)? | Yes No | 1 0
1a | If the method of generating the sequence of randomization was described, was it adequate (table of random numbers, computer-generated, coin tossing, etc.) or inadequate (allocated alternately, according to date of birth, hospital number, etc.)? | Not described/NA Adequate Inadequate | 0 1 −1
2 | Was the study described as double-blind? | Yes No | 1 0
2a | If the method of blinding was described, was it adequate (identical placebo, active placebo, dummy, etc.) or inadequate (comparison of tablet vs. injection with no double dummy)? | Not described/NA Adequate Inadequate | 0 1 −1
3 | Was there a description of withdrawals and dropouts? | Yes No | 1 0

Source: Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: is blinding necessary? Controlled Clin Trials 1996;17(1): 1–12. Reprinted with permission from Elsevier Science.

Each of the items on this quality scale is an accepted criterion that has been empirically validated. The Jadad instrument is one of only a few such scales that has undergone a formal process of development and demonstrated good inter-rater reliability (Moher, Jadad, Nichol, et. al., 1995).

The score assigned to each trial is described in the text of the report and in Evidence Table 1. Components of the score have been noted as follows:

Either “not randomized” or “randomized,” with a “+” after “randomized” if the method of randomization was described and was adequate, and a “−” after “randomized” if the method of randomization was described, but was inadequate.

Either “not double-blind” or “double-blind,” with a “+” after “double-blind” if the method of blinding was described and was adequate, and a “−” after “double-blind” if the method of blinding was described, but was inadequate.

Either “no description of dropouts” or “dropouts described.”

Thus, for example, a trial that was explicitly described as “randomized” would receive 1 point; if it did not provide a description of the methods for generating the sequence of randomization, it would not receive a point (0 points); if it was explicitly described as double-blinded, it would receive 1 point; if it provided a description of an adequate method of blinding, it would receive another 1 point (designated with a “plus” sign); if it did not describe dropouts or withdrawals (and we could not determine them from the number of patients included in the efficacy analyses), the study would not receive a point (0 points). This hypothetical trial; therefore, would receive a quality score of “3” and would be described in Evidence Table 1 as “randomized, double-blind+, no description of dropouts.”

When describing individual trials in the text of the report, we have consistently identified trials with a quality score of 2 or lower.

### Types of Participants

Subjects were required to meet reasonable criteria designed to distinguish migraine from tension-type headache, or if patients with both types of headache were included, results had to be stratified by headache diagnosis. Although the use of a specific set of diagnostic criteria (e.g., Ad Hoc Committee on the Classification of Headache, 1962; Headache Classification Committee of the International Headache Society [IHS], 1988) was not required, diagnoses were required to be based on at least some of the distinctive features of migraine, e.g., nausea/vomiting, severe head pain, throbbing character, unilateral location, phono/photophobia, or aura. Furthermore, secondary headache disorders had to be excluded using reasonable criteria. No further restrictions were placed on studies regarding particular inclusion or exclusion criteria relating to the frequency, duration, or severity of migraine headaches.

Many of the trials reviewed in this report included patients described as having “mixed” migraine and tension-type headaches or “combination” headaches. It was not always clear whether these descriptions referred to patients who had discrete episodes of migraine and discrete episodes of tension-type headache, or to patients with headaches which (in the view of the investigators) combined features of migraine and tension-type headache. As the IHS criteria allow, we considered patients in either of these categories to have migraine. Wherever separate results were reported for migraine and “mixed” or “combination” patients, we described and analyzed these results separately. Trials and treatment groups including only patients with tension-type headache were excluded from consideration.

### Types of Interventions

Each study was required to have at least one arm in which a pharmacological treatment was given regularly during headache-free intervals with the aim of preventing the occurrence of migraine attacks in patients with migraine headaches. Provided that one treatment arm in a study met this criterion, comparator groups could comprise placebo, parenterally administered drug treatments, or behavioral or physical therapies.

We required that the drugs studied be available clinically (in the U.S. or abroad) and included only commercially available dosages. Studies of drugs that have been withdrawn from the U.S. market were excluded.

### Outcome Definitions

The interventions considered in this report are preventive in aim, i.e., they focus on reducing the frequency and/or intensity of recurrent migraine headaches and not on aborting or relieving individual acute episodes. We collected trial data on symptomatic outcomes related to head pain (frequency, severity/intensity, and duration) and other symptoms of migraine (nausea, vomiting, photophobia, phonophobia). Secondary outcomes recorded included medication use, functional status (disability), and quality of life. We did not consider physiological or other measures not directly relevant to the patients’ symptomatic experience.

We preferred combined measures of headache symptoms such as headache indexes (variously defined combinations of frequency, intensity, and duration). In the absence of a headache index, we recorded headache frequency alone. Studies have shown that headache frequency is significantly correlated with both headache intensity and duration (Penzien, Johnson, Seville, et al., 1994). If neither headache index values nor frequency data were reported, we analyzed data on headache intensity.

### Specific Requirements for Outcome Data

#### Source of Data

We required that outcome data be obtained directly from the patient, not judged by the treating physician or study personnel. We preferred that outcome data be based on daily recording of headache symptoms, rather than on global or retrospective assessments.

#### Timing of Outcome Measurement

Outcomes were recorded post-treatment and at followup, if available. Post-treatment was considered to be between 8 and 12 weeks after the start of treatment or immediately following the end of treatment, whichever was later. We considered followup data to be that recorded at the last available time for which the dropout rate was less than 20% and for which data were reported for all treatment groups.

#### Use of Acute Medication

Many trials permitted the use of medication for acute migraine attacks experienced during the trial period. We recorded descriptions of trial rules concerning the use of medication in the Evidence Tables whenever such information was provided in the studies. We did not otherwise model or adjust for this factor in the analysis.

#### Analysis of Crossover Trials

Crossover designs are sometimes used for trials of preventive drugs for migraine. In most cases the data reported do not permit analysis of paired within-patient data. We analyzed crossover trials as if they were parallel-group trials, combining data from all treatment periods. If a carry-over effect was found and data were given by period, then we restricted our analysis to period one data only. In rare cases, complete data were reported, and within-patient improvement scores could be calculated.

### Data Analysis

#### Dichotomous Data

Some studies reported treatment success and failure as a dichotomous outcome. In such cases, we required that the threshold for distinguishing between success and failure be clinically significant; for example, we interpreted a 50% or more decrease in headache frequency or headache index as meeting this criterion.

Dichotomous outcomes meeting our definition of a clinically significant threshold were reported in the Evidence Tables as proportions (or response rates for each treatment) which may be directly compared (difference in proportions). For those physical treatment trials that reported outcomes in dichotomous form, we also used these proportions to calculate odds ratios (Fleiss, 1981). An odds ratio estimate of 1 indicates “even odds” or no treatment effect, while an odds ratio greater than 1 indicates greater likelihood of improvement with the tested treatment than the comparator. The 95% CI for the odds ratio can be interpreted as a test of statistical significance; if the confidence limit excludes 1 (null effect), then the treatments are significantly different. The odds ratio is a relative measure of efficacy and should be interpreted along with the response rates and the difference in response rates between groups. The odds ratio approximates the risk ratio at low event rates; however, the response rates among headache studies are high enough so that these are large differences between the odds ratio and risk ratio, with the odds ratio overestimating risk ratio substantially.

Most of the preventive drug treatment trials we reviewed reported continuous outcome data, rather than dichotomous or ordinal; our meta-analysis of those trials was accordingly based on the continuous data.

#### Ordinal Data

In the few instances in which outcome data were reported on an ordinal scale (e.g., for reduction in headache frequency: none, some, moderate, significant, very significant), we selected a threshold based on the definition of clinically significant improvement (discussed above) and converted these data into a dichotomous outcome.

#### Continuous Data

General. For outcomes reported on a continuous scale (e.g., mean headache index or mean headache frequency), we identified pre- and post-treatment group mean scores wherever possible. When variance data were also reported, these pre- and post-treatment group mean scores were rescaled and standardized for each treatment condition in each study, as described by Hasselblad (1998). The resulting standardized outcome measures were used to:

- Calculate effect sizes for pair-wise comparisons of preventive drug treatments with placebo for every trial with a placebo arm; and
- Calculate summary effect sizes for each type of treatment considered in the meta-analysis.

Each of these analytical procedures is described in greater detail below.

Many trials reported pre- and post-treatment group means, but did not report data on the variance associated with these means. In such cases, we attempted to calculate or estimate variances based on primary data or test statistics, if these were reported.

When a trial used pre- and post-treatment scores to calculate a change score for each patient and used these within-patient change scores to calculate a group mean change score, then we used these group mean change scores. When only post-treatment data were available for each treatment group, we used these data, relying on allocation to achieve between-group balance.

Throughout the report, wherever we have used the word “significant” to describe results, we mean “statistically significant at an alpha level of 0.05 for the two-sided alternative hypothesis.” Wherever we have reported on results that are clinically, rather than statistically, significant, we have explicitly used the word “clinically.”

Meta-analysis. As stated above, whenever pre- and post-treatment group means and variance data were available, we rescaled and standardized the group mean scores for each treatment condition in each study, as described by Hasselblad (1998). We then included the resulting rescaled and standardized outcome measures from individual studies in a multivariable, random-effects model to estimate a summary effect size for each type of treatment, controlling for study (Hasselblad, 1998).

For the purposes of this analysis, interventions were grouped into categories based in part on statistical considerations (such as the number of trials of a given intervention) and in part on clinical considerations (such as the way interventions are combined in clinical use; e.g., cognitive-behavioral therapy usually includes relaxation training).

Pair-wise comparisons. The same rescaled and standardized outcome measures used in the meta-analysis were also used to calculate effect sizes for all pair-wise comparisons of a preventive drug treatment versus a placebo or comparator treatment using techniques described by Hasselblad (1998). These effect sizes are reported in Evidence Tables 2 through 11. They show the results of individual trials in the same framework and terms as were used in the meta-analysis and should help the reader interpret both the results of the meta-analysis and the contribution of individual trials to those results.

This type of pair-wise effect size is a unitless index that describes the distance between two group means in terms of the population’s standard deviation. These effect sizes are relative, and may best be interpreted by referring to the group mean differences observed in the original measures of the study. Unlike the odds ratio, however, the effect size point estimate provides some information about the magnitude of the treatment difference. For general purposes, effect size point estimates can be interpreted by the following conventional frame of reference: 0.2 is small, 0.5 is medium, and 0.8 or more is a large effect size (Cohen, 1988). An effect size may be interpreted as statistically significant if its 95% CI excludes zero (null effect). The effect size can vary between negative infinity and infinity.

### Adverse Events

The incidence of adverse events was recorded and the proportion of patients experiencing adverse events calculated for each treatment group, whenever possible. The difference between rates of adverse events was calculated, along with a 95% CI for the difference. A 95% CI that excludes zero suggests that the rates are significantly different between groups. The identity and rates of specific adverse events reported were summarized for each study, as reported by investigators. Criteria for reporting adverse events vary greatly among trials with regard to terminology used, method of ascertainment, attribution of specific adverse events as drug-related or not, and classification as severe or not.

## Alpha-2 Agonists

This section of the report describes trials that have evaluated the efficacy and safety of alpha-2 agonists for the prevention of migraine. Alpha-2 agonists are antihypertensive agents that “block central vasomotor reflexes and diminish vascular reactivity” (Anthony, Lance, and Somerville, 1972). Of the included trials, most concern clonidine hydrochloride; guanfacine, the other drug represented, is pharmacologically similar to clonidine.

### Studies Identified

#### Overview

The review identified 20 publications reporting on 17 separate controlled trials of alpha-2 agonists (Adam, Gore, and Price, 1978; Anthony, Lance, and Somerville, 1972; Behan, 1985; Boisen, Deth, Hübbe, et al., 1978; Bredfeldt, Sutherland, and Kruse, 1989; Das, Ahuja, and Narainaswamy, 1979; Elkind, Webster, Herbertson, et al, 1989a; Elkind, Webster, Herbertson, et al., 1989b; Kallanranta, Hakkarainen, Hokkanen, et al., 1977; Kåss and Nestvold, 1980; Louis, Schoenen, and Hedman, 1985a; Louis, Schoenen, and Hedman, 1985b; Mondrup and Møller, 1977; Ryan, Diamond, and Ryan, 1975; Ryan and Ryan, 1975a; Ryan and Ryan, 1975b; Shafar, Tallett, and Knowlson, 1972; Sjaastad and Stensrud, 1971; Stensrud and Sjaastad, 1976a; Wilkinson, 1970). One of these publications (Kallanranta, Hakkarainen, Hokkanen, et al., 1977) reported results from two separate trials, one comparing clonidine with placebo (Study 1), and another comparing clonidine with practolol (Study 2).

Four publications were excluded from our analysis for the reasons cited in Exhibit 2.

Exhibit 2 Excluded publications: Alpha-2 agonist trials

Excluded publications | Reason for exclusion
Elkind, Webster, Herbertson, et al., 1989b | Abstract of Elkind, Webster, Herbertson, et al., 1989a-Added no new information.
Louis, Schoenen, and Hedman, 1985b | Abstract of Louis, Schoenen, and Hedman, 1985a-Added no new information.
Ryan and Ryan, 1975a | Reported results from one of two sites more fully described in Ryan, Diamond, and Ryan, 1975
Ryan and Ryan, 1975b | Reported preliminary results from first half of trial described in Ryan, Diamond, and Ryan, 1975

Our analysis thus included 16 published reports on 17 separate trials, with 16 of the trials reporting on clonidine and one reporting on guanfacine (Elkind, Webster, Herbertson, et al., 1989a).

Twelve trials compared alpha-2 agonists with placebo, four compared clonidine with a beta-blocker (metoprolol, prindolol, practolol, and propranolol), and one trial each compared clonidine with an anticonvulsant (carbamazepine) and a serotonin antagonist (pizotifen).

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Two of the 17 included trials were parallel-group in design (Behan, 1985; Elkind, Webster, Herbertson, et al., 1989a); 14 were crossover. One study (Anthony, Lance, and Somerville, 1972) was a partial crossover trial with three interventions. Patients who did not achieve success with one trial medication switched at the end of the first month to one of the others, while those who were successful continued on the initial medication. The investigators reported first-period (1-month) data separately, and we analyzed these data as if the trial were parallel-group in design. One of the crossover trials (Shafar, Tallett, and Knowlson, 1972) compared clonidine with placebo during four 8-week treatment periods. Although the crossover pattern was not described, we assumed that patients received each treatment twice.

Active treatment periods in the included trials ranged from 3 weeks (one trial) to 24 weeks (6 months) (one trial); the average length of the active treatment period was 2.4 months.

Quality scores ranged from 0 (two trials) to 4 (two trials); the average score was 2.4.

#### Patient Populations

Six trials provided no information about the setting in which patients were recruited. In five cases, patients were recruited from neurology departments or hospital clinics (Anthony, Lance, and Somerville, 1972; Boisen, Deth, Hübbe, et al., 1978; Kallanranta, Hakkarainen, Hokkanen, et al., 1977 [two studies]; Mondrup and Møller, 1977). Patients were recruited from headache clinics in two trials (Behan, 1985; Ryan, Diamond, and Ryan, 1975) and from general practice clinics in two trials (Adam, Gore, and Price, 1978; Bredfeldt, Sutherland, and Kruse, 1989). One trial recruited subjects who were inpatients at hospitals (Wilkinson, 1970), and two recruited patients through physician referrals (Bredfeldt, Sutherland, and Kruse, 1989; Shafar, Tallett, and Knowlson, 1972).

All of the trials reviewed included patients with migraine with or without aura. Most did not explicitly exclude patients who also suffered attacks of tension-type headache. In one study, approximately half of the patients had tension-type as well as migraine headaches (Stensrud and Sjaastad, 1976a). One trial reported that investigators “avoided” including patients with a combination of migraine and tension-type headaches, but did not explicitly exclude such patients (Kåss and Nestvold, 1980). Another trial excluded patients who were unable to distinguish attacks of migraine from tension-type headaches (Louis, Schoenen, and Hedman, 1985a). Four trials referred specifically to the Ad Hoc diagnostic criteria for migraine; none referred to the IHS criteria.

Most of the trials had minimum headache frequency requirements for inclusion. In one study, investigators explicitly recruited patients with migraines of “significant frequency and severity” (Shafar, Tallett, and Knowlson, 1972). Two trials did not specify any frequency requirements (Kåss and Nestvold, 1980; Stensrud and Sjaastad, 1976a).

Most of the included trials permitted the use of medication for acute attacks of migraine occurring during the trial.

Six of the 17 trials did not report the average age of patients, and two did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 17 to 65, and the percentage of patients who were women ranged from 64% to 89%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 2.

#### Comparisons With Placebo

Clonidine. Eleven trials compared clonidine with placebo (Adam, Gore, and Price, 1978; Boisen, Deth, Hübbe, et al., 1978; Bredfeldt, Sutherland, and Kruse, 1989; Das, Ahuja, and Narainaswamy, 1979; Kallanranta, Hakkarainen, Hokkanen, et al., 1977; Mondrup and Møller, 1977; Ryan, Diamond, and Ryan, 1975; Shafar, Tallett, and Knowlson, 1972; Sjaastad and Stensrud, 1971; Stensrud and Sjaastad, 1976a; Wilkinson, 1970). Ten trials administered clonidine orally; one (Bredfeldt, Sutherland, and Kruse, 1989) used a transdermal patch.

Three of the 11 trials reported that clonidine was significantly better than placebo, with a reduction in headache frequency observed in Kallanranta, Hakkarainen, Hokkanen, et al., (1977) (Study 1), and a reduction in headache index in Sjaastad and Stensrud (1971) and Stensrud and Sjaastad (1976a). Even these positive studies, however, did not demonstrate large differences between clonidine and placebo. The effect size calculated from Kallanranta, Hakkarainen, Hokkanen, et al. (1977) (Study 1) was a moderate 0.45 (0.05 to 0.85), corresponding to a difference in mean headache frequency of 0.72 headaches per month from a baseline average of nearly three headaches per month in the population studied. Few other studies reported sufficient data to quantify the magnitude of the treatment effect; thus, no meta-analysis of the results was possible.

Guanfacine. A single small (n =37) study compared two doses of guanfacine to placebo (Elkind, Webster, Herbertson, et al., 1989a). This study reported a statistically significant effect on headache frequency with the higher dose (1.0 mg/day), but no effect with the lower dose (0.5 mg/day) when compared to placebo. No data on the magnitude of the effect were reported.

#### Comparisons With Beta-blockers

Clonidine was compared with four different beta-blockers in four separate, relatively small trials. Louis, Schoenen, and Hedman (1985a) found that metoprolol reduced headache index significantly better than clonidine (p<0.05). Similar proportions of patients reported a greater than 50% reduction in headache frequency (28% and 37% for clonidine and metoprolol, respectively). A small study comparing clonidine and propranolol (Kåss and Nestvold, 1980) showed reductions in headache frequency that were not significantly different for the two drugs (38% and 62% for clonidine and propranolol, respectively).

Two studies compared clonidine with the beta-blockers practolol and prindolol, both of which have intrinsic sympathomimetic activity. Kallanranta, Hakkarainen, Hokkanen, et al. (1977) (Study 2) reported that clonidine produced a significantly greater reduction in headache frequency than did practolol (p<0.05); however, the effect size we calculated suggests a modest benefit of 0.21 (−0.19 to 0.60). No difference in headache frequency was found between clonidine and prindolol in the other trial (Anthony, Lance, and Somerville, 1972).

#### Comparisons With Other Agents

Two small trials comparing clonidine with pizotifen and carbamazepine found no statistically significant differences in headache frequency between treatments (Anthony, Lance, and Somerville, 1972; Behan, 1985). The single trial of carbamazepine (Anthony, Lance, and Somerville, 1972) reported a large difference in the proportion of patients experiencing a 50% or greater reduction in headache frequency: 53% versus 33% for clonidine and carbamazepine, respectively; this difference, however, was not significantly different.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

The incidence of adverse events in patients taking clonidine in the included trials ranged from 16% to 86%. Withdrawals due to adverse events were relatively uncommon, occurring in 0% to 11% of patients. Specific adverse events associated with clonidine included drowsiness or tiredness, occurring in up to 38% of patients in two studies, and dry mouth, which was reported less frequently, in 2% to 16% of patients. Even less commonly reported were nausea or gastrointestinal effects, and dizziness or vertigo. In trials comparing clonidine to beta-blockers, adverse events occurred at similar rates for both interventions.

The single trial of guanfacine (Elkind, Webster, Herbertson, et al., 1989a) reported no substantial data on adverse events.

### Conclusions

The existing trials suggest that clonidine is, at most, mildly effective for the prevention of migraine, but this has not been demonstrated conclusively. The positive placebo-controlled studies do not appear to be systematically different from the negative trials. In comparisons with beta-blockers with intrinsic sympathomimetic activity (practolol and prindolol), for which evidence for efficacy is lacking, clonidine has consistently been less effective, though not to a statistically significant degree.

There is insufficient evidence to conclude that guanfacine is effective for the prevention of migraine (one small, placebo-controlled study with no data on the magnitude of effect).

Adverse events (most commonly drowsiness or tiredness) were observed in a high proportion of patients in trials of clonidine, but the reported symptoms were usually neither serious nor cause for withdrawal from these relatively short-term trials. No information was available on adverse events associated with guanfacine.

## Anticonvulsants

A few drugs normally used as anticonvulsants have been employed as migraine preventive agents. The literature review identified controlled trials of divalproex sodium, sodium valproate, carbamazepine, clonazepam, and gabapentin for this indication. This section of the report reviews the evidence for the safety and efficacy of these agents.

### Studies Identified

#### Overview

The literature review identified nine publications reporting on nine separate controlled trials of anticonvulsants used for the prevention of migraine (Anthony, Lance, and Somerville, 1972; Hering and Kuritzky, 1992; Jensen, Brinck, and Olesen, 1994; Klapper, 1994; Klapper, 1996; Mathew, Saper, Silberstein, et al., 1995; Rompel and Bauermeister, 1970; Stensrud and Sjaastad, 1979; Wessely, Baumgartner, Klingler, et al., 1987). All nine publications were included in our analysis.

The included studies reported on the safety and efficacy of the following agents:

Divalproex sodium | 3 trials
Sodium valproate | 2 trials
Carbamazepine | 2 trials
Clonazepam | 1 trial
Gabapentin | 1 trial

Seven trials compared anticonvulsants with placebo, two compared an anticonvulsant with a beta-blocker, and one compared an anticonvulsant with an alpha-2 agonist.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Five of the nine included trials were crossover in design; three were parallel-group. One study (Anthony, Lance, and Somerville, 1972) was a partial crossover trial with three interventions. Patients who did not achieve success with one trial medication switched at the end of the first month to one of the others, while those who were successful continued on the initial medication. The investigators reported first-period (1-month) data separately, and we analyzed these data as if the trial were parallel-group in design.

Active treatment periods in the included trials ranged in length from 1 month (two trials) to 3 months (four trials); the average length of the active treatment periods was 2.2 months.

Quality scores ranged from 1 (one trial) to 5 (one trial); the average score was 3.2.

#### Patient Populations

Four of the nine included trials provided no information about the setting in which patients were recruited. In three cases patients were drawn from headache clinics (Hering and Kuritzky, 1992; Jensen, Brinck, and Olesen, 1994; Klapper, 1996), in one case from a neurology clinic (Anthony, Lance, and Somerville, 1972), and in one case from headache and neurology clinics (Mathew, Saper, Silberstein, et al., 1995).

The majority of the trials reviewed (seven of nine) included patients with migraine with or without aura. One trial was restricted to patients with migraine without aura (Jensen, Brinck, and Olesen, 1994). Another included only patients with what was described as “typical” migraine (Rompel and Bauermeister, 1970); on the basis of the diagnostic criteria described in the article, we concluded that this referred to migraine with aura. Four trials referred specifically to the IHS diagnostic criteria for migraine, and two referred to the Ad Hoc criteria. All but two of the included trials had minimum migraine headache frequency requirements for inclusion (Rompel and Bauermeister, 1970; Wessely, Baumgartner, Klingler, et al., 1987).

Two trials explicitly excluded patients with chronic daily headache and patients with tension-type headache on 15 or more days per month (Klapper, 1996; Mathew, Saper, Silberstein, et al., 1995). In one case, investigators stated that “more than half” of the patients participating in the trial suffered from interval headaches of the tension type, in addition to their migraines (Stensrud and Sjaastad, 1979).

Klapper (1994) required that patients have no previous experience with the drugs being investigated in the trial (divalproex sodium and propranolol). Two other trials included only patients who had never tried preventive medication or who had failed two or fewer adequate trials of such medication (Klapper, 1996; Mathew, Saper, Silberstein, et al., 1995).

Three trials did not report whether patients were allowed to use medication for acute attacks of migraine occurring during the trial (Anthony, Lance, and Somerville, 1972; Klapper, 1994; Rompel and Bauermeister, 1970); the remaining six permitted the use of such medication.

Four of the nine trials did not report the average age of patients, and one did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 34 to 46, and the percentage of patients who were women ranged from 69% to 89%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 3.

#### Comparisons With Placebo

Divalproex sodium. Two parallel-group trials of similar design compared divalproex sodium with placebo (Klapper, 1996; Mathew, Saper, Silberstein, et al., 1995). Klapper (1996) tested three doses of divalproex sodium, 1500 mg/day, 1000 mg/day, and 500 mg/day. In Mathew, Saper, Silberstein, et al. (1995), the dose was individually titrated to achieve a serum level of 70–120 milligrams per liter (mg/L); the average dose taken was 1087 mg/day. In both trials, the active treatment period lasted 12 weeks, including 4 weeks of initial dosage adjustment.

The two trials were consistent in finding all doses of divalproex sodium significantly better than placebo for reducing headache frequency. We were not able to calculate effect sizes from the continuous data reported (variance data were not reported and could not be estimated), but we were able, for each comparison with placebo, to calculate an odds ratio for the number of patients reporting a 50% or greater reduction in headache frequency. The proportion of patients experiencing a 50% or greater reduction in headache frequency was fairly consistent among all the active treatment groups, ranging from 43% to 48%. The resulting odds ratios were all statistically significant in favor of divalproex sodium. The largest point estimate (5.7) was from Mathew, Saper, Silberstein, et al. (1995), which reported a relatively low placebo response rate (14%). Odds ratio point estimates from the Klapper trial (1996) ranged from 2.7 for the 1000-mg dose to 3.1 for the 1500-mg dose, and the confidence intervals were narrower.

Sodium valproate. Sodium valproate is closely related to divalproex sodium. Two crossover trials compared this agent with placebo. Hering and Kuritzky (1992) tested an 800-mg daily dose, administered in two doses; Jensen, Brinck, and Olesen (1994) used a slow-release form of sodium valproate and titrated the dose (1000–1500 mg) to achieve a serum level above 50 mg/L. The latter trial was conducted among patients with migraine without aura only. The length of individual treatment periods was 8 weeks in Hering and Kuritzky (1992) and 12 weeks in Jensen, Brinck, and Olesen (1994).

In both cases, study investigators found that sodium valproate was significantly better than placebo at reducing headache frequency. We were able to calculate an effect size of 0.93 (0.39 to 1.5) from the data reported in one trial (Hering and Kuritzky, 1992) and an odds ratio of 7.1 (2.4 to 21) for the other trial. These confirmed the investigators’ findings.

Carbamazepine. A single crossover trial compared carbamazepine (600 mg/day) with placebo (Rompel and Bauermeister, 1970). Though it received a high quality score (5), the trial was inadequately described in many respects. Some results were reported for headache index (not defined) and headache frequency, but no p-values or other measures of statistical significance were provided. We were able to calculate an odds ratio for the percentage of patients achieving “marked or complete improvement” in headache index during the course of the 6-week trial period; the odds ratio was large (12) and statistically significant. There were other problems with the trial: baseline values were based on patient histories; it was not completely certain that the headache index outcomes reported were based on diary data; and the placebo response reported for the above outcome was low (10%).

Clonazepam. Stensrud and Sjaastad (1979) compared clonazepam with placebo. The trial provided no data that we could use to calculate an effect size or odds ratio. Investigators reported that there was no significant difference between clonazepam and placebo for headache index (p = 0.20).

Gabapentin. A single parallel-group trial with a low quality score (2) compared gabapentin, in a dose of 900 mg/day, with placebo (Wessely, Baumgartner, Klingler, et al., 1987). Limited results were reported in abstract form only. The investigators reported, but did not analyze, continuous data on headache frequency. We were not able to use these data to calculate an effect size (variance data were not reported and could not be estimated).

#### Comparisons With Beta-blockers

The literature review identified two trials comparing an anticonvulsant with a beta-blocking agent (Klapper, 1994; Anthony, Lance, and Somerville, 1972).

Divalproex sodium vs. propranolol. A single, open-label, crossover trial with a low quality score (2) compared divalproex sodium, in an average dose of 1100 mg/day, and propranolol, in an average dose of 140 mg/day (Klapper, 1994). Results were reported in abstract form only. Fifty percent of the 24 patients who started the trial withdrew before completing due to adverse events. The investigators reported mean post-treatment headache frequencies which suggested that divalproex sodium was better than propranolol at reducing headache frequency, but they did not analyze these results, and we were not able to use the reported means to calculate an effect size (variance data were not reported and could not be estimated).

Carbamazepine vs. prindolol. A single trial compared these two agents (Anthony, Lance, and Somerville, 1972). The trial was a partial crossover trial, in which patients who were not successful with their initial medication moved on to another of the study medications after the first month of treatment, while those who did achieve success continued on the initial medication. We analyzed the first-period data (which was reported separately) as if the trial were parallel-group in design. The trial received a low quality score (1).

We were able to calculate an odds ratio for the number of patients with a 50% or greater reduction in headache frequency after 1 month of treatment. The odds ratio was statistically significant in favor of prindolol, which confirmed the investigators’ findings.

#### Comparisons With Alpha-2 Agonists

The literature review identified only one comparison of an anticonvulsant with an alpha-2 agonist. The trial described immediately above (Anthony, Lance, and Somerville, 1972) compared carbamazepine with clonidine. The odds ratio we calculated for headache frequency suggested that clonidine was better than carbamazepine, but not significantly so. Once again, this agrees with the results of investigators’ analysis.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

#### Carbamazepine

In the only study comparing carbamazepine with placebo (Rompel and Bauermeister, 1970), the overall percentage of patients reporting adverse events was significantly higher with carbamazepine (63%) than with placebo (23%). Vertigo/giddiness and drowsiness were both more common with carbamazepine than with placebo (48% vs. 4% and 10% vs. 0%, respectively). One patient (of 48) withdrew due to unspecified adverse events associated with carbamazepine.

One trial was a partial crossover trial of carbamazepine vs. prindolol (Anthony, Lance, and Somerville, 1972). Data on adverse events from this study were reported for the entire trial only; no separate data were reported on the first treatment period. A significantly higher percentage of patients reported adverse events with carbamazepine (53%) than with prindolol (19%). Drowsiness/tiredness/weakness and giddiness/ataxia were more common with carbamazepine (14% vs. 3% and 20% vs. 1%, respectively). Twelve of 51 patients taking carbamazepine (24%) and 8/79 patients taking prindolol (10%) withdrew due to adverse events.

The same trial compared carbamazepine with clonidine (Anthony, Lance, and Somerville, 1972). Investigators found no significant difference in the percentage of patients reporting adverse events with carbamazepine (53%) and clonidine (41 %). Giddiness/ataxia was more common with carbamazepine (20% vs. 0%); dry mouth/sore tongue/bad taste was more common with clonidine (14% vs. 0%). Twelve of 51 patients taking carbamazepine (24%) and 8/73 patients taking prindolol (11 %) withdrew due to adverse events.

#### Clonazepam

A single trial compared clonazepam (l mg/day) with placebo (Stensrud and Sjaastad, 1979). This study also included an extended, uncontrolled trial of clonazepam at higher doses (1–3 mg/day). Data on adverse events were not reported separately for the controlled portion of the trial. The most common adverse events associated with clonazepam were drowsiness and dizziness. Three of 38 patients (8%) withdrew at the end of the controlled trial due to adverse events (lethargy and sleepiness). No data were provided on adverse events associated with placebo.

#### Divalproex Sodium

Two studies compared divalproex sodium with placebo (Klapper, 1996; Mathew, Saper, Silberstein, et al., 1995). None of the three doses of divalproex sodium used in Klapper (1996) was associated with an adverse event rate significantly higher than placebo. Eighty percent, 76%, 74%, and 86% of patients reported adverse events in the placebo, 500-mg, 1000-mg, and 1500-mg groups, respectively. Almost without exception, rates of individual adverse events were higher in the 1500-mg group than in the lower dose groups. Unspecified “gastrointestinal (GI) events” were the major cause of withdrawals in the divalproex sodium groups (three in the 500-mg group, two in the 1000-mg group, and six in the 1500-mg group); two patients withdrew from the placebo group due to adverse events. Mathew, Saper, Silberstein, et al. (1995) did not report the overall percentages of patients reporting adverse events with divalproex sodium and placebo, but found significantly higher rates of nausea (46% vs. 14%), asthenia (31 % vs. 8%), somnolence (30% vs. 5%), vomiting (19% vs. 0%), tremor (13% vs. 0%), and alopecia (13% vs. 0%) in the divalproex sodium group. Nine of 70 patients (13%) withdrew due to adverse events associated with divalproex sodium, 2/37 (5%) due to adverse events associated with placebo.

The one trial that compared divalproex sodium with propranolol (Klapper, 1994) reported data on adverse events only for those patients who withdrew due to adverse events. Of 24 patients evaluated in this crossover trial, nine withdrew while taking divalproex sodium (GI symptoms [three patients], fatigue [two patients], low white blood count [two patients], increasing headaches [one patient], rash [one patient]), and three while taking placebo (fatigue [two patients], increasing headaches [one patient]).

#### Gabapentin

Gabapentin was compared with placebo in a single trial (Wessely, Baumgartner, Klingler, et al., 1987). Very limited data were reported on adverse events for this treatment comparison. Two of 16 patients (13%) in the gabapentin group and 1/20 (5%) in the placebo group withdrew due to nausea, tiredness, and dizziness (no breakdown by treatment group).

#### Sodium Valproate

Two trials compared sodium valproate with placebo (Hering and Kuritzky, 1992; Jensen, Brinck, and Olesen, 1994). Neither trial found a significant difference in the overall percentage of patients reporting adverse events with the two treatments. Hering and Kuritzky (1979) reported that 21% of patients reported adverse events while taking sodium valproate, compared with 7% of patients while taking placebo. Three patients not included in this count withdrew due to unspecified adverse events, in one case associated with sodium valproate and in two cases associated with placebo. Jensen, Brinck, and Olesen (1994) reported that 33% of patients experienced adverse events while taking sodium valproate, compared with 16% while taking placebo. There were no striking differences in the occurrence of individual adverse symptoms. Four patients withdrew due to adverse events while taking sodium valproate, two while taking placebo.

### Conclusions

Strong and consistent evidence supports the efficacy of divalproex sodium and the related compound sodium valproate for the prevention of migraine. The evidence for the efficacy of other anticonvulsant agents is weaker. Carbamazepine has mixed support from one placebo-controlled trial (suggesting efficacy) and one comparison with prindolol and clonidine (suggesting a smaller effect on headache frequency than either comparator). Neither clonazepam nor gabapentin appears to be an effective migraine preventive drug.

Adverse events -- most commonly dizziness and drowsiness -- were frequently observed with anticonvulsants and were a frequent cause of patient withdrawals from trials.

## Antidepressants

This section of the report considers the evidence for the safety and efficacy of antidepressants for the prevention of migraine. The literature review identified trials of the tricyclic antidepressants amitriptyline, clomipramine, and opipramol; the selective serotonin re-uptake inhibitors (SSRIs) femoxetine, fluoxetine, and fluvoxamine; and the tetracyclic antidepressant mianserin. Opipramol, fluoxetine, and mianserin are not available in the US.

The precise relationship between the effect of the above antidepressants on mood and their effect on migraine is unclear, but it is generally thought that the two effects are independent of one another.

### Studies Identified

#### Overview

The literature review identified 21 publications reporting on 17 separate controlled trials of antidepressants used for the prevention of migraine (Adly, Straumanis, and Chesson, 1992; Andersson and Petersen, 1981; Bánk, 1994; Bonuso, Di Stasio, Barone, et al., 1983; Couch and Hassanein, 1976; Couch and Hassanein, 1979; Gomersall and Stuart, 1973; Jacobs, 1972; Kangasniemi, Nyrke, Lang, et al., 1983; Langohr, Gerber, Koletzki, et al., 1985; Mathew, 1981; Monro, Swade, and Coppen, 1984; Monro, Swade, and Coppen, 1985; Nappi, Sandrini, Granella, et al., 1990; Noone, 1980; Orholm, Honoré, and Zeeberg, 1985; Orholm, Honoré, and Zeeberg, 1986; Saper, Silberstein, Lake, et al., 1994; Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981; Ziegler, Hurwitz, Hassanein, et al., 1987; Ziegler, Hurwitz, Preskorn, et al., 1993).

Three publications were excluded from our analysis for the reasons cited in Exhibit 3.

Exhibit 3 Excluded publications: Antidepressant trials

Excluded publication | Reason for exclusion
Monro, Swade, and Coppen (1984) | Abstract of Monro, Swade, and Coppen (1985); added no new information.
Nappi, Sandrini, Granella, et al. (1990) | Examined patients with chronic headache and depression/dysthymic disorder; included patients with chronic tension-type headache (n = 11) and patients with migraine (n = 27), but did not report results separately by headache type.
Orholm, Honoré, and Zeeberg (1985) | Abstract reporting preliminary results from trial more fully described in Orholm, Honoré, and Zeeberg(1986); added no new infonnation.

Couch and Hassanein (1976) was a 12-month interim report on the trial more fully described in Couch and Hassanein (1979). The interim report provided some information not available in the final report. For that reason, we created combined entries for the two trials in Evidence Tables 1 and 12. The trial will be referred to in the text of this report and in Evidence Table 4 as Couch and Hassanein (1976 and 1979). Finally, Ziegler, Hurwitz, Preskorn, et al. (1993) was a study of predictors of response to treatment in the same study population reported on in Ziegler, Hurwitz, Hassanein, et al. (1987). The principal conclusions of the predictor study are summarized briefly in the entry for the main study in Evidence Table 1.

Our analysis thus included 18 published reports on 16 separate trials. The included studies reported on the safety and efficacy of the following agents:

Amitriptyline | 6 trials
Femoxetine | 4 trials
Clomipramine | 2 trials
Fluoxetine | 2 trials
Fluvoxamine | 1 trial
Mianserin | 1 trial
Opipramol | 1 trial

Eleven trials compared antidepressants with placebo; one compared two antidepressants with one another; five trials compared antidepressants with beta-blockers; and one trial compared an antidepressant with timed-release dihydroergotamine (DHE).

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Ten of the 16 included trials were parallel-group in design; six were crossover. One of the crossover trials (Langohr, Gerber, Koletzki, et al., 1985) included three different interventions, but had only two treatment periods, so that each patient tried only two of the three interventions.

The active treatment periods ranged from 1 month in length (one trial) to 6.25 months (27 weeks) (one trial); the average length of the active treatment period was 2.9 months.

Quality scores ranged from 2 (two trials) to 4 (five trials); the average score was 3.2.

#### Patient Populations

Seven trials provided no information about the setting in which patients were recruited. In three cases, patients were recruited from general practice settings or by referral from general practitioners (Jacobs, 1972; Orholm, Honoré, and Zeeberg, 1986; Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981). Noone (1980) recruited patients from two private practices of unspecified type. In one trial (Kangasniemi, Nyrke, Lang, et al., 1983), patients were recruited from a neurologist’s private practice, and in two others (Couch and Hassanein, 1976 and 1979; Saper, Silberstein, Lake, et al., 1994) from specialty headache clinics. In the remaining two cases (Adly, Straumanis, and Chesson, 1992; Gomersall and Stuart, 1973), subjects were recruited through newspaper or other media advertisements.

The majority of the trials reviewed (13 of 16) included patients with migraine with or without aura. Most did not explicitly exclude patients who also suffered attacks of tension-type headache. Four of these 13 trials referred specifically to the Ad Hoc diagnostic criteria for migraine, and 1 referred to the IHS criteria.

Mathew (1981) included patients with migraine only (n = 340) and patients with mixed headache (n = 375) and reported results separately for the two groups; we describe both sets of results below. Saper, Silberstein, Lake, et al. (1994) reported separate results for patients with migraine (n = 58) and patients with chronic daily headache (n = 64); we describe only the migraine results. Finally, Bonuso, Di Stasio, Barone, et al. (1983) compared amitriptyline with timed-release DHE in a population of patients with mixed headache, defined, in this instance, as alternating bouts of migraine and tension-type headache.

Most of the included trials had minimum headache frequency requirements for inclusion. A few required that a certain number or percentage of patients’ attacks be severe in intensity (Adly, Straumanis, and Chesson, 1992; Couch and Hassanein, 1976 and 1979; Gomersall and Stuart, 1973; Ziegler, Hurwitz, Hassanein, et al., 1987).

Three trials did not provide any information about whether patients were allowed to use medication for acute attacks of migraine occurring during the trial (Andersson and Petersen, 1981; Jacobs, 1972; Orholm, Honoré, and Zeeberg, 1986); the remaining thirteen trials permitted the use of such medication.

Eight of the 16 trials did not report the average age of patients, and 3 did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 34 to 44, and the percentage of patients who were women ranged from 67% to 96%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 4.

#### Comparisons With Placebo

Amitriptyline. Three trials compared amitriptyline with placebo (Couch and Hassanein, 1976 and 1979; Gomersall and Stuart, 1973; Ziegler, Hurwitz, Hassanein, et al., 1987). The daily doses of amitriptyline used were 50–150 mg (Ziegler, Hurwitz, Hassanein, et al., 1987),50–100 mg (Couch and Hassanein, 1976 and 1979), and 30–60 mg (Gomersall and Stuart); the length of the treatment period was 8,4, and 27 weeks, respectively. Both Couch and Hassanein (1976 and 1979) and Ziegler, Hurwitz, Hassanein, et al. (1987) studied patients who frequently had severe or disabling attacks and reported outcomes that focused on relatively severe attacks.

The three trials were consistent in finding amitriptyline significantly better than placebo. We were able to calculate statistical measures (odds ratios or effect sizes) only for Couch and Hassanein (1976 and 1979) and so could not combine results from more than one trial.

The primary outcome analyzed by Couch and Hassanein (1976 and 1979) was the reduction in mean migraine index from pre- to post-treatment (4 weeks). The migraine index incorporated frequency and duration and included severe and disabling attacks only. Investigators reported that amitriptyline was significantly better than placebo for this outcome (p<0.01). The interim report (1976) provided mean scores (reported in Evidence Table 4) for 73 of the 100 patients eventually included in the efficacy analysis. On basis of these data, we were able to calculate an effect size of 0.62 (0.15 to 1.1), which confirms the investigators’ findings.

We were also able to calculate an odds ratio of 2.4 (1.1 to 5.4) for the number of patients in each treatment group who reported an improvement of 50% or more in mean migraine index score, which confirms the investigators’ finding that amitriptyline was significantly better than placebo for this outcome (p<0.05).

Very similar results were reported for another index, the mean total headache index, which included attacks of moderate and mild intensity.

Ziegler, Hurwitz, Hassanein, et al. (1987) used a similar daily dose of amitriptyline (50–150 mg) on a similar group of patients, followed over an 8-week treatment period. Mean weekly headache index scores (incorporating frequency, severity, and duration) were calculated for each intervention, using only headaches with a severity score of 4 or more on scale of 1–10. Investigators found that amitriptyline was significantly better than placebo for this outcome (p<0.05). No variance data were reported, and we were unable to estimate variance, so no effect size could be calculated.

Gomersall and Stuart (1973) reported very limited information and used a much lower daily dose of amitriptyline (30–60 mg) than did the other two trials, but still found that amitriptyline was significantly better than placebo for the total number of attacks occurring in the last 26 weeks of each treatment period (p<0.001).

Clomipramine. Two small trials compared clomipramine with placebo. They used different daily doses, but were consistent in finding no significant difference between clomipramine and placebo for headache frequency.

A time series analysis (autoregressive integrated moving average [ARIMAD]) performed by Langohr, Gerber, Koletzki, et al. (1985) showed no significant difference between clomipramine (max 100 mg/day) and placebo for reduction in headache frequency from pre- to post-treatment (4 weeks) (no p-value reported). We were able to calculate an odds ratio using the conventional data the authors reported for the number of patients with a 50% or greater reduction in headache frequency. The odds ratio was 0.95 (0.25 to 3.6), which is not statistically significant.

Noone (1980) found no significant difference between clomipramine (30 mg/day) and placebo for reduction in headache frequency from pre- to post-treatment (8 weeks) (p = 0.46). We were unable to calculate an effect size for this outcome, since median and not mean frequency values were reported.

Femoxetine. Two trials compared femoxetine and placebo (Orholm, Honoré, and Zeeberg, 1985; Zeeberg, Honoré, Dalsgaard-Nielsen, et al., 1981). The two studies involved many of the same researchers, were similar in design, and employed similar analytical strategies. Patients in both trials were recruited from a general practice setting. The two trials agreed in finding no significant difference between femoxetine and placebo for headache index or frequency.

Fluoxetine. One very small (n = 18) parallel-group trial (Adly, Straumanis, and Chesson, 1992) found that fluoxetine, in a dose ranging from 20 mg every other day to 40 mg/day, was significantly better than placebo at reducing median headache index scores at the end of the 8-week treatment period (p<0.05). However, this finding was not repeated in another, larger trial (n =57 patients completed), employing an analysis of variance (ANOVA) analysis and conducted among patients recruited from a headache clinic, which found no significant differences between fluoxetine (20–40 mg/day) and placebo after 16 weeks of treatment (Saper, Silberstein, Lake, et al., 1994). We were not able to calculate odds ratios or effect sizes for either trial.

Mianserin. The only trial comparing mianserin with placebo (Monro, Swade, and Coppen, 1985) reported that mianserin (30 mg/day for 1 week, then 60 mg/day) reduced headache frequency significantly compared with baseline values (p<0.05 at 12 weeks), but was not significantly better than placebo for this outcome (no p-value reported). Similar results were reported for headache severity. We were not able to calculate an odds ratio or effect size on the basis of the data reported in this study.

Opipramol. A single trial compared opipramol with placebo (Jacobs, 1972). The investigators’ analysis found that opipramol (150 mg/day) was significantly better than placebo at 12 weeks for mean reduction in number of attacks per patient (0.05>p>0.02). We could not calculate an effect size for this outcome, because no variance data were reported and the variance could not be estimated.

#### Comparisons Among Antidepressants

The literature review identified only one trial comparing one antidepressant with another. Bank (1994) compared fluvoxamine with amitriptyline. Amitriptyline was administered in a relatively low dose (25 mg/day); the dose of fluvoxamine used was 50 mg/day. The investigators reported that both interventions significantly reduced median headache index scores from pre- to post-treatment (12 weeks) (p<0.0003 for fluvoxamine; p<0.001 for amitriptyline). They did not directly compare the two treatments for this or any other outcome. We were not able to calculate an effect size for reduction in headache index, since median and not mean scores were reported.

#### Comparisons With Beta-blockers

Amitriptyline vs. propranolol. Two trials compared amitriptyline and propranolol (Mathew, 1981; Ziegler, Hurwitz, Hassanein, et al., 1987). Mathew (1981) was a large and complicated trial, with eight different treatment arms. We discuss most of the treatment comparisons from this trial below, but describe the amitriptyline vs. propranolol results here.

Mathew (1981) used relatively low daily doses of amitriptyline (25–75 mg) and propranolol (60–160 mg) and followed patients over a 6-month treatment period. Among patients with mixed migraine and tension-type headache, the study investigator found that amitriptyline was significantly better than propranolol for percentage improvement in headache index scores (p<0.01). We calculated an effect size based on pre- and post-treatment mean headache index scores in both groups. The effect size was −0.15 (−0.62 to 0.32), which does not confirm the investigator's finding. In the investigator's analysis, the combination of propranolol + amitriptyline was found to be superior to either drug on its own (p < 0.01) in this group of patients.

Among patients with migraine only, Mathew (1981) found that propranolol was significantly better than amitriptyline for percentage improvement in headache index scores; our effect size calculation using mean headache index scores did not confirm this finding (effect size: 0.02 [−0.46 to 0.49]). According to the investigator, propranolol + amitriptyline was not significantly better than propranolol alone (p<0.50), but was significantly better than amitriptyline alone for this group of patients.

Ziegler, Hurwitz, Hassanein, et al. (1987) used daily doses of 50–150 mg of amitriptyline and 80–240 mg of propranolol on a group of patients whose migraine headaches were frequently severe or disabling in intensity. Treatment periods were 8 weeks long. Mean weekly headache index scores (incorporating frequency, severity, and duration) were calculated for each intervention, using only headaches with a severity score of 4 or more on scale of 1–10. Investigators reported that there was no significant difference between amitriptyline and propranolol for this outcome (p>0.05). No variance data were reported, and we were unable to estimate variance, so no effect size could be calculated.

Investigators also reported the number of patients in both active treatment groups who achieved a 50% or more reduction in mean weekly headache index scores compared with placebo. We were able to use these data to calculate an odds ratio comparing amitriptyline with propranolol for this outcome. The odds ratio was 1.33 (0.47 to 3.8), which is not statistically significant.

Ziegler, Hurwitz, Preskorn, et al. (1993) studied predictors of response to treatment in this same study population. They reported that response to amitriptyline was correlated with female sex and with baseline headaches of shortest duration and highest frequency. Response to propranolol was correlated with attacks of greatest duration at baseline and with low pulse rise with exercise at baseline. Nonspecific response was associated with male sex, most frequent headaches by history, and least frequent headaches during baseline period.

Femoxetine vs. propranolol. Two trials of very similar design compared these two interventions and reached slightly different conclusions (Andersson and Petersen, 1981; Kangasniemi, Nyrke, Lang, et al., 1983). Andersson and Petersen (1981) found no significant difference between the two treatments for reduction in headache index (no p-value reported), and our odds ratio and effect size calculations confirm this finding. Kangasniemi, Nyrke, Lang, et al. (1983) found that propranolol was significantly better than femoxetine at reducing headache index (p<0.05). In both studies, the direction of effect favored propranolol-treated patients; however, in only one was the effect statistically significant.

Clomipramine vs. metoprolol. A single trial compared these two interventions (Langohr, Gerber, Koletzki, et al., 1985). A time series analysis (ARIMA) performed by investigators showed that metoprolol (max 100 mg/day) was significantly better than clomipramine (max 100 mg/day) for reduction in headache frequency from pre- to post-treatment (4 weeks) (p<0.05). We were able to calculate an odds ratio using the conventional data the authors reported for the number of patients with a 50% or greater reduction in headache frequency. The odds ratio was 0.45 (0.12 to 1.7), which is not statistically significant but is consistent with the investigators' finding, using more powerful statistical techniques permitted by individual patient data, that metoprolol is significantly better than clomipramine.

#### Comparisons With Other Agents

Amitriptyline vs. timed-release DHE. Bonuso, Di Stasio, Barone, et al. (1983) compared these two treatments in a group of patients with mixed migraine and tension-type headache. Amitriptyline was administered in a dose of 75 mg/day, and DHE in a dose of 10 mg/day. Patients were treated for 2 months. The investigators reported, but did not analyze, mean pre-and post-treatment headache index scores for both groups. The associated effect size of 0.82 (0.08 to 1.6) suggests that amitriptyline had a large and statistically significant effect on headache index when compared to timed-release DHE.

The investigators' analysis of the data on headache duration, stratified by severity, showed that DHE was significantly better than amitriptyline at reducing the number of hours of extremely severe and severe, migraine-type pain; amitriptyline was significantly better than DHE at reducing the number of hours of moderate and mild, tension-type HA-like pain (p<0.01 for all comparisons).

Amitriptyline vs. biofeedback alone or in combinations. Mathew (1981) researched the efficacy of amitriptyline alone and combined with several other therapies, both pharmacological and nonpharmacological. The trial compared amitriptyline with a control group (abortive administration of ergotamine + analgesics), biofeedback alone, and propranolol alone. Amitriptyline was also evaluated in the following combinations: amitriptyline + propranolol, amitriptyline + biofeedback, and amitriptyline + propranolol + biofeedback. The final combination evaluated was propranolol + biofeedback. Results were reported separately for patients with migraine and patients with mixed migraine and tension-type headache.

Among patients with migraine, each active treatment group experienced significantly better improvement than did the control group (no p-values reported). The improvement percentages ranged from 35–74% for the active treatment groups, compared with 20% for the control group.

The combination of propranolol + biofeedback yielded the best results: a 74% improvement in mean weekly headache index scores from pre-treatment to the last 3 months of treatment. Adding amitriptyline to this combination did not produce a significant change (73%).

Treatment with biofeedback alone resulted in a 35% improvement. Adding biofeedback to treatment with propranolol or amitriptyline improved both (propranolol, from 62% to 74%; amitriptyline, from 42 to 48%).

Among patients with mixed migraine and tension-type headache, the most effective treatment was the combination of propranolol + amitriptyline + biofeedback, with a 76% improvement in mean weekly headache index scores from pre-treatment to the last 3 months of treatment. Biofeedback alone yielded a 48% improvement. Adding biofeedback to the active drug therapies produced an improvement in every case (from 52% to 62% for propranolol alone; from 60% to 66% for amitriptyline alone; and from 69% to 76% for propranolol + amitriptyline).

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

#### Amitriptyline

Couch and Hassanein (1979) provided only limited information on adverse events associated with amitriptyline and placebo. Five of 55 amitriptyline patients withdrew due to adverse events, including rash, hypertension, nausea, and numbness in the hands and feet. Two of 61 patients withdrew while taking placebo, both because of chest pain. Dry mouth, bad taste, and drowsiness were all significantly more common with amitriptyline than with placebo.

Gomersall and Stuart (1973) found no significant difference in the number of patients reporting adverse events while on amitriptyline (16/20) versus placebo (13/20). One patient withdrew during treatment with placebo due to increased headache; there were no withdrawals from the amitriptyline group due to adverse events. The most common adverse events with amitriptyline that were less common on placebo were drowsiness and dry mouth.

Bánk (1994) found that more patients reported adverse events with amitriptyline (41 %) than with fluvoxamine (23%), but the difference between the two treatments was not statistically significant. Drowsiness was the only adverse event reported with amitriptyline and caused seven patients to withdraw prematurely from the trial. Three patients in the fluvoxamine group withdrew due to adverse events (drowsiness, constipation, and pressure in the abdomen).

Neither of the two trials comparing amitriptyline with propranolol (Mathew, 1981; Ziegler, Hurwitz, Hassanein, et al., 1987) reported substantial data on adverse events.

The only trial comparing amitriptyline with timed-release DHE (Bonuso, Di Stasio, Barone, et al., 1983) reported that the most common adverse events associated with amitriptyline were drowsiness and dry mouth. The most common symptoms associated with DHE were nausea and stomach ache. Three patients in the amitriptyline group and two in the DHE group withdrew due to unspecified adverse events.

#### Clomipramine

Noone (1980) reported a significantly higher rate of adverse events with clomipramine (60% of patients) than with placebo (10%) among patients who completed the crossover trial. No description was provided of the specific symptoms observed. Two patients withdrew from the trial due to unspecified adverse events associated with clomipramine.

Langohr, Gerber, Koletzki, et al. (1985) found a total of 79 adverse events with clomipramine, compared with 16 with placebo. The most common adverse events observed with clomipramine that were not common with placebo were insomnia (15 patients vs. 2) and sweating (9 vs. 1).

#### Femoxetine

Two trials compared femoxetine with placebo (Orholm, Honoré, and Zeeberg, 1985; Zeeberg, Honoré, Dalsgaard-Nielsen, et al., 1981). The first of these found no significant difference between the two treatments in overall rates of adverse events (28% vs. 10%), while the second found significantly more adverse events with femoxetine (26% vs. 4%). Tremor, nausea, and changes in mood were all more common with femoxetine than with placebo.

Neither of the two trials comparing femoxetine with propranolol reported overall adverse event rates (Andersson and Petersen, 1981; Kangasniemi, Nyrke, Lang, et al., 1983). Specific adverse events that were more common with propranolol included tiredness (22% vs. 11% and 38% vs. 4% in the two trials, respectively), menstrual disorder (27% vs. 3%), dizziness (42% vs. 13%), and sleep disturbances (21 % vs. 4%).

#### Fluoxetine

Of the two trials comparing fluoxetine with placebo, Adly, Straumanis, and Chesson (1992) reported that three of nine patients in each group reported adverse events. Saper, Silberstein, Lake, et al. (1994) observed significantly more adverse events with fluoxetine than with placebo (84% of patients vs. 66%); however, there was no difference in the number of patients reporting adverse events judged to be severe (8% vs. 4%). Fatigue was common in both groups (25% fluoxetine and 26% placebo), while sleeping problems were more common with fluoxetine (28% vs. 8%), as were tremors (20% vs. 6%) and stomach pain (13% vs. 0%).

#### Fluvoxamine

See under Amitriptyline, above.

#### Mianserin

A single trial comparing mianserin with placebo (Monro, Swade, and Coppen, 1985) provided no information on adverse events.

#### Opipramol

In a single trial comparing opipramol with placebo (Jacobs, 1972), no patients withdrew due to adverse events; no further information on adverse events was provided.

### Conclusions

Although the drugs referred to as antidepressants in this section of the report share certain clinical uses, they comprise several distinct drug classes, namely tricyclic antidepressants (amitriptyline, clomipramine, and opipramol), selective serotonin re-uptake inhibitors (femoxetine, fluoxetine, and fluvoxamine), and tetracyclic antidepressants (mianserin).

Of all these agents, the tricyclic antidepressant amitriptyline has been most frequently studied for the prevention of migraine and is the only antidepressant with reasonably consistent support for efficacy for this indication. Although this has not been demonstrated conclusively, amitriptyline may be more efficacious for patients with mixed migraine and tension-type headache than for patients with migraine alone. A large study by Mathew (1981) found amitriptyline to be significantly better than propranolol for patients with mixed headache, but not as good as propranolol for patients with migraine only.

None of the other agents reviewed in this section of the report -- clomipramine, opipramol, femoxetine, fluoxetine, fluvoxamine, or mianserin -- has sufficient data to support its efficacy, though substantial uncertainty still exists for these agents.

Tolerability was a problem with the tricyclic antidepressants studied, with anticholinergic symptoms frequently reported. It is possible that other tricyclic antidepressants might be equally effective for the prevention of migraine and carry a lower risk of adverse events. In most studies of pain conditions other than migraine, the various tricyclic antidepressants have been shown to be essentially equianalgesic. Within this class, amitriptyline and clomipramine have the strongest sedative and anticholinergic effects and are the most likely to cause orthostatic hypotension. Other tricyclic antidepressants (e.g., nortriptyline or doxepin) are generally associated with fewer adverse events of these types. Although these other tricyclic antidepressants have not been studied for migraine prevention in controlled trials, their analgesic effects in other pain states -- especially neuropathic conditions -- suggest that they may provide effective analgesia in migraine as well, while producing fewer adverse events.

In the relatively short-term trials reviewed here, adverse events were less frequently reported with fluoxetine and other SSRIs than with amitriptyline and clomipramine. However, the particular adverse events most commonly observed with the SSRIs (nausea and sexual dysfunction) may be of greater concern to many migraineurs than the anticholinergic effects associated with tricyclic antidepressants.

Potential adverse events not observed in these trials include drug interactions. Fluoxetine and other SSRIs inhibit the hepatic P450 system which metabolizes many other drugs used for the prevention of migraine, including beta-blockers, tricyclic antidepressants, several of the anticonvulsants, and calcium antagonists. This creates a potential for drug interactions, and perhaps some risk for the development of a serotonin syndrome if SSRIs are used with serotonin agonists.

## Beta-blockers

This section of the report reviews the evidence for the efficacy and safety of beta-blockers for the prevention of migraine. A number of beta-blockers have been tested in controlled trials for this indication. The most commonly studied agent is propranolol, followed by metoprolol, atenolol, nadolol, timolol, and pindolol. Less frequently studied for migraine prophylaxis are the beta-blockers acebutolol, alprenolol, and oxprenolol. In the studies reviewed here, beta-blockers were compared with placebo, with a large number of other drugs, and with nonpharmacological treatments for migraine such as acupuncture and biofeedback.

### Studies Identified

#### Overview

The literature review identified 93 publications reporting on 75 separate controlled trials of beta-blockers used for the prevention of migraine. Lücking, Oestreich, Schmidt, et al. (1988) described two separate trials of propranolol compared with flunarizine (Study 1 and Study 2). In two other cases, we combined descriptions from separate publications reporting on the same trial. In one case, two publications reported on a single trial of propranolol, amitriptyline, and placebo (Ziegler, Hurwitz, Hassanein, et al., 1987; Ziegler, Hurwitz, Preskorn, et al., 1993). The 1993 publication was a study of predictors of response in the same population reported on in the 1987 article. In the second case, two different publications reported on the same trial of metoprolol and placebo (Steiner, Cook, Joseph, et al., 1985; Steiner, Joseph, Hedman, et al., 1988). The 1985 publication was an abstract of the 1988 article and provided additional information not available in the later article.

Eighteen publications were excluded from our analysis for the reasons cited in Exhibit 4.

Exhibit 4 Excluded publications: Beta-blocker trials

Excluded publication | Reason for exclusion
Børgesen (1976) | Publication duplicate of Børgesen, Nielsen, and Møller (1974)
Diamond and Medina (1975) | Abstract referring to trial described more fully in Diamond and Medina (1976); no new little information provided.
Diener, Scholz, Dichgans, et al. (1989) | Outcome data reported limited to visual evoked potentials; no headache outcomes. Same population as reported in Gerber, Diener, Scholz, et al. (1991).
Gawel, Kreeft, Nelson, et al. (1991) | Abstract of trial reported more fully in Gawel, Kreeft, Nelson, et al. (1992); added no new information.
Havanka-Kanniainen, Hokkanen, and Myllylä (1987b) | Abstract reporting results from trial described more fully in Havanka-Kanniainen, Hokkanen, and Myllylä (1988); added no new relevant information.
Hedman and Andersen (1987) | Abstract reporting results from trial more fully described in Hedman, Andersen, Andersson, et al. (1988); added no new information.
Hedman, Andersen, Andersson, et al. (1988) | Analysis of secondary outcomes in subset of data reported on in Kangasniemi, Andersen, Andersson, et al. (1987).
Louis, Schoenen, and Hedman, 1985b | Abstract of Louis, Schoenen, and Hedman, 1985a; added no new information.
Ludin (1987) | Abstract reporting preliminary results from trial described more fully in Ludin (1989); added no new information.
Pradalier, Serratrice, Collard, et al. (1989a) | Abstract reporting results of trial described more fully in Pradalier, Serratrice, Collard, et al. (1989b); added no new information.
Ryan, Ryan, and Sudilovsky (1982) | Partial publication duplicate of Ryan, Ryan, and Sudilovsky (1983). The two reports are virtually identical for the controlled portion of the trial; Ryan, Ryan, and Sudilovsky (1983) also includes data on the long-term followup of patients successfully treated during the controlled trial.
Sørensen (1989) | Abstract of trial reported more fully in Sørensen, Larsen, Rasmussen, et al. (1991); added no new information.
Soyka and Oestreich (1987) | Abstract of trial reported more fully in Lücking, Oestreich, Schmidt, et al. (1988) (Study 1); added no new information.
Standnes (1982) | Reports results from one center involved in a multicenter trial; complete results reported in Tfelt-Hansen, Standnes, Kangasneimi, et al. (1984).
Stensrud and Sjaastad (1980b) | Publication duplicate of Stensrud and Sjaastad (1980a).
Sudilovsky, Stern, and Meyer (1986a) | Abstract of trial more fully reported in Sudilovsky, Elkind, Ryan, et al. (1987); added no few information.
Viswanathan, Rajendiran, Manohar, et al. (1991) | Abstract reporting results from 1 week after start of treatment only.
Wörz, Reinhardt-Benmalek, Grotemeyer, et al. (1991) | Abstract reporting results from trial more fully described in Wörz, Reinhardt-Benmalek, Foeh, et al. (1992); added no new information.

Our analysis thus included 75 publications reporting on 74 separate trials of beta-blockers. The included studies are listed below:

- Ahuja and Venna (1985)
- Albers, Simon, Hamik, et al. (1989)
- Al-Qassab and Findley (1993)
- Andersson and Petersen (1981)
- Andersson, Dahl, Hansen, et al. (1983)
- Anthony, Lance, and Somerville (1972)
- Baldrati, Cortelli, Procaccianti, et al. (1983)
- Behan and Reid (1980)
- Børgesen, Nielsen, and Møller (1974)
- Briggs and Millac (1979)
- Carroll, Reidy, Savundra, et al. (1990)
- Dahlöf (1987)
- Diamond and Medina (1976)
- Ekbom (1975)
- Ekbom and Lundberg (1972)
- Ekbom and Zetterman (1977)
- Formisano, Falaschi, Cerbo, et al. (1991)
- Forssman, Henriksson, Johannsson, et al. (1976)
- Forssman, Lindblad, and Zbornikova (1983)
- Freitag and Diamond (1984)
- Gawel, Kreeft, Nelson, et al. (1992)
- Gerber, Diener, Scholz, et al. (1991)
- Gerber, Schellenberg, Thom, et al. (1995)
- Grotemeyer, Scharafinski, Schlake, et al. (1990)
- Grotemeyer, Schlake, Husstedt, et al. (1987)
- Havanka-Kanniainen, Hokkanen, and Myllylä (1988)
- Hesse, Møgelvang, and Simonsen (1994)
- Holroyd, France, Cordingley, et al. (1995)
- Johannsson, Nilsson, Widelius, et al. (1987)
- Johnson, Hornabrook, and Lambie (1986)
- Kallanranta, Hakkarainen, Hokkanen, et al. (1977) (Study 2)
- Kangasniemi, Andersen, Andersson, et al. (1987)
- Kangasniemi and Hedman (1984)
- Kangasniemi, Nyrke, Lang, et al. (1983)
- Kåss and Nestvold (1980)
- Kjærsgåard-Rasmussen, Holt-Larsen, Borg, et al. (1994)
- Klapper (1994)
- Kuritzky and Hering (1987)
- Langohr, Gerber, Koletzki, et al. (1985)
- Louis, Schoenen, and Hedman (1985a)
- Lücking, Oestreich, Schmidt, et al. (1988) (Studies 1 and 2)
- Ludin (1989)
- Malvea, Gwon, and Graham (1973)
- Mathew (1981)
- Mikkelsen, Kjærsgåard, Pedersen, and Christiansen (1986)
- Nanda, Johnson, Gray, et al. (1978)
- Olerud, Gustavsson, and Furberg (1986)
- Olsson, Behring, Forssman, et al. (1984)
- Palferman, Gibberd, and Simmonds (1983)
- Penzien, Johnson, Carpenter, et al. (1990)
- Pita, Higueras, Bolaños, et al. (1977)
- Pradalier, Serratrice, Collard, et al. (1989b)
- Ryan (1984)
- Ryan, Ryan, and Sudilovsky (1983)
- Sargent, Solbach, Damasio, et al. (1985)
- Shimell, Fritz, and Levien (1990)
- Sjaastad and Stensrud (1972)
- Solomon (1986)
- Sørensen, Larsen, Rasmussen, et al. (1991)
- Sovak, Kunzel, Sternbach, et al. (1981)
- Steardo, Bonuso, Di Stasio, et al. (1982)
- Steiner, Cook, Joseph, et al. (1985)
- Steiner, Joseph, Hedman, et al. (1988)
- Stellar, Ahrens, Meibohm, et al. (1984)
- Stensrud and Sjaastad (1976b)
- Stensrud and Sjaastad (1980a)
- Sudilovsky, Elkind, Ryan, et al. (1987)
- Sudilovsky, Stern, and Meyer (1986b)
- Tfelt-Hansen, Standnes, Kangasniemi, et al. (1984)
- Vilming, Standnes, and Hedman (1985)
- Weber and Reinmuth (1972)
- Widerøe and Vigander (1974)
- Wörz, Reinhardt-Benmalek, Foeh, et al. (1992)
- Ziegler, Hurwitz, Hassanein, et al. (1987)
- Ziegler, Hurwitz, Preskorn, et al. (1993)

The included studies reported on the efficacy and safety of the following agents:

Propranolol | 46 trials
Metoprolol | 15 trials
Nadolol | 6 trials
Atenolol | 3 trials
Pindolol | 3 trials
Timolol | 3 trials
Acebutolol | 1 trial
Alprenolol | 1 trial
Bisoprolol | 1 trial
Oxprenolol | 1 trial
Practolol | 1 trial
Propranolol + amitriptyline | 1 trial
Propranolol + amitriptyline + biofeedback | 1 trial
Propranolol + analgesics | 1 trial
Propranolol + biofeedback | 1 trial

Thirty-eight of the trials were placebo-controlled; 3 were dosing studies with no placebo arm; 10 provided comparisons of beta-blockers with one another; 13 compared these agents with calcium antagonists, 6 with antidepressants, 6 with NSAIDs, 4 with alpha-2 agonists, 2 with anticonvulsants, 2 with methysergide, 1 with a serotonin antagonist, and 5 with behavioral or physical treatments.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Twenty-six of the 74 included trials were parallel-group in design; 47 were crossover trials; and 1 was a matched-pair trial.

Active treatment periods in the included trials ranged from 1 week (one trial) to 6 months (five trials); the average length of the active treatment periods was 2.6 months.

Quality scores ranged from 0 (one trial) to 5 (one trial); the average score was 3.2.

#### Patient Populations

Forty-seven of the 74 included trials provided no information about the setting in which patients were recruited. In 13 of the trials, patients were recruited from neurology clinics or departments; in 4 others, from migraine clinics or pain centers (Nanda, Johnson, Gray, et al., 1978; Sovak, Kunzel, Sternbach, et al., 1981; Steiner, Cook, Joseph, et al., 1985; Steiner, Joseph, Hedman, et al., 1988). In three trials, patients were outpatients at either clinics, medical practices, or hospitals (Holroyd, France, Cordingley, et al., 1995; Lücking, Oestreich, Schmidt, et al., 1988 [Studies 1 and 2]). In four trials, patients were referred by physicians (Briggs and Millac, 1979; Hesse, Møgelvang, and Simonsen, 1994; Kangasniemi, Nyrke, Lang, et al., 1983; Kjærsgåard-Rasmussen, Holt-Larsen, Borg, et al., 1994).

Most of the trials reviewed (60 of 74) included patients with migraine with or without aura. Two trials were restricted to patients having migraine with aura (Grotemeyer, Schlake, Husstedt, et al., 1987; Kangasniemi, Andersen, Andersson, et al., 1987); four were restricted to patients having migraine without aura (Baldrati, Cortelli, Procaccianti, et al., 1983; Grotemeyer, Scharafinski, Schlake, et al., 1990; Malvea, Gwon, and Graham, 1973; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984). One included patients with mixed migraine and tension-type headaches (Sargent, Solbach, Damasio, et al., 1985). One included patients with tension-type headaches as long as patients could distinguish them from migraine attacks (Stellar, Ahrens, Meibohm, et al., 1984). Twenty-nine trials referred specifically to the Ad Hoc criteria for migraine, and nine referred to the IHS criteria.

Fourteen of the trials excluded patients who had received previous treatment with preventive migraine medications. In five trials, patients were excluded if they could not distinguish migraine from other types of headache attacks (Andersson, Dahl, Hansen, et al., 1983; Kåss and Nestvold, 1980; Louis, Schoenen, and Hedman, 1985a; Olsson, Behring, Forssman, et al., 1984; Vilming, Standnes, and Hedman, 1985). In six trials, patients with "other" or "other vascular" headaches were excluded (Havanka-Kanniainen, Hokkanen, and Myllylä., 1988; Kangasniemi and Hedman, 1984; Olsson, Behring, Forssman, et al., 1984; Ryan, Ryan, and Sudilovsky, 1983; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984; Vilming, Standnes, and Hedman, 1985).

All but 16 of the trials had minimum headache frequency requirements for inclusion. One trial included only patients with a history of two to eight migraines per month; more than 50% of these patients' headaches must also have been accompanied by focal auras (Kangasniemi, Andersen, Andersson, et al., 1987). Ziegler, Hurwitz, Hassanein, et al. (1987) included only patients whose migraine headaches had the following characteristics: more than 50% must have lasted at least 2 hours and more than 50% must have been "disabling" or "severe."

Ten studies did not report whether patients were allowed to use medication for acute attacks of migraine occurring during the trial. Such medications were not permitted in two trials (Behan and Reid, 1980; Sovak, Kunzel, Sternbach, et al., 1981), but were allowed in the remaining 62 trials.

Three trials included only patients who had not previously tried medication for the prevention of migraine (Albers, Simon, Hamik, et al., 1989; Forssman, Henriksson, Johannsson, et al., 1976; Steardo, Bonuso, Di Stasio, et al., 1982). In addition, eight trials excluded patients who had used preventive migraine medications from 2 weeks to 6 months prior to entering the trial (Formisano, Falaschi, Cerbo, et al., 1991; Holroyd, France, Cordingley, et al., 1995; Kangasniemi, Nyrke, Lang, et al., 1983; Pradalier, Serratrice, Collard, et al., 1989b; Shimell, Fritz, and Levien, 1990; Steiner, Cook, Joseph, et al., 1985; Steiner, Joseph, Hedman, et al., 1988; Wörz, Reinhardt-Benmalek, Foeh, et al., 1992).

Eighteen of the 74 trials did not report the average age of patients, and 4 did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 32 to 45, and the percentage of patients who were women ranged from 46% to 100%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 5.

#### Comparisons With Placebo

Propranolol. Propranolol, in doses ranging from 80 to 240 mg/day, was compared with placebo in 21 trials (Ahuja and Verma, 1985; Al-Qassab and Findley, 1993; Børgesen, Nielsen, and Møller, 1974; Dahlöf, 1987; Diamond and Medina, 1976; Forssman, Henriksson, Johannsson, et al., 1976; Johnson, Hornabrook, and Lambie, 1986; Kuritzky and Hering, 1987; Malvea, Gwon, and Graham, 1973; Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986; Palferman, Gibberd, and Simmonds, 1983; Pita, Higueras, Bolaños, et al., 1977; Pradalier, Serratrice, Collard, et al., 1989b; Sargent, Solbach, Damasio, et al., 1985; Solomon, 1986; Stensrud and Sjaastad, 1976b; Stensrud and Sjaastad, 1980a; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984; Weber and Reinmuth, 1972; Widerøe and Vigander, 1974; Ziegler, Hurwitz, Hassanein, et al., 1987).

Three studies (Børgesen, Nielsen, and Møller, 1974; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984; Weber and Reinmuth, 1972) reported the number of patients with a 50% or greater improvement in headache frequency, permitting calculation of odds ratios of 2.3 (0.81 to 6.7), 3.5 (1.8 to 6.7), and 31.5 (5.1 to 195), respectively. Because these results were statistically heterogeneous, and because more data were available for effect sizes, we did not perform a meta-analysis of these odds ratios.

Twelve studies allowed estimation of effect sizes, eight based on headache frequency (Børgesen, Nielsen, and Møller, 1974; Dahlöf, 1987; Johnson, Hornabrook, and Lambie, 1986; Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986; Pita, Higueras, Bolaños, et al., 1977; Pradalier, Serratrice, Collard, et al., 1989b; Sargent, Solbach, Damasio, et al., 1985; Widerøe and Vigander, 1974), and four based on headache indices (Ahuja and Verma, 1985; Forssman, Henriksson, Johannsson, et al., 1976; Stensrud and Sjaastad, 1980a; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984). The 12 effect size estimates were statistically homogeneous (chi-square = 15.0, d.f. = 11, p=0.18) and yielded a combined effect size of 0.55 (0.42 to 0.69). This summary effect size indicates a high degree of certainty that propranolol provides a moderate reduction in headache frequency or index; confidence intervals exclude a small or large effect.

Three placebo-controlled trials of propranolol used a long-acting formulation (Al-Qassab and Findley, 1993; Kuritzky and Hering, 1987; Pradalier, Serratrice, Collard, et al., 1989). Only one of these (Pradalier, Serratrice, Collard, et al., 1989) provided enough data to estimate the magnitude of difference between long-acting propranolol and placebo. These results did not allow us to compare the regular and long-acting formulations of propranolol.

Metoprolol. Four trials compared metoprolol, in doses of 100 mg/day to 200 mg/day, with placebo (Andersson, Dahl, Hansen et al., 1983; Kangasniemi, Andersen, Andersson, et al., 1987; Langohr, Gerber, Koletzki, et al., 1985; Steiner, Joseph, Hedman, et al., 1988). The two trials that used long-acting formulations and relatively high doses (200 mg/day versus 100 mg/day) of metoprolol found statistically significant efficacy compared to placebo (Andersson, Dahl, Hansen et al., 1983; Kangasniemi, Andersen, Andersson, et al., 1987). An effect size estimated from one of these trials (Andersson, Dahl, Hansen et al., 1983) was similar to that of the propranolol meta-analysis: 0.58 (0.08 to 1.1). The other two trials comparing metoprolol with placebo (Langohr, Gerber, Koletzki, et al., 1985; Steiner, Joseph, Hedman, et al., 1988) reported no significant differences; one (Steiner, Joseph, Hedman, et al., 1988) allowed estimation of an effect size of 0.16 (−0.36 to 0.67).

Odds ratios for improvement could be calculated from one trial of long-acting metoprolol (Andersson, Dahl, Hansen et al., 1983) and one of a regular formulation (Langohr, Gerber, Koletzki, et al., 1985). These odds ratios were 3.9 (1.1 to 14) and 2.1 (0.63 to 7.2), respectively. Only the latter is statistically significant, but each represents a clinically important difference between metoprolol and placebo in the proportion of patients with a 50% or greater reduction in headache frequency or index: 22% and 18%, respectively.

Atenolol. Of the three trials comparing atenolol with placebo (Forssman, Lindblad, and Zbornikova, 1983; Johannsson, Nilsson, Widelius, et al., 1987; Stensrud and Sjaastad, 1980a), two found statistically significant differences (Johannsson, Nilsson, Widelius, et al., 1987; Stensrud and Sjaastad, 1980a). None of these trials reported sufficient data to estimate the magnitude of the treatment differences.

Nadolol. Nadolol, at doses of 80, 160, and 240 mg/day, was compared with placebo in three trials. Two of the trials combined data for all nadolol groups in their statistical analysis, noting similar responses among the different dosage groups. Freitag and Diamond (1984) reported that 32% of patients on nadolol compared with none of the patients on placebo experienced a 50% or greater reduction in headache index, a difference which was not statistically significant. Sudilovsky, Stem, and Meyer (1986b) did find a statistically significant difference, but did not report improvement rates or headache index group means. Ryan, Ryan, and Sudilovsky (1983) reported mean headache frequencies for each dosage group separately, but did not report statistical tests of significance.

Timolol. Timolol, in doses of 20 to 30 mg/day, was compared to placebo in three trials (Briggs and Millac, 1979; Stellar, Ahrens, Meibohm, et al., 1984; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984). Two of these (Stellar, Ahrens, Meibohm, et al., 1984; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984) reported the proportion of patients with a 50% or greater improvement in headache frequency with timolol (43% and 55%, respectively) and with placebo (27% and 30%, respectively). In both trials, the differences between timolol and placebo were statistically significant.

Continuous data on headache frequency or index were summarized in effect sizes for Briggs and Millac (1979) and Tfelt-Hansen, Standnes, Kangasniemi, et al. (1984). Effect size estimates of 0.93 (0.39 to 1.5) and 0.54 (0.22 to 0.85), respectively, were consistent with those calculated for propranolol versus placebo comparisons.

Acebutolol, alprenolol, oxprenolol, and pindolol. Two trials comparing pindolol, in doses of 7.5 mg and 15 mg/day, with placebo each failed to find a statistically significant difference (Ekbom and Lundberg, 1972; Sjaastad and Stensrud, 1972). Sjaastad and Stensrud (1972) reported individual patient data, allowing calculation of an effect size of 0.024 (−0.38 to 0.43) for headache index. While this effect size estimate is negligible, the broad confidence intervals do not exclude a small to moderate clinical effect.

Three other beta-blocking agents with intrinsic sympathomimetic activity -- acebutolol, alprenolol, and oxprenolol -- were investigated in one placebo-controlled trial each (Nanda, Johnson, Gray, et al., 1978; Ekbom, 1975; Ekbom and Zetterman, 1977). None of these trials found a significant benefit to the active drug. The number of patients improving by 50% or more was not reported. Headache index data were used to calculate effect sizes for the studies of alprenolol and oxprenolol; the effect sizes were −0.5 (−0.58 to 0.47) and 0.15 (−0.36 to 0.65), respectively. These effect sizes are both negligible, but have wide confidence intervals that do not exclude a clinically important effect.

#### Dosing Studies

Propranolol. Three studies compared long-acting propranolol 80 mg/day with 160 mg/day (Al-Qassab and Findley, 1993; Carroll, Reidy, Savundra, et al., 1990; Havanka-Kanniainen, Hokkanen, and Myllylä., 1988). Although Carroll, Reidy, Savundra, et al. (1990) reported a statistically significant difference favoring the higher dose (p =0.03), this finding was not replicated in the other two studies, where headache frequency was identical with both doses. One of the studies (Havanka-Kanniainen, Hokkanen, and Myllylä., 1988) provided both an odds ratio of 0.71 (0.14 to 3.6) and an effect size estimate of −0.16 (−0.76 to 0.45) for headache frequency.

Nadolol. Three trials compared different doses of nadolol (Ryan, 1984; Ryan, Ryan, and Sudilovsky, 1983; Sudilovsky, Elkind, Ryan, et al., 1987). From one of these -- the only one to provide data on the proportion of patients with at least a 50% improvement in headache index --we calculated an odds ratio for improvement of 3.5 (1.3 to 9.6) for the 160 mg/day versus 80 mg/day comparison (Sudilovsky, Elkind, Ryan, et al., 1987). Neither of the other studies reported tests of statistical significance or sufficient data to calculate odds ratios or effect sizes.

#### Comparisons Among Beta-blockers

Metoprolol vs. propranolol. Metoprolol and propranolol were compared in four trials (Gerber, Diener, Scholz, et al., 1991; Kangasniemi and Hedman, 1984; Olsson, Behring, Forssman, et al., 1984; Steardo, Bonuso, Di Stasio, et al., 1982). With one exception, none of the four trials found any significant differences between the two interventions for headache frequency or index. The sole exception was the smallest of the four trials (Steardo, Bonuso, Di Stasio, et al., 1982). This trial used the highest dose of metoprolol (300 mg/day) and found a very low proportion of patients with a 50% or greater reduction in headache frequency on metoprolol: 6% compared with 67% on propranolol. We calculated an effect size of −1.3 (−2.0 to 0.62) based on continuous headache frequency data from this trial; this effect size suggests that although the difference between the two interventions was large, it was not statistically significant.

Nadololvs. propranolol. Three trials reported comparisons between nadolol and propranolol (Olerud, Gustavsson, and Furberg, 1986; Ryan, 1984; Sudilovsky, Elkind, Ryan, et al., 1987). The same trial that found a significant difference between nadolol 160 mg/day and 80 mg/day reported an odds ratio of 3.5 (1.3 to 9.6) comparing the 37% improvement rate of propranolol-treated patients to the 64% improvement of those taking nadolol 160 mg/day (Sudilovsky, Elkind, Ryan, et al., 1987). The improvement rates were similar in the propranolol and nadolol 80 mg/day arms at 37% and 33% respectively (odds ratio =0.85 [0.29 to 2.5]).

Other comparisons among beta-blockers. Three other trials provided limited data on comparisons of propranolol with atenolol and timolol, and a comparison of metoprolol with bisoprolol (Stensrud and Sjaastad, 1980a; Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984; Worz, Reinhardt-Benmalek, Foeh, et al., 1992). None of these suggested any clinically important differences between the agents and dosages compared.

#### Comparisons With Other Treatments

See the chapters on alpha-2 agonists, anticonvulsants, antidepressants, calcium antagonists, methysergide, nonsteroidal anti-inflammatory drugs, and other serotoninergic agents for comparisons between beta-blockers and these other classes of drugs. For the one trial comparing propranolol, amitriptyline, and biofeedback in various combinations (Mathew, 1981), see the chapter on antidepressants. The remaining four trials comparing beta-blockers with a behavioral or physical treatment (Hesse, Møgelvang, and Simonsen, 1994; Holroyd, France, Cordingley, et al., 1995; Penzien, Johnson, Carpenter, et al., 1990; Sovak, Kunzel, Sternbach, et al., 1981) are summarized in Evidence Table 1; the results from these trials are described in the companion report on behavioral and physical treatments for migraine.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12. Similar adverse events were reported for all beta-blockers. They included fatigue, depression, nausea, dizziness, and insomnia.

#### Propranolol

Of the placebo-controlled trials of propranolol that reported rates of adverse events for both the propranolol and placebo arms, the largest difference in rates was 14% in a study reporting a 42% incidence of adverse events for propranolol and 28% for placebo (Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984).

Many of the studies reported the number of withdrawals due to adverse events. The difference in withdrawal rates in propranolol- and placebo-treated patients ranged from zero (no difference) to 8% higher for propranolol-treated patients.

One of the three placebo-controlled trials of long-acting propranolol reported rates of adverse events for all treatment arms (Pradalier, Serratrice, Collard, et al., 1989). The rates of adverse events and withdrawals due to adverse events were nearly identical for long-acting propranolol and placebo.

#### Metoprolol

In one placebo-controlled trial, the rate of adverse events appeared higher with metoprolol (Kangasniemi, Andersen, Andersson, et al., 1987). In the other two placebo-controlled trials reporting adverse event rates, there was no difference in withdrawals due to adverse events between the active treatment and placebo arm (Andersson, Dahl, Hansen, et al., 1983; Steiner, Joseph, Hedman, et al., 1988).

#### Timolol

Among placebo-controlled trials of timolol, the drug appeared to be well tolerated. In one trial there was no difference in adverse event rates associated with timolol and placebo (Briggs and Millac, 1979). In the other two studies, there were fewer withdrawals due to adverse events in the active treatment groups than in the placebo groups (Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984; Stellar, Ahrens, Meibohm, et al., 1984).

#### Nadolol

The three placebo-controlled trials of nadolol reported very little information on adverse events. In one (Ryan, Ryan, and Sudilovsky, 1983) a significantly higher adverse event rate was reported for the nadolol 240 mg/day group (50% vs. 25% for placebo).

#### Atenolol

One of the three placebo-controlled trials of atenolol reported the rate of adverse events for both placebo and active treatment groups (Forssman, Lindblad, and Zbornikova, 1983). There was a 20% higher rate of adverse events with atenolol. There was no difference in withdrawal rate due to adverse events. Another study reported higher rates of withdrawal due to adverse events for the placebo group (Johannsson, Nilsson, Widelius, et al., 1987).

#### Acebutolol, Alprenolol, Oxprenolol, and Pindolol

Few trials of these agents reported adverse event rates by treatment group. One placebo-controlled trial of pindolol reported higher withdrawals due to adverse events in the active treatment group.

### Conclusions

Propranolol, in a daily dose of 120 mg to 240 mg, has strong and consistent support for efficacy in reducing headache frequency and headache index. Timolol, metoprolol, atenolol, and nadolol are also likely to be beneficial, based on trials comparing these agents to placebo or to propranolol. Beta-blockers with intrinsic sympathomimetic activity -- including acebutolol, alprenolol, oxprenolol, and pindolol -- appear to be ineffective for the prevention of migraine.

There is insufficient evidence to conclude that extended-release preparations of propranolol and metoprolol are more or less effective, or more or less well tolerated, than regular formulations of these drugs.

While some studies had high dropout rates, most patients appear to have tolerated the adverse events associated with beta-blockers (principally fatigue, depression, nausea, dizziness, and insomnia). Dropouts were rarely due to adverse events associated with the active treatments.

## Calcium Antagonists

Calcium antagonists have been increasingly advocated as a useful class of drugs for the prevention of migraine. Verapamil is the calcium antagonist most frequently used for this purpose in the U.S., though it has been studied for this indication in only a few controlled trials. Flunarizine (which is not available in the U.S.) has been more extensively tested as a migraine preventive agent. Controlled trials of nimodipine, nifedipine, nicardipine, and cyclandelate have also been published. All of these last four agents, except for cyclandelate, are available in the US. This section of the report examines the evidence for the safety and efficacy of these agents.

### Studies Identified

#### Overview

The literature review identified 59 publications reporting on 47 separate controlled trials of calcium antagonists used for the prevention of migraine. Fourteen publications were excluded from our analysis for the reasons cited in Exhibit 5.

Exhibit 5 Excluded publications: Calcium antagonist trials

Excluded publication | Reason for exclusion
Agnoli, Bussone, Manzoni, et al. (1989) | Abstract reporting preliminary results from trial described more fully in Agnoli, Bussone, Mailland, et al. (1991); added no new information.
Diamond, Freitag, and Diamond (1990) | Abstract reporting preliminary results from trial described more fully in Diamond and Freitag (1993); added no new information.
Diener, Scholz, Dichgans, et al. (1989) | Study reported no head pain outcome data. Reported visual evoked potentials (VEPs) in population reported on in Gerber, Diener, Scholz, et al. (1991).
Gawel, Kreeft, Nelson, et al. (1991) | Abstract of trial reported more fully in Gawel, Kreeft, Nelson, et al. (1992); added no new information.
Havanka-Kanniainen, Hokkanen, and Myllylä (1985a) | Abstract of trial reported more fully in Havanka-Kanniainen, Hokkanen, and Myllylä (1987a); added no new information.
Kangasniemi and Tokola (1989) | Abstract describing trial in progress; no results reported.
Ludin (1987) | Abstract reporting preliminary results from trial described more fully in Ludin (1989); added no new information.
Mentenopoulos, Manafi, Logothetis, et al. (1985) | Publication duplicate of Mendenopoulos, Manafi, Logothetis, et al. (1985).
Rascol, Montastruc, and Rascol (1985) | Abstract of trial reported more fully in Rascol, Montastruc, and Rascol (1986); added no new information.
Sandrini, Savoini, Cavallini, et al. (1987) | Abstract of trial reported more fully in Nappi, Sandrini, Savoini, et al. (1987); added no new information.
Sørensen (1989) | Abstract of trial reported more fully in Sørensen, Larsen, Rasmussen, et al. (1991); added no new information.
Sørensen, Hansen, and Olesen (1985) | Abstract of trial reported more fully in Sørensen, Hansen, and Olesen (1986); added no new information.
Soyka and Oestreich (1987) | Abstract of trial reported more fully in Lücking, Oestreich, Schmidt, et al. (1988) (Study 1); added no new information.
Viswanathan, Rajendiran, Manohar, et al. (1991) | Abstract reporting results in unacceptably short time frame (1 week after start of treatment only).

The following 45 publications were included in our analysis:

- Agnoli, Bussone, Mailland, et al., 1991
- Al Deeb, Biary, Bahou, et al., 1992
- Albers, Simon, Hamik, et al., 1989
- Ansell, Fazzone, Festenstein, et al., 1988
- Bassi, Brunati, Rapuzzi, et al., 1992
- Bussone, Baldini, D’Andrea, et al., 1987
- Cerbo, Casacchia, Formisano, et al., 1986
- Diamond and Freitag, 1993
- Formisano, Falaschi, Cerbo, et al., 1991
- Freitag, Diamond, and Diamond, 1991
- Frenken and Nuijten, 1984
- Gawel, 1987
- Gawel, Kreeft, Nelson, et al., 1992
- Gelmers, 1983
- Gerber, Diener, Scholz, et al., 1991
- Gerber, Schellenberg, Thorn, et al., 1995
- Grotemeyer, Schlake, and Husstedt, 1989
- Grotemeyer, Schlake, Husstedt, et al., 1987
- Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b
- Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a
- Lamsudin and Sadjimin, 1993
- Leandri, Rigardo, Schizzi, et al., 1990
- Louis, 1981
- Louis and Spierings, 1982
- Lücking, Oestreich, Schmidt, et al., 1988
- Ludin, 1989
- Markley, Cheronis, and Piepho, 1984
- Mastrosimone, Iaccarino, and de Caterina, 1992
- McArthur, Marek, Pestronk, et al., 1989
- Mendenopoulos, Manafi, Logothetis, et al., 1985
- Meyer and Hardenberg, 1983
- Micieli, Trucco, Agostinis, et al., 1985
- Migraine-Nimodipine European Study Group, 1989a
- Migraine-Nimodipine European Study Group, 1989b
- Nappi, Sandrini, Savoini, et al., 1987
- Pini, Ferrari, Guidetti, et al., 1985
- Rascol, Montastruc, and Rascol, 1986
- Shimell, Fritz, and Levien, 1990
- Shukla, Garg, Nag, et al., 1995
- Solomon, 1986
- Solomon, Steel, and Spaccavento, 1983
- Sørensen, Hansen, and Olesen, 1986
- Sørensen, Larsen, Rasmussen, et al., 1991
- Steardo, Marano, Barone, et al., 1986
- Thomas, Behari, and Ahuja, 1991

Freitag, Diamond, and Diamond (1991) was an abstract reporting on the trial more fully described in Diamond and Freitag (1993). The abstract provided data on adverse events that were not reported in the final publication. For that reason, we included the abstract in our analysis and refer to it in the entries for Diamond and Freitag (1993) in Evidence Tables 1 and 12. Lücking, Oestreich, Schmidt, et al. (1988) reported results from two separate trials, which are labeled Study 1 and Study 2 in the text of this report and in the accompanying Evidence Tables.

Our analysis thus included 45 published reports describing 45 separate trials. The included studies reported on the safety and efficacy of the following agents:

Flunarizine | 25 trials
Nimodipine | 11 trials
Nifedipine | 5 trials
Verapamil | 3 trials
Cyclandelate | 3 trials
Nicardipine | 1 trial

Nineteen trials compared calcium antagonists with placebo; 2 were dosing studies with no placebo arm; 3 compared calcium antagonists with one another; 12 trials compared these agents with beta-blockers, 7 with serotonin antagonists, and 3 with other agents.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Thirty of the 45 included trials were parallel-group in design; 15 were crossover.

The active treatment periods ranged in length from 1 month (one trial) to 6 months (three trials); the average length of the active treatment period was 3.4 months.

Quality scores ranged from 2 (seven trials) to 5 (two trials); the average score was 3.3.

#### Patient Populations

Twenty of the 45 included trials provided no information about the setting in which patients were recruited. In eight cases, patients were drawn from headache clinics or headache study centers (Ansell, Fazzone, Festenstein, et al., 1988; Bassi, Brunati, Rapuzzi, et al., 1992; Diamond and Freitag, 1993; Nappi, Sandrini, Savoini, et al., 1987; Pini, Ferrari, Guidetti, et al., 1985; Rascol, Montastruc, and Rascol, 1986; Shukla, Garg, Nag, et al., 1995; Sørensen, Hansen, and Olesen, 1986). Seven different trials recruited patients from neurology clinics or departments (Gelmers, 1983; Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b and 1987a; Migraine-Nimodipine European Study Group, 1989a and 1989b; Sørensen, Larsen, Rasmussen, et al., 1991; Steardo, Marano, Barone, et al., 1986). One trial recruited patients from polyclinic, medical, and neurology departments (Shimell, Fritz, and Levien, 1990), and another from neurology and psychiatric departments (Mendenopoulos, Manafi, Logothetis, et al., 1985). In four trials, patients were recruited from family or general medical practices (Frenken and Nuijten, 1984; Louis, 1981; Louis and Spierings, 1982; Lücking, Oestreich, Schmidt, et al., 1988 [Study 1]). Trial participants were described as hospital outpatients in three studies (Al Deeb, Biary, Bahou, et al., 1992; Lamsudin and Sadjimin, 1993; Lücking, Oestreich, Schmidt, et al., 1988 [Study 2]). Finally, one trial recruited patients through personal referrals and advertisements (McArthur, Marek, Pestronk, et al., 1989).

The majority of the trials reviewed (33 of 45) included patients with migraine with or without aura. Nine trials were restricted to patients with migraine without aura (Agnoli, Bussone, Mailland, et al., 1991; Bussone, Baldini, D’Andrea, et al., 1987; Grotemeyer, Schlake, and Husstedt, 1989; Leandri, Rigardo, Schizzi, et al., 1990; Micieli, Trucco, Agostinis, et al., 1985; Migraine-Nimodipine European Study Group, 1989b; Nappi, Sandrini, Savoini, et al., 1987; Sørensen, Hansen, and Olesen, 1986; Thomas, Behari, and Ahuja, 1991). Three trials included only patients with migraine with aura (McArthur, Marek, Pestronk, et al., 1989; Mendenopoulos, Manafi, Logothetis, et al., 1985; Migraine-Nimodipine European Study Group, 1989a). Twenty-three trials referred specifically to the Ad Hoc diagnostic criteria for migraine, and eight referred to the IHS criteria.

Five trials explicitly excluded patients who also suffered attacks of tension-type headache or required that patients be able to distinguish between attacks of migraine and tension-type headache (Ansell, Fazzone, Festenstein, et al., 1988; Diamond and Freitag, 1993; Leandri, Rigardo, Schizzi, et al., 1990; Louis, 1981; Micieli, Trucco, Agostinis, et al., 1985). Two trials excluded patients with tension-type headaches on six or more days per month (Migraine-Nimodipine European Study Group, 1989a and 1989b), and one trial excluded patients with daily tension-type headaches (Thomas, Behari, and Ahuja, 1991). One trial included patients with migraine or cluster headache, but reported results separately for the two types of headache (Meyer and Hardenberg, 1983).

Most of the included trials had minimum headache frequency requirements for inclusion. A few required that patients’ attacks be moderate to severe in intensity (Frenken and Nuijten, 1984; Louis and Spierings, 1982; Mendenopoulos, Manafi, Logothetis, et al., 1985; Sørensen, Hansen, and Olesen, 1986).

Three trials included only patients who had not previously tried medication for the prevention of migraine (Albers, Simon, Hamik, et al., 1989; Gerber, Schellenberg, Thom, et al., 1995; Steardo, Marano, Barone, et al., 1986). In addition, four trials excluded patients with a history of unsuccessful treatment with preventive agents (Diamond and Freitag, 1993; Gawel, Kreeft, Nelson, et al., 1992; Migraine-Nimodipine European Study Group, 1989a and 1989b).

Seven trials did not report whether patients were allowed to use medication for acute attacks of migraine occurring during the trial (Gawel, 1987; Grotemeyer, Schlake, and Husstedt, 1989; Grotemeyer, Schlake, Husstedt, et al., 1987; Migraine-Nimodipine European Study Group, 1989a and 1989b; Shimell, Fritz, and Levien, 1990; Solomon, 1986); the remaining 38 trials all permitted the use of such medication.

One trial included only migraine patients with low blood pressure, who could not safely take beta-blockers (Grotemeyer, Schlake, and Husstedt, 1989). Another included only patients who experienced vomiting at the beginning of their migraine attacks (Grotemeyer, Schlake, Husstedt, et al., 1987). Otherwise, there were no unusual inclusion or exclusion criteria.

Sixteen of the 45 trials did not report the average age of patients, and five did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 30 to 47, and the percentage of patients who were women ranged from 50% to 90%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 6.

#### Comparisons With Placebo

Flunarizine. Eight trials compared flunarizine with placebo (Al Deeb, Biary, Bahou, et al., 1992; Diamond and Freitag, 1993; Frenken and Nuijten, 1984; Louis, 1981; Mendenopoulos, Manafi, Logothetis, et al., 1985; Pini, Ferrari, Guidetti, et al., 1985; Sørensen, Hansen, and Olesen, 1986; Thomas, Behari, and Ahuja, 1991). All eight trials used a 10-mg daily dose, though in one case (Pini, Ferrari, Guidetti, et al., 1985), patients were treated with 20 mg/day for the first 2 weeks of the treatment period.

More than half of the trials found a statistically significant benefit for flunarizine compared with placebo in reducing headache frequency or headache index. We were able to calculate effect sizes for all but one of the eight trials (Frenken and Nuijten, 1984). Effect sizes from three trials were statistically significant (Louis, 1981; Mendenopoulos, Manafi, Logothetis, et al., 1985; Sørensen, Hansen, and Olesen, 1986). Results from the seven trials were heterogeneous (chi-square = 13.863; degrees of freedom = 6; P = 0.03). The summary effect size from a meta-analysis was 0.52 (0.24 to 0.80).

Three of the eight trials (Al Deeb, Biary, Bahou, et al., 1992; Diamond and Freitag, 1993; Thomas, Behari, and Ahuja, 1991) reported the number of patients exceeding a 50% improvement threshold. From these data we calculated odds ratios for each of the trials. Two trials (Al Deeb, Biary, Bahou, et al., 1992; Diamond and Freitag, 1993) had odds ratios of 1.3 and were not statistically significant. The smallest study (Thomas, Behari, and Ahuja, 1991), a crossover trial with 15 patients, had an odds ratio of 6.0, which showed a larger effect. We calculated a summary odds ratio of 1.9 (0.7 to 5.0), which was not statistically significant.

One small trial (n = 29) compared two different doses of flunarizine (Bassi, Brunati, Rappuzzi, et al., 1992). Both of the treatment groups in this trial took 10 mg of flunarizine per day for the first week. The dosage was then reduced to 3 mg/day in one group. No significant differences were observed in headache index at 4 months between the two dosage groups.

Nimodipine. Five trials compared nimodipine with placebo (Ansell, Fazzone, Festenstein, et al., 1988; Gelmers, 1983; Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b; Migraine-Nimodipine European Study Group, 1989a and 1989b). All five trials used a 120-mg/day dose of nimodipine.

Two of the five trials found a statistically significant effect (Gelmers, 1983; Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b). Both of the Migraine-Nimodipine European Study Group trials (separately reported trials for migraine with and without aura) had unusually large improvements in the placebo groups, which exceeded those in the nimodipine groups. In these studies, flunarizine was not effective at reducing headache index compared with placebo, for either migraine with or without aura.

Effect size estimates based on headache index were available from two studies (Gelmers, 1983; Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b). The effect sizes from each study were similar, 0.78 and 0.85, and both were statistically significant. We calculated a summary effect size of 0.82 (0.32 to 1.3).

One crossover trial compared two different doses of nimodipine (60 mg/day and 120 mg/day) (Meyer and Hardenberg, 1983), but did not find any clinically important differences. However, the treatment period observed was short, extending only 2 months.

Verapamil. Verapamil was compared with placebo in three small trials. Two of the three trials used a dose of 240 mg/day (Markley, Cheronis, and Piepho, 1984; Solomon, 1986); the third used a dose of 320 mg/day (Solomon, Steel, and Spaccavento, 1983).

Two of these three crossover studies reported positive findings (Markley, Cheronis, and Piepho, 1984; Solomon, Steel, and Spaccavento, 1983). The two positive studies reported enough data to calculate effect sizes of 1.14 (0.34 to 1.94) and 0.38 (−0.43 to 1.18), respectively. We calculated a summary effect size of 0.78 (0.09 to 1.5), which was consistent with the individual studies’ findings of statistically significant effects of moderate size. However, each of these crossover studies had a high dropout rate, which could have exaggerated the estimated effectiveness of treatment.

Nifedipine. Two trials compared nifedipine with placebo (McArthur, Marek, Pestronk, et al., 1989; Shukla, Garg, Nag, et al., 1995). One used a dose of 60–90 mg/day (McArthur, Marek, Pestronk, et al., 1989); the other used a much smaller dose of 15 mg/day (Shukla, Garg, Nag, et al., 1995). In each of these crossover studies, headache frequency or index improved only slightly better during the nifedipine period than it had during the placebo period. Effect size estimates were similar: 0.12 (−0.62 to 0.86) in McArthur, Marek, Pestronk, et al. (1989) and 0.17 (−0.35 to 0.70) in Shukla, Garg, Nag, et al. (1995). The observed effects were small, and the confidence intervals surrounding them were large and failed to exclude either a clinically important benefit or harm associated with nifedipine.

Nicardipine. A single crossover trial compared nicardipine, in a dose of 40 mg/day, with placebo (Leandri, Rigardo, Schizzi, et al., 1990). This study found a large reduction in headache index associated with nicardipine. An effect size of 0.47 (−0.05 to 0.98) was not statistically significant but reflected some loss of power from our analysis (which does not use individual patient data). The investigators’ analysis found the effect to be statistically significant.

#### Comparisons Among Calcium Antagonists

The literature review identified three trials comparing one calcium antagonist with another (Bussone, Baldini, D’Andrea, et al., 1987; Lamsudin and Sadjimin, 1993; Nappi, Sandrini, Savoini, et al., 1987). In every case, relatively less well-established agents were compared with flunarizine.

Nimodipine vs. flunarizine. Bussone, Baldini, D’Andrea, et al. (1987) compared nimodipine with flunarizine. Nimodipine was administered in a dose of 120 mg/day, flunarizine in a dose of 10 mg/day. Twenty-five patients were included in the efficacy analysis. Nimodipine-treated patients had a marginally higher rate of at least a 50% reduction in headache index (43% versus 38%) and a greater reduction in mean headache index. However, neither the odds ratio for improvement, 1.3 (0.29 to 5.4), nor the effect size (based on mean headache index) of 0.22 (−0.56 to 1.01) was statistically significant.

Nifedipine vs. flunarizine. Lamsudin and Sadjimin (1993) compared nifedipine (20 mg/day) with flunarizine (10 mg/day). Differences observed in headache index between the two groups were negligible and yielded an effect size estimate of −0.08 (−0.66 to 0.50). Although the results of the two groups were equivalent, the confidence intervals did not exclude the possibility of an important benefit of either drug.

Cyclandelate vs. flunarizine. Nappi, Sandrini, Savoini, et al. (1987) compared cyclandelate with flunarizine. Cyclandelate was administered in a dose of 1600 mg/day, flunarizine in a dose of 5 mg/day. Flunarizine had a greater effect on headache index (p<0.02). The study did not report the magnitude of the difference.

#### Comparisons With Beta-blockers

A total of 13 comparisons of calcium antagonists with beta-blockers (either propranolol or metoprolol) were described in the included trials.

Flunarizine vs. propranolol. Five trials compared flunarizine with the beta-blocker propranolol (Gawel, Kreeft, Nelson, et al., 1992; Lücking, Oestreich, Schmidt, et al., 1988 [Study 1 and Study 2]; Ludin, 1989; Shimell, Fritz, and Levien, 1990). All five trials administered flunarizine in a 10 mg/day dose. The dose of propranolol used ranged from 120 mg/day (three trials) to 180 mg/day (one trial). None of these studies found clinically important differences in the outcomes examined. The outcome was usually headache frequency, but some trials also included headache index and headache severity. Effect size estimates were available for four of the five studies (Gawel, Kreeft, Nelson, et al., 1992; Lücking, Oestreich, Schmidt, et al., 1988 [Study 1 and Study 2]; Ludin, 1989) and ranged from −0.16 to 0.13. We calculated a summary effect size of 0 (−0.21 to 0.21), which indicated that the drugs had equivalent effects, as the confidence intervals excluded more than small differences between them.

Flunarizine vs. metoprolol. Two trials compared flunarizine (10 mg/day) with metoprolol (200 mg/day) (Grotemeyer, Schlake, Husstedt, et al., 1987; Sørensen, Larsen, Rasmussen, et al., 1991). Neither of these studies showed statistically significant differences in headache frequency.

Nifedipine vs. propranolol. Nifedipine and propranolol were compared in two trials. In one (Albers, Simon, Hamik, et al., 1989), nifedipine was administered in a dose of 60–90 mg/day and propranolol in a dose of 120–180 mg/day. In the other trial (Gerber, Diener, Scholz, et al., 1991), patients were treated for 1 month at a relatively low dose (20 mg/day of nifedipine; 80 mg/day of propranolol), then for 2 months at a relatively high dose (40 mg/day of nifedipine; 160 mg/day of propranolol). Their dosage was then successively reduced over the next 3 months (to 10 mg/day of nifedipine and 40 mg/day of propranolol).

The Albers, Simon, Hamik, et al. (1989) trial had a large imbalance in baseline headache frequency between groups and had a greater reduction in headache frequency in the propranolol group. We calculated an effect size of −0.68 (−1.64 to 0.27). The trial was too small (n = 19) for the difference to be statistically significant. Gerber, Diener, Scholz, et al. (1991) reported finding no statistically significant differences. The investigators did not report headache frequency means or other data that might have allowed us to estimate the magnitude or direction of any trend.

Nifedipine vs. metoprolol. The trial described immediately above (Gerber, Diener, Scholz, et al., 1991) also compared nifedipine with metoprolol. Metoprolol was administered in a dose of 100, 200, and 50 mg/day during the low-dose, high-dose, and final phases of the trial, respectively. Metoprolol was reported to have exceeded nifedipine in reducing headache frequency (p<0.05), although no data were reported on the magnitude of this effect.

Nimodipine vs. propranolol. A single small trial (n =19) compared nimodipine with propranolol (Formisano, Falaschi, Cerbo, et al., 1991). Both drugs were administered in a dose of 120 mg/day. Reductions in headache frequency were similar between groups. We calculated an effect size of −0.13 (−1.0 to −0.78) for the comparison between the treatments.

Verapamil vs. propranolol. Solomon (1986) compared verapamil (240 mg/day) with propranolol (120 mg/day). Fifteen patients completed the crossover trial and were included in the efficacy analysis. Mean headache frequency was marginally lower during propranolol periods (4.5 versus 5), but this difference was not statistically significant (no p-value reported).

Cyclandelate vs. propranolol. A single trial compared cyclandelate with propranolol. The 4-month treatment period was broken into a 2-month low-dose phase (1200 mg/day of cyclandelate; 120 mg/day of propranolol) and a 2-month high-dose phase (1600 mg/day of cyclandelate; 160 mg/day of propranolol). A higher proportion of patients had at least a 50% reduction in headache frequency on cyclandelate (71 % versus 53%), but this difference was not statistically significant. We calculated an odds ratio of 2.2 (0.77 to 6.4) for the comparison between these treatments.

#### Comparisons With Serotonin Antagonists

The seven trials described below compared calcium antagonists with pizotifen.

Flunarizine vs. pizotifen. Flunarizine and pizotifen were compared in three trials (Cerbo, Casacchia, Formisano, et al., 1986; Louis and Spierings, 1982; Rascol, Montastruc, and Rascol, 1986). Cerbo, Casacchia, Formisano, et al. (1986) used a relatively high dose of flunarizine (15 mg/day) and a relatively low dose of pizotifen (1.5 mg/day). The other two trials administered flunarizine in a dose of 10 mg/day and pizotifen in doses of 2–3 mg/day (Louis and Spierings, 1982) or 2.19 mg/day (Rascol, Montastruc, and Rascol, 1986).

We were not able to calculate odds ratios or effect sizes for any of these trials. The results reported by investigators were consistent across the three trials. They found no statistically significant difference between flunarizine and pizotifen for a reduction in headache frequency at 4 months, and no statistically significant difference between the two treatments for a reduction in headache index at 2 months.

Nimodipine vs. pizotifen. Three trials compared nimodipine (120 mg/day) with pizotifen 1.5 mg/day (Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a; Micieli, Trucco, Agostinis, et al., 1985) or pizotifen 3 mg/day (Gawel, 1987). None of these trials found any clinically important or statistically significant differences between the two drugs. Two studies (Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a; Gawel, 1987) reported enough data to calculate effect sizes of 0.11 (−0.31 to 0.54) and −0.11 (−0.64 to 0.42), respectively. These effect sizes yielded a summary or combined estimate of −0.02 (−0.41 to 0.45), which suggested equivalent effects but did not exclude the possibility of a small or moderate superiority of either drug.

Cyclandelate vs. pizotifen. A single trial compared cyclandelate (1600 mg/day) with pizotifen (1.5 mg/day) (Mastrosimone, Iaccarino, and de Caterina, 1992). This study found a statistically significant effect on headache index favoring cyclandelate (p<0.001). The study did not report any data with which to estimate the magnitude of the effect.

#### Comparisons With Other Agents

A single trial each (described below) compared flunarizine with dihydroergokryptine (DEK), methysergide, and etilefrine pivalate.

Flunarizine vs. DEK. Agnoli, Bussone, Mailland, et al. (1991) compared flunarizine (5 mg/day) with DEK (20 mg/day). The proportion of patients reporting at least 50% reduction in headache frequency was small in both groups (10% for flunarizine and 7% for DEK). The odds ratio of 1.4 (0.30 to 6.7), which favored flunarizine, was not statistically significant. The investigators analyzed mean headache frequency at 6 months and reported finding a statistically significant benefit favoring DEK. However, despite the fact that mean headache frequency was not reported, the improvement rate data suggested that the magnitude of this difference may have been relatively small.

Flunarizine vs. methysergide. Flunarizine (10 mg/day) and methysergide (6 mg/day) were compared in Steardo, Marano, Barone, et al. (1986). Both drugs were associated with similar reductions in headache frequency. The authors reported that the difference was not statistically significant.

Flunarizine vs. etilefrine pivalate. Grotemeyer, Schlake, and Husstedt (1989) compared flunarizine with etilefrine pivalate. Flunarizine was administered in a dose of 5 mg/day, etilefrine pivalate in a dose of 20 mg/day. This study reported similar reductions in mean headache frequency between the two groups, but investigators did not report having performed tests of statistical significance.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

#### Flunarizine

The adverse events most frequently reported in the flunarizine trials were sedation, weight gain, and abdominal pain. Additional adverse events were observed in a very few instances and may be attributable to the drug. These effects included tiredness, depression, giddiness, and galactorrhea. The rates of adverse events varied widely among the studies. The greatest difference between flunarizine and placebo in the adverse events rate was 14%, observed in a trial that reported the highest adverse events rate (44.4%) in the placebo group (Frenken and Nuitjen, 1984). Of the five studies that described whether or not withdrawals were due to adverse events, only four actually attributed any withdrawals to adverse events (Al Deeb, Biary, Bahou, et al., 1992; Diamond and Freitag, 1993; Sørensen, Hansen, and Olesen, 1986; Thomas, Behari, and Ahuja, 1991). The largest difference between withdrawal rates due to adverse events in the flunarizine and placebo arms was 6% (Thomas, Behari, and Ahuja, 1991).

#### Nimodipine

Six trials of nimodipine were reviewed (Ansell, Fazzone, Festenstein, et al., 1988; Gelmers, 1983; Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b; Migraine-Nimodipine European Study Group, 1989a and 1989b; Meyer and Hardenberg, 1983). The adverse event most frequently reported in these trials was abdominal discomfort. The rates of adverse events varied widely among the trials. The greatest difference in adverse events rates between nimodipine and placebo was 10.4%, observed in a trial that reported the highest adverse events rate (17.4%) in the placebo group (Migraine-Nimodipine European Study Group, 1989b).

All six trials described whether or not withdrawals were due to adverse events. In only two trials were any withdrawals actually attributed to adverse events (Migraine-Nimodipine European Study Group, 1989a and 1989b). In these two trials, the withdrawal rate due to adverse events was higher in the placebo arm than in the active treatment arm.

#### Nifedipine

The single placebo-controlled trial of nifedipine was marked by a high incidence of dizziness, edema, and flushing (McArthur, Marek, Pestronk, et al., 1989). These adverse events frequently led to the discontinuation of treatment.

#### Verapamil

Three trials reported adverse events data for placebo-controlled trials of verapamil (Markley, Cheronis, and Piepho, 1984; Solomon, 1986; Solomon, Steel, and Spaccavento, 1983). The adverse event most frequently reported in these trials was constipation. Although no adverse events were reported by Solomon (1986), Markley, Cheronis, and Piepho (1984) reported a 43% incidence of constipation on verapamil, which led to a 7% withdrawal rate.

#### Nicardipine

The single placebo-controlled trial of nicardipine (Leandri, Rigardo, Schizzi, et al., 1990) attributed a slightly greater frequency of headache and dizziness to nicardipine with than to placebo, although precise rates for all adverse events were not reported. However, withdrawals attributed to adverse events were actually more frequent in the placebo arm.

### Conclusions

Flunarizine has strong and consistent evidence from eight placebo-controlled trials for efficacy in migraine prevention. This evidence is strengthened by comparisons with propranolol, another drug whose efficacy is well-established for migraine prevention, which demonstrate reasonable equivalence.

Other calcium antagonists have been less thoroughly studied. Nimodipine had mixed results in placebo-controlled studies. Of six such trials, four reported nonsignificant differences, but two with sufficient information to quantify the magnitude of benefit suggested a clinically important and statistically significant benefit. This latter conclusion must be interpreted with caution.

Nifedipine had consistently poor results in four trials, two-placebo-controlled and two comparisons with propranolol.

Verapamil is the calcium antagonist most commonly used for migraine prevention in the US. Two small placebo-controlled trials suggested that this phenylalkylamine calcium antagonist is effective in migraine prevention. However, both trials were plagued by high dropout rates. Our best estimate of the efficacy of this agent therefore carries substantial uncertainty.

Nicardipine has a single positive trial supporting its efficacy. The effect size from this trial was intermediate between those associated with the other dihydropyridine calcium antagonists, nifedipine and nimodipine.

Cyclandelate has not been tested in placebo-controlled trials for migraine prevention, but it has been compared with several drugs of established efficacy, viz. flunarizine, propranolol, and pizotifen. Cyclandelate was found to be less effective than flunarizine, but more effective than pizotifen; the comparison with propranolol was uninformative. The uncertainty regarding the efficacy of this agent is still considerable, given the lack of placebo-controlled trials.

The adverse event rates reported for calcium antagonists varied widely between studies, even between studies of the same dose of the same drug, and provide little in the way of reliable information on the risk of adverse events associated with these agents.

Since flunarizine and cyclandelate are not available in the US, verapamil, nicardipine, nifedipine, and nimodipine are the only calcium antagonists available that have actually been studied as treatments for migraine. Extended-release preparations of verapamil (Calan SR®) and nifedipine (Adalat CC® or Procardia XL®) may be better-tolerated than regular verapamil and nifedipine, but these preparations have not been studied for migraine prevention.

## Ergots

Ergot alkaloids, some of which are used to treat acute attacks of migraine, have also been studied as preventive agents. The literature review identified controlled trials of dihydroergotamine (DHE); dihydroergokryptine (DEK); ergotamine tartrate; and the combination agent, Cafergot comp.® (ergotamine + caffeine + butalbital + belladonna alkaloids). This section of the report reviews the evidence for the safety and efficacy of these agents.

### Studies Identified

#### Overview

The literature review identified 17 publications reporting on 15 separate controlled trials of ergots used for the prevention of migraine (Agnoli, Bussone, Mailland, et al., 1991; Agnoli,. Bussone, Manzoni, et al., 1989; Autret and de Chasteigner, 1987; Barrie, Fox, Weatherall, et al., 1968; Bonuso, Di Stasio, Barone, et al., 1983; Bousser, Chick, Fuseau, et al., 1988; Buscaino, Sorge, Bussone, et al., 1991; Cangi, Boccuni, Zanotti, et al., 1989; Canonico, Scapagnini, Genazzani, et al., 1989; Demarez, Darbeau, and Cauquil, 1987; Fiorini, Sances, Martignoni, et al., 1991; Frediani, Grazzi, Zanotti, et al., 1991; Kallos and Kallos-Deffner, 1971; Martucci, Manna, Mattesi, et al., 1983; Neuman, Demarez, Harmey, et al., 1986; Stensrud, Skaug, and Sjaastad, 1971; Stieg, 1977).

Four publications were excluded from our analysis for the reasons cited in Exhibit 6.

Exhibit 6 Excluded publications: Ergot trials

Excluded publication | Reason for exclusion
Agnoli, Bussone, Manzoni, et al. (1989) | Abstract reporting preliminary results from trial described more fully in Agnoli, Bussone, Mailland, et al. (1991); added no new information.
Demarez, Darbeau, and Cauquil (1987) | Abstract reporting on the trial described more fully in Neuman, Demarez, Harmey, et al. (1986). While the full report described 1-month results only, the abstract reported some 2-month efficacy data for the active treatment group; however, no 2-month results were reported for the comparator group (placebo).
Stensrud, Skaug, and Sjaastad (1971) | Placebo-controlled trial of investigational drug (MY-25 = 1-methyl-ergotamine-bitartrate) that was never brought to market.
Stieg (1977) | Trial included both migraine and tension-type headache patients (n’s not reported); no separate results were reported for migraine patients.

Thirteen publications reporting on 13 separate trials were thus included in our analysis. The included studies reported on the safety and efficacy of the following agents:

Dihydroergotamine | 7 trials
Dihydroergokryptine | 5 trials
Cafergot comp.® | 1 trial
Ergotamine | 1 trial

Seven trials compared ergots with placebo, two compared different doses of a single ergot agent, one compared two ergots with one another, two compared ergots with methysergide, and one trial each compared ergots with an antidepressant and a calcium antagonist.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Seven of the 13 included trials were crossover in design; 6 were parallel-group. Three of the crossover trials were analyzed as if they were parallel-group in design for reasons described in Evidence Table 1 (Barrie, Fox, Weatherall, et al., 1968; Fiorini, Sances, Martignoni, et al., 1991; Frediani, Grazzi, Zanotti, et al., 1991).

Active treatment periods in the included trials ranged in length from 1 month (two trials) to 6 months (one trial); the average length of the active treatment periods was 2.3 months.

Quality scores ranged from 1 (one trial) to 4 (three trials); the average score was 2.9.

#### Patient Populations

Eleven of the 13 included trials provided no information about the setting in which patients were recruited. In the remaining two cases patients were drawn from headache clinics (Barrie, Fox, Weatherall, et al., 1968; Martucci, Manna, Mattesi, et al., 1983).

The majority of the trials reviewed (7 of 13) included patients with migraine without aura only. Three trials included patients with both types of migraine (with and without aura) (Barrie, Fox, Weatherall, et al., 1968; Bousser, Chick, Fuseau, et al., 1988; Neuman, Demarez, Harmey, et al., 1986); one of these (Barrie, Fox, Weatherall, et al., 1968) also included patients with hemiplegic migraine and mixed migraine + tension-type headache. One trial included only patients with mixed migraine + tension-type headache (Bonuso, Di Stasio, Barone, et al., 1983). Two trials included only women whose migraines occurred in connection with the menstrual cycle (Fiorini, Sances, Martignoni, et al., 1991; Kallos and Kallos-Deffner, 1971); neither of these trials used a stringent definition of menstrual migraine. Four trials referred specifically to the Ad Hoc diagnostic criteria for migraine, and two referred to the IHS criteria. All but three of the included trials dealing with nonmenstrual headaches had minimum migraine headache frequency requirements for inclusion (Bonuso, Di Stasio, Barone, et al., 1983; Frediani, Grazzi, Zanotti, et al., 1991; Martucci, Manna, Mattesi, et al., 1983). The two trials focusing on menstrual migraine did not state this explicitly, but appeared to require that participants regularly experience migraine headaches at the same point in their menstrual cycles.

Two trials explicitly excluded patients with daily headaches (Autret and de Chasteigner, 1987; Buscaino, Sorge, Bussone, et al., 1991).

Four trials excluded patients who had used migraine preventive therapy during some period of time leading up to the trial (Bousser, Chick, Fuseau, et al., 1988; Buscaino, Sorge, Bussone, et al., 1991; Martucci, Manna, Mattesi, et al., 1983; Neuman, Demarez, Harmey, et al., 1986). One of these trials (Buscaino, Sorge, Bussone, et al., 1991) reported that 40% of patients included had used some type of preventive medication in the more distant past, with varying results. The single trial of Cafergot comp.® included only patients who had used the drug before with good results (Kallos and Kallos-Deffner, 1971).

The two trials restricted to women who experienced migraine attacks in connection with their menstrual cycle did not report whether patients were permitted to use medication for acute attacks occurring during the trial. In one of these trials, preventive medication was taken on a daily basis throughout the menstrual cycle (Fiorini, Sances, Martignoni, et al., 1991); in the other, it was taken only around the time of the expected migraine attack (Kallos and Kallos-Deffner, 1971). The other eleven included trials all permitted the use of medication for acute attacks.

Six trials did not report the average age of patients, and three did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 33 to 47, and the percentage of patients who were women ranged from 45% to 100%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 7.

#### Comparisons With Placebo

Cafergot comp.®. Cafergot comp.® (ergotamine + caffeine + butalbital + belladonna alkaloids) was compared with placebo in a crossover trial among women with migraines associated with the menstrual cycle (Kallos and Kallos-Deffner, 1971). All 20 patients included in the efficacy analysis had used the drug in the past with good results. One capsule was taken twice a day during the perimenstrual period for two menstrual cycles. Mean headache frequency for the two cycles was lower with Cafergot comp.® than with placebo (0.35 attacks vs. 1.55 attacks, respectively), but investigators reported no test of statistical significance.

DHE. Three trials compared timed-release DHE in a dose of 10 mg per day with placebo (Autret and de Chasteigner, 1987; Martucci, Manna, Mattesi, et al., 1983; Neuman, Demarez, Harment, et al., 1986). Each of these studies found significantly lower headache index or headache frequency scores for the DHE-treated patients. In two cases (Autret and de Chasteigner, 1987; Neuman, Demarez, Harment, et al., 1986), we were able to calculate effect sizes which confirmed the investigators’ findings.

One trial comparing timed-release DHE 10 mg + aspirin 80 mg with placebo also reported a significant reduction in headache frequency compared to placebo; our effect size calculations confirmed this result (0.62 [0.16 to 1.1]).

DEK. Two trials, one among patients with migraine associated with menstruation (Fiorini, Sances, Martignoni, et al., 1991) and the other among patients with common migraine (Canonico, Scapagnini, Genazzani, et al., 1989), compared DEK 20 mg daily with placebo. Both reports were abstracts and provided limited information. Fiorini, Sances, Martignoni, et al. (1991) found a nearly two-fold reduction in headache index with DEK that was highly statistically significant. The effect size that we calculated from the first-period headache index data was, however, not statistically significant. Canonico, Scapagnini, Genazzani, et al. (1989) appeared to have a treatment-period interaction which confounded the assessment of efficacy.

#### Dosing Studies

Buscaino, Sorge, Bussone, et al. (1991) compared two different DHE dosing regimens (two 5-mg doses and a single 10-mg dose per day). No difference in headache index was observed between the two groups.

Two different doses of ergotamine (1 mg daily and 0.5 mg daily) were compared by Barrie, Fox, Weatherall, et al. (1968). For reasons described in Evidence Table 1, we analyzed the 1-month data from this trial. At the end of 1 month of treatment, 47% of patients in both dosage groups reported a reduction in headache severity in comparison to baseline values.

#### Comparisons Among Ergots

Frediani, Grazzi, Zanotti, et al. (1991) compared timed-release DHE 10 mg daily and DEK 20 mg daily in a crossover trial; because of a significant carry-over effect, investigators analyzed only the first-period data. DHE and DEK groups showed similar reductions in headache index and headache frequency compared to baseline values; no direct statistical comparisons of the two agents were reported.

#### Comparisons With Other Agents

DHE vs. amitriptyline. Bonuso, Di Stasio, Barone, et al. (1983) compared timed-release DHE 10 mg daily with amitriptyline 75 mg daily in a group of patients with mixed migraine + tension-type headache. Patients were treated for two months. The investigators reported, but did not analyze, mean pre- and post-treatment headache index scores for both groups. Using these data, we calculated an effect size of −0.82 (−1.6 to −0.08) for the DHE vs. amitriptyline comparison, which suggests that amitriptyline was significantly better than DHE for this outcome.

The investigators’ analysis of the data on headache duration, stratified by severity, showed that DHE was significantly better than amitriptyline at reducing the number of hours of extremely severe and severe, migraine-type pain; amitriptyline was significantly better than DHE at reducing the number of hours of moderate and mild, tension-type-headache-like pain (p<0.01 for all comparisons).

DEK vs. flunarizine. Agnoli, Bussone, Mailland, et al. (1991) compared DEK (20 mg/day) with flunarizine (5 mg/day). The proportion of patients reporting a 50% or more reduction in headache frequency was small in both groups (7% for DEK and 10% for flunarizine). The resulting odds ratio favoring flunarizine (0.71 [0.15 to 3.4]) was not statistically significant. The investigators analyzed mean headache frequency at 6 months and reported a statistically significant benefit favoring DEK; however, the data on the proportion of patients reporting a 50% or more improvement suggest that the magnitude of this difference may be relatively small (post-treatment mean headache frequencies were reported only in graphical form and could not be reliably read off the graph).

DEK and ergotamine vs. methysergide. Two separate trials compared DEK (Cangi, Boccuni, Zanotti, et al., 1989) and ergotamine (Barrie, Fox, Weatherall, et al., 1968) with methysergide. Neither trial demonstrated any significant differences between the ergots tested and methysergide.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

Information provided about adverse events in the included trials was very limited, especially since several of the reports (five) were abstracts. The most commonly reported adverse events for all the ergot drugs -- including DHE, DEK, and ergotamine -- were gastrointestinal symptoms, including dyspepsia, epigastric pain, nausea, and vomiting.

### Conclusions

Dihydroergotamine appears to be efficacious for migraine prevention when used daily in a dose of 10 mg, based on four placebo-controlled trials with consistent findings. A single trial suggested that DHE may be less effective than amitriptyline for patients with mixed migraine + tension-type headache. The efficacy of dihydroergokryptine is less certain, but is supported by one placebo-controlled study in women with menstrual migraine and by one direct comparison each with flunarizine and methysergide. Cafergot comp.® and ergotamine do not have support for efficacy in migraine prevention.

The limited data on adverse events reported in trials of ergots suggest that unwanted gastrointestinal symptoms are common with these drugs.

## Methysergide

This section of the report examines the evidence from controlled trials for the safety and efficacy of methysergide. Methysergide is a semi-synthetic ergot alkaloid which is structurally related to methylergonovine. It was one of the first drugs to be used and studied for the prevention of migraine. The use of methysergide has, however, been limited by reports of retroperitoneal fibrosis with long-term, uninterrupted administration.

### Studies Identified

#### Overview

The literature review identified 18 publications reporting on 17 separate controlled trials of methysergide for the prevention of migraine (Andersson, 1973; Barrie, Fox, Weatherall, et al., 1968; Behan and Reid, 1980; Cangi, Boccuni, Zanotti, et al., 1989; Forssman, Henriksson, and Kihlstrand, 1972; Herrmann, Horowski, Dannehl, et al., 1977; Hudgson, Foster, and Newell, 1967; Lance, Fine, and Curran, 1963; Pedersen and Møller, 1966; Presthus, 1971; Ryan, 1968; Shekelle and Ostfeld, 1964; Sicuteri, 1959; Sicuteri, 1973; Steardo, Bonuso, Di Stasio, et al., 1982; Steardo, Marano, Barone, et al., 1986; Titus, Dávalos, Alom, et al., 1986; Titus, Dávalos, and Codina, 1985).

Two publications were excluded from our analysis for the reasons cited in Exhibit 7.

Exhibit 7 Excluded publications: Methysergide trials

Excluded publication | Reason for exclusion
Sicuteri (1959) | Allocation to treatment groups neither randomized nor quasi-randomized.
Titus, Dávalos, and Codina (1985) | Abstract reporting on trial more fully described in Titus, Dávalos, Alom, et al. (1986); added no new information.

Our analysis thus included 16 published reports on 16 separate trials. Four of the included trials compared methysergide with placebo; seven compared it with a serotonin antagonist; two with a beta-blocker; and one each with dihydroergokryptine (DEK), ergotamine, the progestogen, flumedroxone (Demigran®), and flunarizine.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Nine of the 16 included trials were crossover in design; 5 were parallel-group. One of the crossover trials (Barrie, Fox, Weatherall, et al., 1968) had an orthogonally-balanced design. We were only able to use the data from the first period of this trial for reasons that are explained in Evidence Table 1, and so treated it as if it were a parallel-group trial. Two additional publications require comment. One (Cangi, Boccuni, Zanotti, et al., 1989) was an abstract reporting parallel-group interim results from a then ongoing, longer-term crossover trial. The other (Lance, Fine, and Curran, 1963) reported on a partial crossover trial with two interventions. Patients who did not achieve success with the first trial medication switched at the end of the first month to the other, while those who were successful continued on the initial medication. The investigators reported first-period (1-month) data separately, and we analyzed these data as if the trial were parallel-group in design.

Active treatment periods in the included trials ranged in length from 1 month (two trials) to 6 months (two trials); the average length of the active treatment periods was 2.9 months.

Quality scores ranged from 1 (one trial) to 4 (6 trials); the average score was 3.1.

#### Patient Populations

Only 4 of the 16 included reports provided information about the setting in which patients were recruited. In two of the four cases, patients were drawn from neurology departments (Pedersen and Møller, 1966; Steardo, Marano, Barone, et al., 1986); in the other two, patients were recruited from headache clinics (Barrie, Fox, Weatherall, et al., 1968; Lance, Fine, and Curran, 1963).

Thirteen of the 16 trials reviewed included patients with migraine with or without aura. One trial was restricted to patients with migraine without aura (Cangi, Boccuni, Zanotti, et al., 1989). Another included only patients with what was described as "typical" migraine, without further clarification (Hudgson, Foster, and Newell, 1967). Barrie, Fox, Weatherall, et al. (1968) included patients with common, classic, and hemiplegic migraine, and patients with mixed migraine + tension-type headache. One trial referred specifically to the IRS diagnostic criteria for migraine; six referred to the Ad Hoc criteria.

Ten trials had minimum migraine headache frequency requirements for inclusion (Barrie, Fox, Weatherall, et al., 1968; Behan and Reid, 1980; Cangi, Boccuni, Zanotti, et al., 1989; Forssman, Henriksson, and Kihlstrand, 1972; Herrmann, Horowski, Dannehl, et al., 1977; Hudgson, Foster, and Newell, 1967; Lance, Fine, and Curran, 1963; Pedersen and Møller, 1966; Ryan, 1968; Steardo, Marano, Barone, et al., 1986). Four of these also required that patients’ headaches regularly be "severe" or "incapacitating" in intensity (Behan and Reid, 1980; Herrmann, Horowski, Dannehl, et al., 1977; Hudgson, Foster, and Newell, 1967; Lance, Fine, and Curran, 1963).

One trial explicitly excluded patients with tension-type headache or mixed migraine + tension-type headache (Titus, Dávalos, Alom, et al., 1986). As noted above, Barrie, Fox, Weatherall, et al. (1968) included a small number of patients with mixed migraine + tension-type headache. Another trial included patients with several types of headache, but reported results separately for migraine patients (Lance, Fine, and Curran, 1963). Two trials included one patient each with cluster headache (Forssman, Henriksson, and Kihlstrand, 1972; Shekelle and Ostfeld, 1964).

Two trials included only patients who had never tried migraine-preventive medication before (Steardo, Bonuso, Di Stasio, et al., 1982; Steardo, Marano, Barone, et al., 1986). One included only patients who had used such medication at some point in the past (Hudgson, Foster, and Newell, 1967). The remaining 13 trials provided no information on this point.

Four trials did not report whether patients were allowed to use medication for acute attacks of migraine occurring during the trial (Hudgson, Foster, and Newell, 1967; Lance, Fine, and Curran, 1963; Sicuteri, 1973; Titus, Dávalos, Alom, et al., 1986). One trial prohibited the use of such medication (Behan and Reid, 1980), and another permitted it only in "exceptionally severe" cases (Andersson, 1973). In the remaining 10 trials, patients were allowed to use medication to treat acute attacks of migraine.

Eleven of the 16 included trials did not report the average age of patients; 6 did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 30 to 43, and the percentage of patients who were women ranged from 52% to 84%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 8.

#### Comparisons With Placebo

Four placebo-controlled trials of methysergide used doses of 4 to 6 mg per day over 4- to 6-week treatment periods (Lance, Fine, and Curran, 1963; Pedersen and Møller, 1966; Ryan, 1968; Shekelle and Ostfeld, 1964). Two trials described results in terms of the proportion of patients with a 50% or greater reduction in headache frequency (Lance, Fine, and Curran, 1963; Pedersen and Møller, 1966). These studies reported similar response rates among placebo-treated patients (21 % and 27%, respectively). The response rates during methysergide treatment were also similar (68% and 57%, respectively). The resulting odds ratios of 8.1 and 3.6 were both statistically significant, as was the combined odds ratio estimate of 5.1 (1.9 to 13).

Pedersen and Møller (1966) also reported decreased headache frequency based on an analysis of within-patient differences in headache frequency between placebo and methysergide periods. We calculated an effect size of 0.22 (−0.04 to 0.47) for the comparison between these treatments. A similar analysis by Shekelle and Ostfeld (1964) in a smaller crossover study showed a statistically significant reduction in headache frequency after treatment with methysergide. We calculated an effect size of 1.02 (0.48 to 1.6) for this trial. A combined estimate of the effect size was 0.56 (−0.20 to 1.3).

#### Comparisons With Serotonin Antagonists

Four trials compared methysergide with pizotifen (Andersson, 1973; Forssman, Henriksson, and Kihlstrand, 1972; Presthus, 1971; Ryan, 1968). The doses of methysergide used were consistent across the four trials (between 3–4 mg/day), while the doses of pizotifen ranged from 1.5 to 4 mg/day. One trial reported the proportion of patients with a greater than 50% reduction in headache frequency compared with baseline (Andersson, 1973). Response rates were lower than those seen in the placebo-controlled trials (31 % for the methysergide arm and 38% for the pizotifen arm). The difference between the two treatments was not statistically significantly, and the odds ratio estimate of 0.73 (0.31 to 1.7) favored pizotifen.

Two studies comparing methysergide with pizotifen reported sufficient data to calculate effect sizes, both based on headache frequency. Andersson (1973) allowed the calculation of an effect size of −0.17 (−0.57 to 0.23), which favored pizotifen, but failed to reach statistical significance. Presthus (1971) reported individual patient data on headache frequency, which allowed the calculation of an effect size of −0.29 (−0.76 to 0.17), which was very similar to the estimate from Andersson (1973). A combined effect size from the two trials was −0.22 (−0.60 to 0.16).

Two trials comparing methysergide with oxitriptan (5-hydroxytryptophan [HTP]) offered little information on the relative effectiveness of the two drugs. Sicuteri (1973) found no difference between the two treatments for headache index; a calculated effect size of 0.09 was negligible, and the 95% confidence interval was quite broad, ranging from −0.53 to 0.71. Results from Titus, Dávalos, Alom, et al. (1986) did not improve the precision of the estimate, as the proportion of patients with at least a 50% reduction in headache frequency was 75% for methysergide and 71 % for oxitriptan. The odds ratio of 1.2 (0.47 to 3.2) did not exclude a clinically important benefit of either drug.

A single study comparing methysergide with lisuride over 3 months (Herrmann, Horowski, Dannehl, et al., 1977) found similar proportions of patients with a 50% or greater improvement in headache frequency (51 % and 53%, respectively). An odds ratio of 0.93, with a confidence interval ranging from 0.46 to 1.9, did not exclude a clinically important benefit of either drug.

#### Comparisons With Beta-blockers

Methysergide was compared to propranolol in two controlled trials (Behan and Reid, 1980; Steardo, Bonuso, Di Stasio, et al., 1982), one of which also included a metoprolol treatment arm (Steardo, Bonuso, Di Stasio, et al., 1982). The two comparisons of methysergide with propranolol each found a substantial difference in the proportion of patients with a 50% or greater reduction in headache frequency, resulting in similar odds ratios of 0.58 (0.23 to 1.5) and 0.64 (0.20 to 2.0). The combined odds ratio was 0.61 (0.25 to 1.5), which favored propranolol, but was not statistically significant. Headache frequency data from Steardo, Bonuso, Di Stasio, et al. (1982) were used to calculate an effect size of −0.51 (−1.1 to 0.06), which suggested a moderate effect favoring propranolol that narrowly missed being statistically significant.

In contrast to placebo-controlled trials of beta-blockers, in which the effectiveness of propranolol and metoprolol and various other agents without intrinsic sympathomimetic activity was similar, Steardo, Bonuso, Di Stasio, et al. (1982) found that propranolol was significantly more effective than metoprolol at reducing headache frequency. This may have been due to the relatively high dose of metoprolol used in this study (300 mg/day) and to the high proportion of dropouts due to adverse events (especially in the metoprolol arm). The large odds ratio of 18 (2.2 to 153) and the effect size of 0.81 (0.16 to 1.5) calculated on the basis of data from this trial may overstate the certainty of the effectiveness of methysergide relative to metoprolol.

#### Comparisons With Other Agents

One trial each compared methysergide with DEK (Cangi, Boccuni, Zanotti, et al., 1989), ergotamine (Barrie, Fox, Weatherall, et al., 1968), flumedroxone (Demigran®) (Hudgson, Foster, and Newell, 1967), and flunarizine (Steardo, Marano, Barone, et al., 1986). None of these trials demonstrated any significant differences between methysergide and the comparator drug.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

Methysergide was associated with more adverse events than was placebo in each placebo-controlled trial. Gastrointestinal complaints -- including nausea, vomiting, abdominal pain, and diarrhea -- were most common, followed by dizziness, giddiness, drowsiness, lassitude, and paresthesia (an abnormal spontaneous sensation, such as that of burning or numbness). Some studies reported leg symptoms, including restlessness or pain, as the most common side effect of treatment with methysergide.

In comparisons with pizotifen, methysergide had no more frequent adverse events. Weight gain was more common with pizotifen, nausea with methysergide.

The trials reviewed here were too short to detect the fibrotic complications that have been observed with long-term, uninterrupted administration of methysergide. Fibrotic changes in the retroperitoneal, pleuropulmonary, cardiac, and other tissues may have serious consequences. Retroperitoneal fibrosis has been associated with vascular insufficiency of the lower limbs and ureteral obstruction; cardiac fibrosis involving the aortic root or aortic or mitral valves can lead to valvular heart disease; and pleuropulmonary fibrosis can lead to pulmonary effusion or pulmonary insufficiency. The manufacturer’s labeling suggests that the drug be discontinued for 3–4 weeks after each 6-month course of treatment.

### Conclusions

Four placebo-controlled trials suggested that methysergide is moderately effective at reducing headache frequency. These trials were all conducted in the 1960s using earlier or no diagnostic criteria for migraine, and their generalizability to patients diagnosed under the more precise diagnostic criteria of the IHS is uncertain.

In direct comparisons with other migraine preventive agents, methysergide appeared to be no more effective than pizotifen or propranolol. Although the four trials directly comparing methysergide to pizotifen did not demonstrate a statistically significant difference between the two drugs, they supported the conclusion that methysergide is not better than pizotifen to any clinically important degree. Similarly, two direct comparisons of propranolol and methysergide reported lower headache frequency with propranolol; although not statistically significant, the reported differences between the two drugs suggest that methysergide is not better than propranolol to any clinically significant degree. A single trial comparing methysergide and metoprolol reported an unusually low response to metoprolol and may have exaggerated the effectiveness of methysergide relative to this agent.

A handful of trials comparing methysergide to other drugs (oxitriptan, lisuride, DEK, ergotamine, flumedroxone [Demigran®], and flunarizine) were too small to demonstrate equivalence and failed to demonstrate any statistically significant differences.

Short-term adverse events (principally gastrointestinal complaints) led to discontinuation of treatment in up to 20% of patients treated with methysergide in the reviewed trials. The risk of adverse events associated with the long-term use of methysergide (particularly fibrotic changes in the retroperitoneal, pleuropulmonary, cardiac, and other tissues) is, however, probably a greater deterrent to the use of this agent.

## Nonsteroidal Anti-inflammatory Drugs (NSAIDs)

Nonsteroidal anti-inflammatory drugs (NSAIDs) are used both for the prevention of migraine and for the treatment of acute attacks. A companion report summarizes the evidence for the safety and efficacy of NSAIDs for the treatment of acute attacks. The present report considers their use for the prevention of migraine. The literature review identified controlled trials of naproxen, naproxen sodium, aspirin, tolfenamic acid, fenoprofen, flurbiprofen, indobufen, indomethacin, ketoprofen, lornoxicam, and mefenamic acid for this indication.

### Studies Identified

#### Overview

The literature review identified 30 publications reporting on 26 separate controlled trials of NSAIDs used for the prevention of migraine. Seven publications were excluded from our analysis for the reasons cited in Exhibit 8.

Exhibit 8 Excluded publications: NSAID trials

Excluded publication | Reason for exclusion
Buring, Peto, and Hennekens (1990) | Assessment based on annual retrospective report.
Carasso, Peled, and Yehuda (1992) | Test drug (flufenamic acid) used for both prevention of migraine episodes and treatment of acute attacks, but results for these two uses not separately reported.
Carrieri, Orefice, and Sorge (1985) | Preliminary report of trial described more fully in Carrieri, Orefice, and Sorge (1988).
Mongini, Bona, Garnero, et al. (1993) | Fewer than five patients (with migraine) per treatment group.
Solomon, Freitag, Mehta, et al. (1987) | Abstract reporting results from trial more fully described in Diamond, Solomon, Freitag, et al. (1987); added no new information.
Solomon and Kunkel (1991) | Abstract reporting results from trial more fully described in Solomon and Kunkel (1993); added no new information.
Welch (1986) | Publication duplicate of Welch, Ellis, and Keenan (1985).

The following 23 publications, reporting on 23 separate controlled trials, were included in our analysis:

- Anthony and Lance, 1968
- Baldrati, Cortelli, Procaccianti, et al., 1983
- Bellavance and Meloche, 1990
- Carrieri, Orefice, and Sorge, 1988
- Couch, Bearss, and Verhulst, 1987
- Diamond, Solomon, Freitag, et al., 1987
- Grotemeyer, Scharafinski, Schlake, et al., 1990
- Johnson, Hornabrook, and Lambie, 1986
- Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994
- Lindegaard, Övrelid, and Sjaastad, 1980
- Masel, Chesson, Peters, et al., 1980
- Mikkelsen and Falk, 1982
- Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986
- O'Neill and Mann, 1978
- Ryan and Ryan, 1981
- Sances, Martignoni, Fioroni, et al., 1990
- Sargent, Solbach, Damasio, et al., 1985
- Solomon and Kunkel, 1993
- Stensrud and Sjaastad, 1974
- Stemieri, Bussone, Manzoni, et al., 1991
- Szekely, Merryman, Croft, et al., 1989
- Welch, Ellis, and Keenan, 1985
- Ziegler and Ellis, 1985

The included studies reported on the safety and efficacy of the following agents:

Naproxen or naproxen sodium | 7 trials
Aspirin | 5 trials
Tolfenamic acid | 3 trials
Fenoprofen | 2 trials
Flurbiprofen | 1 trial
Indobufen | 1 trial
Indomethacin | 1 trial
Ketoprofen | 1 trial
Lornoxicam | 1 trial
Mefenamic acid | 1 trial

Twenty trials compared NSAIDs with placebo, six compared NSAIDs with beta-blockers, and one compared an NSAID with a serotonin antagonist.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Fourteen of the included trials were crossover in design; nine were parallel-group. In two crossover trials (Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994; Lindegaard, Övrelid, and Sjaastad, 1980), first-period data were analyzed as if the trial were parallel-group (see Evidence Table 1 for details).

Active treatment periods in the included trials ranged in length from 1 month (one trial) to 3 months (13 trials); the average length of the active treatment periods was 2.5 months.

Quality scores ranged from 1 (one trial) to 4 (nine trials); the average score was 3.2.

#### Patient Populations

In six of the included trials patients were recruited from neurology clinics or departments (Anthony and Lance, 1968; Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994; Lindegaard, Övrelid, and Sjaastad, 1980; Masel, Chesson, Peters, et al., 1980; Mikkelsen and Falk, 1982; Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986). The remaining 17 trials provided no information about the setting in which patients were recruited.

The majority of the trials reviewed (19 of 23) included patients with migraine with or without aura. One of these 19 trials explicitly excluded patients with mixed migraine + tension-type headache (Ryan and Ryan, 1981); another explicitly included them (Sargent, Solbach, Damasio, et al., 1985). Four trials were restricted to patients with migraine without aura (Baldrati, Cortelli, Procaccianti, et al., 1983; Grotemeyer, Scharafinski, Schlake, et al., 1990; Sances, Martignoni, Fioroni, et al., 1990; Sternieri, Bussone, Manzoni, et al., 1991). Two trials focused on migraine attacks occurring in conjunction with the menstrual cycle (Sances, Martignoni, Fioroni, et al., 1990; Szekely, Merryman, Croft, et al., 1989). Ten trials referred specifically to the Ad Hoc diagnostic criteria for migraine, and four referred to the IHS criteria. All but one of the included trials had minimum migraine headache frequency requirements for inclusion (Couch, Bearss, and Verhulst, 1987).

Four trials explicitly excluded patients with headaches other than migraine (Bellavance and Meloche, 1990; Diamond, Solomon, Freitag, et al., 1987; Sances, Martignoni, Fioroni, et al., 1990; Sternieri, Bussone, Manzoni, et al., 1991); another excluded patients with frequent tension-type headaches (Solomon and Kunkel, 1993). Szekely, Merryman, Croft, et al. (1989) included one patient each with tension-type and “cluster-like” headaches.

The two trials examining the use of NSAIDs in the perimenstrual period (Sances, Martignoni, Fioroni, et al., 1990; Szekely, Merryman, Croft, et al., 1989) permitted no other medication for the treatment of acute attacks of migraine. Three trials did not report whether patients were allowed to use such medication (Anthony and Lance, 1968; Baldrati, Cortelli, Procaccianti, et al., 1983; Couch, Bearss, and Verhulst, 1987). The remaining 18 trials permitted the use of other medication for acute attacks, but frequently prohibited the use of NSAIDs for this purpose.

Thirteen of the 23 trials did not report the average age of patients, and two did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 30 to 42, and the percentage of patients who were women ranged from 42% to 100%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 9.

#### Comparisons With Placebo

Naproxen and naproxen sodium. Naproxen or naproxen sodium were studied in seven placebo-controlled trials, naproxen in a dose of 500 mg/day (Lindegaard, Övrelid, and Sjaastad, 1980), and naproxen sodium in a dose of 1100 mg/day (Bellavance and Meloche, 1990; Sances, Martignoni, Fioroni, et al., 1990; Sargent, Solbach, Damasio, et al., 1985; Szekely, Merryman, Croft, et al., 1989; Welch, Ellis, and Keenan, 1985; Ziegler and Ellis, 1985). The duration of these trials ranged from 6 weeks to 3 months. Four trials were crossover in design; however, at least one of these found a carry-over effect, so we analyzed first-period data only (Lindegaard, Övrelid, and Sjaastad, 1980).

One small trial reported the number of patients reporting a 50% or greater improvement in headache index as 6% in the placebo arm and 33% in the naproxen arm (Sances, Martignoni, Fioroni, et al., 1990). An odds ratio for improvement of 7.7 (0.87 to 69) was not statistically significant.

Five trials reported sufficient data to calculate effect sizes (Lindegaard, Övrelid, and Sjaastad, 1980; Sances, Martignoni, Fioroni, et al., 1990; Sargent, Solbach, Damasio, et al., 1985; Welch, Ellis, and Keenan, 1985; Ziegler and Ellis, 1985). The five effect sizes were statistically homogeneous (chi-square = 1.06; degrees of freedom = 4; p = 0.90). The summary effect size was 0.29 (0.01 to 0.57), indicating a small clinical effect that was statistically significant.

Aspirin and aspirin + dipyridamole. Two trials compared aspirin 1300 mg/day with placebo (O’Neill and Mann, 1978; Ryan and Ryan, 1981). The small crossover trial by O’Neill and Mann (1978) showed a dramatic reduction in headache frequency. Individual patient data reported in the trial allowed us to calculate an effect size of 1.7 (1.1 to 2.2) based on within-patient aspirin-placebo differences in headache frequency. The large difference was not replicated by Ryan and Ryan (1981), which found a small reduction in headache frequency, the statistical significance of which was not commented upon..

Two studies provided comparisons of aspirin + dipyridamole with placebo (Masel, Chesson, Peters, et al., 1980; Ryan and Ryan, 1981); Ryan and Ryan (1981) also compared aspirin + dipyridamole with aspirin alone. The reduction in headache frequency in the aspirin + dipyridamole group was greater than that observed in the aspirin-only or in the placebo group in Ryan and Ryan (1981); however, no tests of significance were performed or reported. The other trial, a small crossover study (Masel, Chesson, Peters, et al., 1980), reported a statistically significant decline of about 33% in median headache frequency in the aspirin + dipyridamole group, while median headache frequency in the placebo group increased.

Fenoprofen. Two studies compared fenoprofen with placebo, both testing fenoprofen doses of 600 mg/day and 1800 mg/day (Couch, Bearss, and Verhulst, 1987; Diamond, Solomon, Freitag, et al., 1987). Although similar reductions in headache index in all groups were observed by Couch, Bearss, and Verhulst (1987), the other study found a large difference in the proportion of patients reporting a greater than 50% improvement in headache index in the high-dose (59%) and low-dose (31 %) fenoprofen groups, and in the high-dose fenoprofen (59%) and placebo groups (32%). These differences were statistically significant.

Tolfenamic acid. Tolfenamic acid was compared with placebo in two trials of similar design by the same group of investigators (Mikkelsen and Falk, 1982; Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986). Both crossover trials found a statistically significant result favoring tolfenamic acid. Effect sizes of 0.38 (−0.12 to 0.88) and 0.44 (0.17 to 0.79) suggested a moderate effect. A summary effect size of 0.42 (0.05 to 0.78) was statistically significant and suggested moderate clinical importance. Individual patient data from these trials showed an average reduction of 2.5 attacks per 12 weeks between tolfenamic acid and placebo periods.

Other NSAIDs. One trial each compared six other NSAIDs (flurbiprofen, indobufen, indomethacin, ketoprofen, lornoxicam, mefenamic acid) with placebo.

A single crossover study comparing flurbiprofen 200 mg/day with placebo found a trend toward lower headache frequency on flurbiprofen (0.05<p<0.10) (Solomon and Kunkel, 1993). Indobufen 400 mg/day was compared with placebo in a small parallel-group trial that found a significant effect on headache index at 3 months (Carrieri, Orefice, and Sorge, 1988).

Indomethacin at 75 mg/day was compared with placebo in a trial of only 1 month’s duration (Anthony and Lance, 1968). This trial found identical proportions of patients in the indomethacin and placebo groups reporting a greater than 50% reduction in headache frequency or severity (37%). Ketoprofen at a dose of 150 mg/day was found to reduce headache index compared with placebo (p<0.05) in a 6-week trial (Stensrud and Sjaastad, 1974). Lornoxicam at a dose of 12 mg/day for 2 months reduced headache frequency significantly (p<0.05) (Sternieri, Bussone, Manzoni, et al., 1991). Mefenamic acid, in a small crossover study, compared with placebo at 3 months, showed a significant reduction in headache frequency (Johnson, Hornabrook, and Lambie, 1986).

#### Comparisons With Beta-blockers

Aspirin vs. metoprolol. Aspirin 1500 mg/day was compared with metoprolol 200 mg/day in a crossover study with 3- month treatment periods (Grotemeyer, Scharafinski, Schlake, et al., 1990). Metoprolol-treated patients were more likely to experience a greater than 50% reduction in headache frequency (67% versus 14%). The aspirin-treated patients had lower mean headache severity, although this difference was not statistically significant.

Aspirin vs. propranolol. Aspirin 975 mg/day and propranolol 120 mg/day were compared in a small crossover trial (Baldrati, Cortelli, Procaccianti, et al., 1983). The proportion of patients with a greater than 50% reduction in headache index was identical in the aspirin and propranolol groups (75%). An effect size of −0.01 (−0.58 to 0.55) for headache index also suggested that the two drugs had a similar effect. The wide confidence intervals did not exclude a moderate benefit of either drug.

Mefenamic acid vs. propranolol. Mefenamic acid 1500 mg/day was compared with propranolol 240 mg/day in a small crossover study in which headache frequency was very similar between periods (Johnson, Hornabrook, and Lambie, 1986). The effect size of 0.06 (−0.61 to 0.74) provided little precision in comparing these drugs.

Naproxen sodium vs. propranolol. Sargent, Solbach, Damasio, et al. (1985) compared naproxen sodium 1100 mg/day with propranolol 120 mg/day. The investigators found a trend toward reduced headache frequency in the propranolol-treated patients. The effect size was −0.37 (−0.80 to 0.05), which excluded the probability that naproxen reduced headache frequency more than did propranolol.

Tolfenamic acid vs. propranolol. Two studies compared tolfenamic acid 300 mg/day with propranolol 120 mg/day (Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994; Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986). In each trial, the effect size favored propranolol, but was not statistically significant.

#### Comparisons With Serotonin Antagonists

The literature review identified only one comparison of an NSAID with a serotonin antagonist. Naproxen sodium 1100 mg/day and pizotifen 1.5 mg/day were compared by Bellavance and Meloche (1990) in a 3-month parallel-group trial. Both drugs reduced headache index to similar degrees, and the differences between them were not statistically significant.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

Between 13% and 26% of patients taking naproxen or naproxen sodium reported adverse events, and between 2% and 10% withdrew from trials due to adverse events. Rates of adverse events for the other NSAIDs were generally similar to these. Although adverse event rates in NSAID groups were consistently higher than those in placebo groups, the differences were not statistically significant except in trials of flurbiprofen (Solomon and Kunkel, 1993) and lornoxicam (Sternieri, Bussone, Manzoni, et al., 1991), where rates were 16% and 17% higher than placebo, respectively.

The most common adverse events in all the NSAID trials were gastrointestinal. Although most trials combined all gastrointestinal symptoms into a single category, some listed specific adverse events such as nausea, vomiting, gastritis, and blood in the stool. Among trials of all agents, rates of gastrointestinal adverse events ranged from 3% to 45%.

Other specific adverse events that were reported in association with NSAIDs included dizziness, drowsiness, central nervous system symptoms, fatigue, insomnia, and dysuria.

### Conclusions

Multiple trials of naproxen or naproxen sodium consistently showed a moderate reduction in headache symptoms compared with placebo. Some of the other NSAIDs studied -- including flurbiprofen, indobufen, ketoprofen, lornoxicam, mefenamic acid, and tolfenamic acid --appeared to have similar moderate effects, but fewer studies supported the efficacy of these agents. The effects of aspirin, aspirin + dipyridamole, fenoprofen, and indomethacin are less certain. The reviewed trials of these agents described unusually large or small effects that have not been replicated.

In comparisons with beta-blockers, NSAIDs generally had effects which, while not statistically different, appeared to be slightly smaller than those associated with beta-blockers. NSAIDs were certainly not superior to beta-blockers to any clinically important degree.

Gastrointestinal adverse events were common with NSAIDs, and often led to withdrawal from trials. The relatively short-term trials reviewed here were inadequate to assess adverse events that may be associated with the long-term use of NSAIDs.

## Other Serotoninergic Agents

Many of the drugs tested for efficacy in migraine prevention affect serotonin systems or serotonin metabolism, most notably, methysergide, ergotamine, and dihydroergotamine. This section of the report describes trials evaluating the efficacy and safety of other drugs that affect serotoninergic systems or serotonin metabolism for the prevention of migraine. The most frequently studied of these agents are pizotifen, which acts as an antiserotonin and an antihistamine (Arthur and Homabrook, 1971), and lisuride, which “acts at a central level as a partial serotoninergic blocker” and is antiserotoninergic at a peripheral level (Nattero, Biale, and Savi, 1991). Other serotonin antagonists reported on here are iprazochrome (Divascan®, Migrenon®); tropisetron hydrogen chloride (ICS 205-930, Navoban®, Novaban®), a potent 5-HT(3) receptor antagonist usually used as an antinauseant; and oxitriptan. Oxitriptan (L-5-HTP, the levorotatory enantiomer of 5-hydroxytryptophan) is a precursor to serotonin (5-HT).

None of the serotoninergic agents covered in this section of the report (pizotifen, lisuride, iprazochrome, oxitriptan, and tropisetron) is currently available in the US.

### Studies Identified

#### Overview

The literature review identified 47 publications reporting on 44 separate controlled trials of serotonin antagonists used for the prevention of migraine. One publication (Ferrari, Wilkinson, Hirt, et al., 1991) described two separate trials of the same drug (Studies 1 and 2).

Eight publications were excluded from our analysis for the reasons cited in Exhibit 9.

Exhibit 9 Excluded publications: Trials of other serotoninergic agents

Excluded publications | Reason for exclusion
Capildeo and Rose, 1982 | Provided no data allowing comparisons of the two dosing regimens studied (daily vs. nightly regimens with same dose of active drug).
Chappell, Bay, and Botzum, 1991 | Sergolexole maleate is not commercially or clinically available.
De Benedittis and Massei, 1985 | Separate results for migraine provided only on a graph from which it was difficult to obtain precise data.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985a | Abstract of Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a; provided no new information.
Rascol, Montastruc, and Rascol, 1985 | Abstract of Rascol, Montastruc, and Rascol, 1986; provided no new information.
Somerville and Herrmann, 1976 | Abstract of Somerville and Herrmann, 1978; provided no new information.
Sulman, Pfeifer, and Superstine, 1981 | Org GC 94 is not commercially or clinically available.
Titus, Dávalos, and Codina, 1985 | Abstract of Titus, Dávalos, Alom, et al., 1986; provided no new information

Our analysis thus included 39 publications (listed below) reporting on 40 separate trials.

- Andersson, 1973
- Arthur and Hornabrook, 1971
- Behan, 1985
- Bellavance and Meloche, 1990
- Bono, Criscuoli, Martignoni, et al., 1982
- Carroll and Maclay, 1975
- Cerbo, Casacchia, Formisano, et al., 1986
- De Benedittis and Massei, 1986
- Ferrari, Wilkinson, Hirt, et al., 1991 (Studies 1 and 2)
- Forssman, Henriksson, and Kihlstrand, 1972
- Gawel, 1987
- Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a
- Herrmann, Horowski, Dannehl, et al., 1977
- Herrmann, Krištof, and Sastre y Hernandez, 1978
- Hübbe, 1973
- Hughes and Foster, 1971
- Kangasniemi, 1979
- Kangasniemi, Falck, Långvik, et al., 1978
- Krakowski and Engisch, 1973
- Lance and Anthony, 1968
- Lawrence, Hossain, and Littlestone, 1977
- Louis and Spierings, 1982
- Mastrosimone, Iaccarino, and de Caterina, 1992
- Mathew, 1978
- Micieli, Trucco, Agostinis, et al., 1985
- Nattero, Biale, and Savi, 1991
- Osterman, 1977
- Presthus, 1971
- Rascol, Montastruc, and Rascol, 1986
- Ryan, 1971
- Ryan, 1968
- Sances, Martignoni, Rosettino, et al., 1989
- Sicuteri, 1973
- Sjaastad and Stensrud, 1969
- Somerville and Herrmann, 1978
- Titus, Dávalos, Alom, et al., 1986
- Vilming, Standnes, and Hedman, 1985
- Wilkinson, Agnoli, Gerber, et al., 1989
- Zuddas, Mulas, Del Zompo, et al., 1985

The included studies reported on the efficacy and safety of the following agents:

Pizotifen | 26 trials
Lisuride | 6 trials
Oxitriptan | 4 trials
Iprazochrome | 2 trials
Tropisetron | 2 trials

Twenty of the trials were placebo-controlled; 4 compared one of the above agents with another; and 18 compared them with agents from different classes.

The included trials are described in Evidence Table 1.

#### Study Design and Quality

Twenty-two of the 40 included trials were parallel-group in design; 18 were crossover trials. Active treatment periods in the included trials ranged from 1 month (three trials) to 6 months (two trials); the average length of the active treatment periods was 2.9 months.

Quality scores ranged from 1 (one trial) to 5 (two trials); the average score was 3.4.

#### Patient Populations

Twenty-nine of the 40 included trials provided no information about the setting in which patients were recruited. In four cases patients were drawn from neurology clinics (Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a; Hübbe, 1973; Lance and Anthony, 1968; Osterman, 1977), in three cases from a headache clinic or pain research center (Behan, 1985; De Benedittis and Massei, 1986; Rascol, Montastruc, and Rascol, 1986), and in two cases from general practice clinics (Lawrence, Hossain, and Littlestone, 1977; Louis and Spierings, 1982). In two trials patients were referred by physicians (Arthur and Hornabrook, 1971; Kangasniemi, 1979).

Many of the trials reviewed (25 of 40) included patients with migraine with or without aura. In one trial 25 of 26 patients had migraine with aura (Hughes and Foster, 1971), and in two trials patients had migraine without aura (Micieli, Trucco, Agostinis, et al., 1985; Nattero, Biale, and Savi, 1991). Two trials included patients with migrainous neuralgia (Arthur and Hornabrook, 1971; Hughes and Foster, 1971), two were restricted to women having migraine during or close to the time of their menstrual cycles (Sances, Martignoni, Rosettino, et al., 1989; Zuddas, Mulas, Del Zompo, et al., 1985). Fifteen trials referred specifically to the Ad Hoc criteria for migraine, and one referred to the IHS criteria.

All but 13 of the trials had minimum headache frequency requirements for inclusion. Six trials included only patients with severe headaches (Arthur and Hornabrook, 1971; Bellavance and Meloche, 1990; Herrmann, Krištof, and Sastre y Hernandez, 1978; Hughes and Foster, 1971; Kangasniemi, 1979; Lance and Anthony, 1968). Two excluded patients with headache indexes below a certain threshold (defined differently in each trial) (Bono, Criscuoli, Martignoni, et al., 1982; De Benedittis and Massei, 1986). In one study, several patients had been hospitalized for migraine (Sjaastad and Stensrud, 1969).

One trial explicitly excluded patients with tension-type or “tension-vascular” headaches (Titus, Dávalos, Alom, et al., 1986), and one excluded patients with tension-type headaches that could not be clearly distinguished from migraine (Vilming, Standnes, and Hedman, 1985). Patients were excluded from trials for having the following types of headaches (one trial in all but one case): “other types of headache” (Bellavance and Meloche, 1990), “other vascular headaches” (Vilming, Standnes, and Hedman, 1985), “headaches resulting from head trauma or cervical spondylosis” (Somerville and Herrmann, 1978), and “complicated or ophthalmoplegic migraine” (Ferrari, Wilkinson, Hirt, et al., 1991 [Studies 1 and 2]).

In four trials patients were excluded for taking concomitant migraine medications (Ferrari, Wilkinson, Hirt, et al., 1991 [Studies 1 and 2]; Ryan, 1971; Wilkinson, Agnoli, Gerber, et al., 1989). Patients were not allowed to take migraine prophylactic medications in one trial (Lawrence, Hossain, and Littlestone, 1977). The two trials described in Ferrari, Wilkinson, Hirt, et al. (1991) also excluded patients who were receiving prophylactic nonpharmacological treatments (e.g., acupuncture or psychotherapy). One trial excluded patients who had used any investigational drugs in the month preceding the trial (Ryan, 1971). This was the only trial that required patients to have had no previous experience with the drugs being investigated in the trial. None of the trials was restricted to patients who had never tried preventive medication.

Twenty-seven trials permitted patients to use medication for acute attacks of migraine occurring during the trial; 11 trials did not specify whether patients were allowed to use such medications. One trial permitted patients to use ergotamine preparations or morphine only in exceptionally severe cases (Andersson, 1973), and in one trial patients were asked to discontinue or minimize the use of analgesics (De Benedittis and Massei, 1986). Patients in another trial were not permitted to take acute medications that might obscure the efficacy of the study drug (pizotifen) (Arthur and Hornabrook, 1971).

Fourteen of the 40 trials did not report the average age of patients, and 9 did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 31 to 47, and the percentage of patients who were women ranged from 52% to 100%.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 10.

#### Comparisons With Placebo

Pizotifen. Eleven trials compared pizotifen and placebo using, in doses of 1.5 mg to 6 mg daily for a period of 4 to 12 weeks (Arthur and Hornabrook, 1971; Bellavance and Meloche, 1990; Carroll and Maclay, 1975; Hughes and Foster, 1971; Krakowski and Engisch, 1973; Lance and Anthony, 1968; Lawrence, Hossain, and Littlestone, 1977; Osterman, 1977; Ryan, 1968; Ryan, 1971; Sjaastad and Stensrud, 1969). Four of the trials showed a statistically significant efficacy, while two reported nonsignificant effects that favored pizotifen. Five studies did not report any information on tests of statistical significance of the efficacy of pizotifen relative to placebo.

The proportion of patients experiencing a 50% or greater improvement in headache frequency or headache index with pizotifen was 40% and 48% in the two trials reporting this outcome (Arthur and Hornabrook, 1971; Lance and Anthony, 1968), while the corresponding placebo response rates were 12% and 36%, respectively. The trial with the higher placebo response rate (Lance and Anthony, 1968) counted a 50% or greater reduction in either headache frequency or intensity as a positive treatment response. Odds ratios from the two trials favored pizotifen at 5.2 (1.9 to 14.3) and 1.6 (0.53 to 5.1).

Four studies allowed translation of outcomes into effect sizes (Krakowski and Engisch, 1973; Lawrence, Hossain, and Littlestone, 1977; Osterman, 1977; Sjaastad and Stensrud, 1969). These four studies produced similar effect size estimates (test for homogeneity: chi-square = 0.88; d.f. = 3; p = 0.83) which, when combined, yielded a summary effect size of 0.91 (0.50 to 1.3), indicating a large clinical effect that is highly statistically significant.

Lisuride. Four trials compared lisuride with placebo, using doses of 0.075 mg to 0.15 mg daily for a period of 3 to 6 months (Herrmann, Krištof, and Sastre y Hernandez, 1978; Sances, Martignoni, Resetting, et al., 1989; Somerville and Herrmann, 1978; Zuddas, Mulas, Del Zompo, et al., 1985). All four studies reported the statistically significant efficacy of lisuride, though only one trial reported sufficient data to permit any quantitative estimate of the drug’s efficacy (Sances, Martignoni, Rosettino, et al., 1989). The effect size of 0.76 (0.12 to 1.4) from this trial indicates a moderate to large effect and is statistically significant.

A single trial compared the two doses of lisuride used in the placebo-controlled trials (Wilkinson, Agnoli, Gerber, et al., 1989). The proportion of patients with a 50% or greater improvement in headache frequency was 37% both for patients receiving 0.15 mg/day and patients receiving 0.075 mg/day. However, the broad confidence intervals surrounding the resulting odds ratio (0.98 [0.42 to 2.3]) do not exclude the possibility of a clinically important dose-response relationship.

Oxitriptan. Oxitriptan was compared with placebo in three small crossover trials using doses ranging from 300 mg to 2000 mg/day (De Benedittis and Massei, 1986; Kangasniemi, Falck, Långvik, et al., 1978; Mathew, 1978). None of the three trials found a significant improvement in headache index with oxitriptan. Two provided quantitative data that permitted calculation of effect sizes (De Benedittis and Massei, 1986; Kangasniemi, Falck, Långvik, et al., 1978). The effect size estimates were 0.08 (−0.42 to 0.58) and 0.45 (−0.54 to 1.4), resulting in a combined estimate of 0.19 (−0.44 to 0.83). Neither the individual estimates nor the combined estimate is precise enough to exclude the possibility of a clinically important effect, positive or negative.

Tropisetron. Tropisetron was compared with placebo in two studies described in a single report (Ferrari, Wilkinson, Hirt, et al., 1991 [Studies 1 and 2]). The first, a dose-ranging study, failed to find effectiveness of either the 25 or 50 mg/day doses tested; however, a better response to the lower dose (25 mg) spurred a followup placebo-controlled study of 15 mg/day (Study 2). In this trial, the response rate to the 15 mg/day dose (57%) was higher than the response rate to the 25 or 50 mg/day doses tested in Study 1 (37% and 29%, respectively), and the placebo response rates were similar, at 35% compared with 40%. However, the difference of 22% in the response rate between the 15 mg/day dose and placebo was not statistically significant.

Iprazochrome. A single crossover study that compared iprazochrome 15 mg/day for 8 weeks with placebo found no difference in post-treatment headache index (Osterman, 1977).

#### Comparisons Among Serotonin Antagonists

Pizotifen vs. iprazochrome. Two crossover studies compared pizotifen, in doses of 1.5 mg or 3 mg/day, to iprazochrome 15 mg/day (Osterman, 1977; Kangasniemi, 1979). The study using the higher dose of pizotifen over 8 weeks (Osterman, 1977) showed that pizotifen doubled the proportion of patients with a 50% or greater reduction in headache frequency compared to iprazochrome, from 22% to 44%. The associated odds ratio of 2.8 (0.86 to 9.1) was not statistically significant. Continuous headache index data from this trial produced an effect size of 0.73 (0.18 to 1.3), indicating a moderate to large clinical effect that is statistically significant. The other study (Kangasniemi, 1979), which used a dose of 1.5 mg/day of lisuride, found a smaller benefit in headache index, with an effect size of 0.26 (−0.22 to 0.73).

Pizotifen vs. lisuride. A single crossover trial compared pizotifen 4.5 mg/day and lisuride (Nattero, Biale, Savi, et al., 1991). A relatively high dose of lisuride was used (0.225 mg/day). The trial demonstrated a marginally higher proportion of patients experiencing a 50% or greater reduction in headache frequency with lisuride compared with pizotifen (35% vs. 23%, respectively); however, the 12% difference between the two therapies was not statistically significant. The associated odds ratio of 0.57 (0.22 to 1.5) does not exclude the possibility of a clinically important benefit of either agent.

Pizotifen vs. oxitriptan. A single study compared pizotifen, in a low dose of 1.4 mg/day, with oxitriptan (Bono, Criscuoli, Martignoni, et al., 1982). This study found that pizotifen was significantly better in reducing headache index, but did not report sufficient data to estimate the magnitude of this benefit.

#### Comparisons With Calcium Antagonists

Pizotifen vs. flunarizine. Pizotifen and flunarizine were compared in three trials (Cerbo, Casacchia, Formisano, et al., 1986; Louis and Spierings, 1982; Rascol, Montastruc, and Rascol, 1986). Cerbo, Casacchia, Formisano, et al. (1986) used a relatively low dose of pizotifen (1.5 mg/day) and a relatively high dose of flunarizine (15 mg/day). The other two trials administered flunarizine in a dose of 10 mg/day and pizotifen in doses of 2–3 mg/day (Louis and Spierings, 1982), or in an average dose of 2.19 mg/day (Rascol, Montastruc, and Rascol, 1986).

None of these small studies found a statistically significant difference in headache frequency at 4 months between pizotifen- and flunarizine-treated patients. None reported sufficient quantitative data to allow calculation of an odds ratio for improvement or an effect size.

Pizotifen vs. nimodipine. Three trials compared pizotifen at 1.5 mg to 3 mg/day with nimodipine 120 mg/day (Gawel, 1987; Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a; Micieli, Trucco, Agostinis, et al., 1985). None of these trials found any clinically important or statistically significant differences between the two drugs. Two studies (Gawel, 1987; Havanka-Kanniainen, Hokkanen, and Myllylä, 1987a) reported enough data to calculate effect sizes of 0.11 (−0.42 to 0.64) and −0.11 (−0.54 to 0.31); these effect sizes yielded a combined estimate of 0.02 (−0.45 to 0.41), which suggests equivalent effects, but does not exclude the possibility of a small or moderate superiority of either drug.

Pizotifen vs. cyclandelate. A single trial compared pizotifen 1.5 mg/day to cyclandelate 1600 mg/day over 3 months (Mastrosimone, Iaccarino, and de Caterina, 1992). The study reported that cyclandelate-treated patients had a significantly lower total pain index than those treated with pizotifen (p<0.001); however, neither mean scores nor the proportion of patients improving was reported, so the magnitude of benefit could not be assessed.

#### Comparisons With Methysergide

Pizotifen vs. methysergide. Four trials compared pizotifen with methysergide (Andersson, 1973; Forssman, Henriksson, and Kihlstrand, 1972; Presthus, 1971; Ryan, 1968). The doses of pizotifen used ranged from 1.5 mg to 4 mg/day, while doses of methysergide were consistent across the four trials (between 3–4 mg/day). One trial reported the proportion of patients with a greater than 50% reduction in headache frequency compared to baseline (Andersson, 1973). Response rates were lower than those seen in the placebo-controlled trials: 38% for the pizotifen arm and 31% for the methysergide arm. The difference between the two treatments was not significant, and the odds ratio estimate of 1.4 (0.59 to 3.2) favored pizotifen.

Two studies reported sufficient data to calculate effect sizes, both based on headache frequency. Andersson (1973) allowed calculation of an effect size of 0.17 (−0.23 to 0.57), which favored pizotifen but failed to reach statistical significance. Presthus (1971) reported individual patient data on headache frequency which allowed calculation of an effect size of 0.29 (−0.17 to 0.76), which is very similar to the estimate from Andersson (1973). The combined effect size for the two trials was 0.22 (−0.16 to 0.60).

Oxitriptan vs. methysergide. Two trials comparing oxitriptan with methysergide provided little information on the relative effectiveness of the two agents (Sicuteri, 1973; Titus, Dávalos, Alom, et al., 1986). Sicuteri (1973) found no difference in headache index; an effect size point estimate of −0.09, based on data from the trial, was negligible, and the 95% confidence intervals associated with this point estimate were quite broad, ranging from −0.71 to 0.53. Data from Titus, Dávalos, Alom, et al. (1986) did not improve the precision of the estimate, since the proportion of patients with a 50% or greater reduction in headache frequency (overall or for severe headaches) was 75% for methysergide and 71 % for oxitriptan. The corresponding odds ratio of 0.82 (0.31 to 2.2) does not exclude a clinically important benefit of either drug.

Lisuride vs. methysergide. A single study comparing lisuride with methysergide over 3 months (Herrmann, Horowski, Dannehl, et al., 1977) found similar proportions of patients with a 50% or greater improvement in headache frequency: 53% and 51 %, respectively. The associated odds ratio of 1.1 (0.53 to 2.2) does not exclude a clinically important benefit of either drug.

#### Comparisons With Other Classes of Drugs

Pizotifen, in doses of 1.5 mg to 3 mg/day was compared with clonidine (Behan, 1985), prochlorperazine (Hübbe, 1973), metoprolol (Vilming, Standnes, and Hedman, 1985), and naproxen sodium (Bellavance and Meloche, 1990). None of these studies reported any statistically significant differences between pizotifen and the comparator treatment, and none reported sufficient quantitative data to allow the calculation of an odds ratio for improvement or an effect size.

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

#### Pizotifen

Adverse events were reported for between 25% and 91 % of patients taking pizotifen in seven trials that reported overall adverse event rates (Arthur and Hornabrook, 1971; Bellavance and Meloche, 1990; Forssman and Kihlstrand, 1972; Gawel, 1987; Krakowski and Engisch, 1973; Mastrosimone, Iaccarino, and de Caterina, 1992; Rascol, Montastruc, and Rascol, 1986). Withdrawals due to adverse events ranged from 0% to 10% of patients on pizotifen.

The specific adverse event observed most frequently with pizotifen was weight gain, occurring in 17 trials in 10% to 78% of patients. The high degree of variability in the rate of weight gain reported in different studies may be explained by the use of different thresholds for reporting weight gain as an adverse event. Osterman (1977) stratified the weight gain results, reporting that while 78% of patients on pizotifen reported a weight gain of at least 1.5 kg, 30% experienced a weight gain of more than 4 kg.

Drowsiness or somnolence was observed in 15 of the trials at rates ranging from 5% to 60%. Gastrointestinal side effects -- such as increased appetite, nausea, dyspepsia, vomiting, and diarrhea -- were observed in many trials. Dizziness or vertigo was described in eight studies at rates ranging from 2% to 27%. Fatigue was reported in seven trials at rates between 4% and 19%, and depression in four studies at rates between 5% and 13% of participants.

#### Lisuride

None of the seven trials including a lisuride treatment arm reported overall adverse event rates. Withdrawals occurred in 10% to 18% of patients taking lisuride in the four trials that reported the number of withdrawals due to adverse events. Specific adverse events (and rates) reported in more than one study included nonspecific gastrointestinal effects (5%–50%), nausea (3%–5%), vertigo (2%–24%), and drowsiness (3%–12%).

#### Oxitriptan

Of the four trials including an oxitriptan arm, one reported a total adverse event rate of 16% vs. 19% with placebo (De Benedittis and Massei, 1986), and another reported that no adverse events were reported with oxitriptan or placebo (Kangasniemi, Falck, Långvik, et al., 1978). No withdrawals due to adverse events associated with oxitriptan were reported in three trials (De Benedittis and Massei, 1986; Kangasniemi, Falck, Långvik, et al., 1978; Sicuteri, 1973); no information on withdrawals was provided in the fourth (Mathew, 1978). Specific adverse events reported with oxitriptan included gastric distress in one study (16%). Other effects reported occurred in less than 3% of subjects and included weight gain, nausea, diarrhea, pyrosis, and drowsiness.

#### Tropisetron

The two studies of tropisetron noted high rates of constipation occurring in the majority of patients (Ferrari, Wilkinson, Hirt, et al., 1991 [Studies 1 and 2]). In each of these trials, 8% of patients withdrew due to adverse events, for reasons including constipation, nausea and vomiting, hypoglycemia, and skin reaction. Other adverse events not requiring withdrawal occurred, but were not identified.

#### Iprazochrome

Neither of the two trials with an iprazochrome treatment arm reported overall rates of adverse events (Kangasniemi, 1979; Osterman, 1977). In both trials, iprazochrome was associated with a smaller number of adverse events than was pizotifen. In Osterman (1977), there were no significant differences in the adverse events reported with iprazochrome and with placebo.

### Conclusions

There is strong and consistent evidence from 11 placebo-controlled trials and 19 comparisons with other agents suggesting that pizotifen, in doses of 1.5 mg to 4 mg/day, is effective for the prevention of migraine attacks. Pizotifen has been shown in direct comparative trials to be more effective than placebo, iprazochrome, and oxitriptan. In comparisons with drugs known to be efficacious (e.g., flunarizine and metoprolol), pizotifen has been found to be no less effective. However, in the trials reviewed here, pizotifen was generally poorly tolerated, commonly causing substantial weight gain or drowsiness, and was associated with a high incidence of patient withdrawals due to adverse events.

Lisuride has consistent support from four placebo-controlled trials showing significant benefit, and from direct comparisons with pizotifen and methysergide, in which lisuride was no less effective. Lisuride was associated with a lower incidence of adverse events than was pizotifen, and a lower rate of patient withdrawal due to adverse events.

None of the other drugs considered in this section of the report (iprazochrome, oxitriptan, or tropisetron) has been shown to be effective compared to placebo. Iprazochrome and oxitriptan have been shown to be less effective than pizotifen.

## Other Treatments

This section of the report reviews the evidence for the safety and efficacy of two distinct types of treatment for which the literature review identified only a few trials each: hormonal treatments (estrogens and progestogens) and the herbal remedy, feverfew.

As a disorder, migraine frequently begins at puberty in both men and women. In many women, migraine attacks occur in conjunction with the menstrual cycle throughout the reproductive years, and the character and frequency of attacks are often affected by pregnancy and menopause. There is also a strong epidemiological association of migraine with female sex. For all these reasons, researchers have explored the possibility that hormonal treatments might be useful for the prevention of migraine. Estrogens and progestogens, in particular, have been studied among various subsets of migraineurs, including women whose migraine attacks are somehow correlated with the menstrual cycle; women whose attacks are not associated with the menstrual cycle; and, in a few studies, men.

Feverfew (tanacetum parthenium) is a medicinal plant whose leaves have become a popular treatment for the prevention of migraine.

### Studies Identified

#### Overview

The literature review identified six publications reporting on six separate controlled trials of estrogens or progestogens used for the prevention of migraine (Bradley, Hudgson, Foster, et al., 1968; Dennerstein, Morse, Burrows, et al., 1988; Hudgson, Foster, and Newell, 1967; Lundberg, 1969; Ryan, 1978; Smits, van der Meer, Pfeil, et al., 1993) and two publications reporting on two separate controlled trials of feverfew (Johnson, Kadam, Hylands, et al., 1985; Murphy, Heptinstall, and Mitchell, 1988). All eight trials were included in our analysis.

The hormonal trials reported on the safety and efficacy of the following agents:

Flumedroxone | 3 trials
Estradiol | 2 trials
Norgestrel + estradiol | 1 trial

Five of the six hormonal trials were placebo-controlled; the sixth compared flumedroxone with methysergide. Both feverfew trials were placebo-controlled.

The trials are described in Evidence Table 1.

#### Study Design and Quality

Five of the hormonal treatment trials were crossover in design; one (Lundberg, 1969) was parallel-group. One of the feverfew trials was crossover (Murphy, Heptinstall, and Mitchell, 1988), and the other parallel-group (Johnson, Kadam, Hylands, et al., 1985).

Active treatment periods in the hormonal treatment trials ranged in length from 1 month (one trial) to 4 months (one trial); the average length of the active treatment periods was 2.5 months. Active treatment periods in the two feverfew trials were 4 and 6 months.

Quality scores for the hormonal treatment trials ranged from 2 (one trial) to 5 (one trial); the average score was 3.2. For the two feverfew trials, quality scores were 4 and 3.

#### Patient Populations

Four of the six trials of hormonal treatments provided no information about the setting in which patients were recruited. In one of the remaining two cases, patients were drawn from a menstrual disorders clinic (Dennerstein, Morse, Burrows, et al., 1988); in the other, patients were said only to have been referred to the investigator (Lundberg, 1969). One of the feverfew trials recruited patients from a migraine self-help group and through media advertising (Murphy, Heptinstall, and Mitchell, 1988); the other drew patients from a migraine clinic (Johnson, Kadam, Hylands, et al., 1985).

Among the hormonal treatment trials, Bradley, Hudgson, Foster, et al. (1968) included male and female patients with “typical” migraine (which was not defined). Trial results were reported and analyzed separately for men, women with a history of more frequent migraines around the time of menstruation, and women with no such history. Dennerstein, Morse, Burrows, et al. (1988) included only women with migraine attacks of severe intensity that regularly occurred during the 7 days encompassing menstruation. Smits, van der Meer, Pfeil, et al. (1993) included only women with “pure menstrual migraine,” defined as attacks of migraine without aura (as defined by the IHS criteria), regularly occurring no earlier than 2 days before menstruation and no later than the last day of menstruation, with no attacks during the rest of the menstrual cycle. The remaining three trials did not focus on migraine attacks associated with the menstrual cycle: Hudgson, Foster, and Newell (1967) treated a group of patients (sexual mix not described) with frequent, severe attacks of “typical” migraine (again, not defined); Lundberg (1969) included men and women with migraine with or without aura; and Ryan (1978) treated a group of women described only as having migraine of moderate to severe intensity. The feverfew trials both included patients with migraine with aura or migraine without aura. Most of the trials had minimum frequency requirements for inclusion. Apart from Smits, van der Meer, Pfeil, et al. (1993), none of the trials referred to the Ad Hoc or IHS diagnostic criteria.

Three of the hormonal treatment trials included patients who had tried preventive therapy at some point in the past (Dennerstein, Morse, Burrows, et al., 1988; Hudgson, Foster, and Newell, 1967; Lundberg, 1969). Another trial (Smits, van der Meer, Pfeil, et al., 1993) permitted patients on preventive medication to continue taking it during the trial, provided they had been taking it for at least 3 months before the trial started and did not change the medication during the trial. Two of the hormonal treatment trials did not state whether patients were permitted to take medication for acute attacks occurring during the trial (Bradley, Hudgson, Foster, et al., 1968; Hudgson, Foster, and Newell, 1967); the remaining four permitted the use of such medication.

One of the feverfew trials included only patients who had been taking the herb daily for at least 3 months prior to the start of the trial (Johnson, Kadam, Hylands, et al., 1985); this trial also permitted the use of both acute and preventive medications. In the other feverfew trial (Murphy, Heptinstall, and Mitchell, 1988), only 29% of those who completed the trial had used feverfew before, and no acute or preventive medications were permitted during the trial.

Three of the hormonal treatment trials did not report the average age of patients, and one did not report the number of patients who were women. Among those trials that did report such information, the average age of patients ranged from 35 to 40, and the percentage of patients who were women ranged from 64% to 100%. Average ages in the feverfew trials were 46 and 48. In one trial, 74% of patients were women; the other trial did not report on the number of patients who were women.

### Evidence for Efficacy

Efficacy data from the trials reviewed in this section of the report are summarized in Evidence Table 11.

#### Hormonal Treatments

Estradiol. Estradiol was compared with placebo in two trials (Dennerstein, Morse, Burrows, et al., 1988; Smits, van der Meer, Pfeil, et al., 1993). Dennerstein, Morse, Burrows, et al. (1988) studied 19 women with menstrual migraines, randomizing them to receive either a percutaneous estradiol gel (1.5 mg/day) or a placebo gel to be used beginning at least 2 days before an anticipated headache and continuing for 7 days thereafter. Headache frequency during the 7-day perimenstrual period (which did not necessarily correspond precisely with the days of estradiol administration) was lower among women treated with the active preparation. We calculated an effect size for this outcome based on individual patient data reported by the investigators; the effect size was 0.71 (0.26 to 1.2), which is statistically significant in favor of estradiol.

The other trial of estradiol (Smits, van der Meer, Pfeil, et al., 1993) was also conducted among women with menstrual migraine; but, in this case, patients were selected according to a more stringent definition of menstrual migraine, and a much lower dose of estradiol was used. Patients were randomized to receive a patch delivering 50 micrograms of estradiol daily or a placebo patch. The patch was to be applied 2 days before the anticipated onset of menstruation, with another patch to be applied 4 days later. Headache frequency (measured as the number of menstrual cycles accompanied by a migraine attack) did not differ significantly between those cycles in which estradiol was used and those in which placebo was used; 59% of cycles on estradiol and 69% of cycles on placebo were associated with migraine.

Flumedroxone. Two placebo-controlled trials provided data on the efficacy of the drug flumedroxone, a modified oral progestogen designed to have reduced progestogenic effects (Bradley, Hudgson, Foster, et al., 1968; Lundberg, 1969). Bradley, Hudgson, Foster, et al. (1968) randomized patients to receive either 30 mg of a micronized preparation of flumedroxone or placebo daily for 3 months. The investigators’ analysis was stratified to consider separately three patient subgroups: men, women without menstrual exacerbation of headache, and women with menstrual exacerbation of headache. Headache index was reduced with flumedroxone compared to placebo only among women with menstrual exacerbation of their headaches (p<0.05). With 18 patients, this was the largest of the three subgroups studied.

Lundberg (1969) compared flumedroxone 10 mg daily with placebo in a parallel-group trial. The investigator found a highly significant improvement (p<0.0005) in headache frequency associated with flumedroxone; however, the definition used for improvement (fewer headaches than during the pre-treatment period) did not meet our 50% or greater threshold.

Flumedroxone, in a dose of 15 mg/day, was also compared with methysergide in a single crossover study (Hudgson, Foster, and Newell, 1967). The patient population of this trial was poorly characterized: the sexual distribution was not described, and participants were said to suffer from frequent, severe attacks of “typical” migraine, which was not defined. Mean headache frequency was lower with methysergide than with flumedroxone (2.8 vs. 4.3 attacks per month, respectively). No statistical comparison was made by the investigators, and insufficient data were reported to allow us to calculate an effect size.

Ovral® (norgestrel 0.5 mg + ethinyl estradiol 0.005 mg). A combination oral contraceptive (Ovral®) was compared with no treatment in a randomized crossover trial conducted among 40 women with migraine (Ryan, 1978). There was no explicit requirement that patients’ migraines be associated with their menstrual cycle. One Ovral® tablet was administered daily for 3 weeks, followed by no treatment for 1 week, during each month of the 2-month active treatment periods. Headache index scores were worse during treatment with Ovral® than during the no-treatment period (48.70 vs. 32.85, respectively). No tests of statistical significance were reported.

#### Feverfew

Two trials compared feverfew with placebo or no treatment (Johnson, Kadam, Hylands, et al., 1985; Murphy, Heptinstall, and Mitchell, 1988). The trials differed from one another in several important respects.

Johnson, Kadam, Hylands, et al. (1985) recruited patients through a headache clinic who had not only previously tried feverfew, but had been using the herb daily for at least 3 months. The investigators randomized these patients either to continue taking 50 mg of the freeze-dried, pulverized, and encapsulated herb daily, or to take a matching placebo. This small trial (15 patients completed the trial) found an increase in headache frequency among those taking placebo, and little change in those maintained on feverfew. The difference was highly statistically significant, even with a small sample size, with an effect size of 2.3 (1.0 to 3.6).

A subsequent trial was conducted in a larger population of migraineurs recruited from a migraine self-help group and through media advertising (Murphy, Heptinstall, and Mitchell, 1988). Only 29% of the 59 patients who completed the trial and were included in the efficacy analysis had used feverfew before; 8% (5/59) were using the herb at the time of entry into the study. This crossover study reported a highly significant difference in headache frequency between feverfew and placebo periods; however, the magnitude of the difference between the two treatments was much smaller than that observed in the trial discussed immediately above: 1.1 headaches per 2-month treatment period, which yielded an effect size of 0.56 (0.19 to 0.93).

### Adverse Events

The available data on adverse events are summarized in Evidence Table 12.

#### Hormonal Treatments

Adverse events were only slightly more frequent with estradiol than with placebo. In Dennerstein, Morse, Burrows, et al. (1988), amenorrhea was the most commonly reported adverse event (9% of patients on estradiol vs. 0% on placebo). In Smits, van der Meer, Pfeil, et al. (1993), where an estradiol patch was used, itching in the area of the patch was the most common adverse event associated with estradiol that was not reported with placebo (9% vs. 0%). Very few withdrawals were caused by adverse events associated with estradiol.

Progestogenic adverse events -- particularly polymenorrhea, nausea, and mastitis -- were much more frequent with flumedroxone than with placebo in Bradley, Hudgson, Foster, et al. (1968). Six of 14 (43%) women of reproductive age included in the trial reported polymenorrhea. Among male patients taking flumedroxone, adverse events included drowsiness, dyspepsia, and decreased libido. Another placebo-controlled study, using a lower dose of flumedroxone (Lundberg, 1969), provided incomplete information on adverse events, but noted that menstrual disturbances were the most common adverse events, occurring in 8/30 women (27%).

In the only trial comparing the two interventions, adverse events were significantly more frequent during treatment with flumedroxone (23% of patients) than during treatment with methysergide (3% of patients). Thirteen percent of patients (5/40) reported polymenorrhea with flumedroxone (vs. 0% with methysergide).

Limited information was provided on adverse events in the only trial of Ovral® (norgestrel + ethinyl estradiol) (Ryan, 1978). A high proportion of patients (70%) reported one or more adverse events in association with Ovral®. The frequency of individual adverse events was not reported, but at least the following were observed: nausea, vomiting, abdominal cramping, depression, drowsiness, and dry mouth.

#### Feverfew

Johnson, Kadam, Hylands, et al. (1985) reported that more adverse events were experienced by those patients in the placebo group (i.e., those from whom feverfew was withdrawn) than by those continuing with active treatment. Adverse events reported on withdrawal of feverfew included nervousness, and tension-type and other non-migrainous headaches. Other adverse events were infrequent and were reported in similar proportions by patients in the placebo and feverfew groups.

Murphy, Heptinstall, and Mitchell (1988) described a different constellation of adverse events, but reported that these symptoms were no more common during treatment with feverfew than during treatment with placebo. Mouth ulceration was remarkably common, occurring in 22% of patients during treatment with feverfew and in 14% during treatment with placebo. Other adverse events were infrequently reported.

### Conclusions

#### Hormonal Treatments

Data on the use of estrogens and progestogens for migraine prevention are relatively poor, with only a few relatively small trials and marked variation in subject population, dosages employed, and clinical results. The trials of estradiol used perimenstrually in a gel or patch form suggest that a relatively high dose of this hormone may be efficacious in women whose migraine attacks are associated with their menstrual cycles. The trials using lower doses of estradiol perimenstrually or mixed estradiol/progestogen oral contraceptives in a cyclic fashion do not support efficacy for migraine prevention.

Three trials of flumedroxone indicate that this agent can be efficacious, particularly among women whose migraine headaches are associated with their menstrual cycle. The use of this agent is, however, limited by the frequency of polymenorrhea and other adverse events.

The data reviewed in this section of the report do not support the efficacy of estrogens or progestogens in women whose migraines are not associated with their menstrual cycle, or in male migraineurs.

#### Feverfew

Two trials provide evidence that feverfew is efficacious for migraine prevention. One study among a self-selected population of feverfew users showed that withdrawal of feverfew led to a statistically significant increase in headache frequency. Another, more traditional, trial suggested that feverfew was efficacious among a more generalizable population of migraineurs. Although the magnitude of benefit was smaller in this second trial, the effect size estimate obtained was similar to those associated with other migraine preventive medications.

## Future Research

Further research is required into the safety and efficacy of currently available drugs if their use for the long-term prevention of migraine attacks is to be optimized. The recommendations described below may be made.

### Conduct and Reporting of Trials

- (1) The generalizability of the results of trials conducted among patients in headache specialty centers to primary care populations is uncertain. More trials should be conducted among patients recruited from general practice settings.
- (2) The diagnosis of migraine -- even when made according to specific criteria such as the IHS criteria for migraine with aura and migraine without aura -- encompasses a wide range of symptomatology. Researchers should be as precise as possible in describing any operational inclusion or exclusion criteria they employed in addition to headache diagnosis, such as headache frequency, severity, and chronicity.
- (3) The use of medications for the treatment of acute migraine episodes during the trial of preventive therapy was handled in a variety of ways in different studies. Because effective treatment of acute migraine attacks can significantly affect headache severity and duration measures, the uncontrolled use of such medications can confound the results of a preventive trial. Future studies should measure and describe the use of medications for the treatment of acute migraine attacks.
- (4) More head-to-head comparisons of preventive treatments should be performed in order to help clinicians and patients make informed choices among the many available therapies. Such comparative trials are particularly important for older drugs.
- (5) Future trials should use common scales for measuring pain outcomes, if possible. The IHS recommends the use of headache frequency per 4-week observation period as the primary measure of efficacy (International Headache Society Committee on Clinical Trials in Migraine, 1991). The consistent adoption of this recommendation in trials of migraine preventive drugs would greatly facilitate future meta-analyses.
- (6) Because many preventive drugs are poorly tolerated, future trials should expand the scope of the clinically relevant outcomes measured. Overall or disease-specific quality-of-life measures, along with careful assessment and complete reporting of adverse events, would help in evaluating the overall efficacy of the treatment.
- (7) Adverse events should be reported for all patients taking study medication, including those who withdraw prematurely. The number of patients experiencing adverse events with each intervention should be reported, and the specific adverse events reported should be described.

### New Directions for Research

- (8) Adverse events associated with long-term use of some migraine preventive agents have been identified (e.g., fibrotic complications associated with methysergide, weight gain with flunarizine, and gastrointestinal symptoms with many NSAIDs). The relatively short-term clinical trials reviewed in this report do not effectively capture these adverse events. New approaches to ascertaining long-term or rare complications of treatment are needed.
- (9) The real-life management of headache disorders often involves multiple simultaneous interventions, including an acute drug treatment plan (which might include an initial and rescue medication), a preventive drug treatment plan, behavioral therapy or other self-management education, or skills training. Such multidisciplinary interventions, usually delivered in specialty clinics, have been reported to show dramatic response rates in uncontrolled studies. Testing these bundled multiple interventions in a prospective, controlled trial may provide more understanding of how to care for patients with chronic headache disorders than do the short-term, single intervention preventive drug studies reviewed here.
- (10) Further research is needed regarding the delivery of migraine care, in general, and of preventive therapies, in particular. It is important to ascertain whether there are patterns of use of different migraine treatment approaches in different settings and among different types of providers (e.g., generalists versus specialists).
- (11) Limited data suggest that most patients do not remain on migraine preventive drugs for long-term use; however, little is known about the reasons for discontinuing the drugs or about the effect of this discontinuation on patients’ headaches. Preventive drug treatments for migraine are often undertaken with the expectation that after a period of successful treatment (e.g., 6 to 12 months), treatment can be discontinued without the patient’s headaches either worsening or returning to the same intensity experienced prior to treatment. Further research on the effects of withdrawing migraine preventive treatments would help address the issue of whether to discontinue or taper treatment and the best timeframe for doing so.
- (12) Few studies have attempted to identify predictors of response or nonresponse to particular migraine preventive drugs, leaving physicians with little guidance for choosing among efficacious agents. Particularly informative would be tests of association between treatment response and patient-level factors, such as headache characteristics, demographic characteristics, or response (or nonresponse) to other drugs for the acute or preventive treatment of migraine. Furthermore, protocols describing particular selection criteria or order of drug trials in individual patients could be tested in a controlled fashion.