# Summary

## Overview

### Background

Migraine is a common and disabling health problem among adult Americans. Surveys from the U.S. and elsewhere suggest that 6% of men and 15% to 17% of women experience migraine headaches. These headaches result in significant disability and work loss; estimated aggregate indirect costs to employers in the U.S. for reduced productivity due to migraine range from $6.5 billion to $17 billion annually.

Patterns of medical care for the treatment of migraine are highly variable. A substantial proportion of migraineurs never consult a physician about their headaches. Among those who do seek medical attention, many do not continue with the course of treatment prescribed by their physician, citing the availability of nonprescription medications and negative side effects associated with prescription medications among the reasons for self-treatment.

Preventive drug treatments are used by a small percentage of migraineurs -- 3% to 5% of patients in various studies. It is not known whether the patients in these studies who were not using preventive drug therapy had never been offered such treatment or had tried it and found it ineffective or intolerable.

A substantial body of high-quality evidence exists describing the effectiveness of various drugs for the prevention of migraine. Synthesis and dissemination of this information may help correct the underuse or misuse of preventive drug treatment strategies for migraine.

### Scope of the Report

The objective of this evidence report is to provide a comprehensive review and analysis of published reports of randomized controlled trials (RCTs) and other prospective, comparative clinical trials of drug treatments for the prevention of migraine. The present report does not cover all drugs that may be used for the prevention of migraine, but only those that have been studied in controlled trials among a population of migraineurs. These include (in alphabetical order): alpha-2 agonists (clonidine, guanfacine); anticonvulsants (divalproex sodium, sodium valproate, carbamazepine, clonazepam, gabapentin); antidepressants (amitriptyline, clomipramine, femoxetine, fluoxetine, fluvoxamine, mianserin, opipramol); beta-blockers (propranolol, metoprolol, acebutolol, alprenolol, atenolol, bisoprolol, nadolol, oxprenolol, pindolol, practolol, timolol); calcium antagonists (cyclandelate, flunarizine, nicardipine, nifedipine, nimodipine, verapamil); ergots (dihydroergotamine [DHE], dihydroergokryptine [DEK], ergotamine, and the combination agent Cafergot comp.®); methysergide; nonsteroidal anti-inflammatory drugs (NSAIDs) (aspirin, fenoprofen, flurbiprofen, indobufen, indomethacin, ketoprofen, lornoxicam, mefenamic acid, naproxen, naproxen sodium, tolfenamic acid); other serotoninergic drugs (pizotifen, lisuride, oxitriptan, iprazochrome, tropisetron); and other treatments (hormonal preparations [estradiol, mixed estradiol/progestogen oral contraceptives, flumedroxone] and the herbal remedy feverfew). Several drugs for which there is a large body of evidence are unavailable in the U.S., including flunarizine, pizotifen, and lisuride.

## Methodology

The literature review addressed the question “What are the effects on headache pain and/or headache frequency when drug treatments aimed at preventing episodes of migraine are compared with placebo, alternative drug treatments, and non-drug therapies among patients with migraine headache?”

To be considered for this review, studies were required to be prospective, controlled trials of a drug treatment given regularly in headache-free intervals with the aim of preventing the occurrence of migraine attacks in patients with migraine headaches.

Although the use of a specific set of diagnostic criteria (e.g., those developed by the Ad Hoc Committee on the Classification of Headache and the Headache Classification Committee of the International Headache Society [IHS]) was not required, diagnoses were required to be based on at least some of the distinctive features of migraine, e.g., nausea/vomiting, severe head pain, throbbing character, unilateral location, phono/photophobia, or aura. As the IHS criteria allow, we considered patients described as having “mixed” migraine and tension-type headache or “combination” headache to have migraine.

Studies were included only if allocation to treatment groups was randomized or quasi-randomized (based on some nonrandom process unrelated to the treatment selection or expected response); concurrent cohort comparisons and other nonexperimental designs were excluded. Control groups could comprise no intervention, placebo or sham interventions, usual care, or a specified alternative drug or non-drug treatment.

Relevant controlled trials were identified by searching MEDLINE (January 1966 through December 1996) using the MeSH term “headache” (exploded) and a published strategy for identifying randomized controlled trials. Additional search strategies included computerized bibliographical searching of PsycINFO and CINAHL., databases; retrospective and prospective hand-searching of the journals Headache, Cephalalgia, and Headache Quarterly from the inception of each (1961, 1981, and 1990, respectively); searching the reference lists of review articles and included studies; searching books related to headache; and consulting experts in the field. We also searched a database of randomized trials in pain relief which is now part of the Cochrane Controlled Trials Register.

Studies identified by the literature search were screened for further review based on criteria focusing on patient population, intervention, study design, and type of outcome data reported.

Studies passing the initial screen were reviewed for methodological quality based on the following considerations: the use of random allocation; description of an adequate method of concealment of allocation; the use of double-blinding; description of an adequate method of blinding; and a description of dropouts sufficient to determine the number of patients in each treatment group entering and completing the trial. Each trial could score 1 point for each criterion (for a total of from 0 to 5 points), with higher scores indicating higher quality in the conduct or reporting of the trial.

Efficacy data were abstracted from the original reports onto specially designed forms. We collected trial data on symptomatic outcomes related to head pain (frequency, severity/intensity, and duration) and other symptoms of migraine (nausea, vomiting, photophobia, phonophobia). Secondary outcomes recorded included medication use, functional status (disability), and quality of life. We did not consider physiological or other measures not directly relevant to the patients’ symptomatic experience.

We preferred that outcome data be based on daily recording of headache symptoms by patients, rather than on global or retrospective assessments performed by patients or investigators. Outcomes were recorded post-treatment and at followup, if available.

We preferred combined measures of headache symptoms such as headache indexes (variously defined combinations of frequency, intensity, and duration). In the absence of a headache index, we recorded headache frequency alone. If neither headache index values nor frequency data were reported, we analyzed data on headache intensity.

For dichotomous outcomes (e.g., success/failure), we required that the threshold for distinguishing between success and failure be clinically significant; for example, we interpreted a 50% or more decrease in headache frequency or headache index (two of the most common definitions) as meeting this criterion. Dichotomous outcomes meeting our definition of a clinically significant threshold were reported as proportions (or response rates for each treatment) which may be directly compared (difference in proportions). We also used these proportions to calculate odds ratios.

In the few instances in which outcome data were reported on an ordinal scale (e.g., for reduction in headache frequency: none, some, moderate, significant, very significant), we selected a threshold based on the definition of clinically significant improvement (discussed above) and converted these data into a dichotomous outcome.

Most of the trials reported outcomes on a continuous scale (e.g., mean headache index or mean headache frequency). In these cases, whenever variance estimates were also available, we rescaled and standardized the continuous outcome data for each treatment condition in each study using a published method. We used the standardized outcome measures to calculate individual effect sizes for pair-wise comparisons of drug and control treatments. When multiple trials provided effect size estimates of the same drug-placebo or drug-drug comparisons, the effect sizes were tested for homogeneity, and used to calculate summary effect sizes for each type of treatment, using a random-effects model.

Throughout the report, wherever we have used the word “significant” to describe results, we mean “statistically significant at an alpha level of 0.05 for the two-sided alternative hypothesis.” Wherever we have reported on results that are clinically, rather than statistically, significant, we have explicitly used the word “clinically.”

The incidence of adverse events was recorded and the proportion of patients experiencing adverse events calculated for each treatment group, whenever possible. The difference between rates of adverse events was calculated, along with a 95% confidence interval (CI) for the difference. A 95% CI that excludes zero suggests that the rates are significantly different between groups. The identity and rates of specific adverse events reported were summarized for each study.

## Findings

The evidence supporting different agents or classes of agents reviewed in this report varies considerably in quantity and quality. This section summarizes the results of our analysis; the next section describes the most urgent priorities for future research.

### Alpha-2 Agonists

Our analysis included 16 controlled trials of clonidine and one of guanfacine. The principal findings were:

- There is not sufficient evidence to conclude that clonidine is effective for the prevention of migraine. The existing trials suggest that this agent is, at most, mildly effective, but this has not been demonstrated conclusively. Placebo-controlled trials reported both positive and negative results. In comparisons with beta-blockers with intrinsic sympathomimetic activity (practolol and prindolol), for which evidence for efficacy is lacking, clonidine has consistently been shown to be no more effective.
- Adverse events (most commonly drowsiness or tiredness) were observed in a high proportion of patients in trials of clonidine, but the reported symptoms were usually neither serious nor the cause of patient withdrawals from trials.

### Anticonvulsants

Our analysis included nine controlled trials involving the following agents: divalproex sodium, sodium valproate, carbamazepine, clonazepam, and gabapentin. The principal findings of the analysis were as follows:

- Strong and consistent evidence supports the efficacy of divalproex sodium and the related compound sodium valproate for the prevention of migraine.
- The evidence for the efficacy of other anticonvulsant agents is weaker. Carbamazepine has mixed support from one placebo-controlled trial (suggesting efficacy) and one comparison with prindolol and clonidine (suggesting a smaller effect on headache frequency than either comparator). Neither clonazepam nor gabapentin appears to be an effective migraine preventive drug.
- Adverse events -- most commonly dizziness and drowsiness -- were frequently observed with anticonvulsants and were a frequent cause of patient withdrawals from trials.

### Antidepressants

Our analysis included 16 controlled trials involving the following agents: amitriptyline, clomipramine, femoxetine, fluoxetine, fluvoxamine, mianserin, and opipramol. Opipramol, fluoxetine, and mianserin are not available in the U.S. The principal findings of the analysis are described below:

- Of all the antidepressants, the tricyclic amitriptyline has been most frequently studied for the prevention of migraine and is the only agent with reasonably consistent support for efficacy. Although this has not been demonstrated conclusively, amitriptyline may be more efficacious for patients with mixed migraine and tension-type headache than for patients with migraine alone.
- None of the other agents reviewed -- clomipramine, femoxetine, fluoxetine, fluvoxamine, mianserin, or opipramol -- has sufficient data to support its efficacy, though substantial uncertainty still exists for these agents.
- Tolerability was a problem with the tricyclic antidepressants studied (amitriptyline, clomipramine, and opipramol), with anticholinergic symptoms frequently reported. Adverse events were less frequently reported with the selective serotonin re-uptake inhibitors (femoxetine, fluoxetine, and fluvoxamine). However, the particular adverse events most commonly observed with these agents (nausea and sexual dysfunction) may be of greater concern to many migraineurs than the anticholinergic effects associated with tricyclic antidepressants.

### Beta-blockers

Our analysis covered 74 controlled trials, including a large number of trials of propranolol (46 trials) and metoprolol (15 trials), and much smaller numbers of trials of acebutolol, alprenolol, atenolol, bisoprolol, nadolol, oxprenolol, pindolol, practolol, and timolol. The principal findings of the analysis were:

- Propranolol, in a daily dose of 120 mg to 240 mg, has strong and consistent support for efficacy in reducing headache frequency and headache index. Timolol, metoprolol, atenolol, and nadolol are also likely to be beneficial, based on trials comparing these agents to placebo or to propranolol.
- Beta-blockers with intrinsic sympathomimetic activity -- including acebutolol, alprenolol, oxprenolol, and pindolol -- appear to be ineffective for the prevention of migraine.
- There is insufficient evidence to conclude that extended-release preparations of propranolol and metoprolol are more or less effective, or more or less well tolerated, than regular formulations of these drugs.
- While some studies had high dropout rates, most patients appear to have tolerated the adverse events associated with beta-blockers (principally fatigue, depression, nausea, dizziness, and insomnia). Dropouts were rarely due to adverse events associated with the active treatments.

### Calcium Antagonists

Our analysis included 45 controlled trials of the following agents: cyclandelate, flunarizine, nicardipine, nifedipine, nimodipine, and verapamil. Flunarizine, the agent in this class most frequently studied for migraine prevention, is not available in the US, nor is cyclandelate. The main findings of the analysis are described below:

- Flunarizine has strong and consistent evidence from eight placebo-controlled trials for efficacy in migraine prevention. This evidence is strengthened by comparisons with propranolol, another drug whose efficacy is well-established for migraine prevention, which demonstrates reasonable equivalence.
- Other calcium antagonists have been less thoroughly studied. Nimodipine had mixed results in six placebo-controlled studies.
- Nifedipine had consistently poor results in four trials, two placebo-controlled and two comparisons with propranolol.
- Verapamil is the calcium antagonist most commonly used for migraine prevention in the U.S. Two small placebo-controlled trials suggested that this agent is effective in migraine prevention. However, both trials were plagued by high dropout rates. Our best estimate of the efficacy of this agent therefore carries substantial uncertainty.
- Nicardipine has a single positive trial supporting its efficacy. The effect size from this trial was intermediate between those associated with the other dihydropyridine calcium antagonists, nifedipine and nimodipine.
- Cyclandelate has not been tested in placebo-controlled trials for migraine prevention, but it has been compared with several drugs of established efficacy, viz. flunarizine, propranolol, and pizotifen. Cyclandelate was found to be less effective than flunarizine, but more effective than pizotifen; the comparison with propranolol was uninformative. The uncertainty regarding the efficacy of this agent is still considerable, given the lack of placebo-controlled trials.
- The adverse event rates reported for calcium antagonists varied widely between studies, even between studies of the same dose of the same drug, and provided little in the way of reliable information on the risk of adverse events associated with these agents.

### Ergots

Our analysis included 13 controlled trials of the following agents: dihydroergotamine (DHE), dihydroergokryptine (DEK), ergotamine, and the combination agent Cafergot comp.® (ergotamine + caffeine + butalbital + belladonna alkaloids). The principal findings of the analysis are described below:

- Dihydroergotamine appears to be efficacious for migraine prevention when used in a daily dose of 10 mg, based on four placebo-controlled trials with consistent findings. A single trial suggested that DHE may be less effective than amitriptyline for patients with mixed migraine + tension-type headache.
- The efficacy of dihydroergokryptine is less certain, but is supported by one placebo-controlled study in women with menstrual migraine and by one direct comparison each with flunarizine and methysergide.
- Cafergot compo ® and ergotamine do not have support for efficacy in migraine prevention.
- The limited data reported on adverse events reported suggest that unwanted gastrointestinal symptoms are common with all the drugs in this class.

### Methysergide

Methysergide was one of the first drugs to be used for the prevention of migraine. Our analysis included 16 controlled trials of this agent. The main conclusions were as follows:

- Four placebo-controlled trials suggested that methysergide is moderately effective at reducing headache frequency. These trials were all conducted in the 1960s using earlier or no diagnostic criteria for migraine, and their generalizability to patients diagnosed under the more precise diagnostic criteria of the IHS is uncertain.
- In direct comparisons with other migraine preventive agents, methysergide appeared to be no more effective than pizotifen or propranolol.
- A handful of trials comparing methysergide to other drugs (oxitriptan, lisuride, DEK, ergotamine, flumedroxone [Demigran®], and flunarizine) were too small to demonstrate equivalence and failed to demonstrate any statistically significant differences.
- Short-term adverse events (principally gastrointestinal complaints) led to discontinuation of treatment in up to 20% of patients treated with methysergide in the reviewed trials. The risk of adverse events associated with the long-term use of methysergide (particularly fibrotic changes in the retroperitoneal, pleuropulmonary, cardiac, and other tissues) is, however, probably a greater deterrent to the use of this agent.

### Nonsteroidal Anti-inflammatory Drugs (NSAIDs)

Our analysis included 23 controlled trials involving the following NSAIDs: aspirin, fenoprofen, flurbiprofen, indobufen, indomethacin, ketoprofen, lornoxicam, mefenamic acid, naproxen, naproxen sodium, and tolfenamic acid. The main findings of the analysis are described below:

- Multiple trials of naproxen or naproxen sodium consistently showed a moderate reduction in headache symptoms compared with placebo.
- Some of the other agents studied -- including flurbiprofen, indobufen, ketoprofen, lornoxicam, mefenamic acid, and tolfenamic acid -- appeared to have similar moderate effects, but fewer studies supported the efficacy of these agents.
- The effects of aspirin, aspirin + dipyridamole, fenoprofen, and indomethacin are less certain. The reviewed trials of these agents described unusually large or small effects that have not been replicated.
- Gastrointestinal (GI) adverse events were common with NSAIDs and often led to withdrawal from trials. The relatively short-term trials reviewed here were inadequate to assess adverse events that may be associated with the long-term use of NSAIDs.

### Other Serotoninergic Agents

Our analysis included 40 controlled trials involving the following agents: pizotifen, lisuride, oxitriptan, iprazochrome, and tropisetron. None of these agents is currently available in the US. The principal findings of the analysis were as follows:

- There is strong and consistent evidence from 11 placebo-controlled trials and 19 comparisons with other agents suggesting that pizotifen, in doses of 1.5 mg to 4 mg/day, is effective for the prevention of migraine attacks. In direct comparisons with other drugs known to be efficacious (e.g., flunarizine and metoprolol), pizotifen has been found to be no less effective. However, in the trials reviewed here, pizotifen was generally poorly tolerated, commonly causing substantial weight gain or drowsiness, and was associated with a high incidence of patient withdrawals due to adverse events.
- Lisuride has consistent support from four placebo-controlled trials showing significant benefit, and from direct comparisons with pizotifen and methysergide, in which lisuride was no less effective. Lisuride was associated with a lower incidence of adverse events than was pizotifen, and a lower rate of patient withdrawal due to adverse events.
- None of the other drugs considered (iprazochrome, oxitriptan, or tropisetron) has been shown to be effective compared to placebo. Iprazochrome and oxitriptan have been shown to be less effective than pizotifen.

### Other Treatments

In addition to the treatments described above, we reviewed six trials of estrogens or progestogens for the prevention of migraine, and two trials of the herbal remedy, feverfew. The main findings of our analysis were as follows:

- Data on the use of estrogens and progestogens for migraine prevention are relatively poor, with only a few small trials and marked variation in subject population, dosages employed, and clinical results. Trials of estradiol used perimenstrually in a gel or patch form suggest that a relatively high dose of this hormone may be efficacious in women whose migraine attacks are associated with their menstrual cycles. The trials using lower doses of estradiol perimenstrually or mixed estradiol/progestogen oral contraceptives in a cyclic fashion do not support efficacy for migraine prevention.
- Three trials of the progestogen flumedroxone indicate that this agent can be efficacious, particularly among women whose migraine headaches are associated with their menstrual cycle. The use of this agent is, however, limited by the frequency of polymenorrhea and other adverse events.
- The data analyzed do not support the efficacy of estrogens or progestogens in women whose migraines are not associated with their menstrual cycle, or in male migraineurs.
- Two trials provide evidence that feverfew is efficacious for migraine prevention.

## Future Research

Further research is required into the safety and efficacy of currently available drugs if their use for the long-term prevention of migraine attacks is to be optimized. The recommendations described below may be made.

### Conduct and Reporting of Trials

- (1) The generalizability of the results of trials conducted among patients in headache specialty centers to primary care populations is uncertain. More trials should be conducted among patients recruited from general practice settings.
- (2) The diagnosis of migraine -- even when made according to specific criteria such as the IHS criteria for migraine with aura and migraine without aura -- encompasses a wide range of symptomatology. Researchers should be as precise as possible in describing any operational inclusion or exclusion criteria they employed in addition to headache diagnosis, such as headache frequency, severity, and chronicity.
- (3) The use of medications for the treatment of acute migraine episodes during the trial of preventive therapy was handled in a variety of ways in different studies. Because effective treatment of acute migraine attacks can significantly affect headache severity and duration measures, the uncontrolled use of such medications can confound the results of a preventive trial. Future studies should measure and describe the use of medications for the treatment of acute migraine attacks.
- (4) More head-to-head comparisons of preventive treatments should be performed in order to help clinicians and patients make informed choices among the many available therapies. Such comparative trials are particularly important for older drugs.
- (5) Future trials should use common scales for measuring pain outcomes, if possible. The IHS recommends the use of headache frequency per 4-week observation period as the primary measure of efficacy. The consistent adoption of this recommendation in trials of migraine preventive drugs would greatly facilitate future meta-analyses.
- (6) Because many preventive drugs are poorly tolerated, future trials should expand the scope of the clinically relevant outcomes measured. Overall or disease-specific quality-of-life measures, along with careful assessment and complete reporting of adverse events, would help in evaluating the overall efficacy of the treatment.
- (7) Adverse events should be reported for all patients taking study medication, including those who withdraw prematurely. The number of patients experiencing adverse events with each intervention should be reported, and the specific adverse events reported should be described.

### New Directions for Research

- (8) Adverse events associated with long-term use of some migraine preventive agents have been identified (e.g., fibrotic complications associated with methysergide, weight gain with flunarizine, and gastrointestinal symptoms with many NSAIDs). The relatively short-term clinical trials reviewed in this report do not effectively capture these adverse events. New approaches to ascertaining long-term or rare complications of treatment are needed.
- (9) The real-life management of headache disorders often involves multiple simultaneous interventions, including an acute drug treatment plan (which might include an initial and rescue medication), a preventive drug treatment plan, behavioral therapy or other self-management education, or skills training. Such multidisciplinary interventions, usually delivered in specialty clinics, have been reported to show dramatic response rates in uncontrolled studies. Testing these bundled multiple interventions in a prospective, controlled trial may provide more understanding of how to care for patients with chronic headache disorders than do the short-term, single-intervention preventive drug studies reviewed here.
- (10) Further research is needed regarding the delivery of migraine care, in general, and of preventive therapies, in particular. It is important to ascertain whether there are patterns of use of different migraine treatment approaches in different settings and among different types of providers (e.g., generalists versus specialists).
- (11) Limited data suggest that most patients do not remain on migraine preventive drugs for long-term use; however, little is known about the reasons for discontinuing the drugs or about the effect of this discontinuation on patients’ headaches. Preventive drug treatments for migraine are often undertaken with the expectation that after a period of successful treatment (e.g., 6 to 12 months), treatment can be discontinued without the patient’s headaches either worsening or returning to the same intensity experienced prior to treatment. Further research on the effects of withdrawing migraine preventive treatments would help address the issue of whether to discontinue or taper treatment and the best time frame for doing so.
- (12) Few studies have attempted to identify predictors of response or nonresponse to particular migraine preventive drugs, leaving physicians with little guidance for choosing among efficacious agents. Particularly informative would be tests of association between treatment response and patient-level factors, such as headache characteristics, demographic characteristics, or response (or nonresponse) to other drugs for the acute or preventive treatment of migraine. Furthermore, protocols describing particular selection criteria or order of drug trials in individual patients could be tested in a controlled fashion.