# References

Ad Hoc Committee on the Classification of Headache of the National Institute of Neurological Diseases and Blindness. Classification of headache. JAMA. 1962;179:717-8.
Adam EI, Gore SM, Price WH. Double-blind trial of clonidine in the treatment of migraine in a general practice. J R Coll Gen Pract. 1978;28(195):587-90. [pmid: 368333].
Adly C, Straumanis J, Chesson A. Fluoxetine prophylaxis of migraine. Headache. 1992;32(2):101-4. [pmid: 1551787].
Agnoli A, Bussone G, Mailland F, Manzoni GC, Martucci N, Nappi G. Dihydroergokryptine vs. flunarizine in the basic treatment of migraine without aura. Cephalalgia. 1991;11(Suppl 11):216-7.
Agnoli A, Bussone G, Manzoni GC, Martucci N, Nappi G. Dihydroergokryptine (DEK) versus flunarizine (FLU) in common migraine: a multicentre double-blind study. Cephalalgia. 1989;9(Suppl 10):373-4.
Ahuja GK, Verma AK. Propranolol in prophylaxis of migraine. Indian J Med Res. 1985;82:263-5. [pmid: 3908306].
al Deeb SM, Biary N, Bahou Y, al Jaberi M, Khoja W. Flunarizine in migraine: a double-blind placebo-controlled study (in a Saudi population). Headache. 1992;32(9):461-2. [pmid: 1446992].
Albers GW, Simon LT, Hamik A, Peroutka SJ. Nifedipine versus propranolol for the initial prophylaxis of migraine. Headache. 1989;29(4):215-8. [pmid: 2654067].
Al-Qassab HK, Findley LJ. Comparison of propranolol LA 80 mg and propranolol LA 160 mg in migraine prophylaxis: a placebo-controlled study. Cephalalgia. 1993;13(2):128-31. [pmid: 8495455].
Andersson PG. BC-105 and deseril in migraine prophylaxis: a double-blind study. Headache. 1973;13(2):68-73.
Andersson PG, Dahl S, Hansen JH, Hansen PE, Hedman C, Kristensen TN, de Fine Olivarius B. Prophylactic treatment of classical and non-classical migraine with metoprolol: a comparison with placebo. Cephalalgia. 1983;3(4):207-12. [pmid: 6640652].
Andersson PG, Petersen EN. Propranolol and femoxetine, a 5HT-uptake inhibitor, in migraine prophylaxis: a double-blind crossover study. Acta Neurol Scand. 1981;64(4):280-8. [pmid: 7032183].
Ansell E, Fazzone T, Festenstein R, Johnson ES, Thavapalan M, Wilkinson M, Wozniak I. Nimodipine in migraine prophylaxis. Cephalalgia. 1988;8(4):269-72. [pmid: 3064919].
Anthony M, Lance JW. Indomethacin in migraine. Med J Aust. 1968;1(2):56-7. [pmid: 4867513].
Anthony M, Lance JW, Somerville B. A comparative trial of prindolol, clonidine, and carbamazepine in the interval therapy of migraine. Med J Aust. 1972;1(26):1343-6. [pmid: 4404482].
Anthony M, Lord GD, Lance JW. Controlled trials of cimetidine in migraine and cluster headache. Headache. 1978;18(5):261-4. [pmid: 363648].
Arthur GP, Homabrook RW. The treatment of migraine with BC 105 (pizotifen): a double-blind trial. N Z Med J. 1971;73(464):5-9. [pmid: 4925988].
Autret A, De Chasteigner C. DHE methane sulfonate with programmed liberation: preliminary results of a controlled study in common migraine. Cephalalgia. 1987;7(Suppl 6):451-2.
Baldrati A, Cortelli P, Procaccianti G, Gamberini G, D’Alessandro R, Baruzzi A, Sacquegna T. Propranolol and acetylsalicylic acid in migraine prophylaxis: double-blind crossover study. Acta Neurol Scand. 1983;67(3):181-6. [pmid: 6868956].
Bánk J. A comparative study of amitriptyline and fluvoxamine in migraine prophylaxis. Headache. 1994;34(8):476-8. [pmid: 7960733].
Barrie MA, Fox WR, Weatherall M, Wilkinson MI. Analysis of symptoms of patients with headaches and their response to treatment with ergot derivatives. Q J Med. 1968;37(146):319-36. [pmid: 4873708].
Bassi P, Brunati L, Rapuzzi B, Alberti E, Mangoni A. Low-dose flunarizine in the prophylaxis of migraine. Headache. 1992;32(8):390-2. [pmid: 1399560].
Baxter RC, Marsden CD, Parkes JD, Zilkha KJ. Amantadine in migraine. Lancet. 1972;2(774):429. [pmid: 4115247].
Behan PO. Prophylactic treatment for migraine: a comparison of pizotifen and clonidine. Cephalalgia. 1985;5(Suppl 3):524-5.
Behan PO, Reid M. Propranolol in the treatment of migraine. Practitioner. 1980;224(1340):201-3. [pmid: 6988825].
Bellavance AJ, Meloche JP. A comparative study of naproxen sodium, pizotyline, and placebo in migraine prophylaxis. Headache. 1990;30(11):710-5. [pmid: 2074163].
Boisen E, Deth S, Hübbe P, Jansen J, Klee A, Leunbach G. Clonidine in the prophylaxis of migraine. Acta Neurol Scand. 1978;58(5):288-95. [pmid: 367043].
Bono G, Criscuoli M, Martignoni E, Salmon S, Nappi G. Serotonin precursors in migraine prophylaxis. Adv Neurol. 1982;33:357-63. [pmid: 7034490].
Bonuso S, Di Stasio E, Barone P, Steardo L. Timed-release dihydroergotamine in the prophylaxis of mixed headache: a study versus amitriptyline. Cephalalgia. 1983;3(Suppl 1):175-8. [pmid: 6352047].
Børgesen SE. Treatment of migraine with propranolol. Postgrad Med J. 1976;52(Suppl 4[0]):163-5.
Børgesen SE, Nielsen JL, Møller CE. Prophylactic treatment of migraine with propranolol: a clinical trial. Acta Neurol Scand. 1974;50(5):651-6. [pmid: 4611129].
Bousser MG, Chick J, Fuseau E, Soisson T, Thevenet R. Combined low-dose acetylsalicylic acid and dihydroergotamine in migraine prophylaxis: a double-blind, placebo-controlled crossover study. Cephalalgia. 1988;8(3):187-92. [pmid: 3197098].
Bradley WG, Hudgson P, Foster JB, Newell DJ. Double-blind controlled trial of a micronized preparation of flumedroxone (Demigran) in prophylaxis of migraine. Br Med J. 1968;3(617):531-3. [pmid: 4877801].
Bredfeldt RC, Sutherland JE, Kruse JE. Efficacy of transdermal clonidine for headache prophylaxis and reduction of narcotic use in migraine patients: a randomized crossover trial. J Fam Pract. 1989;29(2):153-6. discussion 157–8. [pmid: 2666565].
Briggs RS, Millac PA. Timolol in migraine prophylaxis. Headache. 1979;19(7):379-81. [pmid: 511540].
Buring JE, Peto R, Hennekens CH. Low-dose aspirin for migraine prophylaxis. JAMA. 1990;264(13):1711-3. [pmid: 2204739].
Burns C. Migraine in a rural practice (1958–1963): a five-year study of a controlled clinical trial. J Coll Gen Pract. 1965;10(3):230-8. [pmid: 4378868].
Buscaino GA, Sorge F, Bussone G, Frediani F, et al. Preventive treatment of headache with slow-release dihydroergotamine: comparison of dosage protocols. Curr Ther Res. 1991;49(6):925-35.
Bussone G, Baldini S, D’Andrea G, Cananzi A, Frediani F, Caresia L, Ferro Milone F, Boiardi A. Nimodipine versus flunarizine in common migraine: a controlled pilot trial. Headache. 1987;27(2):76-9. [pmid: 3553069].
Cangi F, Boccuni M, Zanotti A, Mailland F, Sicuteri F. Dihydroergokryptine (DEK) in migraine prophylaxis in a double-blind study vs. methysergide. Cephalalgia. 1989;9(Suppl 10):448-9.
Canonico PL, Scapagnini U, Genazzani E, Zanotti A. Dihydroergokryptine (DEK) in the prophylaxis of common migraine: double-blind clinical study vs. placebo. Cephalalgia. 1989;9(Suppl 10):446-7.
Capildeo R, Rose FC. Single-dose pizotifen, 1.5 mg nocte: a new approach in the prophylaxis of migraine. Headache. 1982;22(6):272-5. [pmid: 7174305].
Carasso RL, Peled O, Yehuda S. Flufenamic acid in prostaglandin migraine. Diamond S, Maliszewski M, editors. Sexual aspects of headaches. Madison (CT). International Universities Press, Inc. 1992:141-7.
Carasso RL, Yehuda S. The prevention and treatment of migraine with an analgesic combination. Br J Clin Pract. 1984;38(1):25-7. [pmid: 6367797].
Carrieri P, Orefice G, Sorge F. Indobufen, a new antiaggregant drug, in the treatment of migraine: a double-blind study compared with placebo. Cephalalgia. 1985;5(Suppl 3):546-7.
Carrieri PB, Orefice G, Sorge F. A double-blind placebo-controlled trial of indobufen in the prophylaxis of migraine. Acta Neurol Scand. 1988;77(6):433-6. [pmid: 3043994].
Carroll JD, Maclay WP. Pizotifen (BC 105) in migraine prophylaxis. Curr Med Res Opin. 1975;3(2):68-71. [pmid: 1095308].
Carroll JD, Reidy M, Savundra PA, Cleave N, McAinsh J. Long-acting propranolol in the prophylaxis of migraine: a comparative study of two doses. Cephalalgia. 1990;10(2):101-5. [pmid: 2193712].
Cerbo R, Casacchia M, Formisano R, Feliciani M, Cusimano G, Buzzi MG, Agnoli A. Flunarizine-pizotifen single-dose double-blind cross-over trial in migraine prophylaxis. Cephalalgia. 1986;6(1):15-8. [pmid: 3516406].
Chappell AS, Bay JM, Botzum GD. Sergolexole maleate and placebo for migraine prophylaxis. Cephalalgia. 1991;11(Suppl 11):170-1.
Clarke CE, MacMillan L, Sondhi S, Wells NE. Economic and social impact of migraine. Q J Med. 1996;89(1):77-84.
Cochrane Controlled Trials Register [computer program]. The Cochrane Library, CD-ROM for Windows (IBM-PC) version. London. BMJ Publishing Group. 1997.
Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale (NJ). L. Erlbaum Associates. 1988.
Couch JR, Bearss CM, Verhulst S. Fenoprofen in migraine prophylaxis. Headache. 1987;27(5):289.
Couch JR, Hassanein RS. Migraine and depression: effect of amitriptyline prophylaxis. Trans Am Neurol Assoc. 1976;101:234-7. [pmid: 800690].
Couch JR, Hassanein RS. Amitriptyline in migraine prophylaxis. Arch Neurol. 1979;36(11):695-9. [pmid: 508127].
Dahlöf C. No clearcut longterm prophylactic effect of one month of treatment with propranolol in migraineurs. Cephalalgia. 1987;7(Suppl 6):459-60.
Das SM, Ahuja GK, Narainaswamy AS. Clonidine in prophylaxis of migraine. Acta Neurol Scand. 1979;60(4):214-7. [pmid: 393047].
De Benedittis G, Massei R. Serotonin precursors in chronic primary headache: a double-blind cross-over study with L-5-hydroxytryptophan vs. placebo. J Neurosurg Sci. 1985;29(3):239-48. [pmid: 3913752].
De Benedittis G, Massei R. 5-HT precursors in migraine prophylaxis: a double-blind cross-over study with L-5-hydroxytryptophan versus placebo. Clin J Pain. 1986;2:123-9.
Demarez JP, Darbeau D, Cauquil J. Dihydroergotamine prophylaxis of migraine. Cephalalgia. 1987;7(Suppl 6):448-51.
Dennerstein L, Laby B, Burrows GD, Hyman GJ. Headache and sex hormone therapy. Headache. 1978;18(3):146-53. [pmid: 352997].
Dennerstein L, Morse C, Burrows G, Oats J, Brown J, Smith M. Menstrual migraine: a double-blind trial of percutaneous estradiol. Gynecol Endocrinol. 1988;2(2):113-20. [pmid: 3055819].
Diamond S, Freitag FG. A double-blind trial of flunarizine in migraine prophylaxis. Headache Quarterly. 1993;4(2):169-72.
Diamond S, Freitag FG, Diamond ML. Flunarizine in migraine therapy. Clin Pharmacol Ther. 1990;47(2):165.
Diamond S, Medina JL. Controlled study of prophylaxis of migraine with propranolol. Clin Pharmacol Ther. 1975;17(2):232.
Diamond S, Medina JL. Double-blind study of propranolol for migraine prophylaxis. Headache. 1976;16(1):24-7. [pmid: 767299].
Diamond S, Solomon GD, Freitag FG, Mehta ND. Fenoprofen in the prophylaxis of migraine: a double-blind, placebo-controlled study. Headache. 1987;27(5):246-9. [pmid: 3298164].
Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ. 1994;309(6964):1286-91. [pmid: 7718048].
Diener HC, Scholz E, Dichgans J, Gerber WD, Jack A, Bille A, Niederberger U. Central effects of drugs used in migraine prophylaxis evaluated by visual evoked potentials. Ann Neurol. 1989;25(2):125-30. [pmid: 2645824].
Edmeads J, Findlay H, Tugwell P, Pryse-Phillips W, Nelson RF, Murray TJ. Impact of migraine and tension-type headache on life-style, consulting behaviour, and medication use: a Canadian population survey. Can J Neurol Sci. 1993;20(2):131-7. [pmid: 8334575].
Ekbom K. Alprenolol for migraine prophylaxis. Headache. 1975;15(2):129-32. [pmid: 1097368].
Ekbom K, Lundberg PO. Clinical trial of LB-46 (d, 1–4-(2-hydroxy-3-isopropyl-aminopropoxy)indol: an adrenergic beta-receptor blocking agent in migraine prophylaxis. Headache. 1972;12(1):15-7. [pmid: 4402287].
Ekbom K, Zetterman M. Oxprenolol in the treatment of migraine. Acta Neurol Scand. 1977;56(2):181-4. [pmid: 331835].
Elkind AH, Webster C, Herbertson RK. Efficacy of guanfacine in a double-blind parallel study for migraine prophylaxis. Cephalalgia. 1989a;9(Suppl 10):369-70.
Elkind AH, Webster C, Herbertson RK. Efficacy of guanfacine in a double-blind parallel study for migraine prophylaxis. Clin Pharmacol Ther. 1989b;45(2):162.
Facchinetti F, Sances G, Borella P, Genazzani AR, Nappi G. Magnesium prophylaxis of menstrual migraine: effects on intracellular magnesium. Headache. 1991;31(5):298-301. [pmid: 1860787].
Ferrari MD, Wilkinson M, Hirt D, Lataste X, Notter M. Efficacy of ICS 205–930, a novel 5-hydroxytryptamine_3_ (5-HT_3_) receptor antagonist, in the prevention of migraine attacks: a complex answer to a simple question. Pain. 1991;45(3):283-91. [pmid: 1876437].
Fioroni L, Sances G, Martignoni E, Facchinetti F, Nappi G, Genazzani AR. Perimenstrual headache prophylaxis with dihydroergokriptine. Cephalalgia. 1991;11(Suppl 11):199-200.
Fleiss JL. Statistical methods for rates and proportions. 2nd ed. New York. John Wiley & Sons, Inc. 1981.
Formisano R, Falaschi P, Cerbo R, Proietti A, Catarci T, D’Urso R, Roberti C, Aloise V, Chiarotti F, Agnoli A. Nimodipine in migraine: clinical efficacy and endocrinological effects. Eur J Clin Pharmacol. 1991;41(1):69-71. [pmid: 1782981].
Forssman B, Henriksson KG, Johannsson V, Lindvall L, Lundin H. Propranolol for migraine prophylaxis. Headache. 1976;16(5):238-45. [pmid: 977330].
Forssman B, Henriksson KG, Kihlstrand S. A comparison between BC 105 and methysergide in the prophylaxis of migraine. Acta Neurol Scand. 1972;48(2):204-12. [pmid: 4556413].
Forssman B, Lindblad CJ, Zbornikova V. Atenolol for migraine prophylaxis. Headache. 1983;23(4):188-90. [pmid: 6350226].
Frediani F, Grazzi L, Zanotti A, Mailland F, Zappacosta BM, Bussone G. Dihydroergokryptine versus dihydroergotamine in migraine prophylaxis: a double-blind clinical trial. Cephalalgia. 1991;11(3):117-21. [pmid: 1909603].
Freitag FG, Diamond S. Nadolol and placebo comparison study in the prophylactic treatment of migraine. J Am Osteopath Assoc. 1984;84(4):343-7. [pmid: 6150909].
Freitag FG, Diamond S, Diamond M. A placebo-controlled trial of flunarizine in migraine prophylaxis. Cephalalgia. 1991;11(Suppl 11):157-8.
Frenken CW, Nuijten ST. Flunarizine, a new preventive approach to migraine: a double-blind comparison with placebo. Clin Neurol Neurosurg. 1984;86(1):17-20. [pmid: 6325065].
Gawel M. A double-blind, cross-over study of nimodipine versus pizotyline in common and classical migraine. Cephalalgia. 1987;7(Suppl 6):453-4.
Gawel M, Kreeft J, Nelson R, Simard D. Flunarizine is comparable to propanolol in the prophylaxis of migraine with and without aura. Cephalalgia. 1991;11(Suppl 11):156.
Gawel MJ, Kreeft J, Nelson RF, Simard D, Amott WS. Comparison of the efficacy and safety of flunarizine to propranolol in the prophylaxis of migraine. Can J Neurol Sci. 1992;19(3):340-5. [pmid: 1393843].
Gelmers HJ. Nimodipine, a new calcium antagonist, in the prophylactic treatment of migraine. Headache. 1983;23(3):106-9. [pmid: 6347970].
Gennari C, Chierichetti MS, Gonnelli S, Vibelli C, Montagnani M, Piolini M. Migraine prophylaxis with salmon calcitonin: a cross-over double-blind, placebo-controlled study. Headache. 1986;26(1):13-6. [pmid: 3781818].
Gerber WD, Diener HC, Scholz E, Niederberger U. Responders and non-responders to metoprolol, propranolol, and nifedipine treatment in migraine prophylaxis: a dose-range study based on time-series analysis. Cephalalgia. 1991;11(1):37-45. [pmid: 2036669].
Gerber WD, Schellenberg R, Thom M, Haufe C, Bolsche F, Wedekind W, Niederberger U, Soyka D. Cyclandelate versus propranolol in the prophylaxis of migraine: a double-blind placebo-controlled study. Funct Neurol. 1995;10(1):27-35. [pmid: 7649498].
Gomersall JD, Stuart A. Amitriptyline in migraine prophylaxis. Changes in pattern of attacks during a controlled clinical trial. J Neurol Neurosurg Psychiatry. 1973;36(4):684-90. [pmid: 4731336].
Grotemeyer KH, Scharafinski HW, Schlake HP, Husstedt IW. Acetylsalicylic acid vs. metoprolol in migraine prophylaxis: a double-blind cross-over study. Headache. 1990;30(10):639-41. [pmid: 2272812].
Grotemeyer KH, Schlake HP, Husstedt IW. Etilefrine pivalate vs. dihydroergotamine and flunarizine in prophylactic treatment of migraine in patients with low blood pressure: a randomized double-blind study. Cephalalgia. 1989;9(Suppl 10):433-4.
Grotemeyer KH, Schlake HP, Husstedt IW, Rolf LH. Metoprolol versus flunarizine: a double blind cross-over study. Cephalalgia. 1987;7(Suppl 6):465-6.
Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Havanka-Kanniainen H, Hokkanen E, Myllylä V. Efficacy of nimodipine in comparison with pizotifen (Sandomigrin) in the prophylaxis of migraine. Cephalalgia. 1985a;5(Suppl 3):530-1.
Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Efficacy of nimodipine in the prophylaxis of migraine. Cephalalgia. 1985b;5(1):39-43. [pmid: 3886153].
Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Efficacy of nimodipine in comparison with pizotifen in the prophylaxis of migraine. Cephalalgia. 1987a;7(l):7-13. [pmid: 3555838].
Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Long-acting propranolol in migraine prophylaxis. Clin Pharmacol Ther. 1987b;41(2):203.
Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Long-acting propranolol in the prophylaxis of migraine: comparison of the daily doses of 80 mg and 160 mg. Headache. 1988;28(9):607-11. [pmid: 3248938].
Headache Classification Committee of the International Headache Society. Classification and diagnostic criteria for headache disorders, cranial neuralgias, and facial pain. Cephalalgia. 1988;8(Suppl 7):1-96.
Hedman C, Andersen AR. Effects of the B_1_-selective adrenoceptor antagonist metoprolol on the symptomatology of classic migraine attacks. Cephalalgia. 1987;7(Suppl 6):461-2.
Hedman C, Andersen AR, Andersson PG, Gilhus NE, Kangasniemi P, Olsson JE, Strandman E, Nestvold K, Olesen J. Symptoms of classic migraine attacks: modifications brought about by metoprolol. Cephalalgia. 1988;8(4):279-84. [pmid: 3064920].
Hering R, Kuritzky A. Sodium valproate in the prophylactic treatment of migraine: a double-blind study versus placebo. Cephalalgia. 1992;12(2):81-4. [pmid: 1576648].
Herrmann WM, Horowski R, Dannehl K, Kramer U, Lurati K. Clinical effectiveness of lisuride hydrogen maleate: a double-blind trial versus methysergide. Headache. 1977;17(2):54-60. [pmid: 324950].
Herrmann WM, Krištof M, Sastre M, Sastre M. Preventive treatment of migraine headache with a new isoergolenyl derivative. J Int Med Res. 1978;6(6):476-82. [pmid: 363486].
Hesse J, Møgelvang B, Simonsen H. Acupuncture versus metoprolol in migraine prophylaxis: a randomized trial of trigger point inactivation. J Intern Med. 1994;235(5):451-6. [pmid: 8182401].
Holroyd KA, France JL, Cordingley GE, Rokicki LA, Kvaal SA, Lipchik GL, McCool HR. Enhancing the effectiveness of relaxation-thermal biofeedback training with propranolol hydrochloride. J Consult Clin Psychol. 1995;63(2):327-30. [pmid: 7751496].
Hübbe P. The prophylactic treatment of migraine with an antiserotonin pizotifen. Acta Neurol Scand. 1973;49(1):108-14. [pmid: 4567747].
Hudgson P, Foster JB, Newell DJ. Controlled trial of demigran in the prophylaxis of migraine. Br Med J. 1967;2(544):91-3. [pmid: 6020856].
Hughes RC, Foster JB. BC 105 in the prophylaxis of migraine. Curr Ther Res Clin Exp. 1971;13(1):63-8. [pmid: 4992568].
International Headache Society Committee on Clinical Trials in Migraine. Guidelines for controlled trials of drugs in migraine. 1st ed. Cephalalgia. 1991;11:1-12.
Jacobs H. A trial of opipramol in the treatment of migraine. J Neurol Neurosurg Psychiatry. 1972;35(4):500-4. [pmid: 4559028].
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Jensen R, Brinck T, Olesen J. Sodium valproate has a prophylactic effect in migraine without aura: a triple-blind, placebo-controlled crossover study. Neurology. 1994;44(4):647-51. [pmid: 8164818].
Johannsson V, Nilsson LR, Widelius T, Javerfalk T, Hellman P, Akesson JA, Olerud B, Gustafsson CL, Raak A, Sandahl G, et al. Atenolol in migraine prophylaxis: a double-blind cross-over multicentre study. Headache. 1987;27(7):372-4. [pmid: 3308768].
Johnson ES, Kadam NP, Hylands DM, Hylands PJ. Efficacy of feverfew as prophylactic treatment of migraine. Br Med J (Clin Res Ed). 1985;291(6495):569-73.
Johnson RH, Hornabrook RW, Lambie DG. Comparison of mefenamic acid and propranolol with placebo in migraine prophylaxis. Acta Neurol Scand. 1986;73(5):490-2. [pmid: 3524092].
Jorgensen PB, Weightman D, Foster JB. Comparison of migraleve and buclizine in prophylaxis of migraine. Curr Ther Res Clin Exp. 1974;16(12):1276-80. [pmid: 4218156].
Kallanranta T, Hakkarainen H, Hokkanen E, Tuovinen T. Clonidine in migraine prophylaxis. Headache. 1977;17(4):169-72. [pmid: 893090].
Kallos P, Kallos-Deffner L. Clinical and experimental evaluation of a new ergot-derivative (ergostine) in the treatment of migraine. Headache. 1971;11(2):68-73. [pmid: 4938337].
Kangasniemi P. Placebo, l-isopropylnoradrenochrome-5-monosemicarbazono, and pizotifen in migraine prophylaxis. Headache. 1979;19(4):219-22. [pmid: 156165].
Kangasniemi P, Andersen AR, Andersson PG, Gilhus NE, Hedman C, Hultgren M, Vilming S, Olesen J. Classic migraine: effective prophylaxis with metoprolol. Cephalalgia. 1987;7(4):231-8. [pmid: 3322569].
Kangasniemi P, Falck B, Långvik VA, Hyyppa MT. Levotryptophan treatment in migraine. Headache. 1978;18(3):161-5. [pmid: 352998].
Kangasniemi P, Hedman C. Metoprolol and propranolol in the prophylactic treatment of classical and common migraine: a double-blind study. Cephalalgia. 1984;4(2):91-6. [pmid: 6428749].
Kangasniemi PJ, Nyrke T, Lang AH, Petersen E. Femoxetine--a new 5-HT uptake inhibitor--and propranolol in the prophylactic treatment of migraine. Acta Neurol Scand. 1983;68(4):262-7. [pmid: 6606930].
Kangasniemi P, Tokola R. Flunarizine in the prophylaxis of migraine patients without aura. Cephalalgia. 1989;9(Suppl 10):425.
Kåss B, Nestvold K. Propranolol (Inderal) and clonidine (Catapressan) in the prophylactic treatment of migraine: a comparative trial. Acta Neurol Scand. 1980;61(6):351-6. [pmid: 6998250].
Kjærsgåard Rasmussen MJ, Holt Larsen B, Borg L, Soelberg Sørensen P, Hansen PE. Tolfenamic acid versus propranolol in the prophylactic treatment of migraine. Acta Neurol Scand. 1994;89(6):446-50. [pmid: 7976233].
Klapper J. Divalproex sodium for migraine prophylaxis. Unpublished manuscript. 1996.
Klapper JA. An open label cross-over comparison of divalproex sodium and propranolol HCl in the prevention of migraine headaches. Headache Quarterly. 1994;5(1):50-3.
Krakowski AJ, Engisch R. A new agent for chemotherapy of migraine headaches: a controlled study. Psychosomatics. 1973;14(5):302-8. [pmid: 4604015].
Kuritzky A, Hering R. Prophylactic treatment of migraine with long acting propranolol: a comparison with placebo. Cephalalgia. 1987;7(Suppl 6):457-8.
Lamsudin R, Sadjimin T. Comparison of the efficacy between flunarizine and nifedipine in the prophylaxis of migraine. Headache. 1993;33(6):335-8. [pmid: 8349477].
Lance JW, Anthony M. Clinical trial of a new serotonin antagonist, BC105, in the prevention of migraine. Med J Aust. 1968;1(2):54-5. [pmid: 4867512].
Lance JW, Fine RD, Curran DA. An evaluation of methysergide in the prevention of migraine and other vascular headaches. Med J Aust. 1963;(June):814-8.
Langohr HD, Gerber WD, Koletzki E, Mayer K, Schroth G. Clomipramine and metoprolol in migraine prophylaxis: a double-blind crossover study. Headache. 1985;25(2):107-13. [pmid: 3886599].
Lawrence ER, Hossain M, Littlestone W. Sanomigran for migraine prophylaxis: controlled multicenter trial in general practice. Headache. 1977;17(3):109-12. [pmid: 330465].
Leandri M, Rigardo S, Schizzi R, Parodi CI. Migraine treatment with nicardipine. Cephalalgia. 1990;10(3):111-6. [pmid: 2245455].
Lindegaard KF, Övrelid L, Sjaastad O. Naproxen in the prevention of migraine attacks: a double-blind placebo-controlled cross-over study. Headache. 1980;20(2):96-8. [pmid: 6989789].
Loh L, Nathan PW, Schott GD, Zilkha KJ. Acupuncture versus medical treatment for migraine and muscle tension headaches. J Neurol Neurosurg Psychiatry. 1984;47(4):333-7. [pmid: 6726258].
Louis P. A double-blind placebo-controlled prophylactic study of flunarizine (Sibelium) in migraine. Headache. 1981;21(6):235-9. [pmid: 7031016].
Louis P, Schoenen J, Hedman C. Metoprolol v. clonidine in the prophylactic treatment of migraine. Cephalalgia. 1985a;5(3):159-65. [pmid: 3899370].
Louis P, Schoenen J, Hedman C. Metoprolol versus clonidine in the prophylactic treatment of migraine. Cephalalgia. 1985b;5(Suppl 3):520-1.
Louis P, Spierings EL. Comparison of flunarizine (Sibelium) and pizotifen (Sandomigran) in migraine treatment: a double-blind study. Cephalalgia. 1982;2(4):197-203. [pmid: 6760980].
Lücking CH, Oestreich W, Schmidt R, Soyka D. Flunarizine vs. propranolol in the prophylaxis of migraine: two double-blind comparative studies in more than 400 patients. Cephalalgia. 1988;8(Suppl 8):21-6. [pmid: 3180198].
Ludin HP. A comparative trial with flunarizine and propranolol in migraine. Cephalalgia. 1987;7(Suppl 6):469-70.
Ludin HP. Flunarizine and propranolol in the treatment of migraine. Headache. 1989;29(4):219-24. [pmid: 2654068].
Lundberg PO. Prophylactic treatment of migraine with flumedroxone. Acta Neurol Scand. 1969;45(3):309-26. [pmid: 5817457].
Malvea BP, Gwon N, Graham JR. Propranolol prophylaxis of migraine. Headache. 1973;12(4):163-7. [pmid: 4566216].
Markley HG, Cheronis JC, Piepho RW. Verapamil in prophylactic therapy of migraine. Neurology. 1984;34(7):973-6. [pmid: 6539877].
Martelletti P, Bussone G, Centonze V, Ferrari A, Frediani F, Giacovazzo M, Micieli G, Nappi G, Polito A, Sternieri E. Activity of cromolyn sodium in dietary migraine: a double-blind placebo-controlled multicenter trial. Cephalalgia. 1991;11(Suppl 11):148-9.
Martucci N, Manna V, Mattesi P, Troiani G, Manzoni GC, Lanfranchi M, Bono G, Micieli G. Ergot derivatives in the prophylaxis of migraine: a multicentric study with a timed-release dihydroergotamine formulation. Cephalalgia. 1983;3(Suppl l):151-5. [pmid: 6352046].
Masel BE, Chesson AL, Peters BH, Levin HS, Alperin JB. Platelet antagonists in migraine prophylaxis: a clinical trial using aspirin and dipyridamole. Headache. 1980;20(1):13-8. [pmid: 6985888].
Mastrosimone F, Iaccarino C, de Caterina G. Efficacy and tolerance of cyclandelate versus pizotifen in the prophylaxis of migraine. J Med. 1992;23(1):1-16. [pmid: 1573338].
Mathew NT. 5-Hydroxytryptophane in the prophylaxis of migraine: a double-blind study. Headache. 1978;18:111.
Mathew NT. Prophylaxis of migraine and mixed headache. A randomized controlled study. Headache. 1981;21(3):105-9. [pmid: 7021472].
Mathew NT, Saper JR, Silberstein SD, Rankin L, Markley HG, Solomon S, Rapoport AM, Silber CJ, Deaton RL. Migraine prophylaxis with divalproex. Arch Neurol. 1995;52(3):281-6. [pmid: 7872882].
Matts SG. Metoclopramide in the treatment of migraine. Practitioner. 1974;212(1272):887-90. [pmid: 4607730].
McArthur JC, Marek K, Pestronk A, McArthur J, Peroutka SJ. Nifedipine in the prophylaxis of classic migraine: a crossover, double-masked, placebo-controlled study of headache frequency and side effects. Neurology. 1989;39(2 Pt 1):284-6. [pmid: 2644581].
Mendenopoulos G, Manafi T, Logothetis I, Bostantjopoulou S. Flunarizine in the prevention of classical migraine: a placebo-controlled evaluation. Cephalalgia. 1985;5(1):31-7. [pmid: 3886152].
Mentenopoulos G, Manafi T, Logothetis J, Bostantzopoulou S. Flunarizine in the prevention of classical migraine: a placebo-controlled evaluation. Cephalalgia. 1985;5(Suppl 2):135-40. [pmid: 3893733].
Meyer JS, Hardenberg J. Clinical effectiveness of calcium entry blockers in prophylactic treatment of migraine and cluster headaches. Headache. 1983;23(6):266-77. [pmid: 6358126].
Micieli G, Cavallini A, Martignoni E, Covelli V, Facchinetti F, Nappi G. Effectiveness of salmon calcitonin nasal spray preparation in migraine treatment. Headache. 1988;28(3):196-200. [pmid: 3290159].
Micieli G, Trucco M, Agostinis C, Mancuso A, Papalia F, et al. Nimodipine vs. pizotifen in common migraine: results of a double-blind cross-over trial. Cephalalgia. 1985;5(Suppl 3):532-533.
Migraine-Nimodipine European Study Group (MINES). European multicenter trial of nimodipine in the prophylaxis of classic migraine (migraine with aura). Headache. 1989a;29(10):639-42.
Migraine-Nimodipine European Study Group (MINES). European multicenter trial of nimodipine in the prophylaxis of common migraine (migraine without aura). Headache. 1989b;29(10):633-8.
Mikkelsen BM, Falk JV. Prophylactic treatment of migraine with tolfenamic acid: a comparative double-blind crossover study between tolfenamic acid and placebo. Acta Neurol Scand. 1982;66(1):105-11. [pmid: 7051739].
Mikkelsen B, Pedersen KK, Christiansen LV. Prophylactic treatment of migraine with tolfenamic acid, propranolol, and placebo. Acta Neurol Scand. 1986;73(4):423-7. [pmid: 3727918].
Minervini MG, Pinto K. Captopril relieves pain and improves mood depression in depressed patients with classical migraine. Cephalalgia. 1987;7(Suppl 6):485-6.
Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Controlled Clin Trials. 1995;16(1):62-73. [pmid: 7743790].
Mondrup K, Møller CE. Prophylactic treatment of migraine with clonidine: a controlled clinical trial. Acta Neurol Scand. 1977;56(5):405-12. [pmid: 339659].
Mongini F, Bona G, Garnero M, Gioria A. Efficacy of meclofenamate sodium versus placebo in headache and craniofacial pain. Headache. 1993;33(1):22-8. [pmid: 8436494].
Monro J, Carini C, Brostoff J. Migraine is a food-allergic disease. Lancet. 1984;2(8405):719-21. [pmid: 6148473].
Monro P, Swade C, Coppen A. Double-blind comparative study of mianserin vs. placebo in the prophylaxis of migraine. Clin Neuropharmacol. 1984;7(Suppl 1):654-655.
Monro P, Swade C, Coppen A. Mianserin in the prophylaxis of migraine: a double-blind study. Acta Psychiatr Scand. 1985;72(Suppl 320):98-103.
Murphy JJ, Heptinstall S, Mitchell JR. Randomised double-blind placebo-controlled trial of feverfew in migraine prevention. Lancet. 1988;2(8604):189-92. [pmid: 2899663].
Nanda RN, Arthur GP, Johnson RH, Lambie DG. Cimetidine in the prophylaxis of migraine. Acta Neurol Scand. 1980;62(2):90-5. [pmid: 7010874].
Nanda RN, Johnson RH, Gray J, Keogh HJ, Melville ID. A double-blind trial of acebutolol for migraine prophylaxis. Headache. 1978;18(1):20-2. [pmid: 348644].
Nappi G, Sandrini G, Granella F, Ruiz L, Cerutti G, Facchinetti F, Blandini F, Manzoni GC. A new 5-HT_2_ antagonist (ritanserin) in the treatment of chronic headache with depression: a double-blind study vs. amitriptyline. Headache. 1990;30(7):439-44. [pmid: 2119355].
Nappi G, Sandrini G, Savoini G, Cavallini A, de Rysky C, Micieli G. Comparative efficacy of cyclandelate versus flunarizine in the prophylactic treatment of migraine. Drugs. 1987;33(Suppl 2):103-98. [pmid: 3304950].
Nattero G, Biale L, Savi L. Lisuride and pizotifen in the treatment of migraine without aura. Cephalalgia. 1991:218-9.
Neuman M, Demarez JP, Harmey JL, Le Bastard B, Cauquil J. Prevention of migraine attacks through the use of dihydroergotamine. Int J Clin Pharmacol Res. 1986;6(1):11-3. [pmid: 3514491].
Noone JF. Clomipramine in the prevention of migraine. J Int Med Res. 1980;8(Suppl 3):49-52. [pmid: 7009254].
Olerud B, Gustavsson CL, Furberg B. Nadolol and propranolol in migraine management. Headache. 1986;26(10):490-3. [pmid: 3546194].
Olsson JE, Behring HC, Forssman B, Hedman C, Hedman G, Johansson F, Kinnman J, Palhagen SE, Samuelsson M, Strandman E. Metoprolol and propranolol in migraine prophylaxis: a double-blind multicentre study. Acta Neurol Scand. 1984;70(3):160-8. [pmid: 6391066].
O’Neill BP, Mann JD. Aspirin prophylaxis in migraine. Lancet. 1978;2(8101):1179-81. [pmid: 82144].
Opavsky J. Magnesium and its combination with cinnarizine in the long-term treatment of headache. Acta Univ Palacki Olomuc Fac Med. 1991;131:157-64. [pmid: 1840336].
Orholm M, Honoré PF, Zeeberg I. A randomized general practice group-comparative study of femoxetine and placebo in the prophylaxis of migraine. Acta Neurol Scand. 1986;74(3):235-9. [pmid: 3538753].
Orholm M, Le Fevre P. Prophylactic treatment of migraine with femoxetine: a randomized comparison with placebo. Cephalalgia. 1985;5(Suppl 3):516-7.
Osterhaus JT, Gutterman DL, Plachetka JR. Healthcare resource and lost labour costs of migraine headache in the U.S. Pharmacoeconomics. 1992;2(1):67-76. [pmid: 10146980].
Osterman PO. A comparison between placebo, pizotifen, and l-isopropyl-3-hydroxy-5-semicarbazono-6-oxo-2.3.5.6-tetrahydroindol (Divascan) in migraine prophylaxis. Acta Neurol Scand. 1977;56(1):17-28. [pmid: 327746].
Palferman TG, Gibberd FB, Simmonds JP. Prophylactic propranolol in the treatment of headache. Br J Clin Pract. 1983;37(1):28-9. [pmid: 6340710].
Pedersen E, Møller CE. Methysergide in migraine prophylaxis. Clin Pharmacol Ther. 1966;7(4):520-6. [pmid: 5328472].
Penzien D, Johnson C, Carpenter D, Holroyd K. Drug vs. behavioral treatment of migraine: long-acting propranolol vs. home-based self-management training. Headache. 1990;30(5):300.
Penzien D, Johnson C, Seville J, Rubman S, Boggess JT, Rains JC. Interrelationships among daily and global self-report measures of headache. Headache Quarterly. 1994;5:8-14.
Pini LA, Ferrari A, Guidetti G, Galetti G, Sternieri E. Influence of flunarizine on the altered electronystagmographic (ENG) recordings in migraine. Cephalalgia. 1985;5(Suppl 2):173-5. [pmid: 4016930].
Pita E, Higueras A, Bolaños J, Perez N, Mundo A. Propranolol and migraine: a clinical trial. Arch Farmacol Toxicol. 1977;3(3):273-8. [pmid: 350168].
Pradalier A, Serratrice G, Collard M, Hirsch E, Feve J, Masson M, Masson C, Dry J, Koulikovsky G, Nguyen G, et al. Double-blind placebo-controlled study of the use of long-acting propranolol in migraine prophylaxis. Cephalalgia. 1989a;9(Suppl 10):367-8.
Pradalier A, Serratrice G, Collard M, Hirsch E, Feve J, Masson M, Masson C, Dry J, Koulikovsky G, Nguyen G, et al. Long-acting propranolol in migraine prophylaxis: results of a double-blind, placebo-controlled study. Cephalalgia. 1989b;9(4):247-53. [pmid: 2692838].
Presthus J. BC 105 and methysergide (Deseril) in migraine prophylaxis. Acta Neurol Scand. 1971;47(4):514-8. [pmid: 4941732].
Rascol A, Montastruc JL, Rascol O. Flunarizine versus pizotifen: a double-blind study in the prophylaxis of migraine. Cephalalgia. 1985;5(Suppl 3):542.
Rascol A, Montastruc JL, Rascol O. Flunarizine versus pizotifen: a double-blind study in the prophylaxis of migraine. Headache. 1986;26(2):83-5. [pmid: 3514549].
Rasmussen BK, Jensen R, Olesen J. Impact of headache on sickness absence and utilisation of medical services: a Danish population study. J Epidemiol Community Health. 1992;46(4):443-6. [pmid: 1431724].
Rompel H, Bauermeister PW. Aetiology of migraine and prevention with carbamazepine (Tegretol): results of a double-blind, cross-over study. S Afr Med J. 1970;44(4):75-80. [pmid: 4905910].
Ryan RE. Double-blind crossover comparison of BC-105, methysergide, and placebo in the prophylaxis of migraine headache. Headache. 1968;8(3):118-26. [pmid: 4892617].
Ryan RE. BC-105, a new preparation for the interval treatment of migraine: a double blind evaluation compared with a placebo. Headache. 1971;11(1):6-18. [pmid: 5554982].
Ryan RE. A controlled study of the effect of oral contraceptives on migraine. Headache. 1978;17(6):250-2. [pmid: 621146].
Ryan RE Sr. Comparative study of nadolol and propranolol in prophylactic treatment of migraine. Am Heart J. 1984;108(4 Pt 2):1156-9. [pmid: 6148878].
Ryan RE Sr, Diamond S, Ryan RE Jr. Double-blind study of clonidine and placebo for the prophylactic treatment of migraine. Headache. 1975;15(3):202-10. [pmid: 1100565].
Ryan RE Sr, Ryan RE Jr. Clonidine--its use in migraine therapy. Headache. 1975;14(4):190-2. [pmid: 1091602].
Ryan RE Sr, Ryan RE Jr. The effects of clonidine in the prophylactic treatment of migraine. Headache. 1975;14(4):199-212. [pmid: 1123303].
Ryan RE Sr, Ryan RE Jr. Migraine prophylaxis: a new approach. Laryngoscope. 1981;91(9 Pt 1):1501-6. [pmid: 7346693].
Ryan RE Sr, Ryan RE Jr, Sudilovsky A. Nadolol and placebo comparison study in the prophylactic treatment of migraine. Panminerva Med. 1982;24(2):89-94. [pmid: 6128710].
Ryan RE Sr, Ryan RE Jr, Sudilovsky A. Nadolol: its use in the prophylactic treatment of migraine. Headache. 1983;23(1):26-31. [pmid: 6131052].
Sances G, Martignoni E, Fioroni L, Blandini F, Facchinetti F, Nappi G. Naproxen sodium in menstrual migraine prophylaxis: a double-blind placebo controlled study. Headache. 1990;30(11):705-9. [pmid: 2074162].
Sances G, Martignoni E, Rosettino G, Fioroni L, Montorsi S, Runge I, Nappi G. Lisuride in menstrual migraine prophylaxis. Cephalalgia. 1989;9(Suppl 10):444-5.
Sandrini G, Savoini G, Cavallini A, Pacchetti C, Micieli G, Nappi G. Efficacy of cyclandelate in migraine prophylaxis. Cephalalgia. 1987;7(Suppl 6):481-2.
Saper JR, Silberstein SD, Lake AE 3rd, Winters ME. Double-blind trial of fluoxetine: chronic daily headache and migraine. Headache. 1994;34(9):497-502. [pmid: 8002320].
Sargent J, Solbach P, Damasio H, Baumel B, Corbett J, Eisner L, Jessen B, Kudrow L, Mathew N, Medina J. A comparison of naproxen sodium to propranolol hydrochloride and a placebo control for the prophylaxis of migraine headache. Headache. 1985;25(6):320-4. [pmid: 3902723].
Scopa J, Jorgensen PB, Foster JB. Migraleve in the prophylaxis of migraine. Curr Ther Res Clin Exp. 1974;16(12):1270-5. [pmid: 4218155].
Shafar J, Tallett ER, Knowlson PA. Evaluation of clonidine in prophylaxis of migraine. Double-blind trial and follow-up. Lancet. 1972;1(747):403-7. [pmid: 4110641].
Shekelle RB, Ostfeld AM. Methysergide in the migraine syndrome. Clin Pharmacol Ther. 1964;5:201-4. [pmid: 14155162].
Shimell CJ, Fritz VD, Levien SL. A comparative trial of flunarizine and propranolol in the prevention of migraine. S Afr Med J. 1990;77(2):75-7. [pmid: 2404346].
Shukla R, Garg RK, Nag D, Ahuja RC. Nifedipine in migraine and tension headache: a randomised double-blind crossover study. J Assoc Physicians India. 1995;43(11):770-2. [pmid: 8773038].
Sicuteri F. Prophylactic and therapeutic properties of 1-methyl-lysergic acid butanolamide in migraine. Int Arch Allergy Appl Immunol. 1959;15:300-7. [pmid: 14446408].
Sicuteri F. The ingestion of serotonin precursors (L-5-hydroxytryptophan and L-tryptophan) improves migraine headache. Headache. 1973;13(1):19-22. [pmid: 4540474].
Sjaastad O, Stensrud P. Appraisal of BC-105 in migraine prophylaxis. Acta Neurol Scand. 1969;45(5):594-600. [pmid: 4904294].
Sjaastad O, Stensrud P. 2-(2.6-dichlorophenylamino)-2-imidazoline hydrochloride (ST 155 or Catapresan) as a prophylactic remedy against migraine. Acta Neurol Scand. 1971;47(1):120-2. [pmid: 4930531].
Sjaastad O, Stensrud P. Clinical trial of a beta-receptor blocking agent (LB 46) in migraine prophylaxis. Acta Neurol Scand. 1972;48(1):124-8. [pmid: 4401692].
Smits MG, van der Meer YG, Pfeil JP, Rijnierse JJ, Vos AJ. Perimenstrual migraine: effect of Estraderm TTS and the value of contingent negative variation and exteroceptive temporalis muscle suppression test. Headache. 1994;34(2):103-6. [pmid: 8163364].
Solomon GD. Verapamil and propranolol in migraine prohylaxis: a double-blind crossover study. Headache. 1986;26:325.
Solomon GD, Freitag FG, Mehta N, Diamond S. Fenoprofen calcium in migraine prophylaxis: a double-blind, placebo-controlled study. Cephalalgia. 1987;7(Suppl 6):473-4.
Solomon GD, Kunkel RS. Flurbiprofen in the prophylaxis of migraine. Cephalalgia. 1991;11(Suppl 11):161. [pmid: 1889074].
Solomon GD, Kunkel RS. Flurbiprofen in the prophylaxis of migraine. Cleve Clin J Med. 1993;60(1):43-8. [pmid: 8443934].
Solomon GD, Steel JG, Spaccavento U. Verapamil prophylaxis of migraine: a double-blind, placebo-controlled study. JAMA. 1983;250(18):2500-2. [pmid: 6355533].
Somerville BW, Hermann WW. Migraine prophylaxis with lisuride: a double-blind study of lisuride versus placebo. Headache. 1976;16:85-6.
Somerville BW, Herrmann WM. Migraine prophylaxis with lisuride hydrogen maleate: a double-blind study of lisuride versus placebo. Headache. 1978;18(2):75-9. [pmid: 348647].
Sørensen PS. Prophylactic effects of flunarizine versus metoprolol in migraine. Cephalalgia. 1989;9(Suppl 10):355-6.
Sørensen PS, Hansen K, Olesen J. Flunarizine in common migraine prophylaxis: a double-blind cross-over study. Cephalalgia. 1985;5(3):540-1.
Sørensen PS, Hansen K, Olesen J. A placebo-controlled, double-blind, cross-over trial of flunarizine in common migraine. Cephalalgia. 1986;6(1):7-14.
Sørensen PS, Larsen BH, Rasmussen MJ, Kinge E, Iversen H, Alslev T, Nohr P, Pedersen KK, Schroder P, Lademann A, et al. Flunarizine versus metoprolol in migraine prophylaxis: a double-blind, randomized parallel group study of efficacy and tolerability. Headache. 1991;31(10):650-7. [pmid: 1769820].
Sovak M, Kunzel M, Sternbach RA, Dalessio DJ. Mechanism of the biofeedback therapy of migraine: volitional manipulation of the psychophysiological background. Headache. 1981;21(3):89-92. [pmid: 7263222].
Soyka D, Oestreich W. Therapeutic effectiveness of flunarizine and propranolol in the interval therapy of migraine. Cephalalgia. 1987;7(Suppl 6):467-8.
Standnes B. The prophylactic effect of timolol versus propranolol and placebo in common migraine: beta-blockers in migraine. Cephalalgia. 1982;2(3):165-70. [pmid: 6758949].
Steardo L, Bonuso S, Di Stasio E, Marano E. Selective and non-selective beta-blockers: are both effective in prophylaxis of migraine? A clinical trial versus methysergide. Acta Neurol (Napoli). 1982;4(3):196-204. [pmid: 7136885].
Steardo L, Marano E, Barone P, Denman DW, Monteleone P, Cardone G. Prophylaxis of migraine attacks with a calcium-channel blocker: flunarizine versus methysergide. J Clin Pharmacol. 1986;26(7):524-8. [pmid: 3531248].
Steiner TJ, Cook GE, Joseph R, Clifford Rose F. Double-blind dose-ranging comparison of metoprolol with placebo in the prophylaxis of classical and common migraine. Cephalalgia. 1985;5(Suppl 3):558-9.
Steiner TJ, Joseph R, Hedman C, Rose FC. Metoprolol in the prophylaxis of migraine: parallel-groups comparison with placebo and dose-ranging follow-up. Headache. 1988;28(1):15-23. [pmid: 3277926].
Stellar S, Ahrens SP, Meibohm AR, Reines SA. Migraine prevention with timolol: a double-blind crossover study. JAMA. 1984;252(18):2576-80. [pmid: 6387197].
Stensrud P, Sjaastad O. Clinical trial of a new anti-bradykinin, anti-inflammatory drug, ketoprofen (19.583 r.p.) in migraine prophylaxis. Headache. 1974;14(2):96-100. [pmid: 4604234].
Stensrud P, Sjaastad O. Clonidine (Catapresan)-double-blind study after long-term treatment with the drug in migraine. Acta Neurol Scand. 1976a;53(3):233-6. [pmid: 773082].
Stensrud P, Sjaastad O. Short-term clinical trial of propranolol in racemic form (Inderal), D-propranolol, and placebo in migraine. Acta Neurol Scand. 1976b;53(3):229-32. [pmid: 773081].
Stensrud P, Sjaastad O. Clonazepam (rivotril) in migraine prophylaxis. Headache. 1979;19(6):333-4. [pmid: 511533].
Stensrud P, Sjaastad O. Comparative trial of Tenormin (atenolol) and Inderal (propranolol) in migraine. Headache. 1980a;20(4):204-7. [pmid: 6993420].
Stensrud P, Sjaastad O. Comparative trial of Tenormin (atenolol) and Inderal (propranolol) in migraine. Ups J Med Sci Suppl. 1980b;31:37-40. [pmid: 7006182].
Stensrud P, Skaug OE, Sjaastad O. Clinical trial of MY-25 (1-methyl-ergotamine-bitartrate) in migraine prophylaxis. Headache. 1971;11(3):128-31. [pmid: 4940168].
Sternieri E, Bussone G, Manzoni GC, Martucci N, Nappi G. Lornoxicam, a new non-steroidal anti-inflammatory drug, in migraine prophylaxis: a double-blind multicenter study. Cephalalgia. 1991;11(Suppl 11):154-5.
Stewart WF, Shechter A, Rasmussen BK. Migraine prevalence: a review of population-based studies. Neurology. 1994;44(6 Suppl 4):S17-23. [pmid: 8008222].
Stieg RL. Double-blind study of belladonna-ergotamine-phenobarbital for interval treatment of recurrent throbbing headache. Headache. 1977;17(3):120-4. [pmid: 330467].
Sudilovsky A, Elkind AH, Ryan RE Sr, Saper JR, Stem MA, Meyer JH. Comparative efficacy of nadolol and propranolol in the management of migraine. Headache. 1987;27(8):421-6. [pmid: 3312113].
Sudilovsky A, Stern M, Meyer JH. Comparative efficacy of nadolol and propranolol in the prophylaxis of migraine. Headache. 1986a;26(6):311-2.
Sudilovsky A, Stern MA, Meyer JH. Nadolol: the benefits of an adequate trial duration in the prophylaxis of migraine. Headache. 1986b;26:325.
Sulman FG, Pfeifer Y, Superstine E. Preventive treatment of serotonin-migraine with 1,3,4,14b-tetrahydro-2,7-dimethyl-2H-dibenzo(b,f)pyrazino-(l,2--d)-(,4)-oxazepine hydrogen maleate (Org GC 94): a double-blind study. Arzneimittelforschung. 1981;31(1):109-12. [pmid: 7011331].
Szekely B, Merryman S, Croft H, Post G. Prophylactic effects of naproxen sodium on perimenstrual headache: a double-blind, placebo-controlled study. Cephalalgia. 1989;9(Suppl 10):452-3.
Tfelt-Hansen P, Standnes B, Kangasniemi P, Hakkarainen H, Olesen J. Timolol vs. propranolol vs. placebo in common migraine prophylaxis: a double-blind multicenter trial. Acta Neurol Scand. 1984;69(1):1-8. [pmid: 6367336].
Thomas M, Behari M, Ahuja GK. Flunarizine in migraine prophylaxis: an Indian trial. Headache. 1991;31(9):613-5. [pmid: 1774179].
Titus F, Dávalos A, Alom J, Codina A. 5-Hydroxytryptophan versus methysergide in the prophylaxis of migraine: randomized clinical trial. Eur Neurol. 1986;25(5):327-9. [pmid: 3536521].
Titus F, Dávalos A, Codina A. 5-hydroxytryptophan versus methysergide in the prophylaxis of migraine: a randomized clinical trial. Cephalalgia. 1985;5(Suppl 3):518-9.
Vilming S, Standnes B, Hedman C. Metoprolol and pizotifen in the prophylactic treatment of classical and common migraine: a double-blind investigation. Cephalalgia. 1985;5(1):17-23. [pmid: 3986895].
Viswanathan KN, Rajendiran C, Manohar DS, Balaraman VT. Cinnarizine-propranalol in migraine prophylaxis: a double-blind clinical study. Cephalalgia. 1991;11(Suppl 11):166-7.
Weber RB, Reinmuth OM. The treatment of migraine with propranolol. Neurology. 1972;22(4):366-9. [pmid: 4552716].
Welch KM. Naproxen sodium in the treatment of migraine. Cephalalgia. 1986;6(Suppl 4):85-92. [pmid: 3539362].
Welch KM, Ellis DJ, Keenan PA. Successful migraine prophylaxis with naproxen sodium. Neurology. 1985;35(9):1304-10. [pmid: 4022376].
Wessely P, Baumgartner C, Klingler D, Kreczi J, Meyerson N, Sailer L, Saltuari L, Schutt P. Preliminary results of a double-blind study with the new migraine prophylactic drug Gabapentin. Cephalalgia. 1987;7(Suppl 6):477-8.
Widerøe TE, Vigander T. Propranolol in the treatment of migraine. Br Med J. 1974;2(921):699-701. [pmid: 4604977].
Wilkinson M. Preliminary report on the use of clonidine (Boehringer Ingelheim) in the treatment of migraine. Res Clin Stud Headache. 1970;3:315-20. [pmid: 4949837].
Wilkinson M, Agnoli A, Gerber WD, Grotemeyer KH, Langer H, Runge I. Multicentre migraine study. Cuvalitr (lisuride 0.025mg) vs. lisuride 0.05 mg tds. Cephalalgia. 1989;9(Suppl 10):353-4.
Wörz R, Reinhardt-Benmalek B, Foeh M, Grotemeyer KH, Scharafinski HW. Migraine prophylaxis with bisoprolol. Headache Quarterly. 1992;3(1):64-72.
Wörz R, Reinhardt-Benmalek B, Grotmeyer KH, Foh M. Bisoprolol and metoprolol in the prophylactic treatment of migraine with and without aura: a randomized double-blind cross-over multicenter study. Cephalalgia. 1991;11(Suppl 11):152-3.
Zeeberg I, Orholm M, Nielsen JD, Honoré PL, Larsen JJ. Femoxetine in the prophylaxis of migraine: a randomised comparison with placebo. Acta Neurol Scand. 1981;64(6):452-9. [pmid: 6753446].
Ziegler DK, Ellis DJ. Naproxen in prophylaxis of migraine. Arch Neurol. 1985;42(6):582-4. [pmid: 4004602].
Ziegler DK, Hurwitz A, Hassanein RS, Kodanaz HA, Preskorn SH, Mason J. Migraine prophylaxis: a comparison of propranolol and amitriptyline. Arch Neurol. 1987;44(5):486-9. [pmid: 3579659].
Ziegler DK, Hurwitz A, Preskorn S, Hassanein R, Seim J. Propranolol and amitriptyline in prophylaxis of migraine: pharmacokinetic and therapeutic effects. Arch Neurol. 1993;50(8):825-30. [pmid: 8352668].
Zuddas A. Usefulness of lisuride on menstrual migraine in a double-blind trial. Cephalalgia. 1985;5(Supp13):514-5.