# Evidence Tables

Evidence Table 1 Study Descriptions and Results^1,2^

Study | Design/Method | Patients/Recruitment | Interventions | Principal Outcomes Analyzed | Results | Dropouts/Notes
Adam, Gore, and Price, 1978 | CrOv QS: 3 (r, db, dd) | N = 96 Age: 38 (range: 11–67) 84% female Chron: N/S Migraine; ≥ 1 paroxysmal HA/mo for ≥ 3 mos, including visual or gastro-intestinal problems Rec: GP clinic in Edinburgh, Scotland | Placebo: n = 70* Clonidine (Dixarit®): 0.025 mg (1 tab), 3x/day; dose could be increased as soon as needed to a maximum of 0.050 mg, 3x/day; n = 70* No baseline period; two 6-mo treatment periods for 2 groups of pts (Grp 1 started with active drug, then switched to placebo after 6 mos; Grp 2 started with placebo, then switched to active drug after 6 mos); no washout; no follow-up Nothing on acute meds | HA frequency: No. of HAs per assessment period; analyzed in 3-mo periods HA intensity: Obtained from pt’s recordings of whether HAs required treatment or caused functional disability. Recorded on 4-point scale (always, usually, sometimes, never). HAs coded as less, equally, or more severe (−1,0, 1) than baseline HAs | Between-group results were reported as the difference in HA frequency (response on clonidine minus response on placebo, measured at the end of each 6 mos). Both treatments reduced HA frequency equally well, as median frequency difference was 0 in each of Groups 1 and 2. The median HA frequency for all 70 pts diminished from 9 HAs/3 mos at baseline to 3 HAs/3 mos at the end of both 6-mo periods. | Dropouts: 26 (27%),3 due to AEs (2 clonidine, 1 placebo) Efficacy results based on frequency and intensity, obtained and defined by physician during assessment periods at 1, 2, 3, & 6 mos for both 6-mo periods. These findings were compared with baseline ratings (for 3 mos prior to treatment) gathered by physician at initial visit
Adly, Straumanis, and Chesson, 1992 | SPPG QS: 3 (r, db, dd) | N = 32 Age: N/S % female N/S Migraine (physician diagnosis and Ad Hoc); ≥ 1 severe, disabling attack/wk Chron: N/S Rec: Newspaper ad | Placebo: n = 9 Fluoxetine: 20 mg every other day for first 4 wks; at that point, dose increased to 20 mg/day for those patients who showed minimal or no improvement during first 4 wks; these patients assessed again 14 days later, and dose increased to 40 mg/day for patients still not improving (all increases in dosage subject to tolerance); n = 9 2-wk baseline period; 8-wk treatment period; no follow-up Use of acute meds permitted | HA index: Calculated on basis of patient diary data on intensity (graded on scale of 1–10), duration, disability, accompanying symptoms, and amount of acute med taken; formula used not described; score calculated for each day, and daily scores then summed for each 2-wk period | HA index: During wks 7–8 of treatment, median HA index scores in the fluoxetine group were significantly lower than they had been at baseline (p<0.01); median scores in the placebo group did not decrease significantly compared to baseline (no p-value reported). There was no significant difference in median baseline HA index scores between the two groups, but post-treatment (wks 7–8) median scores were significantly lower in the fluoxetine group than in the placebo group (p<0.05). The median baseline HA index score in the fluoxetine group was 32; during wks 7–8, it was 6. The corresponding scores in the placebo group were 35 and 24, respectively (ranges not reported). | Dropouts: 14 (44%), 1 due to AEs (associated with fluoxetine) High dropout rate 2 patients in the fluoxetine group and 1 in the placebo group had discontinued migraine prophylactic med just 3 days before starting trial; rest drug- free
Agnoli, Bussone, Mailland, et al., 1991 | SPPG QS: 3 (r, db, dd) | N = 102 Age: N/S 71% female Migraine w/o aura; 4–12 HA days/mo for past 3 mos Chron: N/S Rec: N/S | Flunarizine: 5 mg, 1x/day; n = 41 Dihydroergokryptine (DEK): 10 mg, 2x/day; n = 42 1-mo baseline period (placebo); 6-mo treatment period; 51 % of patients followed up 3 mos after end of treatment Acute meds permitted | HA frequency: No. of HA days/mo Pain total index: Not defined | Baseline mean HA frequencies were comparable in the two groups (flunarizine, 6.4 ± 2.7; DEK, 6.4 ± 2.5). At 6 mos, HA frequency was significantly lower in the DEK group than in the flunarizine group (p=0.025) (post-treatment mean scores were reported only graphically and could not be reliably read off the graph). 3/42 patients in the DEK group (7%) and 4/41 in the flunarizine group (10%) experienced a 50% or more reduction in HA frequency vis-à-vis baseline. Mean HA frequency rose in both groups during the post-treatment follow-up period. Pain total index was significantly lower in the DEK group after 6 mos of treatment and at follow-up (p=0.05 for both timepoints). Mean scores could not be read off the graph on which they were reported. | Dropouts: 19 (19%),4 due to AEs (all DEK) Abstract reporting limited results
Ahuja and Verma, 1985 | CrOv QS: 3 (r, db+, dnd) | N = 26 Age: N/S (range: 17–55) 46% female Migraine (Ad Hoc); hist. ≥ 2 HAs/mo in 3 mos prior to trial (described as “frequent”) Chron: N/S (range: N/S) Rec: Neuro. clinic in India | Placebo: n = 26* Propranolol: 40 mg, 3x/day; n = 26* No baseline period described; two 8-wk treatment periods; no washout; no follow-up Nothing on acute migraine meds | HA index (intensity): Calculated as HA frequency multiplied by no. of HA intensity points (intensity rated on 3-point scale) HA frequency: Not defined, but reported as overall means per 8 wks HA index (duration): Calculated as HA frequency multiplied by duration score (duration rated on 5-point scale; score derived relative to pre-treatment duration) | Propranolol was significantly better than placebo at reducing HA index (intensity) (p < 0.05). Pre-treatment mean values were not provided. The post-treatment mean scores (and SDs) for HA index (intensity) were 20.69 (± 16.84) for propranolol and 38.00 (± 39.10) for placebo. Authors did not report whether they analyzed pre- to post-treatment results for statistical significance. Results were similar for HA index (duration). Results were similar for HA frequency, except that propranolol reduced this outcome significantly from pre- to post-treatment (p-value not reported). | Dropouts: N/S Not clear how baseline or treatment data gathered; not clear if data obtained from pt’s diaries or post hoc from interviews with physician
Albers, Simon, Hamik, et al., 1989 | SPPG QS: 3 (r+, ndb, dd) | N =40 Age: 35 89% female Common or classic migraine (Ad Hoc); ≥ 3 HAs/mo for last 3 mos; no previous migraine prophylactic treatment Chron: N/S Rec: N/S | Propranolol: 40–60 mg, 3x/day (dosage adjusted according to patient’s tolerance); n = 12 Nifedipine: 20–30 mg, 3x/day (dosage adjusted according to patient’s tolerance); n=7 No baseline period; 6-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of HAs/mo | Mean HA frequency (± SD) in the propranolol group was 6.1 (± 0.7) at the start of treatment and 2.2 (± 0.9) for months 4–6. In the nifedipine group, the corresponding figures were 3.6 (± 0.3) and 1.5 (± 0.7), respectively. The investigators did not report whether the difference between the two treatments was statistically significant. | Dropouts: 20 (50%),18 due to AEs (5 propranolol, 13 nifedipine); in addition, 1 pro- pranolol patient who completed the trial did not report adequate data to be included in the efficacy analysis Not double-blind High dropout rate Baseline frequency values established by history
Al Deeb, Biary, Bahou, et al., 1992 | SPPG QS: 2 (nr, db, dd) | N =50 Age: 34 76% female Migraine w/or w/o aura (IHS) Chron: 12 yrs Rec: Hospital outpatients | Placebo: n = 21 Flunarizine: 10 mg, 1x/day; n = 21 6-mo baseline period; 3-mo treatment period; no follow-up Patients permitted to continue with their usual acute meds | HA frequency: Mean number of attacks/3 mos HA severity: Mean severity/3 mos; severity of each attack graded on 4-pt scale (not described) HA duration: Mean duration/3 mos | There was no significant difference between the two groups for reduction in HA frequency from pre- to post-treatment (p=0.08). In the flunarizine group, the mean HA frequency (± SD) was reduced from 13.75 (± 7.7) pre-treatment to 9.9 (± 5.3) post-treatment. In the placebo group, the corresponding figures were 9.83 (± 5.0) and 7.86 (± 5.9), respectively. There was also no significant difference between the two treatments for HA severity (no p-value reported). Six of 21 patients (29%) in the flunarizine group and 5/21 (24%) In the placebo group reported a reduction in mean HA severity of ≥ 50% from pre- to post-treatment. Most patients (12/21 flunarizine, 11/21 placebo) experienced no reduction in mean HA duration. However, 7 patients in each group showed dramatic reductions (85%–100%) in duration from pre- to post- treatment. | Dropouts: 8 (16%),4 due to AEs Not randomized 7/21 patients in the flunarizine group had migraine with aura, compared with 1/21 in the placebo group
Al-Qassab and Findley, 1993 | CrOv QS: 4 (r, db+, dd) | N = 45 Age: 36 (median) (range: 18–65) 80% female Common or classical migraine: ≥ 3 HAs/mo; described as “severe” Excl: pts with contraindications for beta- blockers Chron: 9 (median) (range: 1–49) Rec: General neuro. clinic | Placebo: n = 30* Propranolol (long-acting): 80 mg, 1x/day; n = 30* Propranolol (long-acting): 160 mg, 1x/day; n = 30* 4-wk run-in (placebo); two 2-mo treatment periods; 1-wk washout between treatment periods; no follow-up Patients’ usual meds for acute migraine attacks permitted, except psychotropics or drugs known to interact with beta-blockers | HA frequency: Not defined, but recorded daily by pts HA intensity: Rated on 4-point scale and recorded daily by pts | No baseline scores were provided. Post-treatment median scores for HA frequency were 3.8, 3.8, and 3.2 for propranolol LA 160 mg/day, propranolol LA 80 mg/day, and placebo, respectively. There were no significant differences in HA frequency results between either of the active doses and placebo or between the two active doses. For propranolol LA 160 mg vs. placebo, the p-value was p > 0.96; for propranolol 80 mg vs. placebo, it was p > 0.63; and for propranolol LA 160 mg vs. propranolol LA 80 mg, it was p > 0.75. Results for HA intensity were similar. | Dropouts: 15 (33%), 1 due to AEs (treatment group N/S) Not clear if baseline data gathered
Andersson, 1973 | CrOv QS: 4 (r, db+, dd) | N = 73 Age: 38 84% female Classic or common migraine (Ad Hoc) Chron: N/S Rec: N/S | Methysergide: 1 mg, 4x/day; n = 48* Pizotifen: 0.5 mg, 4x/day; n = 47* No baseline period described; two 3-mo treatment periods; no washout; data used from 3rd month of treatment only, presumably to minimize carry-over effects; no follow-up No acute meds permitted, except in exceptionally severe cases, when ergot preparations or morphine administered | HA index: Frequency times severity; severity of each attack graded on scale of 1–3 (slight, moderate, severe) HA frequency: No. of attacks per month; number of patients reporting > 50% reduction in HA frequency | Mean HA index scores were 16.6 pre-treatment, 9.5 with methysergide, and 7.5 with pizotifen (no variance data reported). There was no significant difference between the two treatments for this outcome (p<0.05). Mean HA frequency (± SD) was reduced from 5.9 (± 2) pre-treatment (n = 49) to 4.1 (± 4) with methysergide (n = 48) and 3.5 (± 3) with pizotifen (n = 47). The investigator found no significant difference between the two treatments for this outcome (0.40<p<0.50). 15/48 patients (31%) reported a > 50% reduction in HA frequency with methysergide, as did 18/47 patients (38%) with pizotifen. | Dropouts: 24 (33%), 13 due to AEs (9 pizotifen, 4 methysergide) Not clear how baseline values established
Andersson, Dahl, Hansen, et al., 1983 | SPPG QS: 3 (r, db, dd) | N = 71 Age: 40 (range: 17–57) 85% female Classical or nonclassical migraine; hist. ≥ 2 yrs; :≥ 3 HAs/mo in mo prior to trial Excl: Other vascular HAs; chronic, daily HAs nonseparable from migraine; contraindication for beta-blockers Chron: 18.4 (range: N/S) Rec: 3 neuro. clinics in Denmark | Placebo: n = 35 Metoprolol (Durules®): 200 mg (in controlled release formulation), 1x/day; n = 30 4-wk baseline period; one 8-wk treatment period; no follow-up Acute migraine meds permitted (ergotamine and analgesics) | HA index: Calculated as sum of intensity score (no. of migraine days multiplied by HA intensity rating) HA frequency: Defined as “number of migraine days” and recorded daily by pt HA intensity: Recorded daily by pt on 3-point scale | Metoprolol was significantly better than placebo at reducing HA index mean values (p ≤ 0.05). In the metoprolol group, HA index was reduced from 17.63 (S.D. = 8.51) at baseline to 11.95 (S.D. = 7.69) after treatment. The reduction was statistically significant (p ≤ 0.001). In the placebo group, HA index increased from 16.33 (S.D. = 7.48) at baseline to 16.51 (S.D. = 7.97) after treatment. The pre- to post-treatment difference was not significant (p > 0.05). Similar results were reported for HA frequency. Ten of 30 (33%) and 4/35 (11 %) of patients treated with metoprolol and placebo, respectively, improved (achieved ≥ 50% reduction in HA index from pre- to post-treatment). The difference between the two results was statistically significant (p ≤ 0.001). | Dropouts: 6 pts (8%), 2 from AEs (metoprolol 1, placebo 1); 3 additional pts dropped out but were not included in the efficacy analyses for which we reported results
Andersson and Petersen, 1981 | CrOv QS: 3 (r, db, dd) | N = 49 Age: 38 (range: 22–68) 69% female Classical or common migraine; ≥ 3 attacks/mo in last 2 mos Chron: 18 yrs (range: 2–40) Rec: N/S | Propranolol: 80 mg, 2x/day; dose reduced by half during first week; n = 37* (completed trial); n = 28* (completed trial and recorded HA data during baseline period) Femoxetine: 200 mg, 2x/day; dose reduced by half during first week; n = 37* (completed trial); n = 28* (completed trial and recorded HA data during baseline period) 1-mo baseline period; two 3-mo treatment periods; no washout, but first month of each treatment period dropped from analysis to minimize carry-over effects No information on acute meds | HA index: Mean number of HA days/30 days multiplied by severity HA frequency: Mean number of attacks/30 days (attacks must be separated by a HA-free day) HA severity: Mean severity/30 days, where each HA scored on scale of 1–3 | We analyzed results from the 28 patients who recorded HA data during the baseline period. Both drugs reduced HA index significantly compared to pre-treatment values (p<0.001 for both comparisons). There was no significant difference between the two interventions (no p-value reported). The mean HA index (± SEM) pre-treatment was 24.5 (± 1.8); after treatment with propranolol, it was 16.0 (± 2.2); after treatment with femoxetine, it was 17.9 (± 1.9). The authors also reported the number of patients with a > 50% reduction in HA index compared with pre-treatment values for each intervention. 10/28 patients (36%) achieved this level of improvement with propranolol, as did 6 of the same 28 patients (21%) with femoxetine. The difference between the two treatments was not significant (no p-value reported). Very similar continuous and categorical results were reported for HA frequency and HA severity. No order effect was detected. | Dropouts: 12 (24%), 4 due to AEs (2 with each treatment)
Ansell, Fazzone, Festenstein, et al., 1988 | SPPG QS: 3 (r, db, dd) | N = 68 Age: N/S (range: 18–60) 74% female Common or classical migraine (World Fed of Neurology); patients with non-migrainous HAs excluded; patients with < 2 HAs/mo during baseline period excluded Chron: N/S Rec: Migraine clinic | Placebo: n= 27 Nimodipine: 40 mg, 3x/day; n = 30 2-mo baseline period (placebo); 4-mo treatment period; no follow-up Acute meds permitted | Patients made clinic visits at approx 4-wk intervals; following outcomes calculated for each visit period; HA index: For each HA, peak HA severity times HA duration was added to peak nausea/vomiting severity times nausea/vomiting duration; these individual HA scores were summed for all attacks during the visit period, and the resulting number was divided by the no. of days in the visit period HA duration was measured in terms of no. of migraine days per attack; severity of HA and of nausea/vomiting were measured on scale of 0–3 (none, mild, severe, incapacitating) HA frequency: No. of attacks per visit period | Significant improvement in median HA index scores was reported in both treatment groups, but there was no statistically significant difference between the nimodipine and placebo groups (no p-values reported; median values for each month reported graphically and could not be reliably read off graph). There was no significant difference between the two groups for median HA frequency at baseline. Neither group improved significantly during treatment, and the changes in the two groups were not significantly different from each other at any timepoint (no data or p-values reported). | Dropouts: 11 (16%), none due to AEs
Anthony and Lance, 1968 | SPPG QS: 4 (r, db+, dd) | N = 38 Age: N/S (range: 19–61) 76% female Migraine Chron: N/S (range: 8 mos - 40 yrs) Rec: Neuro clinic | Placebo: n = 19 Indomethacin: 25 mg, 3x/day; n = 19 1-mo baseline period; 1-mo treatment period; at conclusion of this controlled trial, all patients took indomethacin for an additional 1-mo treatment period; patients who had responded to indomethacin continued to take it and were followed up through 9 mos We analyzed data from controlled portion of trial only Nothing on acute meds | HA frequency: No. of attacks HA severity: Not defined | Investigators analyzed the number of patients who were HA-free, who had a > 50% improvement in HA frequency or severity compared with baseline values, and who were “unimproved” (≤ 50% improvement in frequency or severity). There was no significant difference between indomethacin and placebo for this outcome (no p-value reported). Among patients taking indomethacin, 1/19 (5%) was HA-free; 6/19 (32%) were > 50% improved, and 12/19 (63%) were unimproved. Among patients taking placebo, 2/19 (11%) were HA-free, 5/19 (26%) > 50% improved, and 12/19 (63%) unimproved. | Dropouts: None during controlled portion of trial
Anthony, Lance, and Somerville, 1972 | CrOv (analyzed as SPPG) QS:1 (nr, ndb, dd) | N = 153 Age: N/S (range: 17–65) 79% female Migraine; ≥ 2 attacks/mo Chron: N/S (range: 1–47 yrs) Rec: Neuro clinic | Prindolol: 2.5 mg, 4x/day (dose reduced by half for first 3 days); n = 79* (total); n = 33 (first treatment period) Clonidine: 75 μg, 3x/day (dose reduced by half for first 3 days); n = 73* (total); n = 30 (first treatment period) Carbamazepine: 200 mg, 3x/day (dose reduced by half for first 3 days); n = 51* (total); n = 30 (first treatment period) No baseline period described; initial treatment period of 1 mo; at end of this period, patients with > 50% reduction in HA frequency continue on same med, rest switched to one of the other drugs; patients followed up for varying lengths of time (1–20 mos) Nothing on acute meds | HA frequency: Patients recorded number of HAs; at monthly assessments, classified as either HA-free, > 50% improved, or unimproved | Because of the unusual study design (see under “Interventions,” at left), we analyzed the results from the first month of treatment as if this were a parallel group trial. Among patients taking prindolol during the first month, 21/33 (64%) had a > 50% reduction in HA frequency compared with pre-trial values, as did 16/30 patients (53%) in the clonidine group, and 10/30 (33%) in the carbamazepine group, Prindolol was significantly better than carbamazepine for this outcome (0.01<p<0.025). There was no significant difference between clonidine and carbamazepine (0.1<p<0.2). Investigators did not directly compare prindolol and clonidine. | Dropouts: 12 (8%) during initial month of treatment, all due to AEs (3 prindolol, 3 clonidine, 6 carbamazepine); for entire trial, 28 patients (18%) dropped out due to AEs (8 prindolol, 8 clonidine, 12 carbamazepine) Not clear how pre-treatment frequency established (no baseline period described)
Arthur and Hornabrook, 1971 | CrOv QS: 4 (r, db+, dd) | N = 63 Age: N/S (range: ≤ 10->70) 73% female Common or classical migraine; migrainous neuralgia (5 pts); ≥ 2 severe attacks of migraine or migrainous neuralgia/mo Chron; N/S Rec: 23 pts referred by MDs to neuro. dept. for lack of improvement; 9 pts, both improved & unimproved, were from previous trial of pts with severe HAs | Placebo: n = 52* Pizotifen (BC 105): 3 mg (6 tabs)/day; n = 52* 1-mo baseline period; two 1-mo treatment periods; no washout; no follow-up Ergotamine and analgesic meds permitted during trial, but not acute meds that might obscure efficacy of pizotifen (phenobarbitone, prochlorperazine, et al.); 5 pts took tranquilizers during baseline, but not during treatment with active drug; 2 pts were gradually withdrawn from methysergide during baseline | HA frequency: Definition N/S, but recorded daily by pt as “presence/absence of HAs/day” HA intensity: Recorded daily by pts on 3-point scale | Twenty-one of 52 pts (40%) treated with pizotifen and 6/52 (12%) treated with placebo improved (obtained > 50% reduction in HA frequency from baseline to post-treatment). Pizotifen was significantly better than placebo at reducing HA frequency (p < 0.005). The overall number of HAs decreased from 423 at baseline to 330 in pts taking pizotifen but increased to 457 in patients taking placebo. There were significantly fewer HAs during the pizotifen period than during either the baseline or the placebo periods (p ≤ 0.01, each comparison). | Dropouts: 11 (17%) withdrew and were not included in efficacy analyses; an additional 3 pts, included in efficacy analyses, withdrew due to AEs (pizotifen)
Autret and de Chasteigner, 1987 | SPPG QS: 3 (r,db,dd) | N = 115 Age; 36 % female N/S Common migraine; 3–10 migraine days in previous month; no daily HAs Chron: N/S Rec: N/S | Placebo: n = 57 DHE (timed-release): 5 mg, 2x/day; n = 58 4-wk baseline period (placebo); 8-wk treatment period; no follow-up Acute meds permitted | HA index: Sum of intensity times duration for all attacks HA frequency: No. of attacks; number of days with HA | DHE was significantly better than placebo at reducing HA index compared with baseline values (p≤ 0.0017). Mean within-patient differences (± SD) from baseline to post-treatment were 1.98 (± 3.54) in the DHE group and 0.058 (± 2.80) in the placebo group. There were no significant differences between the two groups for HA frequency, considered either as number of attacks or number of days with HA (no data and no p-values reported). | Dropouts: 0 Abstract reporting limited results
Baldrati, Cortelli, Procaccianti, et al., 1983 | CrOv QS: 3 (r, db, dd) | N = 18 Age: N/S (range: 18–49) 89% female Common migraine (Ad Hoc); ≥ 2 attacks/mo Chron: 13 yrs (range: 3–38) Rec: N/S | Propranolol: Mean daily dose approx 120 mg, taken in three doses; dose increased gradually over 20 days; n = 12* Aspirin: Mean daily dose approx 975 mg, taken in three doses; dose increased gradually over 20 days; n = 12* 1-mo baseline period; two 3-mo treatment periods; 2-wk washout; only last month of each treatment period analyzed; no follow-up Nothing on acute meds | HA index: Defined as 1(F_1_xD_1_) + 2(F_2_xD_2_) + 3(F_3_xD_3_), where 1–3 refers to severity score, F=mean number of attacks/mo, D=mean duration in hrs HA frequency: No. of attacks/mo; no of migraine days/mo HA severity: Mean attack severity; each attack graded on scale of 1–3 (not described) HA duration: Mean attack duration (hrs) | There was no significant difference between the two treatments for reduction in HA index (no p-values reported). The mean percentage reduction in HA index from baseline to the third month of treatment was 64.8% with aspirin and 65.2% with propranolol (no variance data reported). Over the same period of time, 9/12 patients (75%) reported a greater than 50% reduction in HA index with aspirin; the same number of patients (9/12) reported a greater than 50% reduction with propranolol. Investigators reported finding no significant differences between the two treatments for HA frequency (both number of attacks/mo and number of HA days/mo), severity, or duration (no data and no p-values reported). | Dropouts: 6 (33%), 5 due to AEs (3 aspirin, 2 propranolol) High dropout rate (33%)
Bánk, 1994 | SPPG QS: 3 (r, db, dd) | N = 70 Age: 34 (range: 20–62) 73% female Migraine w/or w/o aura (IHS); history > 1 yr; ≥ 3 attacks/mo Chron: N/S Rec: N/S | Fluvoxamine: 50 mg, single dose at bedtime; n = 24 Amitriptyline: 25 mg, single dose at bedtime; n = 20 4-wk baseline period (placebo); 12-wk treatment period Patients permitted to use their usual acute meds (ergotamine compounds, NSAIDs, benzodiazepines) | Patients made clinic visits at approx 4-wk intervals. The following three outcomes were analyzed: HA index: No. of HAs times severity (scale of 1–3) divided by no. of days in visit period HA frequency: No. of HAs divided by no. of days in visit period Corrected HA unit index: Severity of attacks (scale of 1–3) times duration of attacks (scale of 1–3) divided by no. of days in visit period | Both drugs reduced HA index significantly compared with pre-treatment levels. With fluvoxamine, the median pre-treatment HA index was 0.43; after treatment, it was 0.18 (p<0.0003). With amitriptyline, the corresponding figures were 0.41 and 0.24 (p<0.001). The two treatments were not directly compared by investigators. Results were very similar for HA frequency and corrected HA unit index. | Dropouts: 21 (30%), 10 due to AEs (7 amitriptyline, 3 fluvoxamine); in addition, 5 patients (3 amitriptyline, 2 fluvoxamine) did not experience any HAs during the 12-wk treatment period and were excluded from the efficacy analysis by the investigators
Barrie, Fox, Weatherall, et al., 1968 | CrOv (orthogonally balanced) QS: 3 (nr, db+, dd) | N= 105 Age: N/S (range: 17–68) % female N/S Common, classic, or hemiplegic migraine, or migraine + muscle- contraction HA; ≥ 1-yr history; ≥ 1 HA/mo Chron: N/S Rec: HA clinics | Methysergide: 1 mg, 3x/day; n = 16 Methysergide: 2 mg, 3x/day; n = 11 Ergotamine: 0.17 mg, 3x/day; n = 17 Ergotamine: 0.33 mg, 3x/day; n = 15 Ergometrine maleate: 0.33 mg, 3x/day; n = 3 Ergometrine maleate: 0.67 mg, 3x/day; n = 3 No baseline period described; four 4-wk treatment periods; after third period, patients chose which of first three drugs to use for remainder of trial; no washout; no follow-up Aspirin or prochlorperazine used for acute attacks | HA severity: Patients graded each attack on scale of 0, 50, and 100 (mild, moderate, severe); investigators reported the number of patients in each group and in each period who had decreased HA severity (no threshhold specified) compared with the previous period | Results from the second, third, and fourth periods were compromised for the following reasons: (1) in periods 2, 3, and 4 each patient was evaluated vis-á-vis the immediately preceding period; however, it was not possible to trace the sequence of interventions used in particular cases from the data reported; (2) at one of the two sites, patients were permitted to choose which drug to use for acute attacks during the third and fourth periods (aspirin was assigned for one of the first two periods, prochlorperazine for the other, then patients chose which one to use for third and fourth); (3) at both sites, patients were allowed to choose one of the preventive agents used in periods 1–3 to use in period 4. For all these reasons, we were only able to consider the data from the first period of the trial (month 1). Also, period one results from the two ergometrine treatment arms are not considered here, since there were fewer than 5 patients in each group. HA severity: During the first month of treatment, the numbers of patients reporting decreased HA severity vis-á-vis baseline values were: methysergide 3 mg/day, 9/16 (56%); methysergide 6 mg/day, 5/11 (45%); ergotamine 0.5 mg/day, 8/17 (47%); ergotamine 1 mg/day, 7/15 (47%). Investigators did not analyze these results. | Dropouts: 40 patients (38%) were excluded from the efficacy analysis of period 1 data because they did not provide complete enough reports or a sufficient number of reports (4 attacks or more) Baseline data gathered by history and was “not always available”
Bassi, Brunati, Rapuzzi, et al., 1992 | SPPG QS: 2 (r, ndb, dd) | N =40 Age: 30 (range: 18–50) 83% female Migraine w/or w/o aura (IHS); history of ≥ 2 yrs; ≥ 2 HAs/mo; no prophylactic meds in previous 3 mos Chron: 140 mos (range: 2–35 yrs) Rec: Hospital HA dispensary | Flunarizine: 10 mg, 1x/day for one wk, then 3 mg, 1x/day; n = 14 Flunarizine: 10 mg, 1x/day; n = 15 1-mo baseline period (no prophylactic med); 4-mo treatment period; no follow-up Acute meds permitted | HA index: No. of hrs of HA/mo times HA severity; severity of each HA graded on scale of 0–3 (pain absent; slight pain, but no need for analgesics; medium intensity pain, improving with analgesics; strong pain with partial incapacity even after taking analgesics) | Both doses of flunarizine significantly reduced HA index in comparison with baseline values from the second treatment month on (p<0.01 for both groups during the final month of treatment); the lower dose also produced a significant improvement already in the first month (p<0.01). The 3-mg dose outperformed the 10-mg dose during the first month (p<0.05); otherwise, there were no significant differences between the two doses at any timepoint (p-values not reported). Some data were reported (what appear to be median HA index scores and median reductions in HA index scores), but could not be interpretd with confidence. | Dropouts: 11 (28%),2 due to AEs (1 in each group) Low quality score (2); not double-blind
Behan, 1985 | SPPG QS: 2 (r, ndb, dd) | N =60 Age: 30 (average) % female N/S Chron: N/S Common or classical Ms; > 2 Ms/mo Rec: Migraine clinic | Pizotifen (Sanomigran®): 1.5 mg, 1x/night for 1 mo; dose could be increased to 3.0 mg, 1x/night, if HAs unimproved after 1 mo; n = 18 Clonidine (Dixarit®): 50 μg, 2x/day for 1 mo; dose could be increased to 75μg 2x/day, if HAs unimproved after 1 mo; n = 26 No baseline period; 2-mo treatment period; no washout; no follow-up Nothing on acute meds | HA frequency: See below HA intensity: See below No definitions given for either of above outcomes, but data obtained from pts’ diaries. No baseline data gathered. Pts assessed monthly by physician | HA frequency and intensity results were reported as the “reduction” in those outcomes over each month for individual pts. (No information on baseline data was provided, so it is not clear how reductions were determined.) At the end of each month, fewer and less severe HAs were reported from pts taking pizotifen than from those taking clonidine (authors reported that differences between treatments were not analyzed for statistical significance). During the first month, 12/18 pts (67%) and 3/25 pts (12%) in the pizotifen and clonidine groups, respectively, reduced HA frequency. During the second month, 11/13 pts (85%) and 4/19 pts (21%) in the pizotifen and clonidine groups, respectively, reduced frequency. During the first month, 14/18 pts (22%) and 3/22 pts (14%) in the pizotifen and clonidine groups, respectively, reduced HA intensity. During the second month, 11/12 pts (92%) and 1/17 pts (6%) in the pizotifen and clonidine groups, respectively, reduced intensity | Dropouts: 16 (27%), 1 due to AEs (pizotifen) Information obtained from abstract Definition of “improvement” does not meet our criterion of ≥ 50% reduction from baseline to post-treatment Unclear how assessment of outcomes was determined from daily HA recordings
Behan and Reid, 1980 | CrOv QS: 2 (nr, db, dd) | N = 56 Age: N/S (range: 18–56) 66% female Classical or common migraine; ≥2 severe HAs/mo Chron: N/S (range: 6 mos-33 yrs) Rec: N/S | Methysergide: 1 mg, 3x/day; n = 38* (36 patients completed both treatment periods, but 38 appear to have been included in the methysergide vs. baseline comparisons) Propranolol: 40 mg, 3x/day; n = 36* No baseline period described; two 3-mo treatment periods; 1-mo washout (acute analgesics only); no follow-up No drugs other than study meds allowed during treatment periods | HA frequency: Not defined; investigators reported and analyzed the no. of patients reporting no change in HA frequency, < 50% reduction, 50–75% reduction, 75–99% reduction, and complete relief HA severity: Severity data recorded by patients not described; effect of treatment on severity was graded on scale of 0–3 (no effect, mild relief, moderate relief, complete relief) | Both propranolol (p<0.0001) and methysergide (p<0.01) signficantly reduced HA frequency compared with baseline values. There was no significant difference between the two drugs for this outcome (p>0.05). 19/36 patients (53%) reported a reduction in HA frequency of 50% or more with propranolol, as did 15/38 patients (39%) with methysergide. There was no significant difference between the two drugs for HA severity (p=0.168). | Dropouts: 20 (36%), 3 due to AEs (all methysergide) No indication of how baseline values established (no baseline period described) High dropout rate (36%) Low quality score (2); not randomized
Bellavance and Meloche, 1990 | SPPG QS: 3 (r, db, dd) | N = 176 Age: 33 (range: 18–45) 79% female Classical or common migraine (Ad Hoc); ≥ 1-yr history; 4–8 attacks during baseline period, severe enough to cause a reduction in activity or capacity for work; no other types of HA Chron: 12 yrs (range: 1–31) Rec: N/S (“outpatients”) | Placebo: n = 52 Pizotyline: 0.5 mg, 3x/day (gradual escalation to full dose over first 7 days); n = 58 Naproxen sodium: 550 mg, 2x/day; n = 56 2-mo baseline period (placebo); 3-mo treatment period; no follow-up Acute meds permitted | HA index: Severity times duration for each episode, summed for all episodes and divided by the no. of days in the treatment period HA frequency index: No. of migraine attacks divided by the no. of days in the treatment period HA severity: Each attack graded on scale of 1–3 (slight, moderate, severe) HA duration: Each attack graded on scale of 1–3 (<8 hrs, 8–16 hrs, > 16 hrs) | Naproxen sodium was significantly better than placebo at reducing mean HA index scores during all three treatment months; pizotyline was significantly better than placebo during the second treatment month only. There were no significant differences between naproxen sodium and pizotyline during any of the three months for this outcome (no p-values reported). Mean HA index scores were not reported for each month, but only for the baseline (2 mos) and treatment (3 mos) periods as wholes. In the naproxen sodium group, mean HA index scores were reduced from 5.32 at baseline to 2.85 during treatment; in the pizotyline group, the corresponding scores were 5.77 and 3.27; and in the placebo group, they were 5.56 and 5.08 (no variance data reported). Naproxen sodium was significantly better than placebo for this outcome (p<0.0166, Kruskal-Wallis with Bonferroni correction); otherwise, there were no significant differences among the treatments (no other p-values reported). Both naproxen sodium and pizotyline were significantly better than placebo at reducing mean HA frequency index scores (p<0.0166 for both comparisons); there was no significant difference between the two active treatments (no p-value reported). Naproxen sodium was significantly better than placebo and than pizotyline at reducing HA duration during the first month of treatment. Otherwise, there were no significant differences among the treatments for this outcome. | Dropouts: 25 (14%), 7 due to AEs (3 naproxen sodium, 2 pizotyline, 2 placebo); 15 of these 25 patients were included in the efficacy analysis; 21/25 were included in the AE analysis
Boisen, Deth, Hübbe, et al., 1978 | CrOv QS: 2 (r, db, dd) | N =71 Age: N/S (range: N/S) % female N/S Chron: N/S Migraine (paroxysmal HAs with discomfort + 1 or more of: nausea, vomiting, visual disturbances, paraesthesia); ≥ 4 days of Ms/mo in 2 mos before trial Excl: Treatment with MAOls; previous treatment with clonidine Rec: Neurology departments of 4 hospitals in Denmark | Placebo: n = 49* Clonidine: 0.05 mg (in 2 tabs), 2x/day; n = 49* No baseline period; two 8-wk treatment periods; no washout, but first wk of each treatment period excluded from analysis to reduce crossover effects; no follow-up It appears that pts permitted to take other meds during trial | HA frequency: Definition N/S, but derived from pts’ daily recordings of time of onset & cessation of HAs | For HA frequency, during the first treatment period 28 pts taking clonidine reported 407 HAs, whereas 21 pts taking placebo reported 278 HAs. During the second treatment period, 21 pts taking clonidine reported 235 HAs and 28 pts taking placebo reported 372. Thus, a total of 49 pts reported 642 and 650 HAs during 14 wks after taking clonidine and placebo, respectively. The difference between the two treatments for reducing HA frequency was not statistically significant, according to investigators. No with in-group results were provided for comparisons of HA frequency before and after treatment with each intervention. | Dropouts: 22 (31 %),2 due to AEs (clonidine) Not clear if baseline information gathered. Pts’ diaries reviewed by physician every 4 wks In the first trial period, the no. of HAs was 685, and in the second, 607. There was a significant difference between the no. of HAs depending on the order in which treatment was received (p<0.05)
Bono, Criscuoli, Martignoni, et al., 1982 | SPPG QS:3 (r, db, dd) | N = 80 Age: 37 (range: N/S) 82% female Common or classical migraine; hist. ≥3 yrs+ treatment-free for ≥ 3 mos or never treated Excl: Age > 58 or < 18; HI < 6 (not defined) Chron: N/S (range: N/S) Rec: N/S | Oxitriptan (L-5-HTP): 400 mg/day; n = 33 Pizotifen: 1.40 mg/day; n = 34 1-mo baseline with placebo treatment, followed by 2-mo treatment period with active drug Analgesics permitted, but pts asked to avoid foods containing large amounts of amines and amino acids | HA index: Definition N/S HA frequency: Recorded daily (“hour by hour”) by pt and reported as “no. of HAs/mo” HA intensity: Recorded daily by pt on 4-point scale; termed “pain total index” | Investigators reported results only as p-values; no mean scores were provided. Pizotifen was significantly better than oxitriptan at reducing HA index after both the first month (p < 0.01) and the second month (p < 0.02). Although placebo was not used as a treatment, investigators compared each active drug with baseline placebo. Oxitriptan decreased HA index significantly from baseline to post-treatment after the second month (p < 0.02), but not after the first month (n.s., no p-value given). No pre- to post-treatment results were provided for changes in HA index resulting from pizotifen. | Dropouts: 13 (16%),5 due to AEs (oxitriptan)
Bonuso, Di Stasio, Barone, et al., 1983 | SPPG QS:2 (r, ndb, dd) | N =41 Age: N/S (range: 18–55) 68% female Mixed HA (Ad Hoc) Chron: N/S Rec: N/S | Amitriptyline: 75 mg/day (schedule not described); n = 15 DHE (timed-release): 5 mg, 2x/day; n = 15 1-mo baseline period; 2-mo treatment period; no follow-up Acute meds permitted | HA severity: Mean monthly HA severity; no indication of precisely how this was calculated; patients graded HA pain every hr during day on scale of 0–4 (none, mild, moderate, severe, extremely severe); investigators considered it likely that “severe” and “extremely severe” attacks were of the migraine type, whereas “mild” and “moderate” attacks were tension- type; all HAs were included in the analysis HA duration: Mean % decrease (vis-á-vis baseline) in no. of HA hours/month, stratified by HA severity | Mean monthly HA severity scores (± SEM) for the group taking amitriptyline were 17.0 (± 1.6) during the baseline period and 5.4 (± 0.7) during treatment month 2. Corresponding scores in the DHE-treated group were 18.7 (± 1.3) and 10.7 (± 0.9). Investigators did not state whether they found the difference between the two treatments in this respect to be statistically significant. Analysis of the data on HA duration, stratified by severity, showed that DHE was significantly better than amitriptyline at reducing the number of hours of extremely severe (65.1% vs. 48.7% reduction) and severe (71.6% vs. 53.4%), migraine-type pain; amitriptyline was significantly better than DHE at reducing the number of hours of moderate (74.4% vs. 26.0%) and mild (77.1% vs. 22.3%), tension-type HA- like pain (p<0.01 for all four comparisons). | Dropouts: 11 (27%),5 due to AEs (DHE 2, amitriptyline 3) Low quality score (2); not double-blind
Børgesen, Nielsen, and Møller, 1974 | CrOv QS: 4 (r, db+, dd) | N = 45 Age: 38 (range: 18–59) 83% female Common or classical migraine (Ad Hoc); ≥ 1 HA/wk; all pts had failed to respond to known prophylactics; HAs described as "intractable" Chron: 21 (range: 1–50) Rec: Neuro. dept. of hospital in Denmark | Placebo: n = 30* Propranolol (Inderal®): 40 mg, 3x/day (given in doses increasing during first 10 days of each period); n = 30* 4-wk baseline (no prophylactics); two 12-wk treatment periods; no washout, but first 4 wks of each period excluded from analysis to avoid carry-over effect from previous treatment; no follow-up Acute meds permitted (salicylates, ergotamines, narcotics), but not prophylactic meds | HA frequency: Not defined, but reported as "mean attack frequency" HA severity: Recorded by pts on 3-point scale | Propranolol reduced HA frequency significantly better than did placebo (over the 8 wks analyzed of each relevant treatment period) (Wilcoxon’s test; p-value not reported). The mean baseline HA frequency score was reduced from 1.77 to 1.03 after treatment with propranolol and to 1.33 after treatment with placebo. Investigators did not report whether they analyzed the pre- to post- treatment reductions for statistical significance. From data provided, we calculated that 15/30 patients (50%) treated with propranolol and 9/30 patients (30%) treated with placebo improved on HA frequency (achieved ≥ 50% reduction from pre- to post- treatment). Investigators did not report whether they analyzed these results for statistical significance. | Dropouts: 15 (33%), 2 due to AEs (placebo)
Bousser, Chick, Fuseau, et al., 1988 | CrOv QS: 4 (r, db+, dd) | N = 45 Age: 40 (range: 18–66) 68% female Common or classical migraine (Ad Hoc); history > 2 yrs; 3–15 attacks/mo for past 2 mos; not taking migraine prophylactic medication Chron: N/S Rec: N/S | Placebo: n = 38* DHE + aspirin (timed-release): 5 mg + 40 mg, 2x/day; n = 38* No baseline period described; two 8-wk treatment periods; 1-wk washout; no follow-up Acute meds permitted | HA frequency: No. of attacks per 8-wk treatment period HA severity: Mean per attack; severity of each attack graded on scale of 1–4 (mild-severe) HA duration: Mean per attack (in hrs) | DHE + aspirin was significantly better than placebo at reducing HA frequency (p=0.003). Mean HA frequency (± SD) was 11.5 (± 6.2) with DHE + aspirin and 16.6 (± 9.9) with placebo. There were no significant differences between the two treatments for HA severity or duration. | Dropouts: 7 (16%), none due to AEs
Bradley, Hudgson, Foster, et al., 1968 | CrOv QS: 5 (r+, db+, dd) | N = 48 Age: N/S 64% female "Typical" migraine; > 1 attack/mo Chron: N/S Rec: N/S | Placebo: n = 39* (14 men, 18 women with history of more frequent HAs around time of menstruation, 7 women with no such history) Flumedroxone (Demigran®): 10 mg, 3x/day; n = 39* (14 men, 18 women with history of more frequent HAs around time of menstruation, 7 women with no such history) No baseline period described; two 3-mo treatment periods; 1-mo washout (no specific therapy); no follow-up Nothing on acute meds | HA index: Sum of HA severity scores per 3-mo treatment period; each attack graded on scale of 1–3 (mild, moderate, severe) HA frequency: No. of HAs per 3-mo treatment period HA duration: Total HA duration (in hrs) per 3-mo treatment period | Results were reported and analyzed separately for men, women with a history of more frequent HAs around the time of menstruation, and women with no such history. An analysis of within-patient differences found that flumedroxone was significantly better than placebo for HA index among those women patients with a history of more frequent HAs around the time of menstruation (p<0.05). There was no significant difference between the two treatments in the other two patient groups (no p-values reported). No individual patient data or mean within-patient differences were reported. Group mean HA index scores (with ranges) among women with a history of more frequent HAs around the time of menstruation were 31 (8–101) with flumedroxone and 37 (2–116) with placebo. Among men, the corresponding figures were 21.5 (2–169) and 24.5 (1–154), respectively. No group mean scores were reported for women with no history of more frequent HAs around the time of menstruation. Similar results were reported for HA frequency. None of the three patient groups experienced a significant reduction in HA duration with flumedroxone. | Dropouts: 9 (19%), 2 due to AEs (both flumedroxone)
Bredfeldt, Sutherland, and Kruse, 1989 | CrOv QS: 3 (r−, db+, dd) | N = 43 Age: N/S (range: 20–57) 80% female Chron: N/S Migraine (Ad Hoc); hist. of recurrent Ms for ≥ 6 mos; ≥ 1 M in mo before trial; onset of HAs prior to age 40 Excl: Use of prophylactic meds for any reason Rec: Family practice outpatient clinics; physician referral | Placebo: n = 30* Clonidine (Dixarit® via Catapres TTS-2® patches): ≈ 0.2 mg/day via 1 transdermal patch/wk; n = 30* No baseline period; two 6-wk treatment periods; no washout, but first wk of each treatment period excluded from analysis to reduce crossover effects; no follow-up Pts permitted to use OTC meds with acetaminophen or narcotic preparations prescribed by physicians | HA frequency: No. of HAs per day HA intensity: Rated by pt on 5-pt scale (1 = very mild and 5=very severe) | Results were reported only as averages per pt of HA frequency or intensity over the two 5 wks analyzed. Pts taking clonidine reported a slight decrease in each outcome compared with placebo, but the differences for both between-group comparisons were not statistically significant. For HA frequency, pts taking clonidine had an average of 10 HAs during the 10 wks analyzed, whereas pts treated with placebo reported an average of 11.2 (p=0.24). For HA Intensity, pts taking clonidine reported an average intensity of 2.4 during the 10 wks analyzed, whereas pts treated with placebo reported an average of 2.5 (p=0.27). No within-group results were provided for comparisons of HA frequency or intensity before and after treatment with each intervention. | Dropouts: 13 (30%),3 due to AE (clonidine) Not clear if baseline information gathered. Pts' diaries reviewed by physician at 6 and 12 wks
Briggs and Millac, 1979 | CrOv QS: 3 (r, db, dd) | N = 14 Age: N/S (range: N/S) 71% female Common or classical migraine (Ad Hoc); ≥ 2 HAs/mo; all had failed to benefit from previous prophylactic treatment; “frequent” HAs Chron: N/S (range: N/S) Rec: Referrals to neuro. clinic | Placebo: n = 13* Timolol: 10 mg, 2x/day; n = 13* 4-wk baseline (no prophylactics); four 6-wk treatment periods (double crossover); no washout; no follow-up Simple analgesics and ergotamine derivatives permitted for acute migraine attacks (pts asked to use same agent consistently throughout treatment period) | HA frequency: Recorded daily by pt and reported as "number of migraines in each 6-wk period" | At the end of the double crossover trial, the HA frequency mean scores (average of both 6-wk periods) were 4.4 and 6.8 after treatment with timolol or placebo, respectively. Investigators did not report having analyzed these results for statistical significance. | Dropouts: 1 (7%), due to AEs (placebo)
Buscaino, Sorge, Bussone, et al., 1991 | SPPG QS: 4 (r, db+, dd) | N = 90 Age: 37 (range: 18–53) 70% female Common migraine (Ad Hoc); history ≥ 5 yrs; 2–8 HAs/mo in previous 3 mos; no migraine prophylactic med in previous 3 mos; no daily HA Chron: 16 yrs (range: 3–41) Rec: N/S | DHE (timed-release), 5 mg, 2x/day: n = 45 DHE (timed-release), 10 mg, 1x/day: n = 45 1-mo baseline period (no meds); 2-mo treatment period; no follow-up Acute meds permitted | HA index: Not described, but combined HA severity and frequency; severity of each attack graded on scale of 1–3 (does not restrict normal activity; restricts normal activities; bedridden) HA frequency: No. of days with migraine per month | Both dosing regimens significantly reduced HA index scores in comparison with baseline values (p<0.01 for both comparisons); there was no significant difference between the two interventions for this outcome (no p- value reported). At the end of the second month of treatment, HA index had been reduced by 39% in the twice-daily group, and by 55% in the once-daily group. Mean HA index scores were reported only in graphic form and could not be reliably read off the graph. Similar results were reported for HA frequency. | Dropouts: 4 patients (4%) discontinued treatment due to AEs (3 in 2x/day group, 1 in 1x/day group); it appears that these 4 patients were included in the efficacy analysis, though this is not certain 36/90 patients had tried some form of preventive therapy before with results ranging from none to excellent
Bussone, Baldini, D'Andrea, et al., 1987 | SPPG QS: 4 (r, db+, dd) | N = 30 Age: 36 83% female Common migraine (Ad Hoc); ≥ 2 HAs/mo for past 2 yrs Chron: 13 yrs Rec: N/S | Flunarizine: 10 mg, 1x/day (bedtime); n = 13 Nimodipine: 40 mg, 3x/day; n = 12 4-wk baseline period (placebo); 12-wk treatment period; no follow-up Acute meds permitted | HA index: Hours with HA times HA severity; severity graded daily on scale of 0–4 (no pain, mild, moderate, severe, excruciating) | Both flunarizine and nimodipine significantly reduced HA index in comparison with baseline values, nimodipine from one month on, and flunarizine from two months on. In the flunarizine group, the baseline mean HA index score (± SD) was 286.6 ± 352.1; after 3 mos, it was 200.4 (± 301.8) (p<0.002). In the nimodipine group, the corresponding figures were 258.4 (± 211.3) and 116.9 (± 105.0), respectively (p<0.001). There were no significant differences, at any time point, between flunarizine and nimodipine (no p-values reported). 6/14 patients treated with nimodipine (43%) and 6/16 treated with flunarizine (38%) reported a 50% or greater reduction in HA index from baseline to end of treatment. There was no significant difference between the two treatments for this outcome (no p- value reported). | Dropouts: 5 (17%),3 due to AEs (2 flunarizine, 1 nimodipine)
Cangi, Boccuni, Zanotti, et al., 1989 | SPPG QS: 3 (r, db+, dnd) | N = 22 Age: N/S % female N/S Migraine w/o aura (IHS); history ≥ 2 yrs; ≥ 2–3 HAs/mo; no spontaneous remission lasting> 15 days Chron: N/S Rec: N/S | Methysergide: 1 mg, 2x/day; n = 11 Dihydroergokryptine (DEK): 10 mg, 2x/day; n = 11 1-mo baseline period (placebo), followed by 2-mo treatment period; no follow-up Acute meds permitted | HA index: Not defined HA frequency: No. of HA days per month | We analyzed the results for HA frequency, since the HA index used was not described. In the DEK group, the mean number of HA days/mo (± SD) was reduced from 9.8 (± 2.6) during the baseline period to 6.8 (± 2.7) during the second month of treatment; in the methysergide group, the corresponding figures were 8.6 (± 1.7) and 6.0 (± 2.8). The authors did not report whether they found the difference between the two groups to be statistically significant. Mean HA index scores (± SD) in the DEK group were reduced from 103.8 (± 25.48) during the baseline period to 87.17 (± 25.02) during the second month of treatment; the corresponding figures in the methysergide group were 84.4 (± 28.5) and 67.6 (± 31.24). The authors did not report whether they found the difference between the two groups to be statistically significant. | Dropouts: Not described Abstract reporting parallel-group interim results from longer-term crossover trial
Canonico, Scapagnini, Genazzani, et al., 1989 | CrOv QS: 2 (r, db, dnd) | N = 102 Age: N/S (range: 13–58) 72% female Common migraine; 3–10 HA days/mo Chron: N/S Rec: N/S | Placebo: n = 102* Dihydroergokryptine (DEK): 10 mg, 2x/day (half dose for first 5 days); n = 102* 1-mo baseline period (placebo); two 2-mo treatment periods; no washout; no follow-up Acute meds permitted | HA index: Not defined | Both treatments produced a significant reduction in monthly HA index scores during the first treatment period of the trial (55% reduction for DEK; 18% for placebo; p<0.001 vs. baseline for each treatment). During the second treatment period, those patients taking placebo deteriorated, while those taking DEK registered a further significant improvement of 54% (p<0.001 compared with period 1 scores). No overall comparison of the two treatments was reported. | Dropouts: Not described Abstract reporting limited results Low quality score (2); dropouts not described
Carrieri, Orefice, and Sorge, 1988 | SPPG QS: 4 (r, db+, dd) | N = 40 Age: 36 (range: 19–53) 64% female Classical or common migraine (Ad Hoc); history ≥ 2 yrs; ≥ 4 HAs/mo for last 3 mos; avg duration 2 hrs to 4 days Chron: 15 yrs (range: 3–38) Rec: N/S | Placebo: n = 17 Indobufen: 200 mg, 2x/day; n = 18 4-wk baseline period (HA recording and no prophylactic treatment); 3-mo treatment period; no follow-up Patients asked not to take anything except analgesic or ergotamine products for acute attacks for at least 10 days before or during treatment period; in particular, not allowed to take aspirin, dipyridamole, beta blockers, steroids, NSAIDs, antidepressants, or hypnotics | HA index: Frequency times severity; severity of each attack graded on scale of 1–3 HA frequency: No. of attacks/mo | Indobufen, but not placebo, significantly reduced HA index from baseline to month 3. Mean HA index scores (± SD) in the indobufen group were 10.4 (± 3.8) at baseline and 6.1 (± 3.7) after 3 mos (p<0.001, Wilcoxon); corresponding scores in the placebo group were 10.6 (± 4.2) and 10.4 (± 6.4), respectively. The difference between indobufen and placebo for this outcome was statistically signficant (p<0.01, Mann-Whitney U). Similar results were reported for HA frequency. | Dropouts: 5 (13%), none due to AEs
Carroll and Maclay, 1975 | CrOv QS: 4 (r, db+, dd) | N = 27 Age: N/S (range: N/S) % female N/S Common or classical migraine (Ad Hoc); ≥ 3 migraines/mo in 6 mos preceding trial Excl: pts with any disease that might interfere with absorption, metabolism, or excretion of pizotifen Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 14* Pizotifen (Sanomigran®): 0.5 mg, 1x/evening on Days 1 & 2; 0.5 mg, 2x/day on Days 3 & 4; 0.5 mg, 3x/day on Day 5; 0.5 mg, 3x/day for 2 wks or until end of trial– if relief insufficient, dose could be increased to 1 mg, 3x/day; n = 14* 1-mo baseline period with pizotifen; two 2-mo treatment periods; 2-wk washout between treatment periods Nothing on acute migraine meds | HA index: Calculated by multiplying no. of HA attacks by intensity rating HA frequency: Definition N/S, but recorded daily by pt HA intensity: Recorded daily by pt on 3-point scale | We could not analyze the data because of the manner in which they were reported. Results were reported as “improved,” “worse,” or “unchanged” when the patient’s condition at the end of the trial was compared with his/her condition at the end of baseline. The criterion for determining “improvement” was not specified. | Dropouts: 13 (48%),1 due to AEs (pizotifen) 3 mg was the most commonly used dose
Carroll, Reidy, Savundra, et al., 1990 | CrOv QS: 3 (r, db, dd) | N = 51 Age: 39 (range: 17–62) 69% female Common or classical migraine (Ad Hoc); median frequency of ≥ 8 HAs/mo Chron: 14 (median) (range: 2–50) (median) Rec: N/S | Propranolol (long-acting): 80 mg/day; n = 37* Propranolol (long-acting): 160 mg/day; n=37* 4-wk run-in (placebo); two 12-wk treatment periods; 2-wk washout (placebo) between treatment periods; no follow-up Meds for acute migraine attacks permitted | HA frequency: Not defined, but recorded daily by pts HA intensity: Rated on 4-point scale and reported daily by pts | HA frequency was reduced from a median score of 6.10 at baseline to median scores of 3.40 and 3.70 after treatment with propranolol LA 160 mg and propranolol LA 80 mg, respectively. HA frequency was reduced significantly better after treatment with each propranolol dosage than after the baseline run-in period (p < 0.01, each case). The higher dose of propranolol was significantly better at reducing this outcome than was the lower dose (p = 0.03). | Dropouts: 14 pts (27%) withdrew and were not included in efficacy analyses, 5 for AEs (3 propranolol 160 mg; 1 propranolol 80 mg; 1 placebo washout) Not clear if baseline data gathered
Cerbo, Casacchia, Formisano, et al., 1986 | CrOv QS: 1 (nr, db-, dd) | N =27 Age: N/S % female N/S Common or classical migraine (Ad Hoc); 4–14 attacks/mo; history ≥ 2 yrs Chron: N/S Rec: N/S | Pizotifen: 1.5 mg, 1x/day (at night); n = 21* (18 of whom completed both periods) Flunarizine: 15 mg, 1x/day (at night); n = 21* (18 of whom completed both periods) 1-mo baseline period (no HA-specific drugs); two 2-mo treatment periods; 15-day washout (drug-free); no follow-up Acute meds permitted | HA frequency: No. of attacks/mo Total pain index: Duration times severity, divided by duration; severity graded on scale of 1–4 (mild, moderate, intense, severe) HA duration: No. of hrs of pain/mo | An ANOVA analysis performed by the investigators found that both treatments significantly reduced HA frequency compared to baseline values (p<0.01 for flunarizine; p<0.05 for pizotifen). Only flunarizine significantly reduced the total pain index (p<0.05). Both drugs significantly reduced HA duration compared to baseline values (p<0.01 for flunarizine; p<0.05 for pizotifen). There were no significant differences between the two treatments for any of the above outcomes (no p-values reported). Analysis of the data using Student’s t test and the Wilcoxon matched-pairs test confirmed the above results, except in the case of HA duration, for which flunarizine was found to be more effective than pizotifen. No baseline data were reported, and post-treatment data were reported only in graphic form; mean values could not be reliably read off the graphs. | Dropouts: 9 patients (33%) did not complete the trial, 4 due to AEs; 6 of these 9 (including all 4 who withdrew due to AEs) completed at least one treatment phase and were included in the efficacy analysis Not randomized; double-blinding not adequate
Couch, Bearss, and Verhulst, 1987 | SPPG QS: 1 (r, ndb, dnd) | N = 73 Age: N/S % female N/S Migraine Chron: N/S Rec: N/S | Placebo: n =26 Fenoprofen 200 mg: 3x/day; n = 23 Fenoprofen 600 mg: 3x/day; n = 24 4-wk baseline period (placebo); 12-wk treatment period; no follow-up Nothing on acute meds | HA index: Calculated as follows: 3(F_DA_ x D_DA_) + 2(F_S_ x D_S_) + 1(F_MOD_ x D_MOD_), where F = frequency, D = duration, DA = disabling, S = severe, MOD = moderate/mild | Fenoprofen was no more effective than placebo at reducing HA index from week 0 (start of treatment) to week 12 (no p-values reported). Mean week 0 and 12 migraine scores were 216 and 161 in the 600-mg group (25% reduction), 140 and 95 in the 200-mg group (32% reduction), and 222 and 168 in the placebo group (24% reduction) (no variance data reported). | Dropouts: Not described Abstract reporting very limited information Low quality score (1); not double-blind; dropouts not described
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 (12-mo interim report) | SPPG QS: 4 (r, db+, dd) | N =162 Age: N/S 84% female Migraine; ≥ 2 disabling or severe HAs in mo prior to study Chron: N/S Rec: HA clinic | Placebo: n =53 (final report); n =36 (interim report) Amitriptyline: 50 mg/day for first wk; 75 mg/day for second wk; 100 mg/day for wks 3–4; patients instructed to contact investigator if AEs experienced; n =47 (final report); n =37 (interim report) 4-wk baseline period (placebo); 4-wk treatment period; at end of 4-wk treatment period, patients given option of continuing on same med for another 4 wks or taking amitriptyline as an open trial for 4 wks Use of acute meds permitted | Patients graded each HA as “disabling” (must go to bed), “severe” (>50% limitation of activity), “moderate” (10–50% limitation of activity), or “mild” (<10% of activity); most “disabling” and “severe” HAs were migrainous, while “moderate” and “mild” HAs were frequently tension-type or nonspecific in type Both interim and final publications reported results for weighted migraine index (M): M = 2(FxD)_disabling_ + 1(FxD)_severe,_ where F = frequency (no. of HAs/mo) and D = mean duration (hrs) Interim publication also reported results for weighted total HA index (TH): TH = 4(FxD)_disabling_ + 3(FxD)_severe_ + 2(FxD)_moderate_ + 1(FxD)_mild_, where F = frequency and D = duration | Mean weighted migraine index scores (continuous data) for wks 1–4 (pre-treatment) and 5–8 (post-treatment) were not reported in the final publication, but investigators stated that when the pre- to post- treatment differences were compared, amitriptyline was significantly better than placebo (p<0.01). The interim report provided mean scores for 73 of the 100 patients who were eventually included in the efficacy analysis. For the amitriptyline group, the mean weighted migraine index score was 112.1 pre-treatment and 68.5 post-treatment, a difference of −43.7 (no variance data reported). For the placebo group, the corresponding mean scores were 67.7 and 104.1, a difference of +36.3 (no variance data reported). When the pre- to post-treatment differences were compared, amitriptyline was significantly better than placebo (p<0.01). Very similar continuous results were reported in the interim report for the mean weighted total HA index scores (p<0.02 in favor of amitriptyline). Mean weighted migraine index scores (dichotomous data): The final publication reported that an improvement of 50% or more in the mean migraine index score was achieved by 26/47 (55%) patients in the amitriptyline group, and by 18/53 (34%) in the placebo group (p<0.05). Among those patients who had achieved 50% or more improvement by the end of the active treatment period and who chose to continue in the double-blind trial for another 4 wks (amitriptyline, n =23; placebo, n =13), patients in the amitriptyline group maintained their improvement significantly better than did patients in the placebo group (p<0.05). | Dropouts: 62 (38%), 7 due to AEs (5 amitriptyline, 2 placebo); 46/62 dropouts withdrew before the end of the baseline period
Dahlöf, 1987 | CrOv QS: 4 (r, db+, dd) | N =28 Age: N/S (range: 18–60) 93% female Common or classical migraine; hist. ≥ 2 yrs; ≥ 2–8 well-defined migraines/mo, plus fulfillment of ≥ 4 of 7 criteria, including photo-or phonophobia, auras, etc. Excl: Previous treatment with beta-blockers Chron: N/S (range: N/S) Rec: N/S, but “outpatients” | Placebo: n = 28* Propranolol (Inderal®): 40 mg, 3x/day; n = 28* 4-wk run-in; two 1-mo treatment periods, each followed by a 5-mo assessment period; no follow-up (other than the two assessment periods) Patients permitted to use their usual meds for acute migraine attacks | HA frequency: Not defined, but recorded daily by pts Integrated HA: Not defined | Propranolol reduced HA frequency (number of HAs/4 wks) from 4.3 (± 0.4) (SEM) to 3.2 (± 0.4) compared with placebo. Investigators reported that propranolol was significantly better than placebo at reducing this outcome (p < 0.01). No results were provided for pre- to post-treatment results. | Dropouts: 0 Information obtained from abstract
Das, Ahuja, and Narainaswamy, 1979 | CrOv QS:2 (nr, db+, dnd) | N =20 Age: N/S (range: 20–48) 70% female Chron: N/S Migraine (Ad Hoc); hist. of Ms ≥ 1 yr; ≥ 2 Ms/mo in 3 mos before trial Rec: N/S | Placebo: n = 20* Clonidine: 25 μg, 2x/day; n = 20* Baseline data obtained before each of two 6- wk treatment periods; no washout; no follow- up Nothing on acute meds | HA frequency: Definition N/S HA intensity: Reported as a “severity index” from intensity ratings gathered on 3-point scale (1=mild; 2=moderate, inconvenient; 3=severe, incapacitating). Severity index calculated by multiplying no. of HAs/6 wks by intensity ratings | Results were reported only as group mean scores, and investigators did not clarify whether these scores were derived from one or both treatment periods. For HA frequency, the mean scores were 8.2 and 8.0 for pts taking clonidine or placebo, respectively. For HA intensity (severity index), the mean scores were 21.4 and 21.9 for pts taking clonidine or placebo, respectively. Investigators found no statistically significant difference between the two treatments for either HA frequency or intensity (p>0.05 for each outcome measure). Investigators did not provide results for the efficacy of each intervention before and after treatment. They did report, however, that “[a] statistically significant difference was found when the pre-treatment period was compared to the treatment period (clonidine and placebo) indicating that placebo or clonidine were almost equally effective in the prophylaxis of migraine.” | Dropouts: N/S Not clear how baseline data obtained or how results determined from that data Not clear whether data obtained from pts’ diaries or by other means
De Benedittis and Massei, 1986 | CrOv QS:4 (r, db+, dd) | N =40 Age: 41 (range: 18–59) 65% female Migraine (Ad Hoc); hist. ≥ 10 HAs/mo for ≥ 1 yr Excl: < 18 or > 60 yrs + HI < 10 (see “Outcomes” for definition) Chron: N/S (range: N/S) Rec: Pain research & treatment unit of university | Placebo: n = 31 * Oxitriptan (L-5-HTP): 400 mg/day orally; n = 31* 1-mo washout period; two 2-mo treatment periods; no washout between treatment periods; no follow-up Patients asked to discontinue or minimize use of analgesics and to avoid foods containing monoamines; no other acute meds mentioned | HA index: Termed “headache density” and calculated by multiplying HA frequency by HA intensity score HA frequency: Defined as “number of HA days” and termed “headache index” HA intensity: Rated by patient on 11-point scale; investigator grouped pt’s “1–3” ratings as “1,” the “4–6” ratings as “2,” and the “≥ 6” ratings as “3” | The between-group results were provided only on a figure from which it is difficult to determine precise results. However, investigators reported that there was no significant difference between the active drug and placebo for reducing HA index (no p-value given). For HA index, the overall mean score (SEM in parentheses) decreased from 43.8 (± 2.7) at baseline to 26.0 (± 2.9) after the first month and to 25.1 (± 3.2) after the second month following treatment with the active drug. The difference between the pre- and post-treatment mean scores was statistically significant for both reductions (p < 0.0001 for each comparison). Also for HA index, the overall mean score decreased from 43.8 (± 2.7) at baseline to 26.5 (± 2.9) after the first month and to 26.5 (± 3.3) after the second month following treatment with placebo. The difference between the pre- and post-treatment mean scores was statistically significant for both reductions (p < 0.0001 for each comparison). | Dropouts: 9, (23%), 1 due to AEs (placebo)
Dennerstein, Morse, Burrows, et al., 1988 | CrOv QS: 3 (r, db, dd) | N =22 Age: 40 100% female Migraine; regularly occurring attacks during the 7 days encompassing menstruation; typically of severe intensity and not relieved by minor analgesics Chron: N/S Rec: Referrals to menstrual disorders clinic | Placebo: n = 19* Estradiol (percutaneous gel, Oestrogel®): 1.5 mg estradiol in 2.5 g gel per application; applied to upper arms and body using a special graduated applicator; applied for 7 days per cycle, beginning at least 2 days before expected migraine; n = 19* Baseline period lasting 2 menstrual cycles; two 2-cycle treatment periods; no washout; 1-cycle follow-up (no treatment) Acute meds permitted | HA frequency: No. of days with migraine of moderate to severe intensity during 7 days encompassing menstruation | Estradiol was significantly better than placebo at reducing HA frequency during the 7 days encompassing menstruation (p<0.05). A total of 47 days with migraine were reported with estradiol, compared with 86 with placebo. | Dropouts: 3 (14%),1 due to AEs (estradiol); one other patient withdrew due to AEs after 2 mos of treatment with placebo and one mo with estradiol, but was included in the efficacy analysis Most patients also reported migraines at other times of the month “Nearly all” had tried preventive med before, but found it ineffective for their hormonally- triggered HAs
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | SPPG QS: 4 (r, db+, dd) | N = 143 Age: 35 74% female Migraine w/or w/o aura; ≥ 2-yr history; 2–8 attacks/mo in last 3 mos (and during baseline period); no migraine prophylactic meds in last 3 mos; patients with combination HA (migraine and TTH) excluded Chron: 17 yrs Rec: HA clinic out-patients | Placebo: n = 51 Flunarizine: 10 mg, 1x/day (at night); n = 50 4-wk baseline period (placebo); 20-wk treatment phase; no follow-up Use of acute meds permitted | Patients evaluated at approximately 1-mo intervals; following measures calculated and analyzed: HA index: Severity index times the duration index HA frequency: No. of attacks/mo Frequency index: No. of attacks divided by no. of days in evaluation period Severity index: Sum of severity of attacks divided by no. of days in evaluation period; severity of each attack rated on scale of 1–3 (mild-severe) Duration index: Sum of duration of attacks divided by no. of days in evaluation period | There was no significant difference between the two treatments for reduction in HA index from baseline to last visit (p=0.063). Mean change from baseline (± SD) was −2.083 (± 3.816) in the flunarizine group and −0.640 (± 3.900) in the placebo group. Flunarizine was significantly better than placebo at reducing HA frequency (p<0.05). In the flunarizine group, mean HA frequency was 4.2 at baseline and was reduced by an average of 2.3 attacks per month after five months of treatment; corresponding values in placebo group were 4.4 and 1.7 (no variance data reported). 20/50 patients in the flunarizine group (40%) reported a 50% or greater reduction in HA frequency or severity from baseline to final visit, compared to 17/51 patients in the placebo group (33%); the difference between the two treatments was not statistically significant (p=0.54). | Dropouts: 42 patients (29%) dropped out before completing 1 mo of active treatment and were thus excluded from the efficacy analysis; 5 patients treated with flunarizine and 3 treated with placebo withdrew due to AEs, but it is not clear whether they were among the 42 who failed to complete 1 mo of treatment None of the study participants had a history of drug treatment failure for migraine
Diamond and Medina, 1976 | CrOv QS: 3 (r, db, dd) | N = 83 Age: 38 (average) (range: 21–62) 81% female Common or classical migraine; frequency N/S Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 62* Propranolol: 80 mg (or up to 160 mg/day -- see below); n = 62* No baseline period described; two treatment periods at least 4 wks long – at the end of the first 4 wks of each period, pt could choose to stop the drug or continue for up to 6 or 8 wks; at the end of the second, fourth, or sixth wks of each period, pt could choose to double the amount of medication or placebo or to remain on the same dosage; no washout; no follow-up Analgesics, narcotics, or ergotamines permitted for acute migraine attacks, but not prophylactics | HA index: Defined as “total of HA units divided by number of days observed” HA frequency: Termed “HA units,” but not defined | Results were reported as “patients’ preference” for one intervention over the other one, and we could not analyze the results. | Dropouts: 21 (25%),7 due to AEs (propranolol 6, placebo 1) Not clear how data gathered
Diamond, Solomon, Freitag, et al., 1987 | SPPG QS: 4 (r, db+, dd) | N = 118 Age: N/S (range: 19–62) 81% female Classic and/or common migraine (Ad Hoc); history ≥ 2 yrs; ≥ 3 mod-severe HAs/mo; no daily HA or chronic cephalgia other than migraine Chron: N/S Rec: N/S | Placebo: n = 35 Fenoprofen 200 mg: 3x/day; n = 34 Fenoprofen 600 mg: 3x/day; n = 27 2-wk washout period for patients using prophylactic med; 4-wk baseline period (placebo); 12-wk treatment period; no follow- up Use of meds for acute attacks permitted, though not aspirin or other NSAIDs | HA index: (Sum of HA severity x duration for all HAs) ÷ no. of days in treatment period HA frequency: No. of HAs divided by no. of days in treatment period | For both HA index and HA frequency, investigators analyzed the number of patients with no improvement, <50% improvement, and >50% improvement compared with baseline values. For HA index, fenoprofen 600 mg, but not 200 mg, was significantly better than placebo (p<0.001, 600 vs. placebo; no p-value reported for 200 vs. placebo); there was no significant difference between the two doses of fenoprofen (no p-value reported). 16/27 patients (59%) taking fenoprofen 600 mg reported a > 50% improvement, as did 11/34 patients (32%) taking fenoprofen 200 mg and 11/35 patients (31%) taking placebo. Both doses of fenoprofen were significantly better than placebo for HA frequency (p<0.05 for 200 mg; p<0.005 for 600 mg); there was no significant difference between the two doses (no p-value reported). | Dropouts: 16 (14%), 11 due to AEs (4 600 mg, 3200 mg, 4 placebo); another 6 patients (5%) were excluded from the analysis of the data on HA index due to inadequate reporting
Ekbom, 1975 | CrOv QS: 3 (r, db, dd) | N = 33 Age: 41 (range: 17–58) 82% female Common or classical migraine; hist. ≥ 3 HAs/mo (most had more frequent HAs) Chron: N/S (range: N/S) Rec: N/S, but treated at neuro. clinic in Sweden | Placebo: n = 28* Alprenolol: 200 mg, 2x/day; n = 28* No baseline described; two 6-wk treatment periods; 1-wk washout between treatment periods (no meds); no follow-up Patients permitted to take their usual meds (all contained ergotamine) for acute migraine attacks | HA index: Calculated as the sum of HA frequency and intensity for each 3- wk period HA frequency: Not defined, but recorded daily by pts HA intensity: Rated on 3-point scale and recorded daily by pts | The average HA index per patient per wk was 4.0 (± 0.7) (SEM) after treatment with alprenolol and was 3.8 (± 0.7) after treatment with placebo. There were no significant differences between the active drug and placebo for reducing HA index (no p-value reported). No baseline scores were provided. Investigators did not report having analyzed the pre- to post-treatment results for statistical significance. | Dropouts: 5 (15%),1 due to AEs (alprenolol) Investigators provided an overall assessment of HA frequency based on number of HAs per patient
Ekbom and Lundberg, 1972 | SPPG QS: 3 (r, db, dd) | N = 30 Age: 34 (range: 19–56) 87% female Classic or common migraine (Ad Hoc); ≥ 4 attacks/mo Chron: N/S Rec: N/S | Placebo: n = 10 Pindolol 5 mg: 3x/day; n = 9 Pindolol 2.5 mg: 3x/day; n = 7 1-mo baseline period; 1-mo treatment period; no follow-up Patients permitted to use ergotamine compounds to treat acute attacks | HA index: Sum of severity scores; severity of each attack graded on scale of 1–3 HA frequency: No. of attacks/mo HA duration: Per attack, in hrs | Neither dose of pindolol significantly reduced HA index scores compared with baseline values (no p- values reported). In the placebo group, mean HA index scores were 18 during the baseline period and 14 during treatment; in the low-dose pindolol group, the corresponding figures were 21 and 21, respectively; and in the high-dose group, 20 and 16, respectively (no variance data reported). The authors speculated that the doses used may have been too small to have an effect. Similar results were reported for HA frequency and duration. | Dropouts: 4 (13%), all due to AEs (pindolol, dose N/S).
Ekbom and Zetterman, 1977 | CrOv QS: 2 (nr, db, dd) | N = 34 Age: 42 (range: 18–55) 77% female Classical or common migraine (Ad Hoc); ≥ 3 attacks/mo Chron: N/S Rec: Neuro dept | Placebo: n = 30* Oxprenolol: 80 mg, 3x/day; n = 30* No baseline period described; two 8-wk treatment periods; 1-wk washout (no medication); no follow-up Patients permitted to take their usual meds for acute attacks | HA index: No. of HA days times severity of attacks; severity of each attack graded on scale of 1–3 (mild, moderate, severe) HA frequency: No. of attacks | There was no significant difference between the two treatments for HA index. Mean HA index (± SEM) was 30.9 (± 3.7) during treatment with oxprenolol and 33.9 (± 3.8) during treatment with placebo. Similar results were reported for HA frequency. | Dropouts: 4 (12%), none due to AEs Low quality score (2); not randomized
Elkind, Webster, Herbertson, et al., 1989a | SPPG QS: 2 (nr, db, dd) | N = 37 Age: N/S (range: N/S) 84% female Chron: N/S Common or classical migraine; ≥ 3 days of Ms/mo when not taking prophylactic meds Rec: N/S | Placebo: n = 12 Guanfacine: 0.5 mg/day; n = 13 Guanfacine: 1.0 mg/day; n = 12 2-wk washout prior to 4-wk baseline; 12-wk treatment period followed by 2 wks of tapering; follow-up (length N/S) Nothing on acute meds | HA frequency: No. of migraine days/mo Frequency of HAs with nausea/vomiting: Defined as “migraines/mo with nausea/vomiting” | Results were reported only as one-sided p-values for comparisons of each active treatment with placebo. For HA frequency, guanfacine 1.0 mg was significantly better than placebo (p=0.005), whereas guanfacine 0.5 mg was not significantly different from placebo (p=0.62). For frequency of HAs with nausea/vomiting, guanfacine 1.0 mg was again significantly better than placebo (p=0.01), whereas guanfacine 0.5 mg was not significantly different from placebo (p=0.64). No within-group results were provided for comparisons of HA frequency or frequency of HAs with nausea/vomiting before and after treatment with each intervention. | Dropouts: 3 (8%), all due to AEs (treatment group N/S); data from these pts were included in efficacy analyses Results are from 1 site of 2-site study
Ferrari, Wilkinson, Hirt, et al., 1991 | SPPG QS: 4 (r, db+, dd) | Both studies N = 204 Common or classical migraine (Ad Hoc); hist. of migraine ≥ 1 yr; 2–10 HAs/mo in 2 mos prior to & during baseline Excl: Use of migraine prophylactic meds in 2 wks prior to baseline; complicated or ophthalmoplegic migraine; concurrent use of “drugs potentially influencing migraine” or “prophylactic non-drug treatments” Rec: N/S Study 1 N = 146 Age: 42 (range: 18–70) 75% female Chron: N/S (range: N/S) Study 2 N = 58 Age: 41 (range: 18- | Study 1 Placebo: n = 47 Tropisetron HCI (lCS 205–930): 25 mg/day; n = 43 Tropisetron HCI (ICS 205–930): 50 mg/day; n = 45 2-wk washout period from previous prophylactic migraine treatment; 1-mo baseline period of placebo treatment and observation; 3-mo treatment period; no follow-up Analgesic meds permitted; no mention of other acute migraine meds Study 2 Placebo: n = 17 Tropisetron HCI (lCS 205–930): 15 mg/day; n = 30 Same washout, baseline, and treatment periods as in Study 1 Analgesic meds permitted; no mention of other acute migraine meds | HA frequency: Defined as “no. of HAs/mo”; considered the “primary efficacy variable” by investigators HA index: Calculated as no. of HAs multiplied by HA intensity grade HA intensity: Rated daily on 3-point scale by pt | Study 1 Results were reported on graphs from which it was difficult to obtain precise numbers. Investigators reported that neither dose of tropisetron was significantly better than placebo at reducing HA frequency (p > 0.05, both cases). Investigators did not report having compared the two doses of tropisetron. From baseline to 3 mos, there was “virtually no change” in the mean proportional change in HA frequency for the group receiving tropisetron 50 mg. Over the same period, both the placebo and the tropisetron 25 mg groups reduced HA frequency, though not at a statistically significant level (p > 0.05, both cases). Investigators also reported results for “responders” and “partial responders” to treatment. Responders were pts who had achieved ≥ 50% reduction in both HA index and HA frequency from pre- to post- treatment. In Study 1, 20% (9/45), 35% (15/43), and 21% (10/47) of pts were responders to tropisetron 50 mg, Tropisetron 25 mg, and placebo, respectively. There were no significant differences between either active dose and placebo (p > 0.05, both cases). Partial responders were pts who had achieved ≥ 50% reduction in either HA index or HA frequency. Thirteen of 45 (29%),16/43 (37%), and 19/47 (40%) of pts were partial responders to tropisetron 50 mg, 25 mg, and placebo, respectively. Investigators did not report having compared these results for statistical significance. Study 2 Results were reported on graphs from which it was difficult to obtain precise numbers. Investigators reported that 15 mg/day of tropisetron was not significantly better than placebo at reducing HA frequency (p > 0.05). After 3 mos, the tropisetron 15 mg group reduced HA frequency significantly (p < 0.05). Over the same period, the placebo group had reduced HA frequency, but not at a statistically significant level (p > 0.05). Investigators also reported results for “responders” and “partial responders” to treatment. Responders were pts who had achieved ≥ 50% reduction in both HA index and HA frequency from pre- to post- treatment. In Study 2, 43% (13/30) and 23% (4/17) of pts were responders to tropisetron 15 mg and placebo, respectively. There was no significant difference between the active dose and placebo (p > 0.05). Partial responders were pts who had achieved ≥ 50% reduction in either HA index or HA frequency. Seventeen of 30 (57%) and 6/17 (35%) of pts were partial responders to tropisetron 15 mg and placebo, respectively. Investigators did not report having compared these results for statistical significance. | Dropouts: Study 1 -- 11 (8%), 7 due to AEs (4, 50 mg tropisetron; 2, 25 mg tropisetron; 1, placebo) Study 2-- 11 (19%),3 due to AEs (all from 15 mg tropisetron) Data are from 2 trials of a multicenter study, 1 in Belgium, France, and The Netherlands (Study 1), and 1 in the U.K. (Study 2) In 13 patients from Study 1, constipation led to reduction of dose by 0.5–1 capsule every other day; dose not reduced in Study 2
Fiorini, Sances, Martignoni, et al., 1991 | CrOv (analyzed as SPPG) QS: 3 (r, db, dd) | N = 20 Age: 33 100% female Perimenstrual migraine (not defined); normal menstrual cycles Chron: N/S (range: 2–15 yrs) Rec: N/S | Placebo: n =19* Dihydroergokryptine (DEK): 10 mg, 2x/day (half dose administered in first week); n = 19* 2-mo baseline period; 2-menstrual-cycle treatment period; no washout; no follow-up Nothing on acute meds | HA index: Not defined | Mean HA index scores were reported separately for the two treatment sequence groups. We analyzed the data from the first treatment period as if the trial were parallel-group. Among patients taking placebo during the first treatment period (n = 9), mean HA index scores (± SD) were reduced from 93.2 (± 31.1) at baseline to 60.8 (± 33.5). Among those taking DEK first (n = 10), scores were reduced from 84.4 (± ?) at baseline to 32.9 (± 26.7). Both reductions were statistically significant (p<0.01). We calculated an effect size based on post-treatment means only, since an anomalous SD (2.8) was reported for the pre-treatment mean in the DEK-first group. | Dropouts: 1 (5%), not due to AEs Abstract reporting limited results
Formisano, Falaschi, Cerbo, et al., 1991 | SPPG QS: 2 (r, ndb, dd) | N = 22 Age: 39 53% female Migraine w/ or w/o aura (IHS); no prophylactic med in past 3 mos Chron: 20 yrs Rec: N/S | Propranolol: 40 mg, 3x/day; n = 8 Nimodipine: 40 mg, 3x/day; n = 11 1-mo baseline period (placebo); 4-mo treatment period; 1-mo washout period Acute meds permitted | HA frequency: No. of attacks/mo | Both treatments significantly reduced HA frequency from basal levels (at time of admission to trial) to the end of the 4th treatment month (p<0.05 for both drugs). Mean basal frequencies (± SD) were 4.0 (± 1.2) in the nimodipine group and 5.0 (± 2.0) in the propranolol group. During the fourth month of treatment, these mean frequencies were reduced to 2.9 (± 1.7) in the nimodipine group and 2.6 (± 1.5) in the propranolol group. There was no significant difference between the two treatments for this outcome (p-value not reported). | Dropouts: 3 (14%), all due to AEs (2 propranolol, 1 nimodipine) Not clear how “basal” frequency established
Forssman, Henriksson, Johannsson, et al., 1976 | CrOv QS: 4 (r, db+, dd) | N =40 Age: 37 (range: 17–51) 88% female Common or classical migraine; ≥ 3 HAs/mo; “serious and prolonged HAs” Excl: Hist. of earlier treatment with prophylactics Chron: 19 (range: 2–40) Rec: N/S | Placebo: n = 32* Propranolol: 20 mg (½ tab), 3x/day for 7 days; then 40 mg, 3x/day for 7 days; then 80 mg, 3x/day; n = 32* 10-wk baseline (no active drug or placebo); two 12-wk treatment periods; no washout, but first 2 wks of each treatment period excluded from analysis; no follow-up Acute migraine meds permitted (analgesics and ergotamines), but not prophylactics | HA index: Calculated from HA intensity (rated on 3-point scale) and duration HA frequency: Not defined, but recorded daily by pts | HA index was reduced from a mean score (and SD) of 5.14 (± 2.98) at baseline to 4.77 (± 3.45) and 3.00 (± 2.81) after treatment with placebo or propranolol, respectively. Propranolol was significantly better than placebo at reducing this outcome (p < 0.01). Investigators did not report pre- to post-treatment results. | Dropouts: 8 (20%),4 due to AEs (propranolol, 2; (placebo, 2)
Forssman, Henriksson, and Kihlstrand, 1972 | CrOv QS: 4 (r, db+, dd) | N = 22 Age: 40 (range: 16–56) 53% female Classic or common migraine (AdHoc); ≥ 2–3 HAs/mo; one patient had cluster HA Chron: N/S Rec: N/S | Methysergide: 4–6 mg/day (dose adjusted over first 10 days of treatment period); n = 17* Pizotifen: 2–3 mg/day (dose adjusted over first 10 days of treatment period); n = 17* 6-wk baseline period (no prophylactic med); two 10-wk treatment periods; no washout, but only last 6 wks of each treatment period analyzed; no follow-up Acute meds permitted | HA index: Mean HA index per week, where HA index = frequency times severity HA frequency: Mean no. of attacks per week HA severity: Mean severity per attack per week; each attack graded on scale of 1–3 (slight, moderate, severe) HA duration: Mean duration per attack (hrs) | Both pizotifen and methysergide significantly reduced HA index scores in comparison with the baseline period (p<0.01 for both comparisons); there was no significant difference between the two treatments for this outcome (no p-value reported). Mean HA index scores were 3.5 during the baseline period, 2.1 with pizotifen, and 1.8 with methysergide (no variance data reported). Similar results were reported for HA frequency. Neither treatment significantly reduced HA severity or duration compared with baseline. | Dropouts: 5 (23%), 1 due to AEs (experienced with both drugs) One patient included in the efficacy analysis had cluster HA, not migraine
Forssman, Lindblad, and Zbornikova, 1983 | CrOv QS: 4 (r, db+, dd) | N =24 Age: 40 (range: 17–55) 80% female Migraine (Ad Hoc); frequency N/S Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 20* Atenolol: 100 mg, 1x/day; n = 20* 2-mo baseline period; two 3-mo treatment periods; 2-wk washout period between treatment periods; no follow-up period Analgesics and ergotamines, but not prophylactics, permitted for acute migraine attacks | HA index: Calculated as a ratio of “integrated HA” (which combined HA intensity & duration) over HA frequency HA frequency: Defined as “number of HA attacks” and recorded by pts on forms HA intensity: Rated by pt on 3-point scale and recorded on forms | HA frequency was reduced to mean values per day of 0.17 and 0.23 after treatment with atenolol or placebo, respectively. No baseline mean scores were reported. Investigators did not report having analyzed the results for statistical significance. | Dropouts: 4 pts (17%) withdrew, 1 due to AEs (Atenolol), but were included in efficacy analyses
Frediani, Grazzi, Zanotti, et al., 1991 | CrOv (analyzed as SPPG) QS: 4 (r, db+, dd) | N = 30 Age: 34 (range: 20–47) 77% female Migraine w/o aura (IHS) Chron: N/S Rec: N/S | DHE (timed-release): 5 mg, 2x/day; n = 27* (completed both periods); n = N/S (took DHE during first period) Dihydroergokryptine (DEK): 10 mg, 2x/day (half dose administered for first 15 days); n =27* (completed both periods); n = N/S (took DEK during first period) 1-mo baseline period (non-ergot analgesics only); two 4-mo treatment periods; 2-mo washout (non-ergot analgesics only); no follow-up Acute meds permitted | HA index: 1D_1_ + 2D_2_ + 3D_3_, where D_1_ = total no. of hrs/mo with HA of intensity 1, etc. HA frequency: No. of HA days/mo | Investigators found a significant carry-over effect (p<0.05) and so analyzed the first-period data only. DEK significantly reduced HA index (by 35%) in comparison with baseline values (p<0.05); the reduction produced by DHE (27%) was not statistically significant (no p-value reported). The two treatments were not directly compared for this outcome. DEK reduced HA frequency by 31 % compared to baseline, DHE by 23% (no p-values or other measures of statistical significance reported). | Dropouts:, 4 due to AEs (3 DHE, 1 DEK)
Freitag and Diamond, 1984 | SPPG QS: 4 (r, db+, dd) | N = 32 Age: 36 (range: 23–57) 81% female Common or classical migraine (AdHoc); frequency N/S Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 8 Nadolol: Nadolol treatment group comprised pts from 3 groups who had taken 80, 160, and 240 mg of nadolol; had achieved similar results; and had been combined into one group; n = 24 2-mo baseline (placebo); one 3-mo treatment period; no follow-up Patients permitted to take usual acute migraine meds as long as dosages remained constant; no prophylactics; no nonpharmacological treatments (e.g., biofeedback) | HA index: Termed “intensity index” and defined as “sum of intensity units, divided by number of days observed”; “intensity units” derived from HA intensity score (rated on 4-point scale) multiplied by number of HAs with relevant intensity score HA frequency: Termed “frequency index” and defined as “number of distinct HAs (bracketed by 24-hr HA-free periods), divided by the number of days in observation period” | Seven of 22 patients (32%) treated with nadolol improved (achieved ≥ 50% reduction in HA index from pre- to post-treatment), but none of 8 patients improved after treatment with placebo. The difference between the two treatments was not significant (p = 0.073). Authors did not report having analyzed the pre- to post-treatment differences for statistical significance. | Dropouts: 1 pt (3%) was withdrawn due to AEs (nadolol) but was included in efficacy analyses
Frenken and Nuijten, 1984 | SPPG QS: 4 (r, db+, dd) | N = 35 Age: N/S (range: 20–51) 83% female Common or classic migraine (AdHoc); HAs throbbing or pulsating in character and severe or unbearable in intensity; ≥ 1 attack/mo; no cluster HA Chron: 14 yrs (median) (range: 1–35) Rec: Family practice(s?) | Placebo: n =18 Flunarizine: 10 mg, 1x/day; n = 17 All anti-migraine medication withdrawn prior to treatment period (no clear baseline period described); 12-wk treatment period; no follow-up Patients permitted to take their usual acute meds | HA frequency: Mean no. of attacks/mo; % reduction in mean no. of attacks/mo from baseline | After the first month of treatment, the percentage reduction in HA frequency (vis-à-vis baseline) was significantly higher in the flunarizine group than in the placebo group (p=0.029). Mean monthly HA frequency in the flunarizine group was 3.3 at baseline, 2.1 during treatment month 1, 1.5 during treatment month 2, and 0.8 during treatment month 3 (no variance data reported). Corresponding figures for the placebo group were 3.8, 3.4, 3.4, and 2.6, respectively (no variance data reported). | Dropouts: 0 15/35 patients had been treated prophylactically before, 10 of them unsuccessfully Not clear how baseline frequency established (baseline period not clearly described)
Gawel, 1987 | CrOv QS: 3 (r, db, dd) | N = 60 Age: N/S % female N/S Classical and common migraine Chron: N/S Rec: N/S | Pizotifen: 3 mg, 1x/day (bedtime); n =54* (crossover); n = 29 (first period, parallel- group) Nimodipine: 40 mg, 3x/day; n = 54* (crossover); n = 25 (first period, parallel-group) 1-mo baseline period; two 3-mo treatment periods; 1-mo washout; no follow-up Nothing on acute meds | HA frequency: No. of attacks/mo | Investigators observed a dramatic rebound in HA frequency during the washout period among those patients treated first with pizotifen. This rebound effect made it difficult to interpret the crossover results, so we analyzed the first period data as if it were from a parallel-group trial (as did the investigators). Mean HA frequency (± SD) in the pizotifen group went from 7.55 (± 5.94) at baseline to 6.65 (± 6.34) after the first treatment period (p<0.05); the corresponding numbers in the nimodipine group were 7.56 (± 5.79) and 6.04 (± 4.68), respectively (p>0.05). The investigators’ analysis found no significant difference between the two treatments for this outcome (no p-value reported). | Dropouts: 6 (10%); unclear how many (if any) of these were due to AEs Abstract reporting limited results
Gawel, Kreeft, Nelson, et al., 1992 | SPPG QS: 4 (r, db+, dd) | N = 89 Age: 36 90% female Migraine w/ or w/o aura (World Fed of Neurology); 2–8 attacks/mo; no prophylactic med in wk preceding trial; no propranolol in previous 6 mos Chron: > 16 yrs Rec: N/S | Propranolol: Dose titrated over 8 days to max of 80 mg, 2x/day; n = 45 Flunarizine: 10 mg, 1x/day (dose reduced by half for first six days); n = 44 1-mo baseline period (placebo); 4-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of days with migraine; no. of attacks HA severity: Each attack graded on scale of 1–10 (mild-excruciating) HA duration: In hrs | Both treatments significantly reduced the mean no. of days with migraine per month compared with baseline (p<0.001 for both interventions). The percentage reduction at the end of treatment was greater with flunarizine (45%) than with propranolol (29%), but the difference between the two groups did not reach statistical significance (no p-value reported). Both treatments also significantly reduced the mean no. of migraine attacks per month (p<0.0001). Flunarizine was significantly better than propranolol during months 1 and 4 (p<0.01 for both timepoints). Percentage reduction in attack frequency at the end of treatment was 49% for flunarizine and 25% for propranolol. Mean values for these two HA frequency outcomes were reported in graphic form only and could not be reliably read off the graphs. Neither treatment significantly affected HA severity. Mean difference scores (baseline to last evaluable) (± SD) for HA severity were −0.02 (± 2.68) in the flunarizine group and −0.20 (± 2.95) in the propranolol group (no p-values reported). Neither treatment significantly affected HA duration. | Dropouts: 13 patients (15%) withdrew before completing trial, 8 due to AEs (5 propranolol, 3 flunarizine); all 13 completed at least 1 mo of treatment and were included in the efficacy analysis Patients who had been unresponsive to more than two prophylactic meds were excluded
Gelmers, 1983 | SPPG QS: 4 (r, db+, dd) | N =60 Age: 30 62% female Classic or common migraine (Ad Hoc); ≥ 2–3 HAs/mo Chron: 10 yrs Rec: Out-patients at neuro clinic | Placebo: n = 22 Nimodipine: 40 mg, 3x/day; n = 28 2-wk baseline period (no prophylactic meds); 3-mo treatment period; no follow-up Acute meds permitted | Patients graded each HA as “disabling” (requiring bed rest), “severe” (≥50% limitation of activity), or “moderate to mild” (<50% limitation of activity); following index calculated using only attacks of severe or disabling intensity: Weighted migraine index (M): M = 2(FxD)_disabling_ + 1(FxD)_severe_, where F = frequency (no. of HAs/mo) and D = mean duration (hrs) | In the nimodipine group, the mean weighted migraine index (± SD) was reduced from 56 (± 25) pre- treatment to 19 (± 28) after 3 mos; the corresponding scores in the placebo group were 72 (± 39) and 53 (± 32), respectively. This represents a significantly greater percentage reduction in the nimodipine group (66%) than in the placebo group (26%) (p<0.01). | Dropouts: 10 (17%), all due to lack of therapeutic effect (2 nimodipine, 8 placebo)
Gerber, Diener, Scholz, et al., 1991 | SPPG QS: 3 (r, db, dd) | N =58 Age: 42 (range: 18–65) 81% female Migraine w/ or w/o aura (IHS); ≥ 2 attacks/mo in previous mo Chron: 21 yrs (range: 1–55) Rec: N/S | Propranolol: 80 mg/day (low dose); 160 mg/day (high dose); 120,80, and 40 mg/day (reduced dosages); n = 19 (randomized; unclear how many patients included in the efficacy analysis) Metoprolol: 100 mg/day (low dose); 200 mg/day (high dose); 150, 100, and 50 mg/day (reduced dosages); n =22 (randomized; unclear how many patients included in the efficacy analysis) Nifedipine: 20 mg/day (low dose); 40 mg/day (high dose); 30, 20, and 10 mg/day (reduced dosages); n = 17 (randomized; unclear how many patients included in the efficacy analysis) 2-mo baseline period; 6-mo treatment period, divided as follows: 1 mo at low dose, 2 mos at high dose, 3 mos of successive reductions in dose; 2-mo follow-up after end of treatment Patients permitted to use their usual acute meds | HA frequency: No. of days with migraine HA severity: Graded 3x/day on a visual analog scale (not described) HA duration: Measured for each attack (in hrs) | A time-series analysis (ARIMA) performed by the investigators found that, during the high-dose phase of the trial (treatment mos 4–6), a statistically significant (z≤ −1.96) reduction in HA frequency, vis-à-vis baseline, was achieved by 32.0% of patients taking propranolol, 54.4% taking metoprolol, and 7.7% taking nifedipine (number of patients analyzed in each group could not be established). Conventional ANOVA analysis showed significant differences among the three treatments at the 5% level for HA frequency. The Scheffé test revealed significant differences between metoprolol and nifedipine, but not between metoprolol and propranolol or between propranolol and nifedipine. The same combination of ANOVA and Scheffé analyses showed that metoprolol was significantly (p<0.05) better than nifedipine and propranolol for HA severity; there was no significant difference between propranolol and nifedipine for this outcome. | Dropouts: 20 patients (34%) did not complete entire treatment period; 7 withdrew after baseline period; 1 during high-dose period; 12 after high-dose period; not clear which of these patients (if any) were included in the efficacy analysis; not clear how many withdrew due to AEs
Gerber, Schellenberg, Thorn, et al., 1995 | SPPG QS: 3 (r, db, dd) | N = 84 Age: 41 90% female Migraine w/or w/o aura (IHS); ≥ 2-yr history; ≥ 2 attacks/mo for past 3 mos Chron: 20 yrs Rec: N/S | Propranolol: 120 mg/day for 8wks; then 160 mg/day for 8 wks; n =34 Cyclandelate: 1200 mg/day for 8 wks, then 1600 mg/day for 8 wks; n = 28 4-wk baseline period (HA recording); followed by 4-wk placebo period; followed by two 8-wk treatment periods. one low-dose, one high-dose Patients permitted to use their usual acute meds | HA frequency: No. of days per month with reduced working ability due to migraine HA severity: Mean monthly severity score; severity of HA graded 3x/day using a visual analog scale (not described) HA duration: Migraine duration/mo | A time-series (ARIMA) analysis showed that, during the last 4 wks of the high-dose period, 12/28 patients taking cyclandelate (43%) had a statistically significant reduction of HA frequency vis-à-vis baseline, as did 11/34 patients taking propranolol (32%). There was no significant difference between the two treatments for this outcome (no p-value reported). More conventional analysis showed that, during the last 4 wks of the high-dose period, 20/28 (71%) patients taking cyclandelate and 18/34 (53%) patients taking propranolol reported a 50% or greater reduction in HA frequency from baseline. There was no significant difference between the two groups (no p- value reported). Both treatments significantly reduced mean HA frequency during the last 4 wks of the high-dose period compared to baseline values (p<0.001 for both treatments). In the cyclandelate group, mean HA frequency was reduced over this period of time from 6.3 to 2.7; the corresponding figures in the propranolol group were 5.7 and 3.1 (no variance data reported for either group). There was no significant difference between the two groups (no p-value reported). Similar results were reported for HA severity and HA duration. | Dropouts: 22 (26%), "most" due to AEs or lack of motivation None of the patients had used prophylactic meds before
Gomersall and Stuart, 1973 | CrOv QS: 3 (r, db, dd) | N =26 Age: N/S 75% female Classical, common, or hemiplegic migraine (Ad Hoc); > 2 attacks/mo; 50% of attacks of ≥ moderate severity Chron: N/S Rec: Volunteers recruited through British Migraine Assoc and press ads | Placebo: n = 20* Amitriptyline: 30 mg/day for two wks (preferably at night); increased to 60 mg/day if no therapeutic effect observed after two wks; if AEs occurred, dose could be reduced; n = 20* 26-wk baseline period; two 27-wk treatment periods; no washout, but data from first wk of each treatment period excluded to minimize carry-over effects Patients allowed to take their usual acute meds, but asked not to change these during trial | HA frequency: No. of attacks in each trial period; no. of patients improving by 50% or more on amitriptyline vs. placebo | HA frequency: The total number of attacks experienced in 26 wks on amitriptyline (207) was significantly lower than the total number experienced on placebo (356) (p<0.001). Nine of 20 patients (45%) reported a 50% or more reduction in the number of HAs on amitriptyline, compared with placebo. Four of the same 20 patients (20%) had more frequent attacks on amitriptyline than on placebo, but the degree of their improvement on placebo was not quantified. | Droupouts: 6 (23%), 1 due to AEs (placebo)
Grotemeyer, Scharafinski, Schlake, et al., 1990 | CrOv QS: 3 (nr, db+, dd) | N = 28 Age: 31 82% female Common migraine (Ad Hoc); history > 3 yrs; 4–8 attacks/mo; no attacks lasting> 24 hrs Chron: 10 yrs Rec: N/S | Metoprolol: 200 mg, 1x/day; n = 21* Aspirin: 500 mg, 3x/day; n = 21* 2-mo baseline period (no prophylactic treatment); two 3-mo treatment periods; no washout, but first month of each treatment period excluded from the analysis to reduce crossover effects Acetaminophen 500 mg + metoclopramide 10 mg allowed for acute attacks | HA frequency: Mean percentage reduction from baseline to months 2–3; number of patients reporting a < 25%, 25%–50%, and >50% reduction in frequency from baseline to months 2–3 HA intensity: Mean HA intensity; each attack graded on scale of 1–3 (HA alone; HA with reduced activities; no activity possible/bed rest required) | Both treatments significantly reduced HA frequency compared with the run-in period. Mean % reduction (± SD) with aspirin was 26% ± 22% (p<0.001); with metoprolol, it was 50% ± 18% (p<0.00005). When the two treatments were directly compared for this outcome, metoprolol was significantly better than aspirin (p<0.01). 3/21 patients (14%) on aspirin, and 14/21 patients (67%) on metoprolol reported a greater than 50% reduction in HA frequency during the treatment period compared with baseline. Investigators did not analyze this result. Mean HA intensity (± SD) was 2 ± 0.5 during the baseline period; 1.4 ± 0.5 during treatment with aspirin, and 1.6 ± 0.7 during treatment with metoprolol. Study investigators did not analyze this result. | Dropouts: 7 (25%), all due to AEs (2 metoprolol, 5 aspirin) Not randomized
Grotemeyer, Schlake, and Husstedt, 1989 | SPPG QS: 3 (r, db, dd) | N = 34 Age: 33 56% female Migraine w/o aura; low blood pressure (avg systolic 106) Chron: N/S Rec: N/S | Flunarizine: 5 mg, 1x/day; n = ? Etilefrine pivalate: 20 mg, 1x/day; n = ? 2-mo baseline period; 2 mos of treatment with DHE (5 mg/day); then treatment period of 3 mos comparing above two interventions; no follow-up Nothing on acute meds | HA frequency: Not defined | Both interventions significantly reduced HA frequency in comparison to baseline values. The average percentage reduction in the flunarizine group was 42% (± 22%) (p<0.008); in the etilefrine pivalate group, it was 56% (± 23%) (p<0.0002). The two treatments were not directly compared. | Dropouts: 5 (15%), 1 due to AEs (flunarizine) Abstract reporting limited results Population restricted to patients with low blood pressure
Grotemeyer, Schlake, Husstedt, et al., 1987 | CrOv QS: 3 (r, db, dd) | N = 28 Age: 39 79% female Classic or common migraine; vomiting at the beginning of attacks Chron: N/S Rec: N/S | Metoprolol: 200 mg/day (dosing schedule not described); n = 24* Flunarizine: 10 mg/day (dosing schedule not described); n = 24* 2-mo baseline period (no prophylactic med); two 3-mo treatment periods; no washout; no follow-up Nothing on acute meds | HA frequency: Not defined | The mean percentage reduction in HA frequency vis-à-vis baseline was 53% with metoprolol and 56% with flunarizine. Frequency was reduced by 50% or more in 50% of patients on metoprolol (12/24) and 29% of patients on flunarizine (7/24). No mean frequency scores and no p-values were reported. | Dropouts: 4 (14%),2 due to AEs (both metoprolol) Abstract reporting limited results
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | CrOv QS: 3 (r, db, dd) | N = 33 Age: 33 (range: 19–48) 85% female Common or classic migraine (Ad Hoc); ≥ 2 HAs/mo during baseline period; no prophylactic med during baseline period Chron: 14 yrs (range: 1–36) Rec: Patients referred to neuro dept | Placebo: n = 29* Nimodipine: 30 mg, 4x/day; n = 29* 4-mo baseline period to establish eligibility (no baseline data used to evaluate efficacy); two 8-wk treatment periods; no washout, but investigators found no carry-over effect; no follow-up Patients permitted to continue taking their usual acute meds | HA index: Sum of severity scores for all HAs experienced during treatment period; severity of each attack graded on scale of 1–3 (light, severe, very severe) HA frequency: No. of attacks per treatment period HA duration: Mean HA duration (min) | HA index was significantly lower with nimodipine than with placebo (p=0.003). Mean HA index scores were 10.3 (range 1–34) with nimodipine and 13.7 (range 4–39) with placebo. Similar results were reported for HA frequency. Nimodipine did not significantly reduce HA duration in comparison with placebo (p=0.127). | Dropouts: 4 (12%), none due to AEs 20 patients had had prophylactic therapy before
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | CrOv QS: 4 (r, db+, dd) | N = 50 Age: 38 (range: 16–64) 79% female Common or classic migraine (Ad Hoc) Chron: 18 yrs (range: 0.33–54) Rec: Out-patient neuro dept | Pizotifen: 0.5 mg, 3x/day; n = 43* Nimodipine: 40 mg, 3x/day; n = 43* 1-mo baseline period (placebo); two 3-mo treatment periods; 1-mo washout (placebo); no follow-up Patients allowed to take their usual acute meds | HA frequency: No. of attacks/mo; no. of days with HA/mo HA intensity: Each attack graded on scale of 1–3 (mild, moderate, severe); outcome measure analyzed not described HA duration: Duration of attack (in hrs) | Both treatments significantly reduced HA frequency in comparison with baseline values. The mean number of attacks per month (± SD) was 6.2 (± 3.3) at baseline; during the third month of treatment with nimodipine, this number was reduced to 2.3 (± 2.9); with pizotifen, it was reduced to 2.6 (± 2.4) (p<0.001 for both comparisons with baseline). There was no significant difference between the two treatments for this outcome (no p-value reported). Very similar results were reported for the mean number of days with HA per month. There was no significant difference between the two drugs for HA intensity (no results and no p-value reported). HA duration was reduced to a small degree by both drugs. There was no significant difference between them in this respect (no p-value reported). | Dropouts: 7 (14%), none due to AEs
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | CrOv (analyzed as SPPG) QS: 2 (nr, db, dd) | N =48 Age: 37 (range: 18–54) 81 % female Classic or common migraine (Ad Hoc); patients with other types of HA excluded Chron: 19 Rec: N/S | Propranolol (long-acting), 160 mg/day: Taken as a single dose; n = 21 Propranolol (long-acting), 80 mg/day: Taken as a single dose; n = 21 4-wk baseline period (placebo); two 12-wk treatment periods; 4-wk washout (placebo); no follow-up Patients permitted to take their usual meds for acute attacks | HA frequency: No. of attacks; no. of HA days | Because HA frequency (both no. of attacks and no. of HA days) was significantly lower (p<0.001 for both outcomes) during the washout period than during the baseline period, investigators analyzed the results from the first period as if the trial were parallel-group. We followed the same procedure. The mean number of HA days (± SD) was reduced in the 160-mg group from 5.4 (± 2.9) during the baseline period to 4.4 (± 4.4) during the first treatment period; the corresponding numbers in the 80-mg group were 6.2 (± 2.7) and 5.2 (± 4.2), respectively. There was no significant difference between the two doses for this outcome (no p-value reported). A reduction of 50% or more in the number of HA attacks was reported by 17/21 patients (81%) in the 160-mg group and by 18/21 (86%) in the 80-mg group. | Dropouts: 6 (13%),1 due to AEs (dose N/S) Low quality score (2); not randomized
Hering and Kuritzky, 1992 | CrOv QS: 4 (r, db+, dd) | N = 32 Age: 34 (range: 18–54) 79% female Classical or common migraine (Ad Hoc); history ≥ 2 yrs; ≥ 4 attacks/mo Chron: 14 yrs Rec: HA clinic | Placebo: n = 29* Sodium valproate: 400 mg, 2x/day; n = 29* 2-wk baseline period (no prophylactic med); two 8-wk treatment periods; no washout; no follow-up Patients permitted to take their usual meds for acute attacks | HA frequency: No. of attacks per 8-wk treatment period HA severity: Each HA graded on scale of 1–3 (mild, moderate, severe); an "overall severity index" was calculated, but this index was not defined HA duration: Total duration of attacks (hrs) per treatment period | Sodium valproate was significantly better than placebo at reducing HA frequency (p<0.001). Mean HA frequency (± SD) per 8 wks was 8.826 (± 6.066) with sodium valproate and 15.586 (± 8.330) with placebo. Sodium valproate was also significantly better than placebo for HA severity (p<0.005) and duration (p=0.002). | Dropouts: 3 (9%), all due to AEs (1 sodium valproate, 2 placebo) Nothing on carry-over effect
Herrmann, Horowski, Dannehl, et al., 1977 | SPPG QS: 4 (r, db+, dd) | N = 253 Age: N/S 73% female Migraine; ≥ 2 severe attacks/mo Chron: N/S Rec: N/S | Methysergide: 2 mg, 3x/day (gradual increase to full dose over first 4 days); n = 53 Lisuride: 25 mcg, 3x/day (gradual increase to full dose over first 4 days); n = 72 No baseline period described; single 3-mo treatment period; no follow-up Individually preferred meds permitted for acute attacks | HA frequency: No. of attacks/mo; percentage of patients with < 2, 3–6, 7–10, and > 10 attacks/mo; no. of patients with ≥ 50% reduction in no. of attacks/mo HA severity: Percentage of attacks graded as "severe" (scale used not described) HA duration: Percentage of attacks lasting more than 3 hrs | HA frequency: 53% of patients in the lisuride group (38/72) experienced a reduction of 50% or more in the number of attacks/mo, as did 51 % of patients (27/53) in the methysergide group. Investigators did not analyze this outcome. There were no significant differences between lisuride and methysergide for HA severity or duration. | Dropouts: 128 (51%), 70 due to AEs (22 lisuride, 48 methysergide) High dropout rate (51 %) Not clear how baseline values established
Herrmann, Krištof, and Sastre y Hernandez, 1978 | SPPG QS: 3 (r, db, dd) | N = 240 Age: N/S (range: N/S) % female N/S Migraine; > 2 HAs/mo Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 111 Lisuride: Dose gradually increased during first wk of trial until it was 0.075 mg/day; n =103 No baseline period described; one 6-mo treatment period; no follow-up Analgesics permitted during trial | HA frequency: Defined as "no. of HAs/mo"; recorded daily by pts and also assessed by physician supervising trial HA intensity: Definition N/S, but recorded daily by pt | "Success" was defined as a reduction to ≤ 2 HAs/mo and also as a decrease in HA frequency/mo of > 50% compared with baseline frequency. Based on the patients' recordings, HA frequency was reduced to ≤ 2 HAs/mo after 1 month of treatment with lisuride in 12.1% of patients (12/103) and in 3.6% of patients (4/111) treated with placebo. After 6 months, 37.4% of patients (38/103) treated with lisuride and 25.5% of patients (28/111) treated with placebo reduced HA frequency to ≤ 2 HAs/mo. Investigators reported that lisuride was significantly better than placebo at reducing HA frequency (p = 0.05). | Dropouts: 26 (11 %) 2 due to AEs (lisuride) Some pts withdrawn from trial because of "insufficient efficacy" Trial was multi-center study Baseline data estimated post hoc by patients
Hesse, Møgel-vang, and Simonsen, 1994 | SPPG QS: 2 (r, ndb, dd) | N = 85 Age: 45 (range: 25–70) 84% female Migraine w/or w/o aura (IHS); history ≥ 2 yrs; 2–6 attacks/mo; able to distinguish migraine from TIH Chron: 23.4 yrs (range: 2–55) Rec: Newspaper ads or referred by GP; Denmark | Metoprolol + sham acupuncture (metoprolol 100 mg/day + superficial touching of myofascial trigger points in neck region with broad end of needle); n =39 Placebo tablets + acupuncture (dry needling of myofascial trigger points in neck region; number of trigger points needled per treatment, interval between treatments, and total number of treatments determined individually by therapist): n = 38 4-wk baseline period, followed by 17-wk treatment period; no follow-up Nontrial preventive med and nontrial physical treatments not permitted; symptomatic med OK | HA frequency (medians compared) Global rating of attack (scored for each HA on scale of 1–3: mild, moderate, severe; took into account severity, duration, and associated symptoms; medians compared) HA duration (medians compared) | Both treatment groups exhibited significant reductions in median HA frequency over the course of the trial (p<0.01). There was no significant difference between the two treatments (p>0.20). Metoprolol was significantly better than acupuncture for median global rating of attack (p<0.05). There was no significant difference between the two treatments for median HA duration (p>0.10). Adverse events (AEs): 14/39 patients (36%) taking metoprolol reported AEs on open questioning, compared to 3/38 (8%) receiving acupuncture. | Dropouts: 8 (9%) Nonparametric statistical analysis performed by investigators
Holroyd, France, Cordingley, et al., 1995 | Matched pairs QS: 2 (r, ndb, dd) | N = 33 Age: 31.7 (range: 16–52) 79% female Diagnosis of migraine (IHS) from 3 sources; ≥ 1 attack/mo; history ≥ 1 yr; no prophylactic meds for ≥ 6 mo bef. treatment Chron: 15.2 (range: 1–47) Rec: Univ. research clinic; U.S. | Relax. + thermal BF: n = 14; two sessions (time N/S) 4 wks apart, followed by a third session + two telephone consultations (tot.: 12 wks) Relax. + thermal BF + propranolol Hcl: n = 13; same treatment design/schedule as for above therapy, plus 60, 120, or 180 mg of propranolol HCL daily (dose increased as tolerated); at 1 mo, max. tolerated dose was determined, then continued for 2 mo Home practice: Both groups, with tapes, manuals, & equipment (time N/S) | HA index: Av. daily HA activity, comprising HA intensity, duration, & frequency. Calculated as sum of four daily recordings averaged over ea. wk (range: 0–40) HA intensity recorded 4 x/day on 11-point scale Both groups monitored HAs daily by diary for 4 & 12 wks for pretreat. & treatment, respectively; the percentage change in HA index was assessed by physician at end of treatment. | Authors reported that pts who received relax. + thermal BF + propranolol decreased HA index significantly better than did pts who received relax. + thermal BF alone (p < 0.05). The relax. + thermal BF + propranolol group reduced HA index significantly from pre- to posttreat. (p < 0.05); the relax. + thermal BF also reduced HA index levels over this period, but not at a statistically significant level (p < 0.10). At posttreat., 92% of pts (12/13) who received the combined treatment and 57% of pts (8/14) who received relax. + thermal BF alone showed at least a 50% reduction in HA index. There was a statistically significant difference between the two proportions (p < 0.05). | Dropouts: 6 Dropouts were replaced in this matched-pair study.
Hübbe, 1973 | CrOv QS: 4 (r, db+, dd) | N = 43 Age: 35 (range: 18–60) 70% female Migraine; attacks on ≥ 4 days in previous 2 mos Chron: 18 yrs (range: 1–50) Rec: Out-patient neuro clinic | Prochlorperazine: 5 mg, 3x/day; n = 40* Pizotifen: 1 mg, 3x/day; n = 40* No baseline period described; two 8-wk treatment periods; no washout (though first week of each treatment period omitted from efficacy analysis to minimize carry-over effect); no follow-up Acute meds permitted | HA frequency: Total no. of attacks; total no. of attacks during which patient unable to work HA duration: Not defined; measured only for attacks lasting> 12 hrs | HA frequency: The total number of attacks in the last 7 wks of the treatment period was lower with pizotifen than with prochlorperazine (322 vs. 355), but the difference between the two treatments was not significant (no p-value reported). There was also no significant difference between the two treatments in the number of attacks during which patients were unable to work (pizotifen, 191; prochlorperazine, 192; no p-value reported). There was no significant difference between the two treatments for HA duration. | Dropouts: 3 (7%), none due to AEs
Hudgson, Foster, and Newell, 1967 | CrOv QS: 3 (r+, db-, dd) | N = 53 Age: N/S % female N/S "Typical" migraine (not defined); frequent severe attacks, requiring prophylactic treatment at sometime in the past Ghron: N/S Rec: N/S | Methysergide: 1 mg, 3x/day; n = 35* Flumedroxone (Demigran®): 5 mg, 3x/day; n = 35* No baseline period described; two 4-mo treatment periods; 1-mo washout ("without specific treatmenf"); no follow-up Nothing on acute meds | HA frequency: No. of HAs per month | HA frequency: 17/35 patients had 50% or fewer HAs per month with methysergide than with Demigran®; no corresponding figures were reported for cases in which Demigran® was superior. Excluding two patients who had almost daily HAs throughout the trial, the average number of HAs per month on Demigran® was 4.3, compared with 2.8 on methysergide (no variance data and no p-value reported). | Dropouts: 18 (34%), 5 due to AEs (4 Demigran®, 1 methysergide) High dropout rate (34%)
Hughes and Foster, 1971 | CrOv QS: 5 (r+, db+, dd) | N = 26 Age: N/S (range: 23–63) 81% female Classical migraine (25 pts); 1 with migrainous neuralgia; ≥ 2–33 migraines/mo -- "frequent & severe" HAs Chron: N/S (range: 3–50) Rec: N/S, but many pts had participated in previous trials of prophylactic drugs for migraine | Placebo (lactose): n = 26* Pizotifen (BC105): 0.5 mg, 1x/day for 2 days; then 0.5 mg, 2x/day for 2 days; then 0.5 mg, 3x/day for 10 days; then 1 mg, 3x/day for 6 wks; n = 26* No baseline period described; two 2-mo treatment periods; no washout; no follow-up Other acute migraine meds permitted during trial | HA frequency: Defined as "no. of HAs/mo" HA intensity: Definition N/S, but recorded daily by pt | The mean number of HAs for baseline (HA frequency) was calculated for the 2 mos prior to treatment (derived from patients' estimates for the preceding 12 mos). HA frequency was increased from 18.1 at baseline to 18.5 and 20.3 following treatment with pizotifen and placebo, respectively. Investigators reported that there were no significant differences between the two treatments for reducing HA frequency (no p-value given). Nine of 26 patients (35%) had a better response (≤ 50% fewer HAs) after taking pizotifen than after taking placebo. Investigators did not report how many patients responded better on placebo than on pizotifen. | Dropouts: 0 Information obtained from preliminary report No baseline data gathered on HA frequency; such data estimated post hoc by pts for 12 mos preceding trial. pts assessed by investigators at 2, 4, and 8 wks of each half of trial
Jacobs, 1972 | SPPG QS: 4 (r, db+, dd) | N = 47 Age: 42 (range: 23–67) 78% female Migraine Chron: N/S Rec: Referrals from GPs and others | Placebo: n = 13 (completed pre-treatment and first 6-wk treatment period); n = 12 (completed pre-treatment and both treatment periods) Opipramol: 50 mg, 3x/day; n = 14 (completed pre-treatment and first 6-wk treatment period); n = 13 (completed pre-treatment and both treatment periods) 6-wk baseline period, during which patients instructed to "avoid all drugs for migraine as far as humanely and reasonably practicable"; two 6-wk treatment periods Nothing on acute meds | HA frequency: Total no. of attacks in each period; mean no. of attacks per patient in each treatment period; mean reduction in number of attacks per patient in each treatment period (vis-á-vis baseline) | The data summarized here are from those patients who completed the baseline period and both 6-wk treatment periods. HA frequency: Among patients taking opipramol, the mean number of attacks per patient in the baseline period was 5.6; for weeks 7–12 of treatment, it was 2.9. In the placebo group, the corresponding figures were 4.2 and 4.2 (no variance data reported for either group). The mean reduction in number of attacks per patient was 2.8 in the opipramol group and −0.1 in the placebo group; the difference between the two treatments for this outcome was statistically significant in favor of opipramol (0.05>p>0.02). Opipramol was not significantly better than placebo at reducing the frequency of severe attacks, considered on their own (0.3>p>0.2). | Dropouts: 20 (43%), none known to be due to AEs; 2 more patients completed the first 6-wk treatment period, but not the second (see left) High dropout rate
Jensen, Brinck, and Olesen, 1994 | CrOv QS: 4 (r, db+, dd) | N = 43 Age: 46 (range: 27–62) 84% female Migraine w/o aura (IHS); history ≥1 yr; 2–10 migraine days/mo Chron: N/S Rec: HA clinic | Placebo: n = 34* Sodium valproate (slow-release): 1000–1500 mg/day (to attain serum level > 50 mg/L), administered in 3 doses/day; n = 34* 4-wk baseline period (medication-free); two 12-wk treatment periods; 4-wk washout; no follow-up Patients permitted to take usual analgesics for acute attacks | HA frequency: No. of days with migraine per 4-wk period; number of patients reporting ≥ 50% reduction in no. of migraine days per 4-wk treatment period (vs. baseline) HA severity: Measured for each HA on scale of 0–3 (none; no influence on daily activities; inhibits, but does not prohibit, daily activites; prohibits daily activities) HA duration: Recorded for each HA (hrs) | HA frequency (continuous data): The mean number of days with migraine per 4-wk period was significantly lower during treatment with sodium valproate than during the baseline period (p=0.0003) and during treatment with placebo (p=0.0018). The mean number of migraine days per 4-wk period was 6.1 (range 2–10) during the baseline period, 3.5 (CI 2.7 to 4.3) with sodium valproate, and 6.1 (CI 4.8 to 7.4) with placebo. HA frequency (categorical data): During treatment with sodium valproate, 17/34 patients (50%) showed a reduction of ≥ 50% in migraine days per 4-wk period (compared to baseline); 13/34 (38%) showed a reduction of 0–50%, and 4/34 (12%) had more migraine days. During treatment with placebo, the corresponding figures were 6/34 (18%),14/34 (41%), and 14/34 (41%), respectively. The effect of sodium valproate increased over time. During the last 4 wks of treatment, 22/34 patients (65%) reported a reduction of ≥50% in migraine days per 4-wk period with sodium valproate, compared to 7/34 (21 %) with placebo. There was no significant difference between sodium valproate and placebo for HA severity (p=0.45) or HA duration (p=0.9). | Dropouts: 9 (21 %), 6 due to AEs (4 sodium valproate, 2 placebo) Investigators found no significant carry-over effect (p=0.55)
Johannsson, Nilsson, Widelius, et al., 1987 | CrOv QS: 4 (r, db+, dd) | N = 72 Age: 43 (range: 27–63) 70% female Classical or common migraine (Ad Hoc); ≥2 HAs/mo Chron: 26 yrs Rec: N/S | Placebo: n = 63* Atenolol: 100 mg, 1x/day; n = 63* 2-mo baseline period (no prophylactic med); two 3-mo treatment periods; 2-wk washout; no follow-up Acute meds permitted | HA index: Not described, but incorporated intensity and duration HA frequency: No. of days with HA | HA index was significantly reduced (not defined) in 70% of patients (44/63) during treatment with atenolol compared with placebo (p=0.004). The reduction was more than 50% in 33% of patients (21/63). Atenolol was also significantly better than placebo for HA frequency (p=0.010). | Dropouts: 9 (13%), 3 due to AEs (placebo)
Johnson, Horna-brook, and Lambie, 1986 | CrOv QS: 4 (r, db+, dd) | N = 29 Age: 42 (range: 22–67) 76% female Classical or common migraine; ≥1 HA in previous mo Chron: 20 yrs (range: 4–50) Rec: N/S | Placebo: n = 17* Propranolol: 80 mg, 3x/day; n = 17* Mefenamic acid: 500 mg, 3x/day; n = 17* Baseline period ≥1 mo; three 3-mo treatment periods; no washout; no follow-up Acute meds permitted | HA frequency: Mean no. of attacks per 3-mo treatment phase; number of patients reporting a 50% or greater reduction in frequency vs. placebo HA duration: Mean attack duration (hrs); sum of duration for all attacks per 3-mo treatment phase HA severity: Mean attack severity; each attack graded on scale of 1–10 (not described) | Mefenamic acid and propranolol were both significantly better than placebo for mean HA frequency (p<0.05 and p<0.01, respectively): there was no significant difference between the two active treatments (p = 0.65). The mean number of attacks per 3-mo treatment period (± SO) was 20.1 ± 18.0 with placebo, 12.9 ± 10.8 with mefenamic acid, and 13.8 ± 12.0 with propranolol. Compared to the placebo phase, 9/17 patients (53%) showed a ≥ 50% reduction in frequency with mefenamic acid, as did 6 of the same 17 patients (35%) with propranolol (no measure of statistical significance reported). Both mefenamic acid and propranolol were significantly better than placebo for total duration of attacks (p<0.05 and p<0.01, respectively); there was no significant difference between the two active treatments (no p-value reported). Neither mefenamic acid nor propranolol significantly reduced mean attack duration or severity. | Dropouts: 12 (41 %), 3 due to AEs (1 with each intervention) High dropout rate (41 %)
Johnson, Kadam, Hylands, et al., 1985 | SPPG QS: 4 (r, db+, dd) | N = 17 Age: 48 % female N/S Common or classical migraine; history ≥ 2 yrs; ≤8 HAs/mo at time of admission; all patients had been self-administering fresh feverfew leaves daily for ≥ 3 mas Chron: N/S Rec: Migraine clinic | Withdrawal of feverfew (placebo): n = 7 Continuation of feverfew: 50 mg, 1x/day of pulverized, freeze-dried leaves in capsules; n = 8 No baseline period described; 6-mo treatment period; no follow-up Analgesics and patients' usual drugs permitted for acute migraine attacks Prophylactic meds also permitted | Patients (and diary card entries) were assessed at 1- to 2-mo intervals throughout trial for the following outcomes: HA frequency: HAs recorded at onset by patient and reported as "no. of HAs/mo" HA intensity: Recorded by patients on 4-point scale (0=no pain; 1=mild, unpleasant but not affecting work or recreational activities; 2=severe, reducing ability to work or carry out recreational activities; 3=incapacitating, unable to work or carry out recreational activities) | For HA frequency, the post-treatment mean score (± SEM) was 1.50 (± 0.62) for patients continuing treatment with feverfew. (We reported the average of mean scores for the last 3 mos of treatment as the post-treatment score, rather than the average over all 6 mos, to exclude carryover effects from patients' previous use of feverfew.) Investigators reported that there was no change in HA frequency for patients taking active treatment, but did not report having analyzed the pre- to post-treatment results for statistical significance. In the group receiving placebo, HA frequency increased to a mean score of 3.43 (± 1.02) after treatment. Investigators reported that the difference between these pre- and post-treatment scores was statistically significant (p < 0.02). (Pre-treatment values for both groups were estimated and reported by patients retrospectively.) No results were provided for between-group comparisons. | Dropouts: 2 patients (12%), withdrew and were not included in efficacy analyses, 1 due to AEs (placebo)
Kallanranta, Hakka-rainen, Hokkanen, et al., 1977 | Study 1 CrOv QS:0 (nr, ndb, dnd) Study 2 CrOv QS:0 (nr, ndb, dnd) | Study 1 N = 50 Age: 32 (range: 20–49) 72% female Chron: N/S Common or classical migraine; ≥ 1 M in month before trial Study 2<br>N = 50 Age: 36 (range: 22–55) 64% female Chron: N/S Common or classical migraine; ≥ 4 Ms in month before trial Rec: Neurology depts of 2 hospitals in Finland | Study 1 Placebo: n = 50* Clonidine: 25 μg, 3x/day; n = 50* No baseline period; two 4-wk treatment periods; one 1-wk crossover period between treatments (not clear whether washout or not); no follow-up Acute migraine meds permitted during trial Study 2 Practolol: 150 mg, 3x/day; n = 50* Clonidine: 50 μg, 3x/day; n = 50* No baseline period; two 8-wk treatment periods; one 1-wk crossover period between treatments (not clear whether washout or not); no follow-up Acute migraine meds permitted during trial | HA frequency: Recorded by pt as "time of attack" | For Study 1, treatment with 75 μg/day of clonidine for 4 wks reduced the mean no. of HAs/mo (± S.D.) from 3.94 (± 2.19) before treatment to 2.26 (± 1.57) after treatment, whereas the no. decreased to 2.98 (± 1.63) following treatment with placebo. Clonidine was significantly better than placebo at reducing HA frequency (p<0.05). For Study 2, treatment with 150 μg/day of clonidine for 8 wks reduced the mean no. of HAs/mo (± S.D.) before treatment from 4.0 (± 2.20) to 1.88 (± 2.79) after treatment. Treatment with 150 mg/day of practolol for 8 wks reduced the mean no. of HAs/mo to 2.49 (± 3.13). Clonidine was significantly better than practolol at reducing HA frequency (p<0.05). | Dropouts: N/S Trial consisted of 2 parts, 1½ yrs apart Every other pt received first clonidine and then placebo, and every other pt received the treatments in reversed order Not clear how baseline data gathered or how results determined from that data
Kallos and Kallos-Deffner, 1971 | CrOv QS: 1 (r, ndb, dnd) | N =20 Age: N/S (range: 20–45) 100% female Migraine attacks occurring in connection with the menstrual period Chron: N/S Rec: N/S | Placebo: n = 20* Cafergot comp.® (1 cap = ergotamine 1 mg + caffeine 100 mg + butalbital 50 mg + belladonna alkaloids 0.125 mg): 1 cap, 2x/day for 3 days before, during, and two days after menstrual period; n = 20* No baseline period described; 3 treatment periods lasting 2 menstrual cycles each; no washout; no follow-up Nothing on acute meds | HA frequency: No. of attacks during two menstrual cycles | HA frequency: Investigators reported only the total number of attacks reported over two menstrual cycles with each intervention. With placebo, 31 attacks were reported (mean of 1.55 per patient); with Cafergot comp ®, 7 (mean of 0.35 per patient) (no p-values or other measures of statistical significance reported). | Dropouts: Not described All 20 patients had used Cafergot comp.® prophylactically in the past, with good results Low quality score (1); not double-blind; dropouts not described Trial also included an investigational drug (LCC 115 = ergostine + caffeine + pimethixene) that was never brought to market
Kangasniemi, 1979 | CrOv QS: 4 (r, db+, dd) | N = 50 Age: 36 (range: 19–58) 80% female Common or classical migraine (Ad Hoc);≥ 2–4 HAs/mo for 1–3 mos preceding trial; pts had “severe & chronic migraines” Chron: N/S (range: N/S) Rec: Physician referrals to neuro. clinic of hospital | Pizotifen (Sandomigrin®): 0.5 mg, 1x/day on Days 1 & 2; 0.5 mg, 2x/day on Days 3 & 4; 0.5 mg, 3x/day on Day 5 and until end of trial; n = 34* Iprazochrome (Divascan® or Migrenon®): 5 mg, 1x/day on Days 1 & 2; 5 mg, 2x/day on Days 3 & 4; 5 mg, 3x/day on Day 5 and until end of trial; n = 34* No baseline period described; two 3-mo (or two 14-wk) treatment periods (length of treatment period is unclear); 1 mo washout period using placebo between treatment periods; no follow-up Previous long-term migraine meds discontinued 1–3 mos prior to start of trial; ergotomine permitted during trial | HA index: Not defined, but derived from pt’s recordings on “weekly card” HA frequency: Not defined, but recorded by pt on weekly card HA intensity: Rated on 3-point scale by pt | The mean weekly HA index scores after treatment with Migrenon® and pizotifen were 3.2 (± 2.0) (SD) and 2.7 (± 1.9). Pizotifen was slightly more effective than Migrenon®, but not at a statistically significant level (p > 0.05). Investigators also reported that 11/34 pts (32%) decreased weekly HA index > 50% better on pizotifen than on the placebo given during the washout period (not a “true” placebo treatment). Four of 34 pts (12%) decreased weekly HA index > 50% better on Migrenon® than on placebo. Authors did not report whether the difference between these results was statistically significant. No pre- to post-treatment results were provided. | Dropouts: 16 (32%),3 due to AEs (2 pizotifen, 1 Migrenon®) Not clear whether or not baseline data gathered
Kangasniemi, Andersen, Andersson, et al., 1987 | CrOv QS: 4 (r, db+, dd) | N =77 Age: 38 (16–65) 80% female Classical migraine (Ad Hoc); 2–8 HAs/mo, of which ≥ 50% accompanied by focal auras; “frequent” HAs Excl: High daily or monthly use of analgesics or ergotamines; use of narcotic analgesics, chronic treatment with calcium antagonists, clonidine, other beta-blockers, or NSAIDs; contraindications for beta-blockers Chron: 17 (range: 2–51) Rec: 8 neuro. centers in Scandinavia | Placebo: n = 73* Metoprolol (Durules®): 200 mg (slow-release tabs), 1x/day; n = 73* 4-wk run-in (baseline), with no prophylactics; two 8-wk treatment periods; 4-wk washout between treatment periods; no follow-up described Patients permitted to take, but not to change, their usual acute migraine meds | HA frequency: Recorded daily by pts and reported as “total number of migraine attacks/mo” HA intensity: Recorded daily by pts and rated on 3-point scale | Metoprolol was significantly better than placebo at reducing HA frequency (p = 0.004). HA frequency was reduced from a median score of 3.8 at baseline to 1.8 and 2.5 after treatment with metoprolol or placebo, respectively. Investigators did not report having analyzed the pre- to post-treatment differences for statistical significance. Similar results were found for HA intensity. | Dropouts: 4 pts (5%) withdrew, none due to AEs Trial was a multi-center study
Kangasniemi, Falck, Långvik, et al., 1978 | CrOv QS: 2 (nr, db, dd) | N=8 Age: 34 (range: 24–49) 75% female Migraine; all pts “rather resistant” to treatment Chron: > 10 (range: N/S) Rec: N/S | Placebo (levoleucine): 320 mg, 4x/day; n = 8* Oxitriptan (Levotryptophan): 500 mg, 4x/day; n = 8* No baseline period described; two 3-mo treatment periods; no washout, but data from first mo of each treatment period excluded from analysis; no follow-up Nothing on acute migraine meds | HA index: Calculated by multiplying no. of HAs per month by HA intensity score (see below) HA frequency: Defined as “no. of attacks/mo” (see below) HA intensity: Rated on 3-point scale (see below) Not clear how treatment period data obtained; frequency and intensity data determined by “subjective estimate,” but not clear whether estimate provided by pt or physician | The post-treatment mean HA index score was 16.0 (± 16.4) (SD) for pts treated with levotryptophan (for the 2 mos analyzed) and 23.8 (± 18.2) for pts treated with placebo. Investigators reported that although the HA index score was lower for pts taking oxitriptan than for those taking placebo, the difference was not statistically significant (no p-value given). No results were provided for pre- to post-treatment comparisons. Investigators reported that 4/8 pts (50%) had “markedly lower” HA index scores after treatment with the active drug than after treatment with placebo, but did not provide further details. | Dropouts: 0 Results described as “preliminary” Not clear how baseline data gathered HA index estimated at monthly intervals when pt examined by physician
Kangasniemi and Hedman, 1984 | CrOv QS: 4 (r, db+, dd) | N =36 Age: 34 (range: 18–51) 89% female Classical or common migraine (World Fed of Neurology); ≥ 3-yr history; avg duration ≥ 1 hr;3–10 attacks/mo; patients with other types of vascular HA or with chronic daily HA excluded Chron: 16 yrs Rec: Neuro dept | Propranolol: 80 mg, 2x/day; n = 33* Metoprolol (controlled-release): 200 mg, 1x/day; n = 34* 4-wk baseline period (placebo); two 8-wk treatment periods; 4-wk washout (placebo); ten patients followed up for six months after end of trial Acute meds permitted | HA index: Severity times no. of migraine days; severity of each attack graded on scale of 1–3 (light, moderate, severe) HA frequency: No. of attacks per 4 wks; no. of migraine days per 4 wks | There were no statistically significant differences between metoprolol and propranolol for any of the outcomes measured (p-values not reported). Both drugs significantly reduced HA index in comparison with baseline values (p≤ 0.001 for both comparisons). Mean HA index scores (± SD) were 9.7 (± 4.9) during the baseline period (n = 35), 5.4 (± 3.5) during treatment with propranolol (n = 33), and 4.9 (± 3.2) during treatment with metoprolol (n = 34). 15/33 patients (45%) reported a 50% or greater reduction in HA index scores with propranolol in comparison with baseline values, as did 17/34 (50%) with metoprolol. | Dropouts: 3 (8%),2 due to AEs (both propranolol); 2 of the 3 dropouts provided enough data to be included in the efficacy analysis for some outcome variables 28% of patients had tried preventive treatment before
Kangasniemi, Nyrke, Lang, et al., 1983 | CrOv QS: 3 (r, db, dd) | N = 29 Age: 37 (range: 24–47) 86% female Classical or common migraine; no prophylactic meds in previous 2 mos Chron: 17 yrs (range: 4–40) Rec: Neurologist’s private practice | Propranolol: 80 mg, 2x/day; dose reduced by half during first week; n = 24* Femoxetine: 200 mg, 2x/day; dose reduced by half during first week; n = 24* 1-mo baseline period; two 3-mo treatment periods; no washout, but first month of each active treatment period dropped from analysis to minimize carry-over effects; 1-mo placebo treatment period at end of study Patients allowed to take their usual meds for acute attacks (generally tolfenamic acid or ergotamine) | HA index: No. of HA days multiplied by severity (severity of each attack graded on scale of 1–3) HA frequency: No. of attacks per month | Propranolol significantly decreased HA index compared with pre-treatment values (p<0.01); no significant change was seen with femoxetine (no p- value reported). When the two treatments were directly compared for this outcome, propranolol was significantly better than femoxetine (p<0.05). During the pre-treatment period, the mean HA index (± SEM) was 10.30 (± 1.42); after treatment with propranolol, it was 7.07 (± 1.04); and after treatment with femoxetine, 9.68 (± 1.98). Very similar results were reported for HA frequency. | Dropouts: 5 (17%), 3 due to AEs associated with propranolol
Kåss and Nestvold, 1980 | CrOv QS:3 (r, db, dd) | N = 23 Age: 40 (range: 22–62) 70% female Chron: N/S Common or classical migraine Excl: Previous use of study meds; combination of M +TTHs “avoided” Rec: N/S | Propranolol (Inderal®): 80 mg, 2x/day; n = 21* Clonidine (Catapresan®): 50 μg, 2x/day; n = 21 * 4-wk washout prior to treatment; one 4-wk baseline period prior to each of two 16-wk treatment periods; first 4 wks of each treatment period excluded from analysis to reduce crossover effects; no follow-up Acute migraine meds permitted during trial | HA frequency: Defined as no. of days with HAs HA intensity: Rated by pts on 4-pt scale (N/S) | For HA frequency, results were reported as the total of HA days reported by each pt for each treatment type. Investigators reported that 10/21 pts (48%) and 9/21 pts (43%) had fewer HA days after treatment with propranolol and clonidine, respectively, whereas 2/21 pts (10%) had no changes in HA frequency, regardless of the treatment taken. Investigators reported that neither treatment was significantly better than the other (no p-value given). A comparison of the last 4 wks of treatment data with that from the 4-wk baseline revealed that 13/21 pts (62%) improved (had > 50% reduction in HA frequency from pre- to post-treatment) after being treated with propranolol, whereas 8/21 pts (38%) improved after taking clonidine. Investigators did not report whether or not there was a statistically significant difference between these results. | Dropouts: 2 (9%), none due to AEs Pts were initially hospitalized for 2 days, then treated as outpatients
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | CrOv (analyzed as SPPG for some outcomes) QS: 4 (r, db+, dd) | N = 76 Age: 43 (median) (range: 19–65) 79% female Migraine w/or w/o aura (IHS); history ≥ 1 yr; 2–8 HAs/mo over last 3 mos Chron: 20 yrs (median) (range: 1–40) Rec: Referrals to neuro depts | Propranolol: 40 mg, 3x/day; n = 56* (total completing trial); n = 29 (took propranolol in first treatment period and completed trial) Tolfenamic acid: 100 mg, 3x/day; n = 56* (total completing trial); n = 27 (took tolfenamic acid in first treatment period and completed trial) 1-mo baseline period (no prophylactic med); two 3-mo treatment periods; 1-mo washout (placebo); no follow-up Patients allowed to take meds for acute attacks | HA index: No. of migraine hrs per month HA frequency: No. of migraine days per month HA severity: Mean HA severity; each attack graded on scale of 1–3 (able to work; unable to work, but not in bed; in bed) | Investigators analyzed several outcomes for the first treatment period (vs. baseline) only. HA index: Both treatments significantly reduced the average number of migraine hours per month during the first treatment period compared with baseline (no p-value reported). Among patients taking tolfenamic acid in the first period (n = 27), the mean reduction in HA index score (± 2 SDs) was 6.9 (−55.7 to +41.9); among patients taking propranolol (n = 29), it was 15.7 (−106.6 to +75.1). Over the course of the entire trial, there was no significant difference between the two treatments for HA index (no p-value reported). The mean difference (± 2 SDs) between scores with tolfenamic acid and with propranolol was 2.9 (−47.9 to + 53.7) (n = 56 patients completing treatment with both drugs). There were no significant differences between the two treatments for HA frequency or HA severity. | Dropouts: 20 (26%), 14 due to AEs (9 propranolol,5 tolfenamic acid) Investigators tested for carry- over and period effects for all the main efficacy parameters and found none
Klapper, 1994 | CrOv QS: 2 (r, ndb, dd) | N=24 Age: N/S % female N/S Migraine w/or w/o aura (IHS); ≥ 2 HAs/mo; no previous experience with study drugs Chron: N/S Rec: N/S | Propranolol: Dose titrated to highest level tolerated; avg dose 140 mg/day, range 80–240 mg/day; n = 12* Divalproex sodium: Dose titrated to highest level tolerated; avg dose 1100 mg/day, range 750–1500 mg/day; n = 12* 2-wk+ lead-in period of dosage adjustment; followed by 2-mo treatment period; then 2- wk+ washout and dosage adjustment period; followed by second 2-mo treatment period; no follow-up Nothing on acute meds | HA frequency: Mean no. of HAs per 2-mo treatment period | HA frequency: The mean number of HAs per 2 mos was 10.9 with divalproex sodium and 20.4 with propranolol (no variance data and no p-value reported). Investigators did not state whether they found the difference between the two treatments to be significant for this outcome. | Dropouts: 12 (50%), all due to AEs (9 divalproex sodium, 3 propranolol) Abstract reporting limited results Open-label trial High dropout rate (50%)
Klapper, 1996 | SPPG QS: 4 (r, db+, dd) | N = 176 Age: 41 (range: 17–76) 89% female Migraine w/or w/o aura (IHS); history ≥ 6 mos; ≥ 2 attacks in previous 3 mos; patients with chronic daily HA or TTH on ≥ 15 days/mo excluded Chron: 22 yrs Rec: HA clinic | Placebo: n = 42 Divalproex sodium, 500 mg/day: Given in two doses; n = 45 Divalproex sodium, 1000 mg/day: Given in two doses; n = 40 Divalproex sodium, 1500 mg/day: Given in two doses; n = 44 4-wk baseline phase (placebo); 12-wk treatment phase (4 wks dose escalation + 8 wks maintenance at randomized dose); no follow-up Patients permitted to use symptomatic meds to treat acute attacks, but use of such meds must average < 3 days/wk | HA frequency: Mean 4-wk attack frequency; percentage reduction in mean 4-wk attacks frequency; percentage of patients reporting a> 50% reduction in frequency HA severity: Peak severity per attack (scale used not described) HA duration: Per attack, in hrs | The mean reductions in HA frequency from baseline to post-treatment, adjusted for differences in baseline frequency, were 0.5 attacks per 4 wks in the placebo group, and 1.7, 2.0, and 1.7 attacks per 4 wks in the 500-mg, 1000-mg, and 1500-mg divalproex sodium groups, respectively. Each of the divalproex sodium doses was significantly better than placebo for this outcome (p.≤0.05). Investigators did not directly compare the three doses of active medication for this outcome. The proportions of patients reporting a 50% or greater reduction in mean 4-wk attack frequency were 21 % in the placebo group (9/42), 44% in the 500-mg group (20/45),43% in the 1000-mg group (17/40), and 45% in the 1500-mg group (20/44). Each of the divalproex sodium doses was significantly better than placebo for this outcome (p≤0.05). Investigators did not directly compare the three doses of active medication for this outcome. No significant differences were observed among the four treatments for HA severity or duration. | Dropouts: 5/176 patients (3%) did not provide any HA data and were excluded from the efficacy analysis; 39 patients (22%) discontinued treatment before the end of the 12-wk treatment period, but provided some data for the efficacy analysis; 27 of these 39 patients withdrew due to AEs (12,1500 mg; 6, 1000 mg; 7,500 mg; 2, placebo) Only patients who were previously untreated or had failed ≤ 2 trials of prophylactic med were included
Krakowski and Engisch, 1973 | SPPG QS: 4 (r, db+, dd) | N =29 Age: 38 (range: N/S) 82% female Common or classical migraine; ≥ 6 HAs in 4 wks prior to trial Chron: 24 (range: N/S) Rec: N/S, but pts "ambulatory" | Placebo: n = 9 Pizotifen: 2 mg, 3x/day; n = 13 4-wk baseline period with placebo; 12-wk treatment period; no washout, but data from first mo of each treatment period excluded from analysis; 4-wk "post-treatment" period with placebo; no other follow-up described Nothing on acute migraine meds | HA index: Calculated as the sum of severe HAs times 3, moderate HAs times 2, and mild HAs times 1 HA frequency: Defined as "total no. of HAs" and reported as no. of HAs/mo HA intensity: Rated on 3-point scale | Results for HA index were reported as the difference of mean changes at the end of the trial compared with baseline. Pizotifen was significantly better than placebo at reducing HA index from pre- to post- treatment (p < 0.05). Investigators reported a mean HA index score for each 4-wk period. From baseline (average of 4 wks) to 16 wks (the average of last 4 wks of 12-wk treatment period), pizotifen reduced mean HA index from 31.8 to 16.8, a reduction that was statistically significant (p < 0.001). Placebo reduced that outcome over the same period from 36.2 to 32.8, a reduction that was not significant (p > 0.05). | Dropouts: 7 (24%), not clear if any due to AEs on placebo; none due to AEs on pizotifen Not clear how data gathered; no mention of pt diaries. Data appear to have been obtained post hoc by physician at weeks 0, 4, 6, 8, 12, and 20
Kuritzky and Hering, 1987 | CrOv QS: 3 (r, db, dd) | N = 38 Age: N/S (range: 17–53) % female N/S Classical or common migraine; ≥ 2- yr history; ≥ 3 attacks/mo Chron: 14 yrs Rec: N/S | Placebo: n =31 * Propranolol (long-acting): 160 mg, 1x/day; n = 31* 4-wk baseline period; two 4-wk treatment periods; no washout; no follow-up Acute meds permitted | HA frequency: No. of attacks/mo HA severity: Each attack graded on scale of 1–3; outcome measure not described HA duration: Not described | Propranolol was significantly better than placebo for HA frequency (p=0.014). Mean frequency with propranolol was 3.23; with placebo, it was 5.56 (no variance data reported). Similar results were reported for HA severity (p=0.003) and HA duration (p=0.002). | Dropouts: 7 (18%), 2 due to AEs (proprano lol) No carry-over effect Abstract reporting limited results
Lamsudin and Sadjimin, 1993 | SPPG QS: 3 (r, db, dd) | N = 83 Age: N/S 59% female Classic or common migraine; ≥ 2 attacks/mo Chron: N/S Rec: Hospital outpatient depts | Flunarizine: 5 mg, 2x/day; n = 40 Nifedipine: 10 mg, 2x/day; n = 38 1-mo baseline period (placebo); 3-mo treatment period; no follow-up Use of acute meds permitted | HA index: Calculated for HAs of disabling, severe, or moderate intensity only (not mild); = 3(FxD)_disabling_ + 2(FxD)_severe_ + 1(FxD)_moderate_, where F = frequency (no. of HAs/mo) and D = duration (hrs) | Both treatments significantly reduced HA index, compared to baseline values, from one month on. In the nifedipine group, mean scores (± SD) were 26.28 (± 25.93) for the baseline period and 9.07 (± 13.78) for the final treatment month (p<0.00001). In the flunarizine group, the corresponding scores were 26.41 (± 24.56) and 6.69 (± 14.35), respectively (p<0.00001). There were no significant differences between the two treatments for this outcome (no p- values reported). | Dropouts: 5 (6%), none due to AEs
Lance and Anthony, 1968 | SPPG QS: 4 (r, db+, dd) | N = 50 Age: 39 (range: N/S) 84% female Migraine; ≥ 2- 8 severe HAs/mo; av. 24- to 48-hr HA duration Chron: N/S (range: N/S) Rec: Neuro. clinic | Placebo: n = 25 Pizotifen: 0.025 mg, 3x/day on Day 1; 0.05 mg, 3x/day on Day 3; 1.0 mg, 3x/day from Day 4 through 1 mo; n = 25 No baseline period described; 1-mo treatment period; no follow-up Nothing on acute migraine meds | HA frequency: Definition N/S HA intensity: Definition N/S | Twelve of 25 pts (48%) treated with pizotifen improved (obtained ≥ 50% reduction in HA frequency or intensity [N/S] from pre- to post-treatment), whereas 9/25 pts (36%) treated with placebo improved. Pizotifen was more effective at reducing HA frequency or intensity than placebo, but not at a statistically significant level (p = 0.4). Investigators did not report pre- or post-treatment mean values for either HA frequency or intensity. | Dropouts: 5 pts (12%), included in efficacy analyses, withdrew from trial (2 due to AEs, treatments N/S) Not clear if baseline data gathered Not clear how data obtained
Lance, Fine, and Curran, 1963 | SPPG QS: 3 (nr, db+, dd) | N = 90 Age: N/S 71% female Classical or common migraine; ≥ 2 incapacitating HAs/mo Chron: N/S Rec: HA clinic | Placebo: n = 34 Methysergide: 2 mg, 3x/day; n = 56 No baseline period described; 1-mo treatment period; patients who responded well were maintained on the same drug and followed up for up to 9 mos; patients who did not respond to initial drug were crossed over to alternative drug for 1 month and re- evaluated at that time; we considered only the initial, 1-mo controlled portion of the trial Nothing on acute meds | HA frequency: No. of attacks; investigators reported no. of patients HA-free, > 50% Improved, unchanged, and worse at end of treatment period | Methysergide was significantly more effective than placebo at reducing HA frequency (p<0.001). 38/56 patients (68%) taking methysergide and 7/34 (21%) taking placebo reported a 50% or greater reduction in HA frequency compared with baseline values. | Dropouts: 6 (7%), all due to AEs (all methysergide); all 6 dropouts were included in the efficacy analysis Report described results of treatment of patients with several different types of HA, and from controlled and uncontrolled portions of the trial; data reported here concern only those migraine patients who participated in the controlled portion of the trial Not clear how baseline values established
Langohr, Gerber, Koletzki, et al., 1985 | CrOv (5 groups, 2 periods) QS: 3 (r, db, dd) | N =63 Age: 44 (range: 24–60) 67% female Common or classical migraine (Ad Hoc); ≥ 1 HAlwk Chron: 21 yrs (range: 5–41) Rec: N/S | Placebo: n = 27* Metoprolol: Dosage gradually increased to maximum of 100 mg/day; n = 21* Clomipramine: Dosage gradually increased to maximum of 100 mg/day; n = 20* Patients randomized to five treatment groups: clomipramine followed by placebo; placebo followed by clomipramine; metoprolol followed by placebo; placebo followed by metoprolol; clomipramine followed by metoprolol 6-wk baseline period; two 4-wk treatment periods; 4-wk washout; 6-wk follow-up Use of acute meds permitted | HA frequency: No. of attacks; reduction from pre-to post-treatment HA duration | A time series analysis (ARIMA) performed by the investigators showed that metoprolol was significantly better than clomipramine at reducing HA frequency (p<0.05). No significant differences could be established between metoprolol and placebo, or between clomipramine and placebo (no p-values reported). Investigators also reported the number of patients reporting a > 50% improvement in HA frequency, based on conventional statistical methods. The numbers were as follows: with clomipramine, 5/20 patients (24%); with metoprolol, 9/21 patients (44%); and with placebo, 7/27 patients (26%) (no p-values reported). | Dropouts: 27 (43%), 18 due to AEs associated with clomipramine; also, 2 patients who completed the trial were (for some unspecified reason) excluded from the investigators' efficacy analysis
Lawrence, Hossain, and Littlestone, 1977 | SPPG QS: 4 (r, db+, dd) | N =36 Age: N/S (range: 16–64) 72% female Common or classical migraine; ≥ 4 HAs/mo Excl: pts taking MAOls Chron: 16 (range: 2–36) Rec: 3 GP clinics | Placebo: n = 14 Pizotifen: 0.5 mg, 1/day for 2 days; 0.5 mg, 2x/day for 2 days; 0.5 mg, 3x/day for 10 days; then 1.0 mg, 3x/day for 10 wks; n = 14 No baseline period described; one 3-mo treatment period; no follow-up Pts permitted to take mild hypnotics, analgesics, and ergotamine during trial, but not migraine prophylactic meds | HA index: Calculated weekly by multiplying no. of HAs by HA intensity score HA frequency: Definition N/S, but recorded daily by pts HA intensity: Rated on 3-point scale daily by pt | Results were reported as weekly individual HA index values, categorized according to degree of improvement. However, the criterion for determining "improvement" was not specified. Investigators reported that pizotifen was more effective than placebo at reducing HA index, but did not report whether they analyzed the differences for statistical significance (no p-value given). From the last 4 weeks of data, we calculated mean scores of 8.6 (± 10.3) (SD in parentheses) and 14.9 (± 10.1) for patients treated with pizotifen and placebo, respectively. We calculated an effect size of 0.62 (−0.14 to 1.4) for the difference between the two treatments. The effect size suggests that pizotifen is better than placebo, but not at a statistically significant level. | Dropouts: 8 pts (22%), not included in efficacy analyses, withdrew, none due to AEs; 1 additional pt, included in efficacy analyses, withdrew due to AEs (placebo) Not clear how baseline data gathered or how results determined from those data
Leandri, Rigardo, Schizzi, et al., 1990 | CrOv QS: 4 (r, db+, dd) | N =36 Age: N/S 73% female Migraine w/o aura (IHS); 2–8 attacks/mo in previous yr; no TTH; no prophylactic med in previous 4 mos Chron: 8 yrs (range: 1–25) Rec: N/S | Placebo: n = 30* Nicardipine: 20 mg, 2x/day (dosage reduced by half for first 3 days); n = 30* 2-mo baseline period; two 2-mo treatment periods; no washout; no follow-up Acute meds (analgesics or ergotamine) permitted | HA index: Monthly no. of attacks times mean severity HA frequency: Monthly no. of attacks HA severity: Monthly mean severity; graded daily on scale of 0–3 (no HA; mild HA; strong HA interfering with work or other activity; very strong HA necessitating bed rest) HA duration: Monthly mean (hrs) | Both nicardipine (p<0.01) and placebo (p<0.05) significantly reduced HA index compared with the pre- treatment period. Nicardipine was significantly better than placebo for this outcome (p<0.01). Mean HA index scores (± SD) were 12.61 (± 10.96) pre- treatment, 8.09 (± 7.58) after treatment with placebo, and 2.35 (± 2.39) after treatment with nicardipine. Separate analysis of the HA index scores for the two treatment orders suggested that, as a group, patients who took nicardipine first achieved significant improvement over baseline scores and maintained this improvement through the placebo period. Patients starting on placebo improved significantly only after crossing over to nicardipine. Nicardipine was also significantly better than placebo for HA frequency, HA severity, and HA duration (p<0.01 for all three outcomes). | Dropouts: 6 (17%),3 due to AEs (1 nicardipine, 2 placebo)
Lindegaard, Ovrelid, and Sjaastad, 1980 | CrOv (analyzed as SPPG) QS: 2 (r, db, dnd) | N = 28 Age: N/S (range: 16–60) 68% female Classic or common migraine (Ad Hoc); ≥ 3 HAs/mo Chron: 17 yrs Rec: Neuro dept out- patients | Placebo: n = 13 Naproxen (Naprosyn®): 250 mg, 2x/day; n = 15 Baseline period of at least 2 mos (drug-free); two 6-wk treatment periods; one-week washout; no follow-up Patients could take dextropropxyphene for acute attacks | HA index: Frequency times severity HA frequency: No. of attacks/wk HA severity: Severity of each attack graded on scale of 1–3 HA duration: Hrs per wk | Because of a positive treatment-period interaction, we analyzed first-period data only. Mean HA index (± SEM) was 3.4 (± 0.72) among patients taking naproxen during the first treatment period and 4.0 (± 0.87) among patients taking placebo. Investigators did not analyze the first-period data separately. Mean HA frequency (± SEM) was 1.2 (± 0.24) in the naproxen group and 1.4 (± 0.33) in the placebo group. | Dropouts: Not described Low quality score (2); dropouts not described Investigators recommended further studies with higher doses of naproxen
Louis, 1981 | SPPG QS: 4 (r, db+, dd) | N =58 Age: 29 (median) (range: 20–47) 50% female Classic or common migraine; attacks clearly distinguishable from TTHs; ≥ 6 attacks in previous 6 mos Chron: N/S Rec: General practice out- patients | Placebo: n = 29 Flunarizine: 5 mg, 2x/day; n = 29 No baseline period described; 3-mo treatment period; no follow-up Use of acute meds permitted | HA frequency: No. of attacks per 3 mos Frequency of severe HA: No of days with severe HA per 3 mos HA severity: Outcome measure not described HA duration: Outcome measure not described | The median percentage reduction in HA frequency at 3 mos, compared with pre-treatment values, was 57% in the flunarizine group (range: 0–100%) and 14% in the placebo group (range: 0–56%). The difference between the two treatments was statistically significant (p<0.001) in favor of flunarizine. We calculated an ES for HA frequency based on categorical data reported on the number of patients with a median of 0, 1, 2, 3, 4, and 5 attacks per 3-mo treatment period. For the flunarizine group, the number of patients in these six frequency groups was 5, 8, 8, 7, 0, and 1, respectively; in the placebo group, the number of patients in the six groups was 0, 0, 9, 15,3, and 2, respectively. The investigators' analysis found a significant difference in favor of flunarizine for this outcome (p<0.0001). Flunarizine was also significantly better than placebo at reducing the median frequency of severe HAs (p<0.001; data reported only in graphic form). Neither HA severity nor duration were affected by flunarizine. | Dropouts: 0 Baseline values based on patient history over 6 mos preceding trial
Louis, Schoenen, and Hedman, 1985a | CrOv QS:4 (r, db+, dd) | N = 31 Age: 36 (range: 18–57) 81% female Chron: 19 (range: 2–40) Migraine; hist. of Ms ≥2 yrs; ≥3–10 HAs/mo with duration ≥ 2 hrs; must have met 4 of 6 criteria that included prodromas, hemicrania, & phono-or photophobia Excl: Inability to distinguish HA types; current use of prophylactic HA meds Rec: N/S, but were out-patients | Metoprolol: 50 mg, 2x/day; n = 31* Clonidine: 50 μg, 2x/day; n = 31* 4-wk baseline; two 8-wk treatment periods; 4-wk washout between treatment periods; no follow-up Acute migraine meds permitted during trial | HA Index: Calculated by multiplying no. of migraine days by HA intensity rating for each attack (1=mild; 2=moderate; 3=severe) and summing them HA frequency: Definition N/S, but obtained from pts' diaries | The median HA index scores after treatment with clonidine or metoprolol were 10.2 and 8.4, respectively. Metoprolol was significantly better than clonidine at reducing HA index (p<0.05). The median HA index score at baseline was reduced from 11.2 to 10.2 after treatment with clonidine, a reduction that was not statistically significant (p>0.05). However, the median HA index score was reduced from 11.2 at baseline to 8.4 after treatment with metoprolol, a reduction that was statistically significant (p<0.001). Of pts treated with clonidine, 8/29 (28%) improved (achieved > 50% reduction in HA frequency from pre-to post-treatment). Of those treated with metoprolol, 10/27 (37%) improved. | Dropouts: 8 (26%),4 due to AES (3 clonidine, 1 washout period); data from these pts were included in efficacy analyses All results reported as median values per 4 wks
Louis and Spierings, 1982 | SPPG QS: 3 (r, db, dd) | N = 75 Age: 37 (median) (range: 17–57) 56% female Classical or common migraine (Ad Hoc); HAs moderate-severe and throbbing; ≥ 6 attacks in past 6 mos Chron: 17 yrs (median) (range: 2–32) Rec: General practices | Pizotifen: 2–3 mg/day in 3 administrations (dose adjusted during first month of treatment); n = 30 Flunarizine: 10 mg, 1x/day (at night); n = 36 No baseline period described; 4-mo treatment period Acute meds permitted | HA frequency: No. of attacks/mo HA severity: Each attack graded on 4-pt scale (not described) HA duration: Not described | Both drugs had a significant effect on HA frequency from the second month on (no p-values reported). The mean reduction in the number of attacks over the 4-mo treatment period was 54% in the flunarizine group and 45% in the pizotifen group. There were no significant differences between the two drugs for this outcome (no p-value reported). Both drugs also significantly reduced HA severity compared to pre-treatment values (p<0.001 for both groups). From month 2 on, flunarizine was significantly better than pizotifen for this outcome (p=0.026 for month 4). Neither treatment significantly affected HA duration. | Dropouts: 9 (12%),2 due to AEs (1 each flunarizine and pizotifen) Not clear how baseline/pre-treatment values established (no baseline period described)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | SPPG QS: 3 (nr, db+, dd) | N =434 Age: 42 82% female Classical or common migraine (Ad Hoc); ≥ 2 attacks/mo in past 6 mos or single attacks lasting several days Chron: N/S Rec: Medical practices | Propranolol: 40 mg, 2x/day for 2 wks, then 3x/day; n = 170 Flunarizine: 10 mg, 1x/day (at night); n = 166 2-wk washout period; 4-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks/mo HA duration: Overall attack duration (hrs/mo) | Mean HA frequency (± SD) was reduced in the flunarizine group from 6 (± 6) after one month of treatment to 4 (± 4) after 4 months. A similar reduction was observed in the propranolol group, from 6 (± 6) to 4 (± 5). Mean HA duration (± SD) was reduced from 17 (± 33) after one month to 10 (± 16) after 4 months in the flunarizine group, and from 17 (± 24) to 11 (± 18) in the propranolol group. There were no statistically significant differences between the two treatments for these outcomes (no p- values reported). | Dropouts: 98 (23%),17 due to AEs (6 flunarizine, 11 propranolol) Not randomized 1-mo results used in lieu of pre-treatment/baseline data Most patients had classical migraine
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | SPPG QS: 3 (nr, db+, dd) | N=87 Age: 43 74% female Classical or common migraine (Ad Hoc); ≥ 2 attacks/mo in past 6 mos or single attacks lasting several days Chron: N/S Rec: Hospital outpatient depts | Propranolol: 40 mg, 2x/day for 2 wks, then 3x/day; n = 34 Flunarizine: 10 mg, 1x/day (at night); n = 35 2-wk washout period; 4-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks/mo HA duration: Overall attack duration (hrs/mo) | Mean HA frequency (± SD) was reduced in the flunarizine group from 6 (± 6) after one month of treatment to 4 (± 5) after 4 months. A similar reduction was observed in the propranolol group, from 5 (± 6) to 3 (± 5). Mean HA duration (± SD) was reduced from 25 (± 39) after one month to 19 (± 29) after 4 months in the flunarizine group, and from 19 (± 37) to 14 (± 14) in the propranolol group. There were no statistically significant differences between the two treatments for these outcomes (no p- values reported). | Dropouts: 18 (21%),6 due to AEs (2 flunarizine, 4 propranolol) Not randomized 1-mo results used in lieu of pre-treatment baseline data Most patients had classical migraine
Ludin, 1989 | SPPG QS: 4 (r, db+, dd) | N = 59 Age: 34 71% female Common or classical migraine; ≥ 6 attacks in past 6 mos Chron: N/S Rec: N/S | Propranolol: 40 mg, 3x/day; n = 32 Flunarizine: 10 mg, 1x/day; n = 27 1-mo baseline period (placebo); 4-mo treatment period; no follow-up Patients allowed to use their usual acute meds | HA index: Total monthly duration times severity HA frequency: No. of attacks/mo HA severity: Each attack graded on scale of 1–3 (no interference with daily activities, interference with daily activities, normal daily activities impossible); mean attack severity calculated for each month HA duration: In hrs; mean attack duration calculated for each month of trial | Mean HA index (± SD) was not significantly reduced in the flunarizine group (no p-value reported) and was actually slightly higher during the last month of treatment (93.0 [± 154.1]) than during the baseline period (92.9 [± 90.3]). In the propranolol group, the mean HA index was reduced over the same period of time from 121.4 (± 123.2) to 66.9 (± 74.1) (p<0.005). Both treatments significantly reduced mean HA frequency compared with baseline values. Pre-treatment mean frequency (± SD) in the flunarizine group was 6.6 (± 4.9); during the last month of treatment, it was 4.8 (± 6.2) (p<0.01). Corresponding values in the propranolol group were 6.1 (± 3.9) and 3.7 (± 4.2), respectively (p<0.0005). 13/27 (48%) of patients in the flunarizine group achieved a 50% or more reduction in monthly HA frequency during the trial, as did 16/32 (50%) of patients in the propranolol group. Propranolol, but not flunarizine significantly reduced mean HA intensity. Neither treatment affected mean HA duration. Investigators reported that there were no significant differences between the two treatments for any of the outcome measures analyzed (no p-values reported for between-group comparisons). | Dropouts: 11 patients (19%) withdrew before completing the trial, 5 due to AEs (2 flunarizine, 3 proranolol); these 11 patients were nonetheless included in the efficacy analysis (last available scores used for later timepoints)
Lundberg, 1969 | SPPG QS: 3 (r, db, dd) | N = 50 Age: 35 74% female Classic or common migraine; ≥ 1 attack/mo Chron: N/S Rec: Referrals to investigator | Placebo: n = 23 Flumedroxone: 5 mg, 2x/day; n = 21 No baseline period; 1-mo treatment period; open trial followed double-blind trial Acute meds (ergotamine or analgesics) permitted | HA frequency: No. of attacks/mo | Flumedroxone was significantly better than placebo at reducing HA frequency compared with pre-treatment values (p<0.0005). After 1 month of treatment, 1 patient in the flumedroxone group (5%) was unchanged, 13 (62%) had fewer attacks than before, and 7 (33%) were completely free of attacks. Corresponding figures in the placebo group were 14 patients (61%), 8 (35%), and 1 (4%), respectively. | Dropouts: 6 (12%), none due to AEs Baseline values taken from patient histories "Small number" of patients had been treated with progestogens or methysergide before, with unsatisfactory results
Malvea, Gwon, and Graham, 1973 | CrOv QS: 2 (r, ndb, dd) | N = 31 Age: N/S (range: 25–57) 86% female Common migraine; ≥ 1 HN/wk Chron: N/S Rec: Clinic of unspecified type | Placebo: n = 29* Propranolol: Dose N/S; n = 29* 30-day baseline period (no prophylactic med); two 6-wk treatment periods; no washout; no follow-up Acute meds (analgesics, narcotics, ergots) permitted | HA index: Sum of severity scores; severity of each attack graded on scale of 1–3 (mild/annoying, moderate/interfering, severe/incapacitating) | Mean total HA index scores per day were 25.4 during the baseline period, 23.3 on placebo, and 18.6 on propranolol (no variance data reported). Investigators did not report whether they found the difference between placebo and propranolol to be statistically significant. | Dropouts: 2 (6%), neither due to AEs Low quality score (2); not double-blind
Markley, Cheronis, and Piepho, 1984 | CrOv QS: 3 (r, db, dd) | N =20 Age: 33 86% female Common or classic migraine; ≥ 3 HAs/mo in past yr Chron: 13 yrs Rec: N/S | Placebo: n = 14* Verapamil: 80 mg, 3x/day; n = 14* 4-wk baseline period (no prophylactic med); two 8-wk treatment periods; no washout; no follow-up Use of acute meds permitted | HA index: Severity times duration for each attack; individual attack scores then summed for each week HA frequency: No. of HAs per week HA severity: Each attack graded on scale of 1–5 (warning of potential HA, but no pain; mild; moderate; severe; excruciating) HA duration: Recorded (in hrs) for each attack | Verapamil was significantly better than placebo for HA index (p<0.005). Mean weekly HA index scores, post-treatment, were 72.6 for verapamil and 116.4 for placebo (no variance data reported). Post-treatment mean weekly HA frequency was also significantly lower with verapamil (2.8) than with placebo (3.4) (p<0.05; no variance data reported). Verapamil was also significantly better than placebo for HA duration (p<0.05). HA severity was not significantly affected (no data and no p-value reported). | Dropouts: 6 patients (30%) withdrew during 1st treatment period with intractable HAs; 2 others (10%) withdrew before completing trial (one due to AEs with verapamil), but were included in the efficacy analysis 8/14 patients included in the efficacy analysis had had no success when treated with prophylactic med in past
Martucci, Manna, Mattesi, et al., 1983 | CrOv QS: 3 (r, db, dd) | N = 90 Age: 37 (range: 20–50) 60% female Common migraine (Ad Hoc); history ≥ 5 yrs; no migraine preventive therapy in previous 6 mos Chron: N/S Rec: HA clinics | Placebo: n = 79* DHE (timed-release): 5 mg, 2x/day; n = 79* No baseline period described; two 45-day treatment periods; no washout; no follow-up Patients permitted to take their usual meds for acute attacks | HA index: Severity times frequency HA frequency: No. of attacks HA severity: Not described; severity graded each day on scale of 0–4 (no HA; no medication required; no disability after medication; partial disability with medication; total disability, even with medication) HA duration: Mean per attack (in hrs) | Results for all outcomes were reported separately for "daily migraine" (occurring during the day), "night migraine" (patient awakens with HA), and "awakening migraine" (onset within 1 hr of awakening). It was not clear whether this division represented a stratified analysis of different HA episodes or of different subgroups of patients. Mean HA index was lower with DHE than with placebo for all three HA types/patient groups (19.47 vs. 26.92 for daily; 0.28 vs. 1.63 for night; 11.57 vs. 16.49 for awakening); no variance data or p-values were reported. HA frequency was significantly lower with DHE than with placebo in all three HA types/patient groups (p<0.01, daily; p<0.005, night; p<0.02, awakening). HA severity was significantly lower with DHE than with placebo for night migraines (p<0.05); otherwise, there were no significant differences between the two treatments for HA severity or duration. | Dropouts: 11 (12%),6 due to AEs (all DHE)
Masel, Chesson, Peters, et al., 1980 | CrOv QS: 4 (r, db+, dd) | N =40 Age: 35 (median) (range: 21–64) 92% female Migraine; > 1 attack/mo Chron: N/S Rec: Referrals to neuro dept | Placebo: n = 25* Aspirin + dipyridamole: 325 + 25 mg, 3x/day; n = 25* No baseline period described; two 3-mo treatment periods; no washout; no follow-up All patients given acetaminophen 325 mg + codeine 30 mg to take for acute migraine attacks; aspirin and antihistamines not permitted as treatments for acute attacks | HA frequency: No. of HAs/mo HA severity: Each attack graded on continuum from 0–100 (no pain-maximum pain tolerable) | HA frequency was significantly lower with aspirin + dipyridamole than before treatment (p<0.01) or with placebo (p<0.01; Mann Whitney U-test). Median frequency was 2.00 pre-treatment, 2.33 with placebo, and 1.33 with aspirin + dipyridamole. Similar results were reported for HA severity. | Dropouts: 15 (38%), none due to AEs High dropout rate (38%) Not clear how pre-treatment values established
Mastrosimone, laccarino, and de Caterina, 1992 | SPPG QS: 4 (r, db+, dd) | N = 61 Age: 43 (range: 24–51) 72% female Classical or common migraine (Ad Hoc); > 2-yr history; markedly reduced sense of well-being during attacks; > 4 HAs during anamnestic baseline period Chron: 12 yrs Rec: N/S | Pizotifen: 0.5 mg, 3x/day; n = 26 Cyclandelate: 800 mg, 2x/day; n = 35 1-mo anamnestic baseline period (no migraine meds); 1-mo placebo baseline period; 3-mo treatment period; no follow-up Acute meds permitted | Daily total pain index: Score calculated every day =sum of severity scores for every hr of day, where severity graded on scale of 0–4 (no HA - very severe HA); mean daily score/mo calculated HA frequency: No. of attacks/mo | Both drugs reduced the total pain index significantly in comparison to baseline values from the first month of treatment on (p<0.001 for both treatments and all months). Cyclandelate was signficantly better than pizotifen, beginning in the first month and continuing through the second and third months of treatment (p<0.001 for all three months). During the third treatment month, the total pain index was reduced by 64.0% in the cyclandelate group and 52.1 % in the pizotifen group. Very similar results were reported for HA frequency. During the third month of treatment, HA frequency was reduced by 77.6% in the cyclandelate group and 31.5% in the pizotifen group. | Dropouts: 0/61 during active treatment periods; 23/84 patients were excluded before active treatment began for noncompliance or as placebo responders (> 40% reduction in frequency of attacks during placebo baseline period compared to anamnestic baseline period)
Mathew, 1978 | CrOv QS: 2 (r, db, dnd) | N = 12 Age: N/S (range: N/S) % female N/S Common or classical migraine Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 12* Oxitriptan (5-HTP): 300 mg/day; n = 12* No baseline described; two 8-wk treatment periods; no washout; no follow-up No mention of acute migraine meds | HA index: Not defined | Investigators reported that "5-HTP was not superior to placebo in preventing migraine attacks," but did not provide further information. | Dropouts: N/S Information obtained from abstract
Mathew, 1981 | SPPG QS:2 (r, ndb, dd) | Migraine-only: N = 340 Age: 36 94% female Chron: N/S Rec: N/S Mixed HA: N =375 Age: 40 96% female Chron: N/S Rec: N/S | Control (abortive admin. of ergotamine + analgesic): n = 33 (migraine), 35 (mixed); total ergotamine intake s; ≤ 6 mg/wk Propranolol: n = 38 (migraine), 38 (mixed); 20 mg 3x/day initially; increased to 40 mg 3 or 4x/day within first month of treatment, as tolerated Amitriptyline: n =32 (migraine), 31 (mixed); 25 mg/day for 2 wks, then increased to 50–75 mg/day in first month, as tolerated Biofeedback (combined EMG + thermal) + relax. (AT phrases): n = 31 (migraine), 31 (mixed); ten 1-hr sessions over 6 mos; home practice ≥ 30 min, at least 1x/day Propranolol + amitriptyline: n = 38 (migraine), 36 (mixed); combined using dosages described above Propranolol + biofeedback (as above): n = 33 (migraine), 34 (mixed); combined using dosage and procedure described above Amitriptyline + biofeedback (as above): n =38 (migraine), 39 (mixed); combined using dosage and procedure described above Propranolol + amitriptyline + biofeedback (as above): n = 30 (migraine), 37 (mixed); combined using dosages and procedure described above 1-mo baseline period; 6-mo treatment period; no follow-up Use of acute meds permitted | HA index: Average weekly HA index, derived from frequency and severity ratings HA frequency: Definition N/S HA intensity: Scale used for grading N/S, but recorded for each attack | Improvement was expressed as the percentage of change in mean weekly HA index scores from pre-treatment to the last 3 mos of treatment. Migraine results: Each active treatment group experienced significantly better improvement than did the control group (no p-values reported). The improvement percentages ranged from 35–74% for the active treatment groups, compared with 20% for the control group. The combination of propranolol + biofeedback yielded the best results (74%); adding amitriptyline to this combination did not produce a significant change (73%). Propranolol alone resulted in a 62% improvement, amitriptyline alone in a 42% improvement (p < 0.01 in favor of propranolol). Propranolol + amitriptyline (64%) was not significantly better than propranolol alone (62%) (p<0.50). Treatment with biofeedback alone resulted in a 35% improvement. Adding biofeedback to treatment with propranolol or amitriptyline improved both (propranolol, from 62% to 74%; amitriptyline, from 42 to 48%). Mixed HA results: Percentage improvement scores in the active treatment groups ranged from 48%–76%, compared to 18% for the control group. The most effective treatment was the combination of propranolol + amitriptyline + biofeedback (76%). Amitriptyline alone was significantly better than propranolol alone (60% vs. 52%) (p < 0.01), and the combination of propranolol + amitriptyline (69%) was superior to either drug on its own (p < 0.01). Biofeedback alone yielded a 48% improvement. Adding biofeedback to the active drug therapies produced an improvement in every case (from 52% to 62% for propranolol alone; from 60% to 66% for amitriptyline alone; and from 69% to 76% for propranolol + amitriptyline). | Dropouts: Migraine-only, 67 (20%),18 due to AEs; mixed HA, 94 (25%), 29 due to AEs Low quality score (2); not double-blind
Mathew, Saper, Silberstein, et al., 1995 | SPPG QS: 4 (r, db+, dd) | N = 107 Age: 46 78% female Migrain w/ or w/o aura (IHS); history ≥ 6 mos; ≥ 2 attacks in previous 3 mos; patients with chronic daily HA or TTH on ≥15 days/mo excluded Chron: 25 yrs Rec: HA and neuro clinics | Placebo: n = 36 Divalproex sodium: Dose titrated to achieve serum level of approximately 70–120 mg/L; average dose 1087 mg/day; n = 69 4-wk baseline phase (placebo); 12-wk treatment phase (4 wks dose adjustment + 8 wks maintenance); no follow-up Patients permitted to use symptomatic meds to treat acute attacks, but use of such meds must average < 3 days/wk | HA frequency: Mean 4-wk attack frequency; percentage reduction in mean 4-wk attacks frequency; percentage of patients reporting a ≥ 50% reduction in frequency HA severity: Peak severity per attack, on scale of 0–4 (none-excruciating) HA duration: Per attack, in hrs | Divalproex sodium was significantly better than placebo at reducing HA frequency. Mean 4-wk HA frequencies at baseline were 6.4 in the placebo group and 6.0 in the divalproex sodium group; during the treatment phase, these numbers were reduced to 5.7 and 3.5, respectively (p≤0.001; no variance reported). Mean change scores (from baseline to treatment phase) were also significantly higher in the divalproex sodium group (p<0.001; mean change scores not reported). The proportions of patients reporting a 50% or greater reduction in mean 4-wk attack frequency were 14% in the placebo group (5/36) and 48% in the divalproex sodium group (33/69). Divalproex sodium was significantly better than placebo for this outcome (p<0.001). No significant differences were observed between the two treatments for HA severity or duration. | Dropouts: 17 (16%), 11 due to AEs (9 divalproex sodium, 2 placebo); 15 of the 17 dropouts provided some efficacy data and were included in the efficacy analysis Only patients who were previously untreated or had failed ≤ 2 trials of prophylactic med were included
McArthur, Marek, Pestronk, et al., 1989 | CrOv QS: 2 (nr, db, dd) | N = 24 Age: N/S % female N/S Classic migraine (Ad Hoc) Chron: N/S Rec: Personal referral and ads | Placebo: n = 14* Nifedipine: 20 mg, 3x/day for 3 days; increased to 30 mg, 3x/day if no AEs; n = 14* 1-mo baseline period (no prophylactic med); two 3-mo treatment periods; 1-wk washout; no follow-up Use of acute meds permitted | HA frequency: No. of attacks of classic migraine per month | All patients (n = 14) who completed at least 10 wks of treatment in each phase of the trial were included in the efficacy analysis. There was no significant difference between nifedipine and placebo for post-treatment HA frequency (p=0.56). Mean HA frequency (± SEM) during the third month of treatment was 1.9 (± 0.5) with nifedipine and 2.1 (± 0.4) with placebo. | Dropouts: 10 (42%),6 due to AEs (5 nifedipine. 1 placebo)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | SPPG QS: 5 (r+, db+, dd | N = 30 Age: 44 (median) (range: 20–65) 80% female Classical migraine (Ad Hoc); ≥ 1-yr history; ≥ 4 mod-severe attacks in previous 3 mos; no other types of HA; no prophylactic med in last 2 mos Chron: 5 yrs Rec: Neuro and psychiatric dept | Placebo: n = 11 Flunarizine: 10 mg, 1x/day (at night); n = 9 1-mo baseline period (medication-free); 3- mo treatment period; 15 patients (8 placebo, 7 flunarizine) continued in double-blind trial for additional month Acute meds permitted during treatment period | Severity of each attack (HA and other symptoms) graded on scale of 1–4 (mild, mild to moderate, moderate, rather severe); following outcome measures calculated: Migraine index: No. of attacks/mo times mean monthly severity of attack Corrected migraine index: Migraine index times mean monthly duration of attack HA frequency: Mean no. of attacks/mo Attack severity: Mean monthly severity Attack duration: Mean duration/mo (in hrs) | Flunarizine was significantly (p<0.05) better than placebo for reduction in the corrected migraine index from pre-treatment to end of treatment (after 3 mos in 5 patients and after 4 mos in 15 patients). In the flunarizine group, the mean corrected migraine index (± SEM) was 34.7 (± 10.2) pre-treatment and 6.2 (± 2.5) at the end of treatment; in the placebo group, the corresponding means were 37.0 (± 9.3) and 61.6 (± 18.9), respectively. Mean migraine index scores in the flunarizine group were reduced from 13.3 pre-treatment to 3.6 after 3 mos. In the placebo group, scores rose slightly over the same period of time from 17.5 to 18.6 (no variance data or p-values reported). Differences between the two treatments for reduction in HA frequency were statistically significant only during the third month of treatment (p=0.033). | Dropouts: 10 patients (33%) withdrew before the end of the baseline period; 5 (17%) withdrew after completing 3 mos of treatment (3 placebo, 2 flunarizine), none due to AEs 10/20 patients completing the trial had been treated with prophylactic med before, generally with moderate or unsatisfactory results
Meyer and Hardenberg, 1983 | CrOv as: 3 (r, db+, dnd) | N =35 Age: 41 78% female Classic or common migraine (n = 27) or cluster HA (n = 8) (Ad Hoc); ≥ 2 HAs/mo Chron: N/S Rec: N/S | Nimodipine, 60 mg/day: 20 mg, 3x/day; n = 27* (migraine) Nimodipine, 120 mg/day: 40 mg, 3x/day; n = 27* (migraine) 1-wk baseline period (no prophylactic med); two 8-wk treatment periods; 1-wk washout; no follow-up Acute meds permitted, with some restrictions | HA frequency: Mean frequency/mo (not clear whether no. of attacks or no. of HA days) HA severity: Outcome measure not described; each HA graded as mild, moderate, or severe HA duration: Not described | Both doses of nimodipine significantly reduced mean HA frequency per month in comparison to baseline values (no p-values reported). There was no significant difference between the two doses for this outcome (no p-value reported). Pre- and post-treatment mean frequencies themselves were not reported. Neither dose significantly reduced HA severity or duration (no data and no p-values reported). | Dropouts: Not described
Micieli, Trucco, Agostinis, et al., 1985 | CrOv QS: 3 (r, db, dd) | N = 22 Age: 47 55% female Common migraine; no interval HA; no prophylactic med in previous 6 mos Chron: 23 yrs Rec: N/S | Pizotifen: 0.5 mg, 3x/day; n =20* Nimodipine: 40 mg, 3x/day; n = 20* 1-mo baseline period (placebo); two 3-mo treatment periods; 1-mo washout (placebo); no follow-up Acute meds permitted | HA index: Not described HA frequency: No. of attacks/mo | Post-treatment mean scores for HA index and HA frequency were reported only for the first treatment period and only for the two treatment groups combined. Reductions were significant from baseline to 3 mos (p<0.001 for both outcomes). Investigators reported that an ANOVA analysis showed no significant differences between the two treatments (no p-values reported). | Dropouts: 2 (9%); reasons for withdrawal not stated Abstract reporting limited results
Migraine- Nimodipine European Study Group, 1989a | SPPG QS: 4 (r, db+, dd) | N = 89 Age: 34 79% female Classic migraine (Ad Hoc); 2–8 migraine days/mo (including baseline period); ≥ 2 classic attacks in previous 6 mos; no cluster HA; TTHs ≤ 6 days/mo Chron: 13.5 yrs (median) Rec: Neuro depts | Placebo: n =46 (intention-to-treat); n =39 (valid for efficacy analysis) Nimodipine: 40 mg, 3x/day; n = 43 (intention-to-treat); n = 33 (valid for efficacy analysis) 4-wk baseline period; 12-wk treatment period; no follow-up Nothing on acute meds | HA index: No. of migraine days times HA severity per 4 wks; included attacks with and without aura HA frequency: No. of migraine days per 4 wks | An intention-to-treat analysis showed no significant difference between nimodipine and placebo for reduction in HA index from pre- to post-treatment (no p-value reported). Mean monthly HA index values in the nimodipine group were 7.7 during the baseline period and 2.1 during the treatment period (no variance data reported). Corresponding values in the placebo group were 8.1 and 0.9, respectively. Results were similar when the smaller group of patients valid for the efficacy analysis were considered. Mean monthly HA index scores in the nimodipine group were 11.35 during the baseline period, 3.24 after one mo of treatment, 2.69 after two months, and 2.47 after three mos. Corresponding scores in the placebo group were 10.30, 3,46, 3.08, and 1.00, respectively (no variance data reported). The difference between the two groups was not significant (no p-value reported). Similar results were reported for HA frequency. | Dropouts: 17 patients (19%) were excluded from the analysis of efficacy, 7 due to AEs (3 nimodipine, 4 placebo); the other 10 were excluded at the completion of the baseline period Patients who had tried 2 or more prophylactic drugs w/o success were excluded
Migraine- Nimodipine European Study Group, 1989b | SPPG QS: 4 (r, db+, dd) | N = 192 Age: 38 78% female Common migraine (Ad Hoc); 2–8 migraine days/mo (including baseline period); ≤ 1 attack of classic migraine in previous 6 mos; no cluster HA; TTH ≤ 6 days/mo Chron: 16 yrs (median) Rec: Neuro depts | Placebo: n = 98 (intention-to-treat); n = 85 (valid for efficacy analysis) Nimodipine: 40 mg, 3x/day; n = 94 (intention-to-treat); n = 76 (valid for efficacy analysis) 4-wk baseline period; 12-wk treatment period; no follow-up Nothing on acute meds | HA index: No. of migraine days times HA severity per 4 wks HA frequency: No. of migraine days per 4 wks | An intention-to-treat analysis showed no significant difference between nimodipine and placebo for reduction in HA index from pre- to post-treatment (p=0.91). Mean monthly HA index values in the nimodipine group were 9.27 during the baseline period and 4.19 during the treatment period (no variance data reported). Corresponding values in the placebo group were 8.78 and 3.87, respectively. Results were similar when the smaller group of patients valid for the efficacy analysis were considered. Mean monthly HA index scores in the nimodipine group were 9.39 during the baseline period, 5.35 after one mo of treatment, 5.67 after two months, and 3.29 after three mos. Corresponding scores in the placebo group were 8.55,4.87,3.40, and 3.50, respectively (no variance data reported). Analysis of covariance showed no significant difference between the two treatments for this outcome (p=0.58). Similar results were reported for HA frequency. | Dropouts: 31 patients (16%) were excluded from the analysis of efficacy, 4 due to AEs; 12 of the 31 were excluded for protocol violations during the baseline period Patients who had tried 2 or more prophylactic drugs w/o success were excluded
Mikkelsen and Falk, 1982 | CrOv QS: 4 (r, db+, dd) | N = 38 Age: 35 (median) (range: 18–52) 87% female Classic or common migraine (Ad Hoc); history > 1 yr; > 2 HAs/mo Chron: N/S Rec: Neuro dept | Placebo: n = 31 * Tolfenamic acid: 100 mg, 3x/day; n = 31* No baseline period described; two 10-wk treatment periods; 2=wk washout; no follow-up Acute meds permitted | HA frequency: No. of attacks HA severity: Recorded for each attack on scale of 1–5 (not described) HA duration: Total duration (in hrs) | Tolfenamic acid was significantly better than placebo for HA frequency (p<0.01). 22 patients had fewer attacks on tolfenamic acid; 6 had fewer attacks on placebo, and 3 had the same number of attacks with both interventions. Based on individual patient data reported by investigators, we were able to calculate the mean within-patient difference in HA frequency for tolfenamic acid vs. placebo. The mean difference was 2.3 (± 3.2). Tolfenamic acid was significantly better than placebo for both HA severity and HA duration (p<0.01 for both outcomes). | Dropouts: 7 (18%), 3 due to AEs (2 tolfenamic acid, 1 placebo)
Mikkelsen, Kjærsgaard Pedersen, and Christiansen, 1986 | CrOv QS: 4 (r, db+, dd) | N = 39 Age: 38 (median) (range: 15–65) 84% female Classic or common migraine (Ad Hoc); ≥1-yr history; ≥ 3 HAs/mo Chron: N/S Rec: Neuro dept | Placebo: n = 31* Propranolol: 40 mg, 3x/day; n = 31* Tolfenamic acid: 100 mg, 3x/day; n = 31* No baseline period described; three 12-wk treatment periods; no washout; no follow-up Data analyzed for last 11 wks of each treatment period only Acute meds permitted | HA frequency: No. of attacks HA severity: Mean severity per attack; each attack graded on scale of 1–10 (not described) HA duration: Total duration of attacks (in hrs); mean duration per attack (in hrs) | There was a significant difference among the three treatments for HA frequency (p<0.005, Friedmann's test), with the number of attacks significantly larger with placebo. No significant difference was found between tolfenamic acid and propranolol for this outcome (95% confidence limits, −1.6 to +1.5 attacks). Based on individual patient data reported by investigators, we calculated mean within-patient differences in HA frequency for the various treatment comparisons. For tolfenamic acid vs. placebo, the mean difference was 2.29 (± 5.2); for propranolol vs. placebo, it was 2.5 (± 4.8); and for tolfenamic acid vs. propranolol, it was −0.23 (± 4.6). Tolfenamic acid, but not propranolol, was significantly better than placebo for HA intensity. There was no significant difference between the two active treatments for this outcome. None of the three interventions significantly reduced mean HA duration (per attack). Tolfenamic acid and propranolol were both significantly better than placebo, and not different from one another, for total HA duration. | Dropouts: 8 (21 %), 3 due to AEs (2 propranolol, 1 tolfenamic acid) Statistical analysis showed no carry-over effect
Mondrup and Møller, 1977 | CrOv QS: 4 (r, db+, dd) | N = 32 Age: 35 (range: 17–54) 76% female Chron: 12 (range: 1–40) Common or classical migraine (Ad Hoc); ≥ 2 Ms/mo for > 1 yr Excl: Previous use of clonidine Rec: Neurology dept. of hospital in Denmark | Placebo: n = 21* Clonidine: 50 μg, 2x/day for 1 wk; dose then increased to 75 μg, 2x/day for 11 wks; n = 21* Baseline period (length N/S); two 12-wk treatment periods; three 4-wk washout periods, 1 before and after each treatment period; no follow-up Acute migraine meds permitted during trial | HA index: Calculated by multiplying the HA intensity ratings (1 =mild; 2=moderate; 3=severe) and summing them HA frequency: Recorded by pt as "dates of attacks" and reported as "no. of HA days" | Results were reported only as median differences. For HA index, the median difference between clonidine and placebo was −4 (with 95% confidence limits of from −10 to +5 days). For comparisons of pre- to post-treatment results for HA index, investigators reported only that there were no significant differences between the two treatments (no p-value given). For HA frequency, the median difference between clonidine and placebo was −2 days (with 95% confidence limits of from −6 to +2 days). Investigators reported that there was no statistically significant difference between the two treatments for frequency (no p-value given). A comparison of HA frequency from baseline to post-treatment revealed a 16% reduction from treatment with clonidine and a 30% reduction from treatment with placebo. Investigators reported that the difference between the two treatments was not significant (no p- value given). | Dropouts: 11 (34%), none due to AEs Data recorded by pts and assessed every 4 wks by investigators Investigators reported that the large no. of withdrawals and small no. of pts may have biased results
Monro, Swade, and Coppen, 1985 | SPPG QS: 4 (r, db+, dd) | N = 38 Age: N/S % female N/S Classical or common migraine (World Fed Neurol); ≥ 1 attack/wk Chron: N/S Rec: N/S | Placebo: n = 18 Mianserin: 30 mg, 1x/day (at night) for first wk; then 60 mg, 1x/day (at night) for duration of trial; n = 16 2-wk baseline period (placebo); 16-wk treatment period; no follow-up Acute attacks treated with metoclopramide + acetaminophen (po), ergotamine + caffeine (po), or ergotamine (in) | HA frequency: Mean no. of attacks/4 wks HA severity: Sum of severity ratings for each 4-wk segment of treatment period (each HA graded on scale of 1–3) | Compared with pre-treatment values, mianserin resulted in a significant reduction in HA frequency at 4 and 12 wks (p<0.01 and p<0.05, respectively). Placebo did not produce a significant reduction at any timepoint (no p-values reported). When the two treatments were directly compared for this outcome, there was no significant difference between them (no p-value reported). Mean HA frequencies were reported only in graphic form and could not be reliably read off the graph. Similar results were reported for HA severity. | Dropouts: 4 (11 %) (no reasons specified)
Murphy, Heptinstall, and Mitchell, 1988 | CrOv QS: 3 (r, db, dd) | N = 72 Age: 46 (range: 24–72) 74% female Common or classical migraine; ≥ 1 HA/mo for ≥ 2 yrs Chron: N/S Rec: Migraine self-help group; media publicity | Placebo: n = 59* Feverfew: 1 cap/day (cap weights ranged from 70–114 mg [mean 82 mg]); n = 59* 1-mo baseline (placebo); two 4-mo treatment periods; no washout; no follow-up No meds permitted during trial for acute migraine attacks | HA frequency: No. of attacks HA intensity: Recorded daily by patients on 4- point scale (0=no pain; 1=mild, not interfering with daily activities; 2=severe, reducing working capacity; 3=very severe, requiring rest in bed) | For HA frequency, the post-treatment mean values (± SEM) were 3.6 (± 0.2) and 4.7 (± 0.3) for patients treated with feverfew and placebo, respectively. Investigators reported that feverfew was significantly better at reducing HA frequency than was placebo (p < 0.005). Investigators did not report having analyzed the pre- to post-treatment differences for statistical significance. | Dropouts: 12 patients (17%) withdrew and were not included in efficacy analyses, 5 due to AEs (feverfew 2, placebo 3); another patient lost her diary twice, so was also excluded from efficacy analyses 18 (24%) of 76 patients originally selected for the study had previously used feverfew; of the 59 patients completing the trial, 42 had never previously taken the active drug; on entry to trial, 5 patients were still using the treatment
Nanda, Johnson, Gray, et al., 1978 | CrOv QS: 4 (r, db+, dd) | N =43 Age: N/S 74% female Migraine; > 2 attacks/mo Chron: N/S Rec: Migraine clinic | Placebo: n = 33* Acebutolol: 400 mg, 2x/day (dose gradually increased over first 2 wks); n = 33* 4-wk baseline period; two 12-wk treatment periods; 4-wk washout (placebo); no follow-up Patients permitted to take their usual meds for acute attacks | HA frequency: No. of HAs per 4 wks HA severity: Mean attack severity; each attack graded on scale of 1–10 (not described) HA duration: Mean duration per attack (in hrs) | Both acebutolol and placebo significantly reduced mean HA frequency compared with baseline values (p<0.01), but there was no significant difference between the two interventions (no p-values reported). Overall mean frequencies were not reported. Neither intervention significantly affected HA severity or duration (no p-values and no further results reported). | Dropouts: 10 (23%), none due to AEs No carry-over effect High dropout rate (23%)
Nappi, Sandrini, Savoini, et al., 1987 | SPPG QS: 2 (r, db-, dd) | N =40 Age: N/S % female N/S Common migraine (Ad Hoc); history of ≥ 2 yrs; ≥ 3 attacks/mo; no prophylactic treatment in last 2 mos Chron: N/S Rec: Outpatients at HA clinic | Flunarizine: 5 mg, 1x/day (bedtime); n = 18 Cyclandelate: 800 mg, 2x/day; n = 19 1-mo baseline period (no medication); 1-mo placebo period; 3-mo active treatment period; no follow-up Acute meds permitted | HA index: No. of attacks/mo times severity; severity of each attack graded on scale of 1–3 (working capacity not affected; not able to work; bed rest required) HA frequency: No. of migraine days/mo | HA index scores were significantly lower during the second (p<0.05) and third (p<0.001) months of treatment with cyclandelate than during the baseline (placebo) period. Flunarizine produced significantly lower scores, compared to baseline (placebo) values, beginning with the first month of treatment (p<0.01; for mos 2 and 3, p<0.001). The percentage reduction in HA index scores from baseline (placebo) to the third treatment month was significantly greater in the flunarizine group than in the cyclandelate group (p<0.02). HA index scores and percentage reduction data were reported only in graphic form and could not be reliably read off the graphs. Both drugs significantly reduced HA frequency, cyclandelate beginning in the first month of treatment, flunarizine in the second month. Investigators did not state whether they found any significant differences between the two treatments for this outcome. Data on frequency were reported only in graphic form and could not be reliably read off the graphs. | Dropouts: 3 (8%), all due to AEs (2 flunarizine, 1 cyclandelate)
Nattero, Biale, and Savi, 1991 | CrOv QS: 2 (r, ndb, dd) | N = 110 Age: 38 (range: 17–66) 63% female Common migraine (IHS); frequency N/S Chron: N/S (range: N/S) Rec: N/S | Lisuride: 0.075 mg, 3x/day; n = 43* Pizotifen: 1.5 mg, 3x/day; n = 43* 4-wk run-in with acute, but not prophylactic, migraine meds permitted; two 16-wk treatment periods; 4-wk washout between treatment periods; no follow-up Analgesics permitted; no mention of other acute migraine meds | HA frequency: Defined as ''frequency of HAs/4 wks" HA intensity: Recorded daily by pts on 3-point scale | Ten of 43 pts (23%) and 15/43 pts (35%) reduced HA frequency by ≥ 50% from baseline to post-treatment in the lisuride and pizotifen groups, respectively. Each treatment group improved significantly from pre- to post-treatment (p < 0.05, each case). Investigators did not report between-group results. | Dropouts: 63 pts (57%) withdrew due to unspecified reasons; treatment groups N/S; 4 additional pts were not included in efficacy analyses Information obtained from abstract
Neuman, Demarez, Harmey, et al., 1986 | SPPG QS: 3 (nr, db+, dd) | N =40 Age: 47 45% female Migraine; ≥ 3 attacks/mo; no anti-migraine therapy in 15 days prior to trial Chron: N/S Rec: N/S | Placebo: n = 20 DHE (timed-release): 5 mg, 2x/day; n = 20 No baseline period described; 1-mo treatment period; no follow-up Acetaminophen permitted for the treatment of acute attacks | HA frequency: No. of attacks per month HA severity: Mean per attack; each attack graded on scale of 1–3 (mild; requires treatment, but not incapacitating; incapacitating) | DHE was significantly better than placebo at reducing HA frequency (p<0.001). Pre-treatment mean HA frequency (± SD) was 3.3 (± 0.6) in both treatment groups. After 1 month, mean frequency was 1.3 (± 0.6) in the DHE group and 3.0 (± 1.0) in the placebo group. Similar results were reported for HA severity. | Dropouts: 0 Not clear how baseline values established Not randomized
Noone, 1980 | CrOv QS: 4 (r+, db, dd) | N =21 Age: N/S % female N/S Common or classical migraine; ≥ 3 attacks in previous 8 wks Chron: N/S Rec: 2 private practices | Placebo: n = 10* Clomipramine: 10 mg, 3x/day; n = 10* No baseline period; two 8-wk treatment periods; no washout; no follow-up Use of acute meds permitted | HA frequency: Median no. of attacks HA severity: No. of severe attacks divided by the total no. of attacks (severe = requires patient to stop what he is doing and lie down) HA duration | Both interventions significantly reduced HA frequency from pre-treatment levels (p=0.0039 for both comparisons), but there was no significant difference between the two treatments for this outcome (p=0.46). The median HA frequency pre-treatment was 6 (range: 3–18). Post-treatment median frequencies were 3 (2–12) for clomipramine and 3.5 (1–20) for placebo. Neither intervention significantly affected HA severity or HA duration. | Dropouts: 11 (52%),2 due to AEs (both clomipramine) Very high dropout rate No washout Not clear how pre-treatment values established (no baseline period)
Olerud, Gustavsson, and Furberg, 1986 | SPPG QS: 4 (r, db+, dd) | N =28 Age: N/S (range: 17–61) 79% female Classic or common migraine (Ad Hoc); ≥ 2 attacks/mo in previous 4 mos Chron: N/S (range: 2–45 yrs) Rec: N/S | Propranolol: 40–80 mg, 2x/day; n = 14 Nadolol: 40–160 mg, 1x/day; n = 13 Baseline period (placebo) of at least 1mo; 6-mo treatment period; no follow-up Acute meds (analgesics or ergotamine) permitted | HA frequency: No. of attacks per month HA severity: Each attack graded on scale of 1–4 (mild, moderate, severe, incapacitating); median severity per attack reported HA duration: Median duration (in hrs) per attack | Both drugs significantly reduced median HA frequency compared with baseline values (p<0.01 for both comparisons); there was no significant difference between the two drugs for this outcome (no p-value reported). In the propranolol group, median HA frequency (with range) was reduced from 3.6 (1.6–15.0) pre-treatment to 1.9 (0.3–5.6) during treatment. In the nadolol group, the corresponding figures were 5.6 (2.5–25.5) and 2.7 (0.0–23.6), respectively. 8/14 patients in the propranolol group (57%) and 5/13 in the nadolol group (38%) reported a > 50% reduction in HA frequency; the investigators did not analyze this result. Neither treatment significantly affected HA severity or duration. | Dropouts: 1 patient (4%) withdrew after 3 mos due to AEs associated with nadolol, but was included in the efficacy analysis; one patient in the propranolol group completed the trial, but was not included in the efficacy analysis due to incomplete data
Olsson, Behring, Forssman, et al., 1984 | CrOv QS: 4 (r, db+, dd) | N =56 Age: 37 (range: 19–59) 73% female Classical or common migraine (World Fed of Neurology); 3–10 attacks/mo; patients with other types of vascular HA, chronic daily HA, and "non-separable" TTH excluded Chron: 21 yrs (range: 5–43) Rec: Neuro depts | Propranolol: 40 mg, 2x/day; n = 53* Metoprolol: 50 mg, 2x/day; n = 56* 4-wk baseline period (placebo); two 8-wk treatment periods; 4-wk washout (placebo); no follow-up Acute meds (ergotamine or analgesics) permitted | HA index: Severity times no. of migraine days; severity of each attack graded on scale of 1–3 (light, moderate, severe) HA frequency: No. of attacks per 4 wks; no. of migraine days per 4 wks | There were no statistically significant differences between metoprolol and propranolol for any of the outcomes measured (p-values not reported). Both drugs significantly reduced HA index in comparison with baseline values (p≤ 0.001 for both comparisons). Median HA index scores were 12.4 during the baseline period (n = 56), 8.7 during treatment with propranolol (n = 53), and 9.7 during treatment with metoprolol (n = 56). 16/53 patients (30%) reported a 50% or greater reduction in HA index scores with propranolol in comparison with baseline values, as did 21/56 (37%) with metoprolol. | Dropouts: 3 (5%), none due to AEs; all three included in efficacy analysis to point of withdrawal 16% of patients had tried preventive meds before
O'Neill and Mann, 1978 | CrOv QS: 2 (nr, db, dd) | N = 12 Age: 35 (range: 18–53) 42% female Classical or common migraine; ≥ 1 HN/mo Chron: 15 yrs (range: 3–40) Rec: N/S | Placebo: n = 12* Aspirin: 650 mg, 2x/day; n = 12* No baseline period described; two 3-mo treatment periods; no washout; no follow-up Abortive therapy permitted for acute attacks | HA frequency: No. of attacks per 3-mo treatment period | Investigators defined a positive treatment response to. aspirin as a > 50% reduction in HA frequency compared with placebo. 9/12 patients (75%) had such a response (p≤0.0001). Based on individual patient data reported by investigators, we calculated the mean Within-patient difference in HA frequency; it was 5.7 (± 3.4). | Dropouts: 1 patient (8%) withdrew after 4 mos (3 on placebo, 1 on aspirin) due to AEs (aspirin), but was included in the efficacy analysis Low quality score (2); not randomized
Orholm, Honoré, and Zeeberg, 1986 | SPPG QS: 3 (r, db, dd) | N = 65 Age: N/S 85% female Migraine; history ≥ 3 yrs; ≥ 6 attacks in previous 2 mos; avg duration ≥ 4 hrs; not using prophylactic med Chron: N/S Rec: 25 general practices | Placebo: n =28 Femoxetine: 200 mg/day initially, increasing over first nine days to 600 mg/day; if AEs experienced, dose could be reduced to 400 mg/day; n = 25 No baseline period described; 16-wk treatment period; no follow-up Nothing on use of acute meds | HA index: Not defined; median HA index/two-wk period reported HA frequency: Number of attacks; median/two-wk period reported | Investigators employed a nonparametric type of ANOVA analysis, assessing treatments, time course, and interaction between treatment and time course simultaneously. This analysis revealed no significant variation with time regardless of treatment, no difference between treatments disregarding time-course, and no interaction between treatment and time. HA index, wks 1–2 vs. wks 15–16: In the femoxetine group, the median HA index during wks 1–2 was 7.3; during wks 15–16, it was 6.3. In the placebo group, the median HA index for wks 1–2 was 6.8; for wks 15–16, it was 4.5 (no ranges specified). At the end of the study, the 95% confidence limits for the difference between femoxetine and placebo for this outcome were −1.8 to 4.4. HA frequency, wks 1–2 vs. wks 15–16: In the femoxetine group, median HA frequency was 2.1 in wks 1–2 and 2.3 in wks 15–16. In the placebo group, these values were 2.3 and 2.0, respectively (no ranges specified). At the end of the study, the 95% confidence limits for the difference between femoxetine and placebo for this outcome were −1.1 to 1.0. | Dropouts: 12 (18%),6 due to AEs (2 placebo, 4 femoxetine)
Osterman, 1977 | CrOv QS: 4 (r, db+, dd) | N = 30 Age: 37 (range: 23–49) 70% female Common or classical migraine (Ad Hoc); ≥ 2–3 HAs/mo Chron: 20 (range: 4–34) Rec: Neuro. dept. of hospital; 13 pts had never been treated with prophylactic meds | Placebo: n = 27* Iprazochrome (Divascan®): 2.5 mg, 1x/evening on Day 1; dosing schedule gradually increased by 1 cap/day to a total of 2 caps, 3x/day (15 mg/day) on Day 11 and until end of trial; n = 27* Pizotifen: 0.5 mg, 1x/evening on Day 1; dosing schedule gradually increased by 1 cap/day to a total of 2 caps, 3x/day (3 mg/day) on Day 11 and until end of trial; n = 27* No baseline period described; three 8-wk treatment periods; no washout, but first 2 wks of data from each treatment period excluded from analysis; no follow-up Ergotamine and other acute migraine meds permitted | HA index: Calculated weekly by multiplying no. of HAs by respective HA intensity scores HA frequency: Defined as "occurrence of HA" HA intensity: Rated on 3-point scale daily by pt | Results were reported as the "total mean of the individual HA indices/wk" for each treatment group. The total post-treatment mean values for pts treated with pizotifen, iprazochrome, and placebo were 1.6, 2.1, and 2.4, respectively. Investigators did not report pre-treatment mean values. They also did not report whether they analyzed pre-to post-treatment results for statistical significance. HA index was reduced significantly better by pizotifen than by placebo (p < 0.001) or by iprazochrome (p < 0.01). However, there were no significant differences between iprazochrome and placebo for this outcome (no p-value given). | Dropouts: 2 (7%) pts withdrew early & were not included in efficacy analyses (1 due to AEs from pizotifen); efficacy data also obtained from 1 additional pt, treated with only iprazochrome & placebo, who withdrew early Not clear if baseline data gathered
Palferman, Gibberd, and Simmonds, 1983 | CrOv QS: 4 (r, db+, dd) | N = 16 Age: 41 80% female Migraine Chron: 18 yrs Rec: N/S | Placebo: n = 10* Propranolol: 40 mg, 3x/day; n = 10* No baseline period described; two 8-wk treatment periods; no washout; no follow-up | HA index: Sum of severity scores per 4 wks; severity graded daily on scale of 0–4 (no HA, mild, moderate, severe, worst possible) HA frequency: No. of days with HA | Mean HA index scores were 52 on placebo and 47 on propranolol (no variance reported). The difference between the two treatments was not statistically significant (p>0.05). Similar results were reported for HA frequency. | Dropouts: 6 (38%), 1 due to AEs (placebo) Trial also included 20 patients with nonmigraine HAs, who are not described here
Pedersen and Møller, 1966 | CrOv QS: 4 (r, db+, dd) | N = 102 Age: N/S % female N/S Classic or common migraine (Ad Hoc); ≥ 1 HN/mo Chron: N/S (''fresh cases" to those lasting "many years") Rec: Neuro dept | Placebo: n = 60* Methysergide (prolonged-action): 6 mg/day (dosing schedule not described); n = 60* No baseline period described; two 6-wk treatment periods; 1-wk transition period (3 mg methysergide + placebo/day for all patients); no follow-up Ergotamine tartrate prescribed for acute treatment of severe attacks | HA frequency: No. of patients with a > 50% reduction in no. of HAs per 6-wk treatment period compared with pre- treatment values; mean within-patient difference between number of attacks in placebo period and in methysergide period HA severity: Each attack graded as "mild," "moderate," or "severe"; investigators analyzed the difference in the distribution of the various degreees of severity | HA frequency: 34/60 patients (57%) reported a 50% or greater reduction in the number of HAs during treatment with methysergide compared to pre-treatment values; 16/60 patients (27%) reported a reduction of this magnitude during treatment with placebo. The investigators' analysis found the difference between the two treatments to be statistically significant (no p-value reported). Investigators also calculated the difference between the number of attacks in the placebo period and in the methysergide period for each patient and then calculated the mean difference for the entire group (no individual patient or group mean data reported). Their analysis found that the reduction in HA frequency with methysergide was statistically significant (p=0.05; two-tailed test). Methysergide was significantly better than placebo for HA severity (no measure of statistical significance reported). | Dropouts: 42 (41%),7 due to AEs Not clear how pre-treatment values established Carry-over effect detected High dropout rate (41%)
Penzien, Johnson, Carpenter, et al., 1990 | SPPG QS: 2 (r, ndb, dd) | N = 22 Age: N/S % female N/S Migraine Chron: N/S Rec: N/S; U.S. | Relax. + thermal BF + cog-beh. coping skills (home-based): n = 11; three sessions (time N/S) × 6 wks + telephone consultations; therapist N/S; home practice (amt. N/S) Propranolol (60–160 mg Inderal® LA): n = 11; two sessions × 6 wks + telephone consultations | HA index: Definition N/S Both groups monitored HAs daily by diary for 4, 6, & 4 wks for pretreat., treatment, & posttreat., respectively. | Authors reported that there were no significant differences between treatments for reductions in HA index (mean reductions: behavioral, 42%; propranolol, 44%). Both groups reduced HA index significantly from pre- to posttreat. (p-values not given). Forty-six percent (5/11) and 55% (6/11) of pts in the behavioral and propranolol groups, respectively, were improved (achieved > 50% reduction in HA index from pre- to posttreat.). Thirty-six percent (4/11) and 18% (2/11), respectively, were moderately improved (achieved 25–50% reduction), and 18% (2/11) and 27% (3/11), respectively, were not improved (<25% reduction). | Dropouts: 0 Abstract reporting preliminary results
Pini, Ferrari, Guidetti, et al., 1985 | SPPG QS: 2 (nr, db, dd) | N =29 Age: 40 83% female Common or classic migraine; history > 5 yrs Chron: N/S Rec: Out-patients at university HA study center | Placebo: n = 14 (see note) Flunarizine: 10 mg, 2x/day for 2 wks; then 10 mg, 1x/day (bedtime); n = 14 (see note) 2-mo baseline period (placebo); treatment period lasted "up to 120 days"; no follow-up Acute meds permitted | HA index: Not described Corrected HA index: Not described HA severity: Not described | Flunarizine significantly reduced HA index compared with baseline values (p=0.013); placebo did not (p=0.308). Mean pre-and post-treatment HA index scores (± SD) were 0.54 (± 0.26) and 0.31 (± 0.38), respectively, in the flunarizine group (a reduction of 42.6%), and 0.33 (± 0.26) and 0.30 (± 0.32), respectively, in the placebo group (a reduction of 9.1%). The two treatments were not directly compared by investigators. Similar results were reported for the corrected HA index. Neither flunarizine nor placebo significantly affected HA severity (no data reported). | Dropouts: 0 Article reports that "half” of 29 patients received placebo, and “half” flunarizine. We used n = 14 for both groups in our calculations Low quality score (2); not randomized
Pita, Higueras, Bolaños, et al., 1977 | CrOv QS: 3 (r, db, dd) | N = 9 Age: 32 (range: 23–39) 78% female Classic or common migraine (Ad Hoc); ≥ 3–4 HAs/mo; previously un-responsive to preventive therapy Chron: 13 yrs (range: 1–27) Rec: Referrals from neurologists and psychiatrists | Placebo: n = 8* Propranolol: 40 mg, 4x/day; n = 8* No baseline period described; two 2-mo treatment periods; no washout; patients who reported success with propranolol continued treatment and were followed up at two-month intervals Acute meds permitted | HA frequency: Mean no. of attacks per 2-mo treatment period | Propranolol was significantly better than placebo at reducing HA frequency (p=0.01). Mean frequency was 7.5 (± 5.1) during treatment with placebo and 2.25 (± 1.2) with propranolol. | Dropouts: 1 (11%), due to AEs associated with propranolol No carry-over effect
Pradalier, Serratrice, Collard, et al., 1989b | SPPG QS: 4 (r, db+, dd) | N = 55 Age: 37 (range: 18–65) 76% female Migraine w/ or w/o aura (IHS); ≥ 2-yr history; 2–8 HAs/mo; no preventive med in two wks preceding trial Chron: N/S Rec: N/S | Placebo: n = 24 Propranolol (long-acting): 160 mg, 1x/day; n = 31 4-wk baseline period (placebo); 12-wk treatment period; no follow-up Patients permitted to take their usual med for acute attacks | HA frequency: No. of attacks per month | Propranolol was significantly more effective than placebo at reducing HA frequency (p=0.01). Mean HA frequencies (± SD) in the propranolol group were 6.11 (± 0.93) at the start of treatment and 3.15 (± 0.77) after 12 wks; corresponding figures in the placebo group were 6.00 (± 1.37) and 6.41 (± 1.70), respectively. | Dropouts: 14 (25%), none due to AEs; all 14 dropouts were included in the efficacy analysis Most patients had tried some type of preventive med before
Presthus, 1971 | CrOv QS: 3 (r, db, dd) | N = 21 Age: 43 (range: 24–53) 52% female Classic or common migraine Chron: N/S Rec: N/S | Methysergide: 1 mg, 3x/day; n = 19* Pizotifen: 0.5 mg, 3x/day; n = 19* No baseline period described; two 5-wk treatment periods; 1-wk washout (no medication); no follow-up; data from last 4 wks of each treatment period used for efficacy analysis Patients permitted to take meds for acute attacks | HA frequency: No. of attacks during last 4 wks of treatment period HA intensity: Sum of intensity scores for all HAs during last 4 wks of treatment period HA duration: Sum of duration of all HAs during last 4 wks of treatment period | The investigator reported individual patient data and analyzed them using students T test and the Wilcoxon rank sum test. No statistically significant differences were found between the two treatments for HA frequency, intensity, or duration (p>0.10 for all three outcomes). | Dropouts: 2 (10%),1 due to AEs (pizotifen)
Rascol, Montastruc, and Rascol, 1986 | SPPG QS: 5 (r+, db+, dd) | N = 35 Age: 38 (median) (range: 28–59) 71% female Common or classical migraine (Ad Hoc); history ≥ 2 yrs; ≥ 6 attacks in last 6 mos Chron: N/S Rec: Out-patient HA clinic | Pizotifen: Dose gradually increased over first week to 2.19 mg/day (three 0.73 mg tabs; partial doses taken in morning and at night [precise dosing schedule not described]); n = 14 Flunarizine: 10 mg, 1x/day; n = 21 No baseline period described; 4-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks/mo; no. of migraine days (as % of total number of days in observation period) HA severity: Not described | Both treatments significantly reduced the mean number of attacks per month compared with pre-treatment values, flunarizine in months 2, 3, and 4 (p<0.01, all three months), and pizotifen in months 3 and 4 (p<0.05 for both months). After 4 months, the number of attacks was reduced by 65% in the flunarizine group and by 45% in the pizotifen group. The difference between the two groups was not statistically significant (no p-value reported). The number of migraine days per month was reduced over 4 months to 37% of the pre-treatment number in the flunarizine group and to 50% of the pre-treatment number in the pizotifen group. There were no significant differences between the two treatments for any month (no p-values reported). No actual HA frequencies (either no. of attacks or no. of migraine days) were reported. There were no significant differences between the two treatments for HA severity (no data and no p-values reported). | Dropouts: 3 (9%),2 due to AEs (1 each flunarizine and pizotifen); these 3 patients included in efficacy analysis Approximately 2/3 of patients had never used prophylactic meds before Not clear how baseline/pre-treatment values derived (no baseline period described)
Rompel and Bauermeister, 1970 | CrOv QS: 5 (r+, db+, dd) | N = 48 Age: N/S (range: 14–60) 69% female "Typical" migraine (with aura) Chron: N/S Rec: N/S | Placebo: n = 48* Carbamazepine (Tegretol®): 200 mg. 3x/day; n = 45* No baseline period described; two 6-wk treatment periods; no washout; no follow-up Nothing on acute meds | HA index: Not described, but appears to have somehow combined frequency and severity; investigators reported no. of patients much worse, slightly worse, unchanged, slightly to moderately improved markedly to completely improved HA frequency: No. of attacks/mo | HA index was markedly or completely improved in 26/45 patients taking carbamazepine (58%) and in 5/48 patients taking placebo (10%) (no p-value or other measure of statistical significance reported). Pre-treatment HA frequency averaged 2.97 HAs/month for the entire patient group. During the treatment phase, 30 attacks were reported by 45 patients during treatment with carbamazepine (0.67 attacks/patient); with placebo, 48 patients reported 186 attacks (avg 3.87 attacks/patient) (no p-value or other measure of statistical significance reported). | Dropouts: 3 (6%), 1 due to AEs (carbamazepine); drop-outs not included in efficacy analysis Investigators suspected a carry-over effect, but could not demonstrate one statistically Not completely certain that HA index outcomes based on diary data Baseline values based on patients' histories
Ryan, 1968 | CrOv QS: 3 (r, db+. dnd) | N = 62 Age: N/S % female N/S Classic or common migraine; ≥ 3–4 HAs/mo Chron: N/S Rec: N/S | Placebo: n = 62* Methysergide: 2 mg, 2x/day; n = 62* Pizotifen: 2 mg, 2x/day; n = 62* No baseline period described; three 4-wk treatment periods; no washout; no follow-up Acute meds permitted | HA index: Calculated per 4-wk treatment period; HA index = (1xF_1_) + (2xF_2_) + (3xF_3_ ), where F_1_ = frequency of HAs of severity 1, F_2_ = frequency of HAs of severity 2. etc.; severity of each attack graded on scale of 1–3 (slight, moderate, severe) HA frequency: No. of HAs per 4-wk treatment period | Mean HA index was 8.9 with pizotifen, 11.3 with methysergide, and 17.0 with placebo (no variance data reported). Mean HA frequency was 4.7 with pizotifen, 6.2 with methysergide, and 8.9 with placebo (no variance data reported). No statistical analysis of these results was described. | Dropouts: Not described Nothing on carry-over effect
Ryan, 1971 | SPPG QS: 4 (r, db+, dd) | N = 60 Age: N/S (range: N/S) % female N/S Migraine; hist. of ≥ 3 HAs/mo Excl: Hypersensitivity to antimigraine or antiamine drugs; physical conditions possibly interfering with study meds; use of investigational drugs ≤ 1 mo prior to entering trial; use of concomitant meds Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 20 Pizotifen (BC-105): Dose increased daily by one capsule from 0.5 mg, 1x/day to 1.0 mg, 3x/day for 2 wks; after 2 wks, and at 4- wk intervals, pts were assessed and dosage was according to a protocol; n = 25 Previous interval treatment discontinued 4 wks prior to entering baseline; 4-wk baseline (control) period; 12-wk treatment period; 4-wk post-drug period; no follow-up Other acute migraine meds permitted | HA index: Calculated as sum of no. of severe HAs x 3, moderate HAs x 2, and mild HAs x 1 HA frequency: Defined as “total no. of HAs of all severity in past 4 wks” HA intensity: Recorded daily by pt on 4-point scale (from “no HA” to “severe HA”) | The mean HA index values for pizotifen and placebo decreased from 21.53 and 10.00 at baseline to 15.68 and 6.65, respectively, after 12 wks of treatment. Investigators reported that there were no differences between the two treatments, but did not report whether or not they analyzed the results for statistical significance. Both treatments were effective at reducing HA index from pre- to post-treatment, but neither did so at a statistically significant level (no p-values given). Investigators noted that the mean HA index at baseline was twice as large for the pizotifen group as for the placebo group. | Dropouts: 15 pts (25%) withdrew, 1 due to AEs (pizotifen); of the 15, 9 were not included in efficacy analyses; not clear whether remaining 6 were included or not
Ryan, 1978 | CrOv QS: 2 (r, ndb, dd) | N = 40 Age: N/S 100% female Migraine; moderate or severe in intensity Chron: N/S Rec: N/S | No treatment: n = 40* Norgestrel + ethinyl estradiol (Ovral®): 0.5 mg + 0.05 mg, 1x/day for 3 wks, followed by no treatment for 1 wk; n = 40* No baseline period described; two 2-mo treatment periods; no washout; no follow-up Acute meds permitted | HA index: 2(no. of mild-moderate attacks) + 3(no. of severe attacks) HA frequency: No. of attacks per 2-mo treatment period | HA index scores were worse during treatment with Ovral® than with no treatment. Mean HA index scores per 2-mo treatment period were 48.70 with Ovral® and 32.85 with no treatment (no variance data and no p-value reported). HA frequency was also higher with Ovral®: 464 HAs per 2-mo treatment period vs. 319 with no treatment (no p-value reported). | Dropouts: 0 Low quality score (2); not double-blind
Ryan, 1984 | SPPG QS: 3 (r, db, dd) | N = 48 Age: N/S 73% female Common or classic migraine; ≥ 3 HAs/mo Chron: N/S Rec: N/S | Propranolol: 160 mg/day (dosing schedule not described); n = 14 Nadolol, 160 mg/day: (Dosing schedule not described); n = 16 Nadolol, 80 mg/day: (Dosing schedule not described); n = 15 1-mo baseline period (placebo); 3-mo treatment period; no follow-up Patients permitted to use their usual meds for acute attacks | HA index: Not defined, but included severity; severity of each attack graded on scale of 1–4 (mild, moderate, severe, disabling) HA frequency: No. of attacks per month | In the nadolol 80 mg group, mean HA index scores were reduced from 12.73 during the baseline period to 4.84 during the treatment period (no variance data and no p-values reported). In the nadolol 160 mg group, the corresponding figures were 10.43 and 5.83, respectively; and in the propranolol group, they were 14.71 and 8.01, respectively (no variance data and no p-values reported). The investigator did not compare the three treatments statistically for this outcome. Mean HA frequency scores in the nadolol 80 mg group were 6.13 during the baseline period and 2.74 during the treatment period (no variance data and no p-values reported). In the nadolol 160 mg group, the corresponding figures were 5.56 and 2.93, respectively; and in the propranolol group, they were 7.42 and 4.54, respectively (no variance data and no p-values reported). The investigator did not compare the three treatments statistically for this outcome. | Dropouts: 3 (6%), 1 due to AEs (nadolol 80 mg/day)
Ryan, Diamond, and Ryan, 1975 | CrOv QS: 3 (r, db, dd) | N = 133 (Chicago, 61; St. Louis, 72) Age: 41 (median) (range: 20–64) 78% female Chron: 22 (median) (range: 1–53) Migraine; ≥ 3 Ms/mo Rec: 2 HA clinics, 1 in Chicago and 1 in St. Louis | Placebo: n = 133* Clonidine: 0.025 mg, 2x/day for 2 wks; if relief insufficient, dose could be increased to 0.050 mg, 2x/day for 2 wks; if relief still insufficient, dose could be further increased to 0.075 mg, 2x/day for 4 wks; n = 133* No baseline period; two 8-wk treatment periods; one 2-day washout between treatment periods; no follow-up Other acute migraine meds permitted during trial | HA index: Calculated by multiplying attacks by the HA intensity rating no. for each attack (1 =mild; 2=moderate; 3=severe) and summing them HA frequency: Defined as no. of HAs per wk and reported as "change in mean weekly frequency," categorized according to intensity (severe, moderate, mild) | No overall mean scores were reported for HA index. No statistical difference was found for this outcome between pts receiving clonidine and pts receiving placebo (no p-value given). Neither treatment was found to reduce the frequency of mild, moderate, or severe HAs significantly from pre- to post-treatment. Investigators reported that there was no significant difference between the two treatments. | Dropouts: 0 Not clear how results determined from baseline data Investigators reviewed pts' diaries every 2 wks to assess frequency & intensity Investigators stated that the efficacy of the treatments could not be definitely established because pts were taking other meds concurrently
Ryan and Ryan, 1981 | SPPG QS: 3 (r, db+, dnd) | N =160 Age: N/S (range: 21–65) % female N/S Classic or common migraine; ≥ 3 HAs/mo; frequency "rather constant" over past 6 mos; no "mixed" HA Chron: N/S Rec: N/S | Placebo: n =40 Aspirin: 325 mg, 4x/day; n = 40 Dipyridamole: 75 mg, 4x/day; n = 40 Aspirin + dipyridamole: 325 + 75 mg, 4x/day; n = 40 4-wk baseline (no aspirin, dipyridamole, or other migraine-preventive med); one 8-wk treatment period; no follow-up Use of symptomatic meds permitted for acute attacks, but patients not allowed to take aspirin, dipyridamole, anturane, beta blockers, steroids, anti-inflammatory drugs, or antidepressants during trial | HA index: Not defined HA frequency: No. of attacks per 4 wks | Because HA index was not defined, we preferred the results reported for HA frequency. Mean HA frequencies in the aspirin + dipyridamole group were 9.15 and 7.15 during the baseline period and weeks 5–8, respectively; corresponding figures in the aspirin group were 8.15 and 7.13; in the dipyridamole group, 8.13 and 8.12; and in the placebo group, 7.79 and 7.64 (no variance data and no p- values reported). Results for HA index were similar, except that dipyridamole reduced mean HA index slightly more than it did mean HA frequency (from 12.05 to 8.02). | Dropouts: Not described
Ryan, Ryan, and Sudilovsky, 1983 | SPPG QS: 4 (r, db+, dd) | N = 80 Age: N/S (range: 18–60) 78% female Common or classical migraine; ≥ 3 HAs/mo Excl: Pts allergic to or with past failure to respond to beta-blockers; pts with cluster HAs Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 20 Nadolol: 80 mg/day; n = 20 Nadolol: 160 mg/day; dose gradually increased to full dose by 10th wk; at wk 20, dose tapered off to 80 mg/day; n = 20 Nadolol: 240 mg/day; dose gradually increased to full dose by 10th wk; at wk 20, dose tapered off to 80 mg/day; n = 20 2-mo baseline (placebo); 3-mo treatment period; no controlled follow-up Patients' usual acute migraine medications permitted, but prophylactics disallowed | HA frequency: Not defined, but recorded at onset by pts in diaries HA intensity: Rating scale N/S, but recorded by pts in diaries | HA frequency was reduced from mean scores of 6.9, 6.73, 6.8, and 8.45 at baseline (4-wk means of month 2 of baseline) to 4.25, 4.05, 2.10, and 3.28 after treatment (4-wk means of month 5) with placebo, 80 mg, 160 mg, and 240 mg of nadolol, respectively. Investigators did not report having analyzed the between-group or pre- to post-treatment differences for statistical significance (no variances or p-values reported). | Dropouts: 1 pt (1%) withdrew (not clear from which treatment group) and was not included in efficacy analyses; not clear whether dropout due to AEs
Sances, Martignoni, Fioroni, et al., 1990 | SPPG QS: 3 (nr, db+, dd) | N = 40 Age: 38 (range: 19–45) 100% female Migraine w/o aura (IHS); regular attacks the week before, or during, menstrual period, and HA-free the rest of the cycle; regular menstrual cycle Chron: N/S Rec: N/S | Placebo: n = 17 Naproxen sodium: 550 mg, 2x/day; n = 18 2-mo baseline period (HA recording); one 3-menstrual-cycle treatment treatment period; this followed by 3-menstrual-cycle open phase, in which all patients took active drug (not considered here) Patients began treatment on the 7th day before the expected onset of menstruation and continued through the 6th day of menstrual flow | HA index: Frequency + (Duration x Severity); severity of each attack graded on scale of 1–3 (mild, moderate, severe); duration reported in hrs for each attack HA frequency: No. of HA days | Mean HA index scores (± SD) for the baseline period were 75.1 (± 49.8) in the naproxen group and 78.6 (± 39.1) in the placebo group. For the third month of treatment, the scores were, respectively, 49.4 (± 38.6) and 69.1 (± 29.8). The improvement seen in the naproxen group was statistically significant (p<0.01); that seen in the placebo group was not (no p-value reported). There was no significant difference between the two groups for this outcome (p>0.05). 6/18 patients (33%) taking naproxen sodium reported a ≥ 50% improvement in HA index scores in month three compared to baseline values, as did 1/17 patients (6%) taking placebo. Similar results were reported for HA frequency; naproxen sodium was significantly better than placebo only for the third month (p<0.05). | Dropouts: 5 (13%), 2 due to AEs (intervention N/S) Not randomized
Sances, Martignoni, Rosettino, et al., 1989 | SPPG QS: 2 (nr, db, dd) | N = 40 Age: N/S (range: 20–45) 100% female Only pts with migraine during menstrual periods; frequency N/S Chron: N/S (range: 2–31) Rec: N/S | Placebo: n = 20 Lisuride: 0.05 mg, 3x/day; n = 20 2-mo run-in; 3-mo treatment period, followed by 3-mos of open, uncontrolled treatment; no follow-up Analgesic meds permitted | HA index: Obtained from HA duration & intensity ratings and termed "pain total index" HA frequency: Recorded daily by pt as "days of HA" HA intensity: Not defined; rating scale N/S | No between-group results were provided. From baseline to 3 mos, lisuride reduced HA index from 81.7 (± 38) (SD) to 47.3 (± 32), a reduction that was statistically significant (p < 0.001). Placebo reduced HA index from 102 (± 50) at baseline to 95.8 (± 57) at 3 mos. Investigators reported that the difference was not significant (p > 0.05). | Dropouts: 4 (10%), all due to AEs (treatments N/S); not clear whether or not they were included in efficacy analyses Information provided in abstract Not clear how baseline data gathered
Saper, Silberstein, Lake, et al., 1994 | SPPG QS: 4 (r, db+, dd) | N = 122 Age: 38 (range: 20–59) (migraine) 93% female (migraine) Migraine (IHS); history ≥ 2 yrs; 4–12 attacks/mo with duration ≥ 4 hrs (n = 58); or CDH (n = 64) Chron: N/S Rec: 2 HA clinics | Placebo: n = 26 (migraine) Fluoxetine: 20 mg/day for 2 mos; dose then increased to 20 mg, 2x/day for those patients who had shown no therapeutic response, but who tolerated drug; n = 31 (migraine) 4-wk baseline period (placebo); 12-wk treatment period; no follow-up Use of acute med permitted, with some restrictions | HA index: Not described Frequency of severe HA: No. of days/wk with severe HA HA-free days: No. of HA-free days/wk | We analyzed results for migraine patients only. The investigators' ANOVA analysis found no significant differences between fluoxetine and placebo for HA index, frequency of severe HA, or HA-free days; no data and no p-values were reported for any of these outcomes. | Dropouts: 14 (11 %) overall, none due to AEs; 3 of the 14 dropouts were evidently included in the efficacy and AE analyses, but their identity and the basis on which they were included are not stated; only one migraine patient who began the trial was excluded from the efficacy and AE analyses
Sargent, Solbach, Damasio, et al., 1985 | SPPG QS: 3 (r, db, dd) | N = 149 Age: 30 (range: 18–62) 79% female Common or classical migraine or combination of migraine and muscle-contraction HA; ≥ 1-yr history of migraine; avg of 12 migraine days over ≥ 6 attacks in last 3 mos Chron: 20 yrs Rec: N/S | Placebo: n = 43 Propranolol: 40 mg, 2x/day for 2 wks, 3x/day for 12 wks, 2x/day for 1 wk; n = 44 Naproxen sodium: 550 mg, 2x/day; n = 42 2-wk baseline period (placebo); 3-wk dose escalation phase (propranolol); 12-wk treatment period; 1-wk dosage reduction period (propranolol); no follow-up Patients allowed to treat acute attacks with analgesic approved by investigator | HA frequency: Reduction in no. of HA days/wk, baseline to post-treatment HA severity: Not described; severity graded every day on scale of 0–3 (none, mild, moderate, severe) | Efficacy data were reported for the 12-wk full dosage phase of the trial only. There were no significant differences among the study medications for median HA frequency (p=0.92 naproxen sodium vs. placebo; p=0.16 propranolol vs. placebo; p=0.17 naproxen sodium vs. propranolol). Mean difference scores (± SD) from baseline to post-treatment were −0.48 (± 2.02) for naproxen sodium, 0.21 (± 1.86) for propranolol, and −0.25 (± 1.57) for placebo. Similar results were reported for HA severity. | Dropouts: 20 (13%), 3 due to AEs (all naproxen sodium) Baseline values derived from patients' histories
Shafar, Tallett, and Knowlson, 1972 | CrOv QS: 3 (r, db, dd) | N = 65 Age: N/S (range: 18–66) 84% female Chron: N/S) (range: N/S) Migraine; hist. ≥ 1 M/mo for ≥ 1 yr; Ms of "significant frequency & severity" Rec: Referred by GPs | Placebo: n = 50* (42* in larger grp; 8* in smaller grp) Clonidine: 50 μg, 2x/day for 16 wks; n = 50* (42* in larger grp; 8* in smaller grp) Four-wk baseline; four 8-wk treatment periods, 2 active & 2 placebo; no washout between treatment periods; crossover point N/S, but assumed to be every 8 wks; 12-mo open follow-up using clonidine Other acute migraine meds permitted during trial | HA index: Termed a "weighted score"; calculated by multiplying no. of HAs (frequency) by HA intensity rating for each attack (1=mild; 2=moderate; 3=severe) and summing them HA frequency: Definition N/S, but reported as mean no. of HAs/mo | Investigators performed a post hoc stratification, separating 8 pts with near-daily HAs from the 42 remaining pts. For the 42 pts with less frequent HAs, HA index decreased from 15.07 at baseline to 11.12 and 13.23 after treatment with clonidine and placebo, respectively. Clonidine was better than placebo at reducing HA index, but not at a statistically significant level (p<0.1). For the group with less frequent HAs, each treatment reduced HA index from pre- to post-treatment, but authors did not report whether or not the reductions were statistically significant (p-values not given). For the group with more frequent HAs, HA index increased from 45.25 at baseline to 48.08 and 47.80 after treatment with clonidine and placebo, respectively. Investigators did not report whether or not they analyzed the treatment results for statistically significant differences for either between- or within- group comparisons. | Dropouts: 15 (23%), 1 due to AEs (clonidine) Not clear how baseline data gathered or how results determined from that data 14 of 50 pts returned incomplete records or failed to take correct no. of tablets. Nevertheless, investigators included their data in analyses because data from at least one 8-wk period per treatment was completed adequately. Consequently, length of treatment periods varied (larger group, 3–7 mos; smaller group, 3–9 mos)
Shekelle and Ostfeld, 1964 | CrOv QS: 4 (r, db+, dd) | N = 16 Age: N/S (range: 22–46) 83% female Classic (n = 1) or common migraine (n = 16) or cluster HA (n = 1) (all Ad Hoc) Chron: N/S Rec: N/S | Placebo: n = 13* Methysergide: 2 mg, 3x/day; n = 13* No baseline period described; two 5-wk treatment periods; no washout, but data analyzed from last 4 wks of each treatment period only; no follow-up Patients given mild analgesic to take for acute episodes | HA frequency: No. of HA days during last 4 wks of placebo treatment minus no. of HA days during last 4 wks of methysergide treatment; calculated for each patient; results analyzed sequentially with Rushton's t test | HA frequency: The only outcome analyzed by investigators was the difference in the total number of HA days reported by each patient on placebo and on methysergide. Their analysis of the data from individual patients showed methysergide to be significantly better than placebo at reducing the number of HA days (p<0.05). | Dropouts: 3 (19%), none due to AEs 1 patient included in the efficacy analysis had cluster HA
Shimell, Fritz, and Levien, 1990 | SPPG QS: 4 (r, db+, dd) | N = 58 Age: 35 (range: 16–61) 70% female Common or classic migraine (Ad Hoc); 2–8 attacks/mo for past 6 mos; no prophylactic med in last mo Chron: N/S Rec: Out-patients at polyclinic and medical and neuro depts | Propranolol: 60 mg, 3x/day; this dose achieved gradually over 20 days; n = 29 Flunarizine: 10 mg, 1x/day (at night); this dose achieved gradually over 4 days; n = 28 No baseline period described; 4-mo treatment period; no follow-up Nothing on acute meds | HA frequency: No. of attacks/mo HA severity: Each attack graded as unbearable, severe, moderate, or slight; investigators reported only the percentage of patients whose HAs were severe in tensity before and after treatment HA duration: Not described | Both drugs reduced HA frequency significantly from wk 1 to wks 4 and 16. The mean number of attacks/mo in the flunarizine group was 4.57 in wk 1, 3.11 in wk 4, and 1.35 in wk 16 (no variance and no p- values reported). The corresponding numbers in the propranolol group were 5.71, 3.29, and 1.17 (no variance and no p-values reported). There was no significant difference between the two treatments for this outcome (no p-value reported). Neither treatment significantly affected HA severity or HA duration. | Dropouts: 10 (17%); 1 patient left the country and was excluded from the analysis; 9 other patients withdrew before completing trial, 5 due to AEs (2 flunarizine, 3 propranolol); these 9 patients were included in the efficacy analysis 1-wk results used as baseline
Shukla, Garg, Nag, et al., 1995 | CrOv QS: 4 (r, db+, dd) | N = 36 Age: 30 79% female Migraine w/or w/o aura (IHS); ≥ 4 attacks/mo in past yr Chron: 9 yrs Rec: HA clinic | Placebo: n = 28* Nifedipine: 5 mg, 3x/day; n = 28* 2-wk baseline period (no prophylactic med); two 4-wk treatment periods; 2-wk washout; no follow-up Acute meds permitted | HA index: Frequency times severity times duration HA frequency: No. of attacks/mo HA severity: Not clear how outcome calculated (categorical data only reported); severity graded every day on scale of 0–3 (no pain; mild, reducing activity by < 50%; moderate, reducing activity by > 50%, but not requiring bed rest; severe, requiring bed rest) HA duration: Mean duration (hrs) | Neither nifedipine nor placebo significantly reduced HA index in comparison with baseline values; there was no significant difference between the two interventions for this outcome (no p-values reported). Mean HA index scores (± SEM) were 808.6 (± 158.2) at baseline, 750.6 (± 141.8) after treatment with placebo, and 616.4 (± 150.0) after treatment with nifedipine. Nifedipine did significantly reduce HA frequency both in relation to baseline values and placebo values (p<0.05 for both comparisons). Mean HA frequency (± SEM) was 10.4 (± 1.76) during the baseline period, 10.1 (± 1.78) after treatment with placebo, and 6.3 (± 1.85) after treatment with nifedipine. Nifedipine also significantly reduced HA severity compared to baseline and placebo (p<0.05). It did not significantly affect HA duration (no p-values reported). | Dropouts: 8 (22%), none due to AEs
Sicuteri, 1973 | SPPG QS: 2 (r, ndb, dd) | N = 40 Age: N/S 65% female Migraine Chron: N/S Rec: N/S | Methysergide: 1 mg, 2x/day; n = 20 Oxitriptan (L-5-hydroxytryptophan or 5-HTP): 100 mg, 2x/day; n = 20 40-day baseline period; 40-day treatment period; no follow-up Nothing on acute meds | HA index: Calculated per 40-day period; HA index = (1xF_1_) + (2xF_2_) + (3xF_3_), where F_1_ = frequency of moderate HAs, F_2_ = frequency of medium HAs, and F_3_ = frequency of severe HAs HA frequency: No. of HAs per 40-day period | Both oxitriptan and methysergide significantly reduced the HA index compared with pre-treatment values. The mean migraine index (± SEM) in the oxitriptan group was 9.7 (± 0.45) pre-treatment and 4.1 (± 0.52) post-treatment (p<0.001); the mean reduction from pre- to post-treatment was 5.6 (± 0.56). In the methysergide group, the mean migraine index (± SEM) was 9.9 (± 0.59) before treatment and 4.2 (± 0.66) post-treatment (p<0.001); the mean reduction from pre- to post-treatment was 5.9 (± 0.87). When the mean reductions in the migraine index were compared, there was no significant difference between the two treatments (p>0.8). Very similar results were reported for HA frequency. | Dropouts: 0 Low quality score (2); not double-blind
Sjaastad and Stensrud, 1969 | CrOv QS: 3 (r, db, dd) | N = 24 Age: 39 (range: 16–57) 92% female Common or classical migraine (Ad Hoc); 1–2 HAs/2 wks in baseline period (length N/S) Chron: N/S (range: N/S) Rec: N/S, but several pts had been hospitalized for migraine & others had participated in extensive trials of anti-migraine meds | Placebo: n =20* Pizotifen: 1 mg, 4x/day; n = 20* Length of baseline period not clear; two 8-wk treatment periods; no washout; some pts treated with pizotifen for 3–12 mos after trial; no other follow-up described Ergotamine and salicylates permitted | HA frequency: Defined as "no. of HA days" HA intensity: Recorded by pt on 3-point scale | From individual data provided, we calculated overall mean reductions in HA frequency from baseline to 7 wks of 9.9 and 5.6 for placebo and pizotifen, respectively. Baseline data were not provided, and investigators did not report the statistical significance of the difference between the two results (no p-values given). | Dropouts: 4 pts (17%), not included in efficacy analyses withdrew, 1 due to AEs (pizotifen) Data from first week of each treatment period excluded from analysis
Sjaastad and Stensrud, 1971 | CrOv QS: 3 (r, db, dd) | N = 30 Age: N/S (range: N/S) 87% female Chron: N/S) (range: N/S) Common or classical migraine (Ad Hoc); pts “generally severely affected” & had ≥ 1 HA/wk during baseline Rec: N/S | Placebo: n = 26* Clonidine (Catapresan®): 25 μg, 3x/day; n = 26* One-wk baseline; two 3-wk treatment periods; 1-wk washout between treatment periods; no follow-up Other acute migraine meds permitted during trial | HA index: Calculated as no. of HA days multiplied by intensity score (graded from 1+ to 3+) HA frequency: Results reported as average reduction in no. of HA days | Ten of 26 pts (38%) experienced at least a 50% reduction in HA index after taking clonidine. Investigators did not report the reductions, if any, associated with the placebo treatment. A mean reduction in HA index of 27% was also brought about by clonidine (compared with placebo). This reduction was significantly better than that of placebo (p<0.025). Clonidine reduced HA frequency 26% better than did placebo. Investigators did not report having analyzed this comparison for statistically significant differences. | Dropouts: 4 (13%), for “unknown reasons”
Sjaastad and Stensrud, 1972 | CrOv QS: 4 (r, db+, dd) | N =28 Age: N/S (range: 18–62) 79% female Classical or common migraine; ≥2 attacks/mo Chron: N/S Rec: N/S | Placebo: n = 24* Pindolol: 2.5 mg or 5 mg, 3x/day; n = 24* 3-wk baseline period (no prophylactic med); two 4-wk treatment periods; 3-wk washout; no follow-up Acute meds permitted | HA index: No. of HA days times severity; severity of each attack graded on scale of 1–3 HA frequency: No. of HA days | There were no significant differences between pindolol and placebo for HA index or HA frequency (no p- values reported). However, 3 patients were markedly improved on pindolol, showing a greater than 50% reduction in HA index. | Dropouts: 4 (14%),3 due to AEs (pindolol)
Smits, van der Meer, Pfeil, et al., 1993 | CrOv QS: 3 (r, ndb+, dd) | N = 20 Age: 40 (range 30–48) 100% female “Pure” menstrual migraine = attacks of migraine w/o aura (IHS), regularly occurring no earlier than 2 days before menstruation and no later than last day of menses; HAs during previous 12 cycles; no HAs during rest of cycle Chron: N/S Rec: N/S | Placebo: n = 19* Estradiol (Estraderm TTS 50® patch): 50 μg/day, via 10-cm patch; one patch applied 48 hrs before expected onset of menstruation; another patch applied 4 days later; n = 19* No baseline period described; three 1-cyle treatment periods (two sequences: P-E-P and E-P-E); no washout; no follow-up Acute meds (aspirin, acetaminophen, or ergotamine) permitted Prophylactic meds permitted, provided taken for at least 3 mos prior to trial and not changed during trial | HA frequency: No. of menstrual cycles accompanied by migraine attack HA severity: Not defined; each attack graded on scale of 1–3 (mild, moderate, severe) HA duration: Mean duration per attack (in hrs) | HA frequency: Of the cycles occurring during Estraderm TTS® and placebo treatment, 17 (59%) and 20 (69%), respectively, were accompanied by migraine attacks. There was no significant difference between the two treatments during the first two periods (95% CI, −0.19 to 0.40) or during the last two periods (95% CI, −0.10 to 0.54). There were also no significant differences between the two treatment groups for HA severity or duration. | Dropouts: No patients withdrew from the trial, but one (5%) did not provide data for the main efficacy analysis
Solomon, 1986 | CrOv QS: 2 (nr, db, dd) | N =20 Age: N/S % female N/S Classic or common migraine; ≥ 2 HAs/mo for > 1 yr Chron: N/S Rec: N/S | Placebo: n = 15* Propranolol (long-acting): 120 mg, 1x/day; n = 15* Verapamil: 80 mg, 3x/day; n = 15* No baseline period described; three 2-mo treatment periods; no washout; no follow-up Nothing on acute meds | HA frequency: No. of attacks/mo HA severity: Mean per attack; severity of each attack graded on scale of 1–4 (not described) HA duration: Mean per attack (hrs) | Propranolol, but not verapamil, was significantly (p<0.05) better than placebo for HA frequency; there was no significant difference between the two active treatments (no p-value reported). Mean HA frequency was 6.0 with placebo, 5.0 with verapamil, and 4.5 with propranolol (no variance data reported). Both verapamil and propranolol were significantly better than placebo for HA intensity (p<0.05), but there was no significant difference between the two active drugs (no p-value reported). There were no significant differences among the three treatments for HA duration. | Dropouts: Abstract reports only no. of patients who completed trial and no. who withdrew due to AEs (5 -- 3 verapamil, 2 placebo) Abstract reporting limited information
Solomon and Kunkel, 1993 | CrOv QS: 3 (r, db, dd) | N = 31 Age: 36 (range: 19–49) 83% female Migraine w/or w/o aura (IHS); history ≥2 yrs; 2–8 HAs in previous month; no cluster HA; no frequent TTHs Chron: 17 yrs (range: 4–35) Rec: N/S | Placebo: n = 23* Flurbiprofen: 100 mg, 2x/day; n = 23* 2-wk baseline period (placebo); two 8-wk treatment periods; 2-wk washout; no follow-up Patients permitted to take a hydrocodone-acetaminophen compound or an isometheptene-acetaminophen compound for relief of acute attacks; ergotamine + caffeine could be used if other two agents ineffective | HA frequency: No. of attacks per 8 wks HA severity: Mean per attack; each attack graded on scale of 1–5 HA duration: Total hrs with migraine per 8 wks | There was no significant difference between flurbiprofen and placebo for HA frequency (0.05<p<0.10). Overall mean HA frequencies were 4.39 with flurbiprofen and 5.73 with placebo (no variance data reported). 10/23 patients (43%) reported a ≥ 50% reduction in frequency with flurbiprofen compared to placebo. Flurbiprofen was significantly better than placebo for HA severity (p<0.05) and duration (p<0.015). | Dropouts: 8 (26%), 2 due to AEs (flurbiprofen) No carry-over effect
Solomon, Steel, and Spaccavento, 1983 | CrOv QS: 4 (r, db+, dd) | N = 23 Age: 39 75% female Classic or common migraine (Ad Hoc); ≥ 2 attacks/mo Chron: N/S Rec: N/S | Placebo: n = 12* Verapamil: 80 mg, 4x/day; n = 12* No baseline period described; two 3-mo treatment periods; 5-day washout; no follow-up Acute meds permitted | HA index: Sum of severity scores divided by no. of days observed; severity of each attack graded on scale of 1–3 (mild TTH that responds to simple analgesics and does not interfere with activity, no nausea or vomiting; moderate unilateral vascular HA associated with nausea, responds to ergots or more potent analgesics, may interfere with activity; severe unilateral HA, with vomiting or severe incapacitation) Migraine frequency: No. of migraines per month | Mean HA index scores were significantly lower with verapamil (0.44) than with placebo (0.61) (no variance data reported; p<0.05). Mean migraine frequency was also significantly (p<0.05) lower with verapamil (3.8) than with placebo (6.7) (no variance data reported). | Dropouts: 11 (48%), 2 due to AEs (both with placebo) High dropout rate No baseline period No carry-over effect was observed 5/12 patients included in the efficacy analysis had been unsuccessfully treated with propranolol in the past
Somerville and Herrmann, 1978 | SPPG QS: 4 (r, db+, dd) | N = 150 Age: N/S (range: N/S) % female N/S Common or classical migraine; ≥ 2, but ≤ 15 HAs/mo in 1 mo prior to trial; migraine defined as “recurrent paroxysmal HA lasting ≥ 1 hr, associated with ≥ 1 of 5 symptoms, including nausea, vomiting, & photophobia” Excl: pts with HAs caused by head trauma or pts with cervical spondylosis Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 52 Lisuride: Dose gradually increased to 0.025 mg, 3x/day, on Day 5 and used thereafter; n = 58 No baseline period described; 3-mo treatment period; successful pts from either treatment were treated for an additional 3 mos; no other follow-up described No mention of acute migraine meds | HA frequency: Derived from pts’ recordings of dates & duration of HAs HA intensity: Rating scale N/S, but recorded at onset by pts | Results were provided in a graph from which we could not obtain results for an analysis. Success was defined as a reduction in HA frequency from > 2 HAs/mo before treatment to 0–2 HAs/mo after treatment. Using this criterion, investigators reported that pts treated with lisuride reduced HA frequency better than did pts treated with placebo (p < 0.05). | Dropouts: 40 pts (27%) withdrew early, none due to AEs, and were not included in efficacy analyses; an additional 17 (11 %), included in efficacy analyses, withdrew due to AEs (lisuride 12, placebo 5) Of the 40 pts described above, some withdrew early “due to lack of effect” (placebo 17, lisuride 8)
Sørensen, Hansen, and Olesen, 1986 | CrOv QS: 3 (r, db, dd) | N = 29 Age: 40 (median) (range: 19–63) 79% female Common migraine (Ad Hoc); ≥ 1-yr history; 2–6 attacks/mo; HA severity usually grade 2–3; no daily HA Chron: 17 yrs (median) (range: 2–30) Rec: HA clinic out-patients | Placebo: n = 29* Flunarizine: 10 mg, 1x/day (at night); n = 29* 1-mo baseline period (no medication); two 4-mo treatment periods; 1-mo washout (placebo); no follow-up Acute meds permitted | HA index: Duration times severity (migraine attacks only) HA frequency: No. of attacks/mo HA severity: Mean severity per attack; severity of each attack graded on scale of 1–3 (working capacity not affected, unable to work, bed rest required) HA duration: Total no. of hrs with migraine; mean duration of attacks (in hrs) | Investigators analyzed data from the last 3 months of each treatment period only. Flunarizine was significantly better than placebo at reducing HA index (p = 0.01). Compared with baseline values, HA index was reduced by 36% during treatment with flunarizine (by 56% in the last month of treatment) and by 6% during treatment with placebo (13% in the last month of treatment). Similar results were reported for HA frequency (p = 0.001) and for total HA duration (p = 0.02). There were no significant differences between flunarizine and placebo for mean severity or duration of individual attacks. | Dropouts: 2 (7%), 1 due to AEs (flunarizine); data from both patients were included in the efficacy analysis No carry-over effect detected 19 patients had tried prophylactic med before, only 2 successfully
Sørensen, Larsen, Rasmussen, et al., 1991 | SPPG QS: 4 (r, db+, dd) | N = 149 Age: 42 (median) (range: 20–64) 79% female Migraine w/or w/o aura (IHS); ≥ 1-yr history; 2–8 migraine days/mo in past 3 mos Chron: 17 yrs (median) (range: 1–50) Rec: Neuro dept out-patients | Metoprolol (slow-release): 200 mg, 1x/day (at night); n = 69 Flunarizine: 10 mg, 1x/day (at night); n = 58 1-mo baseline period (placebo); 5-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of migraine days/mo HA severity: Each attack graded on scale of 1–3 (not described) HA duration: Hrs with migraine per migraine day (attacks lasting overnight considered to be two migraine days with individual durations) | Both drugs significantly reduced HA frequency compared with baseline values (p<0.001 for both drugs for all months). The reduction was significant already in the first month for both drugs; thereafter, flunarizine was increasingly efficacious over time, whereas metoprolol reached maximum effect already during the first month. The mean change in HA frequency (± SEM) from baseline to month 5 was −2.2 (± 0.4) in the flunarizine group and −1.5 (± 0.4) in the metoprolol group; the difference between the two treatments was not statistically significant (p=0.25). Similar results were reported for HA severity and HA duration | Dropouts: 22 (15%), 11 due to AEs (10 flunarizine, 1 metoprolol)
Sovak, Kunzel, Sternbach, et al., 1981 | SPPG QS: 2 (r, ndb, dd) | N =58 Age: N/S (range: 30–57) 100% female Common or classical migraine; no HAs between attacks; severe, “vascular-type” pain; no meds for BF group Chron: N/S Rec: Pain treatment center; U.S. | Drug therapy (propranolol + analgesics): n =20; dosages and treatment regimen not described Thermal BF + relax. (AT phrases): n = 28; eight to ten 45-min sessions (2 x/wk for first 2 wks, then at intervals increasing until there were 4 wks between the last two sessions); home practice: 2 x/day with equipment + 10-min tape | HA index: Composed of HA incidence, intensity (scale N/S), & duration Both groups monitored HAs daily by diary during treatment (length of time N/S). | Authors did not report results for comparisons between the two treatment groups for HA index. Changes from pre- to posttreat. for each group were reported only on figures from which it was difficult to determine precise results. Fifty-four percent (15/28) and 45% (9/20) of pts in the thermal BF and drug therapy groups, respectively, improved with treatment. Authors did not report the cutoff percentage used to determine “improvement.” | Dropouts: 10
Steardo, Bonuso, Di Stasio, et al., 1982 | SPPG QS: 1 (nr, ndb, dd) | N =99 Age: N/S % female N/S Common or classic migraine (Ad Hoc); no previous experience with migraine- preventive meds Chron: N/S Rec: N/S | Methysergide: 6–10 mg/day, according to body weight; n = 25 Propranolol: 40 mg, 3x/day (full dose achieved gradually); n = 24 Metoprolol: 100 mg, 3x/day (full dose achieved gradually); n = 16 No baseline period described; 6-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks per 6-mo period | All three drugs significantly reduced mean HA frequency compared with pre-treatment values (p<0.001 for methysergide and propranolol; p<0.05 for metoprolol). During the 6-mo treatment period, mean HA frequency (± SEM) was 10.92 (± 1.46) in the methysergide group, 7.67 (± 1.25) in the propranolol group, and 16.13 (± 1.31) in the metoprolol group. Investigators did not directly compare the treatments for this outcome. A reduction in HA frequency of 50% or greater was reported by 14/25 patients (56%) in the methysergide group, 16/24 patients (67%) in the propranolol group, and 1/16 (6%) in the metoprolol group. Investigators did not analyze these results. | Dropouts: 34 (34%), 18 due to AEs (6 methysergide, 4 propranolol, 8 metoprolol) Not clear how baseline values established High dropout rate (34%) Low quality score (1); not randomized, not double-blind None of the included patients had used migraine- preventive medication before; the trial also included a group of patients unresponsive to previous preventive treatment, who were nonrandomly assigned to treatment with propranolol; we have excluded this treatment group from consideration
Steardo, Marano, Barone, et al., 1986 | SPPG QS: 4 (r, db+, dd) | N = 104 Age: 30 (range: 16–51) 59% female Common or classical migraine (Ad Hoc); ≥ 2 attacks/mo in previous 8 mos; no prior prophylactic treatment Chron: 11 yrs Rec: Neuro dept out-patients | Methysergide: Dose gradually increased over first wk to 2 mg, 3x/day; n = 51 (randomized; n’s for later months N/S) Flunarizine: 10 mg, 1x/day (at night); n = 53 (randomized; n’s for later months N/S) 1-mo baseline period; 5-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks/mo HA severity: Severity of each attack graded on scale of 1–4 (mild, no reduction in activity; moderate, < 50% reduction in activity; severe, > 50% reduction in activity, but bed rest not required; disabling, bed rest required) HA duration: Hrs per attack | Both drugs significantly reduced mean HA frequency compared with baseline values (p<0.001 for each drug for every month of treatment). The effect was significant after only one month, leveled off after the second month, and remained approximately constant for the remainder of the trial. Analysis of covariance showed no significant differences between the two drugs for any month studied (no p-values reported). Mean HA frequencies were reported only in graphic form and could not be accurately read off the graph. Among patients reporting at least one HA during treatment month 5 (n’s N/S), flunarizine reduced HA intensity by an estimated average of 0.28 (p=0.0030 vs. baseline), while methysergide resulted in an estimated average increase in severity of 0.09 (p=0.40 vs. baseline). The investigators did not directly compare the two treatments for this outcome. Both treatments reduced HA duration to a degree that was statistically significant for most months; there were no significant differences between the two treatments (no p-values reported). | Dropouts: 19 (18%), 7 due to AEs (all methysergide) Patients had never under-gone migraine prophylactic treatment
Steiner, Joseph, Hedman, et al., 1988 AND Steiner, Cook, Joseph, et al., 1985 | SPPG QS: 4 (r, db+, dd) | N =59 Age: 38 76% female Classical or common migraine; ≥ 2- yr history; 2–8 attacks/mo; co-existing TTH OK provided patient could distinguish from migraine; no preventive meds in 4 wks preceding trial Chron: N/S Rec: Migraine clinic | Placebo: n =31 Metoprolol: 50 mg, 2x/day; n = 28 4-wk baseline period (placebo); 8-wk treatment period; patients then given opportunity to continue in 12-wk follow-up, with responders continuing on same med, placebo nonresponders switching to metoprolol 50 mg, 2x/day, and metoprolol nonresponders switching to 100 mg, 2x/day Patients allowed to take their usual meds for acute attacks | HA index: Sum of severity scores per 4 wks HA frequency: No. of attacks per 4 wks; no. of migraine days per 4 wks HA severity: Per attack; severity graded every day on scale of 0–3 (no HA, mild, moderate, severe/incapacitating) | We analyzed results from the initial, double-blind portion of the trial only. Mean HA index scores were significantly decreased compared with baseline values in the metoprolol group (p=0.012), but not in the placebo group (p=0.074); there was no significant difference between the two treatments for this outcome (p=0.081). Mean HA index scores (± SD) in the placebo group were 10.8 (± 5.4) during the baseline period and 9.4 (± 4.8) during treatment; in the metoprolol group, the corresponding figures were 11.2 (± 6.0) and 8.2 (± 5.7), respectively. HA frequency: Both treatments significantly reduced the mean no. of attacks per 4 wks and the mean no. or HA days per 4 wks compared with baseline values; there was no significant difference between them for no. of attacks (p=0.13), and metoprolol was significantly better than placebo for no. of migraine days (p=0.05). Neither treatment significantly affected HA severity. | Dropouts: 5 (8%), 1 due to AEs (metoprolol); all 5 patients were included in the efficacy analysis
Stellar, Ahrens, Meibohm, et al., 1984 | CrOv QS: 5 (r+, db+, dd) | N =107 Age: 43 (range: 18–66) 72% female Classic or common migraine (Ad Hoc); ≥ 3 attacks during baseline period; history of co-existing TTHs OK provided patient could distinguish from migraine attacks Chron: N/S Rec: N/S | Placebo: n = 94* Timolol: 20–30 mg/day, taken in two doses; n = 94* 1-mo baseline period (placebo); two 2-mo treatment periods; no washout, but data from first 2 wks of each treatment period not incuded in efficacy analysis to minimize carry-over effects; no follow-up Acute meds permitted | HA frequency: No. of HAs per month HA severity: Mean severity per attack (scale used to grade individual attacks not described) HA duration: Mean duration (in hrs) per attack | Mean HA frequency was reduced from 6.8 during the baseline period to 5.0 with placebo and 4.3 with timolol (no variance data reported). Timolol was significantly better than placebo for this outcome (p<0.01). A 50% or greater reduction in HA frequency compared with baseline values was reported by 25/94 patients (27%) with placebo and by 40/94 patients (43%) with timolol. Investigators did not state whether or not they found the difference between the two treatments for this outcome to be statistically significant. Neither intervention significantly affected HA severity or duration. | Dropouts: 9 patients (8%) withdrew prematurely, 2 due to AEs (timolol); an additional 4 patients (4%) were excluded from the efficacy analysis for protocol violations
Stensrud and Sjaastad, 1974 | CrOv QS: 4 (r, db+, dd) | N = 26 Age: N/S (range: 17–55) 88% female Classic or common migraine (Ad Hoc); ≥ 3 HAs/mo; most patients had "relatively intractable migraine" Chron: N/S Rec: N/S | Placebo: n = 24* Ketoprofen: 50 mg, 3x/day; n = 24* No baseline period described; two 6-wk treatment periods; "approximately" one-wk washout; no follow-up Acute meds permitted, though patients encouraged to avoid using them | HA index: Frequency times severity; severity of each attack graded on scale of 1–3 (not described) HA frequency: No. of HA days | Ketoprofen was significantly better than placebo for HA index (p<0.05). 16/24 patients (67%) improved with ketoprofen compared to placebo, 3 were unchanged, and 5 were worse; improvement was> 50% in only 5/24 cases (21%). The mean percentage reduction in HA index with ketoprofen compared to placebo was 23%. Total HA index was reduced from 677 on placebo to 520 on ketoprofen. Ketoprofen was also significantly better than placebo for HA frequency (p<0.02). 19/24 patients (79%) improved with ketoprofen compared to placebo, 5/24 were worse; improvement was > 50% in only 3/24 cases (13%). The mean percentage reduction in HA frequency was 18%, and the total number of HA days was reduced from 344 on placebo to 274 on ketoprofen. | Dropouts: 2 (8%), for unspecified reasons
Stensrud and Sjaastad, 1976a | CrOv QS: 3 (nr, db+, dd) | N =29 Age: 45 (range: 25–61) 83% female Chron: N/S) (range: N/S) Common or classical migraine; ≈ 50% of pts also had TTHs Rec: N/S | Placebo: n = 27* Clonidine (Catapresan®): 75–150 μg/day; n = 27* 4- to 32-mo baseline (mean of 10 mos) treatment with clonidine (75–150 μg/day); two 7-wk treatment periods; no washout between treatment periods, but data from first 2 wks of each period excluded from analyses; no follow-up Nothing on acute meds | HA index: Calculated as no. of HA days multiplied by intensity score (graded from 1 to 3) HA frequency: Defined as no. of HA days | The overall mean HA index score increased from 10.3 at baseline to 11.1 and 14.1 after treatment with clonidine or placebo, respectively. Clonidine was significantly more effective than placebo (p<0.02), although both interventions increased, rather than decreased, HA index from pre- to post-treatment. | Dropouts: 2 (7%), not specified if 1 was due to AEs; 1 was not pts were treated during baseline with clonidine because investigators wished to determine whether the clonidine effect would be maintained over a lengthy period
Stensrud and Sjaastad, 1976b | CrOv QS: 4 (r, db+, dd) | N =20 Age: 44 (range: 15–60) 70% female Common or classical migraine (Ad Hoc); frequency N/S Chron: N/S (range: N/S) Rec: N/S, but "outpatients" | Placebo: n = 19* Propranolol (Inderal®): 40 mg, 4x/day; n = 19* No baseline period described; two 4-wk treatment periods; 1-wk washout between treatment periods; no follow-up Analgesics or ergotamines permitted for acute migraine attacks | HA index: Calculated as HA days multiplied by HA intensity score HA frequency: Defined as "HA days," and recorded on forms by pts HA intensity: Rated on 3-point scale by pts | The post-treatment mean scores for HA index were 7.47 and 12.32 for propranolol and placebo, respectively. No baseline mean scores were provided. For reductions in HA index, propranolol was significantly better than placebo (p < 0.001). Investigators did not report pre- to post-treatment results. | Dropouts: 1 (5%), due to AEs (propranolol) Not clear if baseline data gathered
Stensrud and Sjaastad, 1979 | CrOv QS:3 (r, db, dd) | N = 38 Age: N/S (range: 20–60) 71% female Migraine (Ad Hoc); ≥ 3–4 attacks/mo Chron: N/S Rec: N/S | Placebo: n = 38* Clonazepam (Rivotril®): 0.5 mg 2x/day; n = 38* 4-wk baseline period (drug-free); two 4-wk treatment periods; no washout; patients not experiencing side-effects with clonazepam 1 mg/day given option of continuing in open trial of 1–3 mg/day for up to a year Patients permitted to use analgesics or ergotamine to treat acute attacks | HA index: Sum of HA severity scores; each attack graded on scale of 1–3 (not described) HA frequency: No. of HA days/treatment period | HA index scores were reduced by 24% during treatment with clonazepam compared with baseline levels; this was not a statistically significant reduction (no p-value reported); treatment with placebo resulted in an 8% reduction vis-à-vis baseline. On average, HA index scores were 2.0 points lower with clonazepam than with placebo, but this difference was not significant (p=0.20). HA frequency was reduced by 50% during treatment with clonazepam compared with baseline levels (p<0.05); treatment with placebo resulted in only an 8% reduction vis-à-vis baseline. On average, patients reported 3.6 fewer days with HA with clonazepam than with placebo (p=0.055). This result may have been significant if investigators had corrected for the carry-over effect, which was found to be significant. | Dropouts: 1 (3%) during controlled portion of trial; reason for withdrawal N/S More than half of the patients suffered from interval HAs in addition to their migraines
Stensrud and Sjaastad, 1980a | CrOv QS: 4 (r, db+, dd) | N =35 Age: N/S (range: 25–60) 69% female Classic or common migraine (Ad Hoc); approx 50% of patients also had "more continuous" HA Chron: N/S Rec: N/S | Placebo: n = 28* Propranolol: 80 mg, 2x/day; n = 28* Atenolol: 50 mg, 2x/day; n = 28* No baseline period described; two 6-wk treatment periods; 1-wk washout; no follow-up Patients allowed to use analgesics or ergotamine to treat acute attacks | HA index: Frequency times severity; severity of each attack graded on scale of 1–3 HA frequency: No. of HA days | Significantly lower HA index scores were recorded with atenolol than with placebo (p<0.05); the differences between propranolol and placebo and between propranolol and atenolol were not statistically significant (no p-values reported). Total HA index scores were 498 for the placebo period, 410 for the atenolol period, and 437 for the propranolol period. When 7 high-frequency outlier patients (suspected of recording data on interval HAs) were excluded from the analysis, both atenolol and propranolol were significantly better than placebo for HA index (p<0.05); there was still no significant difference between the two active treatments (no p-value reported). Total HA index scores for this reduced group were 320 during the placebo period, 187 during the atenolol period, and 190 during the propranolol period. Very similar results were reported for HA frequency. | Dropouts: 7 (20%), 1 due to AEs (propranolol) "Most" patients had previously tried preventive meds, with little or moderate success
Sternieri, Bussone, Manzoni, et al., 1991 | SPPG QS: 3 (r, db, dd) | N = 100 Age: N/S 73% female Migraine w/o aura (IHS); 3–12 HA days/mo for previous 3 mos; no other types of HA Chron: N/S Rec: N/S | Placebo: n = 50 Lornoxicam: 4 mg, 3x/day; n = 46 1-mo baseline period (placebo); 2-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of HA days/mo | Lornoxicam significantly reduced HA frequency in comparison with baseline values (p<0.05) and was significantly better than placebo for this outcome (p<0.05). Mean HA frequency (± SEM) during the baseline period was 7.8 ± 0.6 for both treatment groups. After 2 mos of treatment, mean HA frequency in the lornoxicam group was 5.3 ± 0.5, compared with 7.3 ± 0.6 in the placebo group. | Dropouts: 8 patients (8%) withdrew before completing the trial, 6 due to AEs (4 lornoxicam, 2 placebo), but appear to have been included in the efficacy analysis. Four other patients (4%) were excluded from the efficacy analysis due to poor compliance. Abstract reporting limited interim results
Sudilovsky, Elkind, Ryan, et al., 1987 | SPPG QS: 4 (r, db+, dd) | N = 140 Age: 39 76% female Classic or common migraine (Ad Hoc); ≥ 3 attacks/mo in previous year Chron: 21 yrs Rec: N/S | Propranolol: 80 mg, 2x/day; n = 27 Nadolol, 160 mg/day: 1x/day; n = 33 Nadolol, 80 mg/day: 1x/day; n =33 1- to 2-mo baseline period (placebo); 2-mo treatment period; no follow-up Acute meds permitted | HA index: Defined as [4(no. of disabling HAs) + 3(no. of severe HAs) + 2(no. of moderate HAs) + 1(no. of mild HAs)], divided by the number of days for which patient evaluated HA frequency: No. of HA days divided by the number of days for which patient evaluated; no. of HAs the number of days for which patient evaluated | Nadolol, 160 mg, 1x/day was significantly more effective than nadolol 80 mg, 1x/day (p<0.05) and propranolol 80 mg, 2x/day (p<0.05) at reducing HA index from baseline to month 2; there was no significant difference between the lower dose of nadolol and propranolol for this outcome (no p-value reported). A reduction in HA index scores of 50% or greater was reported by 21/33 patients (64%) in the nadolol 160 mg group, 11/33 patients (33%) in the nadolol 80 mg group, and 10/27 patients (37%) in the propranolol group. Similar results were reported for HA frequency. | Dropouts: 47 patients (34%) were excluded from the analysis of the primary 2-mo efficacy outcomes; 8 of these had withdrawn due to AEs (80 mg nadolol, 2; 160 mg nadolol, 4; propranolol,4)
Sudilovsky, Stern, and Meyer, 1986b | SPPG QS: 2 (r, db, dnd) | N = 154 Age: N/S % female N/S Migraine Chron: N/S Rec: N/S | Placebo: n =N/S Nadolol, 240 mg/day: Dosing schedule not described; n = N/S Nadolol, 160 mg/day: Dosing schedule not described; n = N/S Nadolol, 80 mg/day: Dosing schedule not described; n = N/S 2-mo baseline period (placebo); 2-mo treatment period; no follow-up Acute meds permitted | HA frequency index: Not defined HA intensity index: Not defined HA pain index: Not defined | Results were not reported separately for the various doses of nadolol. Investigators analyzed the number of patients reporting a 50% or greater reduction (compared with baseline) in the HA indexes listed at left. Nadolol was significantly better than placebo for all three indexes (p<0.05). | Dropouts: Not described Abstract reporting limited results
Szekely, Merryman, Croft, et al., 1989 | CrOv QS: 3 (r, db, dd) | N = 30 Age: N/S 100% female "Peri-menstrual exacerbations of HA"; efficacy analysis included patients with common (n=16) and classical (n=1) migraine, mixed HA (n=3), muscle-contraction HA (n=1), and cluster-like HA (n=1) (all Ad Hoc) Chron: N/S Rec: N/S | Placebo: n = 22* Naproxen sodium: 550 mg, 2x/day; n = 22* 2-menstrual-cycle baseline period (HA recording); two 2-cycle treatment periods; study meds taken from 8th day after ovulatory rise in temperature through the 8th day of menstrual week; no washout; no follow-up No other meds taken during attacks | HA index: Not defined, but combined frequency, severity, and duration HA frequency: Not defined HA severity: Not defined HA duration: Not defined | Naproxen sodium significantly reduced HA index in comparison to baseline (p<0.001) and was significantly better than placebo for this outcome (p=0.03). HA index scores were not reported. HA frequency was significantly reduced in comparison with baseline values in both treatment groups (p<0.00001). Naproxen sodium was significantly better than placebo for this outcome (p=0.2). There were no significant differences between naproxen sodium and placebo for HA severity or duration (p=0.4 for both outcomes). | Dropouts: 8 (27%), 2 due to AEs (intervention N/S) Abstract with limited information High dropout rate (27%) Efficacy analysis included 1 patient with TTH and 1 with "cluster-like" HA
Tfelt-Hansen, Standnes, Kangasniemi, et al. | CrOv QS: 4 (r, db+, dd) | N = 96 Age: 40 74% female Common migraine (Ad Hoc); 2–6 attacks/mo; patients with other types of HA excluded Chron: 21 yrs Rec: HA clinics and neuro depts | Placebo: n = 80* Propranolol: 80 mg, 2x/day; n = 80* Timolol: 10 mg, 2x/day; n = 80* 4-wk baseline period (no prophylactic med); three 12-wk treatment periods; no washout, but only last 10 wks of each treatment period analyzed to minimize carry-over effects; no follow-up Acute meds permitted | HA index (freq x sev): Frequency times severity HA index (freq x sev x dur): Frequency times severity times duration HA frequency: No. of attacks per 4 wks HA severity: Each attack graded on scale of 1–3 (bothering, cannot work, must go to bed); mean HA severity per month reported HA duration: Mean duration of attacks/mo | We analyzed continuous data on HA index (freq x sev) and dichotomous data on HA frequency. Both timolol and propranolol were significantly better than placebo for HA index (freq x sev) (p<0.01 for both comparisons); the difference between the two active drugs (0.95) was not significant (95% CI, −0.43 to 1.97). Mean HA index scores (± SD) were 9.03 (± 7.28) for placebo, 6.66 (± 5.87) for propranolol, and 5.71 (± 5.14) for timolol. A 50% or greater reduction in HA frequency was reported by 44/80 patients on timolol (55%), 48/80 patients on propranolol (60%), and 24/80 patients (30%) on placebo. Both treatments were significantly better than placebo for this outcome (p<0.01); investigators did not directly compare the two active treatments. | Dropouts: 16 patients (17%) did not provide enough data to be included in the efficacy analysis; not clear how many of these were due to AEs No carry-over effect
Thomas, Behari, and Ahuja, 1991 | CrOv QS: 3 (nr, db+, dd) | N =29 Age: 30 (range: 20–43) 87% female Common migraine (Ad Hoc); history > 2 yrs; ≥ 3 HAs/mo in previous 3 mos; patients with daily attacks of TTH excluded Chron: N/S Rec: N/S | Placebo: n = 15* Flunarizine: 10 mg, 1x/day (bedtime); n = 15* No baseline period described; two 12-wk treatment periods; 2-wk washout; no follow-up Acute meds permitted | Severity of each HA graded on scale of 1–3 (mild, moderate, severe); duration graded on scale of 1–3 (2–8 hrs, 8–12 hrs, > 12 hrs) Clinic visits approx every 4 wks; following out-comes calculated at each visit: HA index: No. of HAs multiplied by severity, divided by no. of days in visit period Corrected HA unit index: Severity of attacks multiplied by duration, divided by no. of days in visit period HA frequency: No. of HAs divided by no. of days in visit period | Flunarizine significantly reduced median HA index scores compared with baseline values (p<0.01) and compared with placebo (p<0.05). Median scores were 6.7 (range: 3–16) pre-treatment, 6.0 (range: 0–16) on placebo, and 3.0 (range: 0–8.6) on flunarizine. Similar results were reported when group median scores were compared for corrected HA unit index and HA frequency. We used individual patient data reported by investigators to calculate group mean HA index scores (± SD) for pre-treatment (8.10 ± 3.84) and post-treatment with flunarizine (2.84 ± 2.17) and placebo (6.3 ± 5.22). We then used these means to calculate an ES comparing flunarizine and placebo for reduction in mean HA index from pre- to post-treatment. Using the same individual patient data, we established that 12/15 patients (80%) experienced a 50% or more reduction in HA index from pre- to post-treatment on flunarizine, compared with 6 of the same 15 patients (40%) on placebo. Investigators did not compare the two treatments for this outcome. | Dropouts: 14 (48%), 1 due to AEs,1 due to pregnancy, 10 for unknown reasons High dropout rate Not randomized Not clear how baseline values established (no baseline period described)
Titus, Dávalos, Alom, et al., 1986 | SPPG QS: 2 (r, ndb, dd) | N = 124 Age: 31 (range: 12–56) 62% female Migraine; "tension" and "tension-vascular" HAs not included Chron: N/S Rec: N/S | Methysergide: 3 mg/day (dosing schedule not described); n = 40 Oxitriptan (5-Hydroxytryptophan [5-HTP]): 600 mg/day (dosing schedule not described); n = 45 6-mo baseline period (no anti-migraine drugs); 6-mo treatment period; follow-up mentioned, but not described Nothing on acute meds | HA frequency: No. of attacks; no. of attacks of severe intensity (scale used to grade severity not described) | HA frequency: 30/40 patients (75%) in the methysergide group and 32/45 (71%) in the oxitriptan group and showed a 50% or greater reduction in the number of attacks or the number of severe attacks compared to baseline values. There was no significant difference between the two treatments for this outcome (p = 0.68). | Dropouts: 39 patients (31 %) "lost to follow- up"; not clear whether any of these withdrew due to AEs Low quality score (2); not double-blind High dropout rate (31%)
Vilming, Standnes, and Hedman, 1985 | CrOv QS: 4 (r, db+, dd) | N = 35 Age: 38 (range: 18–60) 83% female Common or classical migraine; 3–10 HAs/mo of > 2-hr duration + 4 other migraine-related symptoms, including prodromas with or without aura, phono-or photophobia Excl: Other types of vascular HAs, nonseparable TTHs and migraine, contraindications of study meds Chron: 20 (range: 2–43) Rec: N/S | Metoprolol: 50 mg, 2x/day; n = 30* Pizotifen: 0.5 mg, 1x/day on Days 1 & 2; 0.5 mg, 2x/day On Days 3 & 4; 0.5 mg, 3x/day on Day 5 and thereafter; n = 30* 4-wk run-in with placebo prior to treatment; two 8-wk treatment periods; 4-wk washout period with placebo between treatment periods; no follow-up Ergotamine and analgesic meds permitted | HA index: Calculated as sum of intensity scores multiplied by no. of HA days HA frequency: Defined as "no. of migraine days" HA intensity: Recorded daily by pt on 3-point scale | Investigators found no significant difference between pizotifen and metoprolol for reductions in HA index (p> 0.05). HA index was reduced from a median baseline value of 13.0 to median values of 7.1 and 8.6 after treatment with pizotifen and metoprolol, respectively. The pre- to post-treatment reductions were statistically significant for both drugs (p < 0.01, each case). Fourteen of 33 pts (42%) taking pizotifen and 10/34 (29%) taking metoprolol reduced HA index ≥ 50% from baseline to post-treatment. The difference between the two treatments was not significant (p > 0.05). | Dropouts: 5 (14%),4 due to AES (3 pizotifen, 1 metoprolol); all 5 included in efficacy analyses until they withdrew
Weber and Reinmuth, 1972 | CrOv QS: 3 (r, db, dd) | N = 25 Age: 41 (range: 19–61) 52% female Migraine; frequency N/S Chron: N/S (range: N/S) Rec: N/S | Placebo: n = 19* Propranolol: 20 mg, 4x/day; n = 19* No baseline described; two 3-mo treatment periods; no washout; no follow-up Acute migraine meds (salicylates, ergotamines) permitted, but not prophylactic use of ergotamines or methysergide | HA frequency: Not defined; not clear how data gathered | Fifteen of 19 pts (79%) receiving propranolol improved on HA frequency (achieved ≥ 50% improvement from pre- to post-treatment); 2/19 pts (11%) receiving placebo improved on this outcome. Investigators did not report having analyzed the between-group or pre- to post-treatment results for statistical significance. | Dropouts: 6 (24%), none due to AEs Not clear how data obtained; no mention of HA diaries; HA frequency assessed at 4-wk intervals by investigators
Welch, Ellis, and Keenan, 1985 | CrOv QS: 3 (r, db, dd) | N = 46 Age: 39 (range: 22–71) 88% female Common or classic migraine (Ad Hoc); ≥ 1-yr history; ≥ 2 HAs/mo in last 3 mos Chron: N/S Rec: N/S | Placebo: n = 31 * Naproxen sodium (Anaprox®): 550 mg, 2x/day; n = 31* 2-wk baseline period (placebo); two 8-wk treatment periods; 2-wk washout (placebo); no follow-up Acetaminophen, a narcotic preparation (usually codeine), or ergotamine permitted for treatment of acute attacks | HA index: Computed on average weekly basis; 7[1 (F_1_) + 2(F_2_) + 3(F_3_)]/no. of days in period, where F_1_=no. of days with mild HA, F_2_=no. of days with moderate HA, F_3_=no. of days with severe HA HA frequency: Days per wk with HA HA duration: Hrs per wk with HA | Naproxen sodium was significantly better than placebo for HA index (p=0.02). Mean HA index scores (± SD) were 2.61 (± 2.01) with naproxen sodium and 3.47 (± 2.16) with placebo. 10/31 patients (32%) reported a > 50% improvement in HA index score on naproxen sodium compared with placebo. There was no significant difference between the two treatments for HA frequency (p=0.11). Mean HA frequency (± SO) was 1.57 (± 1.14) with naproxen sodium and 1.88 (± 1.08) with placebo. | Dropouts: 15 (33%), 5 due to AEs (4 naproxen sodium, 1 placebo) No carry-over effects
Wessely, Baum-gartner, Klingler, et al., 1987 | SPPG QS: 2 (nr, db, dd) | N = 45 Age: 43 89% female Classical or common migraine Chron: N/S Rec: N/S | Placebo: n = 19 Gabapentin: 300 mg, 3x/day; n = 14 3-mo baseline period; 3-mo treatment period; no follow-up Acute meds permitted | HA frequency: No. of attacks/month | HA frequency was reduced from 6.5 attacks per month (baseline) to 4.1 attacks per month (during treatment period) in the gapapentin group; corresponding figures in the placebo group were 4.3 and 4.0, respectively (no variance data reported). Investigators did not report whether they found the difference between the two treatments to be statitistically significant. | Dropouts: 12 (27%),3 due to AEs (2 gabapentin, 1 placebo) Abstract reporting limited interim results
Widerøe and Vigander, 1974 | CrOv QS: 3 (r, db, dd) | N = 30 Age: 38 (average) (range: 18–55) 87% female Common or classical migraine (Ad Hoc); average of 3 HAs/mo in 1 mo prior to trial Chron: N/S (range: N/S) Rec: pts who had achieved ≥ 50% reduction in HA frequency in previous uncontrolled pilot study by same authors; all had been taking prophylactics (propranolol) for ≈ 6 mos | Placebo: n = 26* Propranolol: 40 mg, 4x/day; n = 26* No baseline described; two 3-mo treatment periods; no washout; no follow-up Patients’ usual medications for acute migraine attacks apparently permitted, but this is not clear | HA frequency: Not defined, but recorded daily by pts and reported as “average monthly number of attacks” | HA frequency was reduced from an average of 3 HAs/mo at baseline to an average of 0.4 and 1.7 HAs/mo after treatment with propranolol or placebo, respectively. Investigators did not report having analyzed the differences between treatments for statistical significance. | Dropouts: 4 (13%), none due to AEs
Wilkinson, 1970 | CrOv QS:3 (r, db, dd) | N = 27 Age: 38 (range: 22–63) 89% female Chron: N/S (range: N/S) Common or classical migraine; hist. of ≥1 classical M/mo; "many" pts had classical Ms Excl: Current use of antimigraine prophylactics; previous use of clonidine Rec: Inpatients of 3 hospitals | Placebo (lactose): n = 23* Clonidine: 25 μg, 2x/day; n = 23* Clonidine: 50 μg, 2x/day; n = 23* 2-wk baseline; three 6-wk treatment periods; no washout between treatment periods, but data from first 2 wks of second and third treatment periods excluded from analyses; no follow-up Nothing on acute meds | HA frequency: Definition N/S, but obtained from pts' diaries HA intensity: Rating scale N/S, but obtained from pts' diaries | Results were reported only as pts' "preferences" (not defined). Fourteen of 23 (61 %) and 7/23 pts (30%) preferred clonidine or placebo, respectively. Two of 23 (9%) had no preference. Investigators did not report whether or not they analyzed these results for statistically significant differences. No within-group results were provided for comparisons of HA frequency or intensity before and after treatment with each intervention. | Dropouts: 4 (15%), 2 for unspecified reasons; 2 because they "were worse" This study reports preliminary results from 23 pts who had completed treatment (from a trial with 82 pts)
Wilkinson, Agnoli, Gerber, et al., 1989 | SPPG QS: 3 (r, db, dd) | N = 127 Age: N/S (range: N/S) % female N/S Common or classical migraine; 2–8 HAs/mo Excl: Use of concomitant migraine prophylactic meds Chron: N/S (range: N/S) Rec: N/S | Lisuride (Cuyalit®): 0.025 mg, 3x/day; n = 43 Lisuride (Cuyalit®): 0.05 mg, 3x/day; n = 49 1-mo baseline; 3-mo treatment period, followed by 1-mo washout without meds; no follow-up Ergotamine apparently permitted, but this is not clear | HA index: Calculated as the sum of severe HAs times 4, moderate HAs times 2, and mild HAs times 1 HA frequency: Defined as "no of attacks" HA intensity: Recorded by pt on 3-point scale | Investigators did not provide specific results for HA index, but reported that both lisuride groups improved from pre- to post-treatment. There were no statistically significant differences between the two dosages (p > 0.05). From baseline to the end of 3 mos, 16/43 pts (37%) treated with lisuride 0.025 mg, 3x/day, reduced HA frequency ≥ 50%. Over the same period, 18/49 pts (37%) treated with lisuride 0.05 mg, 3x/day, reduced HA frequency ≥ 50%. Investigators stated that there were no major differences between the two treatments, but did not report whether or not they analyzed the results for statistical significance. | Dropouts: 35 pts (28%) withdrew, 15 due to AEs (lower dose 9, higher dose 6) Trial was multi-center study in 5 European cities
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | CrOv QS: 3 (r, db, dd) | N = 125 Age: 39 78% female Migraine w/or w/o aura (IHS); ≥ 2-yr history; ≥ 3 attacks/mo; no other types of HA; no migraine-preventive med in month prior to trial Chron: 20 yrs Rec: Neuro clinics and pain centers | Metoprolol: 50 mg, 2x/day; n = 78* Bisoprolol: 5 mg, 1x/day (a.m.); n = 78* 1-mo baseline period (HA recording); two 3-mo treatment periods; no washout, but data from first month of each treatment period excluded from analysis to minimize carry-over effects; no follow-up Acute meds permitted | HA frequency: No. of attacks per month HA severity: Severity of each attack graded on scale of 1–4 (mild, moderate, severe, very severe) HA duration: Per attack, in hrs | There were no significant differences between the two treatments for HA frequency (p>0.05). Mean HA frequency (± SD) was 4.0 (± 1.56) during the baseline period, 2.05 (± 1.84) during treatment with bisoprolol, and 1.99 (± 1.51) during treatment with metoprolol. A reduction of 50% or more in HA frequency was reported by 41/78 patients (53%) with bisoprolol and 40/78 patients (51%) with metoprolol. Neither drug significantly reduced mean HA severity or duration. | Dropouts: 32 (26%), 14 due to AEs (not broken down by inter-vention); an additional 15 patients were excluded from the efficacy analysis due to protocol violations No carry-over effect Dose was doubled in a few patients (approx 10%) after 4 wks
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | SPPG QS:3 (r, db, dd) | N = 59 Age: N/S 87% female Classic or common migraine (Ad Hoc); history ≥ 3 yrs; ≥ 6 attacks in previous 2 mos; avg duration ≥ 4 hrs; not using prophylactic med Chron: N/S Rec: GP referrals | Placebo: n = 25 Femoxetine: 200 mg/day for first wk, 300 mg/day therafter; n = 20 No baseline period described; 12-wk treatment period; no follow-up Patients allowed to take meds for acute attacks | HA index: No. of HA days/two-wk period x severity (severity graded on scale of 1–3); medians/two-wk period reported (in graphic form only) HA frequency: Number of attacks; medians/two-wk period reported (in graphic form only) HA duration: In hrs; median duration/two-wk period reported (in graphic form only) | Median values for the principal efficacy outcomes were reported in graphic form only and could not be reliably read off the graphs. Investigators employed a nonparametric type of ANOVA analysis, assessing treatments, time course, and interaction between treatment and time course simultaneously. HA index, frequency, and duration were all significantly reduced over time in both groups. Direct comparison between femoxetine and placebo showed no significant differences (p-values between 0.7–0.17 for the three outcomes). Differences between treatments disregarding time-course were never significant (all p-values > 0.10). | Dropouts: 14 (24%), 3 due to AEs (all with femoxetine)
Ziegler and Ellis, 1985 | CrOv QS: 3 (r, db, dd) | N = 40 Age: 40 82% female Common or classic migraine; ≥ 2 HAs/mo for ≥ 1 yr Chron: N/S Rec: N/S | Placebo: n = 34* Naproxen sodium (Anaprox®): 550 mg, 2x/day; n = 34* 2-wk baseline period (placebo); two 8-wk treatment periods; 2-wk washout (placebo); no follow-up Acute meds permitted, but patients instructed to avoid all other drugs with anti- platelet or prostaglandin synthesis-inhibiting effect, especially aspirin | HA Index: Computed on average weekly basis; 7[1 (F_1_) + 2(F_2_) + 3(F_3_)]/no. of days in period, where F_1_=no. of days with mild HA, F_2_=no. of days with moderate HA, F_3_ =no. of days with severe HA HA duration: Hrs per wk with HA | Naproxen sodium was significantly better than placebo for HA Index (p=0.004). Mean HA index scores (± SD) were 2.79 (± 2.47) with naproxen sodium and 3.82 (± 2.73) with placebo. 13/34 patients (38%) reported a > 50% improvement in HA index score on naproxen sodium compared with placebo. Naproxen sodium was also significantly better than placebo for HA duration (p=0.02). | Dropouts: 6 (15%), 1 due to AEs (naproxen sodium)
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 (study of predictors of response in the same study population) | CrOv QS: 3 (r, db, dd) | N = 54 Age: 38 (range: 22–57) 73% female Migraine; > 50% of HAs “disabling” or “severe”; > 50% of HAs of duration ≥ 2 hrs; ≥ 2 HAs/mo in last 3 mos; ≤ 3 HAs/wk in last 3 mos; pain not confined to neck or posterior head regions Chron: N/S Rec: N/S | Placebo: n= 30* Propranolol: Initially 80 mg/day; could be increased after 4 wks to maximum of 240 mg/day; n = 30* Amitriptyline: Initially 50 mg/day; could be increased after 4 wks to maximum of 150 mg/day; n = 30* 4-wk baseline period; three treatment periods; these of 8 wks’ duration each, except in the following cases: (a) if no response to placebo after 4 wks, then patient proceeded to next treatment; (b) if “toxic reaction” experienced in first 4 wks of treatment, then patient proceeded to next treatment after 4 wks; 4-wk “crossover” periods after baseline period and each of first two treatment periods (taper prior agent, 1 wk; placebo washout, 1 wk; start next agent, 2 wks); no follow-up Acetaminophen or codeine permitted for acute attacks | Weekly HA Index: Total of daily HA index scores for 7 days; daily score = HA severity (scale of 1- 10) multiplied by duration (hrs) for all HAs of severity ≥ 4; investigators reported both continuous (mean weekly HA index scores) and categorical data (no. of patients with ≥50%, 11–49%, and ≤ 10% reduction in mean weekly HA index scores) | Both active treatments produced significantly lower mean weekly HA Index scores than did placebo (p<0.05 for both comparisons). There was no significant difference between the two active treatments (p>0.05). Mean weekly scores were 404.6 for propranolol, 429.4 for amitriptyline, and 510.8 for placebo (no variance data reported). A good response with propranolol or amitriptyline was defined as a reduction of 50% or more In mean weekly HA Index score vis-á-vis the score achieved on placebo. Ten of 30 patients (33%) had a good response with propranolol, as did 12/30 (40%) with amitriptyline. Five of 30 (17%) and 12/30 (40%) patients reported a “moderate” response (reduction of 11–49%) with propranolol and amitriptyline, respectively, and 13/30 (43%) and 8/30 (27%) recorded a “poor” response (≤10% reduction) with propranolol and amitriptyline, respectively. There was no significant difference between the two active treatments for this outcome (p=0.29). Ziegler, Hurwitz, Preskorn, et al. (1993) studied predictors of response to treatment in this study population. They reported that specific response to amitriptyline was correlated with female sex and with baseline HAs of shortest duration and highest frequency. Response to propranolol was correlated with attacks of greatest duration at baseline and with low pulse rise with exercise at baseline. Nonspecific response was associated with male sex, most frequent HAs by history, and least frequent HAs during baseline period. | Dropouts: 24 (44%), 3 due to “toxic reactions” (not clear to which intervention); 3 of the 24 dropouts were excluded before treatment began due to a low rate of HAs during the baseline period
Zuddas, Mulas, Del Zompo, et al., 1985 | SPPG QS: 3 (r, db+, dnd) | N =30 Age: 32 (range: 19–39) 100% female Migraine associated with menstrual cycle, defined as from 2 days before until 3 days after first day of cycle; half of pts experienced photophobia; HA duration range: 5–72 hrs Chron: 17 (range: 12–28) Rec: N/S | Placebo: n = 15 Lisuride: Dose gradually increased until it was 0.025 mg, 3x/day on Day 7 and thereafter; n = 15 No baseline described; 3-mo treatment period; no follow-up No mention of acute migraine meds | HA index: Not defined, but reported for 3 mos HA frequency: Defined as "no. of HAs in 3 mos" HA intensity: Rated on 3-point scale for 3 mos | Investigators defined success as (1) an improvement of > 40% for each outcome and (2) the disappearance of or marked improvement of menstruation-related HAs, with improvement defined as "a reduction in HA intensity rating from 3 to 1." Investigators reported that lisuride was significantly better than placebo, but did not specify the outcome being measured or a p- value. In the lisuride group, > 65% of patients improved significantly, but investigators did not specify the outcome being measured (no p-value given). In the placebo group, < 40% of pts improved on the same outcome. | Dropouts: N/S Information obtained from abstract Not clear how data obtained

1 Key to abbreviations: ad = advertisement; AE = adverse events; a.m. = ante meridiem; ANOVA = analysis of variance; approx = approximately; ARIMA = autoregressive integrated moving average; Assoc = Association; AT = autogenic; av or avg = average; bef. = before; BF = biofeedback; CDH = chronic daily headache; Chron = chronicity; cog.-beh. = cognitive-behavioral; CrOv = crossover; db = double-blind; db+ = double-blinding described; db− = double-blinding inadequate; dd = dropouts described; DEK = dihydroergokryptine; DHE = dihydroergotamine; dnd = dropouts not described; ea. = each; ES = effect size; Excl = exclusion criteria; Fed = Federation; GP = general practice; Grp = Group; HA = headache; HCI = hydrochloride; HI = headache index; hist. = history; hr = hour; IHS = International Headache Society; in = intranasal; kg = kilogram; L = liter; L-5-HTP = oxitriptan; LA = long-acting; M = migraine; MAOI = monoamine oxidase inhibitor; max = maximum; mcg = microgram; MD = medical doctor; meds = medications; mg = milligram; MINES = Migraine-Nimodipine European Study Group; mo = month; mod = moderate; N/S = not specified; N = population size (n = sample size); N/S = not specified; n.s. = not (statistically) significant; ndb = not double-blinded; neuro. = neurology; no. = number; nr = not randomized; NSAID = nonsteroidal anti-inflammatory drug; OK = okay; OTC = over-the-counter; p.o. = per os (orally); pt = patient (or "points"); QS = quality score; r = randomized; r+ = randomization described; r− = randomization inadequate; Rec = recruitment setting; relax. = relaxation; SD = standard deviation; SEM = standard error of the mean; SPPG = single-period parallel-group; tab = tablet; tot. = total; TTH = tension-type headache; TTS = transdermal therapeutic system; U.K. = United Kingdom; Univ. = University; U.S. = United States; vs. = versus; w/= with; w/o = without; wk = week; yr = year; μg = microgram; 5-HTP = oxitriptan

2 An asterisk denotes a crossover trial.

Evidence Table 2 Efficacy of Alpha-2 Agonisfs 1, 2

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO (AND DOSING STUDIES)
Clonidine
Adam, Gore, and Price, 1978 | Clonidine (Dixarit®), 0.075–0.150 mg/day for 6 mos | - | - | 70* | - | - | n.s. (no p-value reported) HF
Adam, Gore, and Price, 1978 | Placebo | - | - | 70* | | | n.s. (no p-value reported) HF
Boisen, Deth, Hübbe, et al., 1978 | Clonidine, 0.1 mg/day for 8 wks | - | - | 49* | - | 13.1 | n.s. (no p-value reported) HF
Boisen, Deth, Hübbe, et al., 1978 | Placebo | - | - | 49* | - | 13.3 | n.s. (no p-value reported) HF
Bredfeldt, Sutherland, and Kruse, 1989, | Clonidine (Dixarit®), ≈ 0.2 mg/day via 1 transdermal (Catapres TTS- 2®) patch/wk for 6 wks | - | - | 30* | - | 10.0 | n.s. (no p-value reported) HF
Bredfeldt, Sutherland, and Kruse, 1989, | Placebo | - | - | 30* | - | 11.2 | n.s. (no p-value reported) HF
Das, Ahuja, and Narainaswamy, 1979 | Clonidine, 50 μg/day for 6 wks | - | - | 20* | - | 8.2 | n.s. (p > 0.05) HF
Das, Ahuja, and Narainaswamy, 1979 | Placebo | - | - | 20* | - | 8.0 | n.s. (p > 0.05) HF
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 1) | Clonidine, 75 μg/day for 4 wks | - | - | 50* | 3.94 | 2.26 | 0.45 (0.05 to 0.85) HF
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 1) | Placebo | | - | 50* | 3.94 | 2.98 | 0.45 (0.05 to 0.85) HF
Mondrup and Møller, 1977 | Clonidine, 100 μg/day for 1 wk; dose then increased to 150 μg/day for 11 wks | - | - | 21* | 24.4 (median) | 20.5 (median) | n.s. (no p-value reported) HF
Mondrup and Møller, 1977 | Placebo | - | - | 21* | 24.4 (median) | 17.1 (median) | n.s. (no p-value reported) HF
Ryan, Diamond, and Ryan, 1975 | Clonidine, 0.05–0.15 mg/day for 8 wks | - | - | 133* | | | n.s. (no p-value reported) HI
Ryan, Diamond, and Ryan, 1975 | Placebo | - | - | 133* | - | - | n.s. (no p-value reported) HI
Shafar, Tallett, and Knowlson, 1972 (Data are from group with less frequent HAs) | Clonidine, 100 μg/day for 16 wks | - | - | 42* | 15.07 | 11.12 | n.s. (p < 0.1) HI
Shafar, Tallett, and Knowlson, 1972 (Data are from group with less frequent HAs) | Placebo | - | - | 42* | 15.07 | 13.23 | n.s. (p < 0.1) HI
Sjaastad and Stensrud, 1971 | Clonidine (Catapresan®), 75 μg/day for 3 wks | - | - | 26* | - | - | p < 0.025 (clonidine better) HI
Sjaastad and Stensrud, 1971 | Placebo | - | - | 26* | - | - | p < 0.025 (clonidine better) HI
Stensrud and Sjaastad, 1976a | Clonidine (Catapresan®), 75–150 μ/day for 7 wks | - | - | 27* | 10.3 | 11.1 | p < 0.02 (clonidine better, though both increased) HI
Stensrud and Sjaastad, 1976a | Placebo | - | - | 27* | 10.3 | 14.1 | p < 0.02 (clonidine better, though both increased) HI
Wilkinson, 1970 | Clonidine, 100 μg/day for 6 wks | - | - | 23* | - | - | -
Wilkinson, 1970 | Placebo (lactose) | - | - | 23* | - | - | -
Wilkinson, 1970 | Clonidine, 50 μg/day for 6 wks | - | - | 23* | - | - | -
Wilkinson, 1970 | Placebo | - | - | 23* | - | - | -
Wilkinson, 1970 | Clonidine, 100 μg/day for 6 wks | - | - | 23* | - | - | -
Wilkinson, 1970 | Clonidine, 50 μg/day for 6 wks | - | - | 23* | - | - | -
Guanfacine
Elkind, Webster, Herbertson, et al., 1989a | Guanfacine, 1.0 mg/day for 12 wks | - | - | 12 | - | - | p= 0.005 (guanfacine better) HF
Elkind, Webster, Herbertson, et al., 1989a | Placebo | - | - | 12 | - | - | p= 0.005 (guanfacine better) HF
Elkind, Webster, Herbertson, et al., 1989a | Guanfacine, 0.5 mg/day for 12 wks | - | - | 13 | - | - | n.s. (p = 0.62) HF
Elkind, Webster, Herbertson, et al., 1989a | Placebo | - | - | 12 | - | - | n.s. (p = 0.62) HF
Elkind, Webster, Herbertson, et al., 1989a | Guanfacine, 1.0 mg/day for 12 wks | - | - | 12 | - | - | -
Elkind, Webster, Herbertson, et al., 1989a | Guanfacine, 0.5 mg/day for 12 wks | - | - | 13 | - | - | -
COMPARISONS WITH ANTICONVULSANTS
Clonidine vs. carbamazepine
Anthony, Lance, and Somerville, 1972 | Clonidine, 225 μg/day for 1 mo | 16/30 (53%) | 2.3 (0.80 to 6.5) ≥ 50% reduction in HF | 30 | - | - | n.s. (0.1 < p < 0.2) HF
Anthony, Lance, and Somerville, 1972 | Carbamazepine, 600 mg/day for 1 mo | 10/30 (33%) | 2.3 (0.80 to 6.5) ≥ 50% reduction in HF | 30 | - | - | n.s. (0.1 < p < 0.2) HF
COMPARISONS WITH BETA-BLOCKERS
Clonidine vs. metoprolol
Louis, Schoenen, and Hedman, 1985a | Clonidine, 100 μg/day for 8 wks | 8/29* (28%) | 0.65 (0.21 to 2.0) > 50% reduction in HF | 31* | 11.2 (median) | 10.2 (median) | p < 0.05 (metoprolol better) HI
Louis, Schoenen, and Hedman, 1985a | Metoprolol, 100 mg/day for 8 wks | 10/27* (37%) | 0.65 (0.21 to 2.0) > 50% reduction in HF | 31* | 11.2 (median) | 8.4 (median) | p < 0.05 (metoprolol better) HI
Clonidine vs. practolol
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 2) | Clonidine, 150 μg/day for 8 wks | - | - | 50* | 4.0 | 1.88 | 0.21 (−0.19 to 0.60) HF
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 2) | Practolol, 150 mg/day for 8 wks | - | - | 50* | 4.0 | 2.49 | 0.21 (−0.19 to 0.60) HF
Clonidine vs. prindolol
Anthony, Lance, and Somerville, 1972 | Clonidine, 225 μg/day for 1 mo | 16/30 (53%) | 0.65 (0.24 to 1.8) ≥ 50% reduction in HF | - | - | - | -
Anthony, Lance, and Somerville, 1972 | Prindolol, 10 mg/day for 1 mo | 21/33 (64%) | 0.65 (0.24 to 1.8) ≥ 50% reduction in HF | - | - | - | -
Clonidine vs. propranolol
Käss and Nestvold, 1980 | Clonidine (Catapresan®), 100 μg/day for 16 wks | 8/21* (38%) | 0.38 (0.11 to 1.32) > 50% reduction in HF | 21* | - | - | n.s. (no p-value reported) HF
Käss and Nestvold, 1980 | Propranolol (Inderal®), 160 mg/day for 16 wks | 13/21* (62%) | 0.38 (0.11 to 1.32) > 50% reduction in HF | 21* | - | - | n.s. (no p-value reported) HF
COMPARISONS WITH SEROTONIN ANTAGONISTS
Clonidine vs. pizotifen
Behan, 1985 | Clonidine (Dixarit®), 100 μg/day for 1 mo; 100–150 μg/day for 2d mo | - | - | 26 | - | - | -
Behan, 1985 | Pizotifen (Sanomigran®), 1.5 mg/night for 1 mo; 1.5 – 3.0 mg/night for 2d mo | - | - | 18 | - | - | -

1 Key to abbreviations: HA = headache; HF = headache frequency; HI = headache index; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not significant (statistically); TTS = transdermal therapeutic system; wk = week; μg = microgram

2 An asterisk denotes a crossover trial.

Evidence Table 3 Efficacy of Anticonvulsants^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO (AND DOSING STUDIES)
Divalproex sodium
Klapper, 1996 | Divalproex sodium, 1500 mg/day for 3 mos | 20/44 (45%) | 3.1 (1.2 to 7.9) ≥ 50% reduction in HF | 44 | - | 1.7 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Klapper, 1996 | Placebo | 9/42 (21%) | 3.1 (1.2 to 7.9) ≥ 50% reduction in HF | 42 | - | 0.5 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Klapper, 1996 | Divalproex sodium, 1000 mg/day for 3 mos | 17/40 (43%) | 2.7 (1.03 to 7.1) ≥ 50% reduction in HF | 40 | - | 2.0 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Klapper, 1996 | Placebo | 9/42 (21%) | 2.7 (1.03 to 7.1) ≥ 50% reduction in HF | 42 | - | 0.5 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Klapper, 1996 | Divalproex sodium, 500 mg/day for 3 mos | 20/45 (44%) | 2.9 (1.1 to 7.5) ≥ 50% reduction in HF | 45 | - | 1.7 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Klapper, 1996 | Placebo | 9/42 (21%) | 2.9 (1.1 to 7.5) ≥ 50% reduction in HF | 42 | - | 0.5 (reduction from baseline) | p≤0.05 (divalproex sodium better) HF
Mathew, Saper, Silberstein, et al., 1995 | Divalproex sodium, 1087 mg/day (average) for 3 mos | 33/69 (48%) | 5.7 (1.98 to 16) ≥ 50% reduction in HF | 69 | 6.0 | 3.5 | p≤0.001 (divalproex sodium better) HF
Mathew, Saper, Silberstein, et al., 1995 | Placebo | 5/36 (14%) | 5.7 (1.98 to 16) ≥ 50% reduction in HF | 36 | 6.4 | 5.7 | p≤0.001 (divalproex sodium better) HF
Sodium valproate
Hering and Kuritzky, 1992 | Sodium valproate, 800 mg/day for 2 mos | - | - | 29* | - | 8.826 | 0.93 (0.39 to 1.5) HF
Hering and Kuritzky, 1992 | Placebo | - | - | 29* | - | 15.586 | 0.93 (0.39 to 1.5) HF
Jensen, Brinck, and Olesen, 1994 | Sodium valproate (slow-release), 1000–1500 mg/day for 3 mos | 22/34 (65%) | 7.1 (2.4 to 21) ≥ 50% reduction in HF | 34* | 6.1 | 3.5 | p=0.0018 (sodium valproate better) HF
Jensen, Brinck, and Olesen, 1994 | Placebo | 7/34 (21%) | | 34* | 6.1 | 6.1 | p=0.0018 (sodium valproate better) HF
Carbamazepine
Rompel and Bauermeister, 1970 | Carbamazepine, 600 mg/day for 6 wks | 26/45 (58%) | 12 (3.9 to 35) Marked or complete improvement in HI | 45* | - | 0.67 | - HF
Rompel and Bauermeister, 1970 | Placebo | 5/48 (10%) | 12 (3.9 to 35) Marked or complete improvement in HI | 48* | - | 3.87 | - HF
Clonazepam
Stensrud and Sjaastad, 1979 | Clonazepam, 1 mg/day for 1 mo | - | - | 38* | - | - | p=0.20 (n.s.) HI
Stensrud and Sjaastad, 1979 | Placebo | - | - | 38* | - | - | p=0.20 (n.s.) HI
Gabapentin
Wessely, Baumgartner, Klingler, et al., 1987 | Gabapentin, 900 mg/day for 3 mos | - | - | 14 | 6.5 | 4.1 | - HF
Wessely, Baumgartner, Klingler, et al., 1987 | Placebo | - | - | 19 | 4.3 | 4.0 | - HF
COMPARISONS WITH BETA-BLOCKERS
Divalproex sodium vs. propranolol
Klapper, 1994 | Divalproex sodium, 1100 mg/day (average) for 2 mos | - | - | 12* | - | 10.9 | - HF
Klapper, 1994 | Propranolol, 140 mg/day (average) for 2 mas | - | - | 12* | - | 20.4 | - HF
Carbamazepine vs. prindolol
Anthony, Lance, and Somerville, 1972 | Carbamazepine, 600 mg/day for 1 mo | 10/30 (33%) | 0.29 (0.10 to 0.81) ≥ 50% reduction in HF | - | - | - | -
Anthony, Lance, and Somerville, 1972 | Prindolol, 10 mg/day for 1 mo | 21/33 (64%) | 0.29 (0.10 to 0.81) ≥ 50% reduction in HF | - | - | - | -
COMPARISONS WITH ALPHA-2 AGONISTS
Carbamazepine vs. clonidine
Anthony, Lance, and Somerville, 1972 | Carbamazepine, 600 mg/day for 1 mo | 10/30 (33%) | 0.44 (0.15 to 1.2) ≥ 50% reduction in HF | - | - | - | -
Anthony, Lance, and Somerville, 1972 | Clonidine, 225 μg/day for 1 mo | 16/30 (53%) | 0.44 (0.15 to 1.2) ≥ 50% reduction in HF | - | - | - | -

1 Key to abbreviations: HF = headache frequency; HI = headache index; HS = headache severity; mg = milligram; mo = month or months; N = population studied (n = sample size); n.s. = not (statistically) significant; μg = microgram

2 An asterisk denotes a crossover trial.

Evidence Table 4 Efficacy of Antidepressants^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio or p-value | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio or p-value | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO
Amitriptyline
Couch and Hassanein, 1976 and 1979 | Amitriptyline, 50–100 mg/day for 1 mo | 26/47 (55%) | 2.4 (1.1 to 5.4) ≥ 50% reduction in HI | 37 | 112.1 | 68.5 | 0.62 (0.15 to 1.1) HI
Couch and Hassanein, 1976 and 1979 | Placebo | 18/53 (34%) | 2.4 (1.1 to 5.4) ≥ 50% reduction in HI | 36 | 67.7 | 104.1 | 0.62 (0.15 to 1.1) HI
Gomersall and Stuart, 1973 | Amitriptyline, 30–60 mg/day for 6.5 mos (26 wks) | - | - | 20* | - | 207 | p<0.001 (amitriptyline better) HF
Gomersall and Stuart, 1973 | Placebo | - | - | 20* | - | 356 | p<0.001 (amitriptyline better) HF
Ziegler, Hurwitz, Hassanein, et al., 1987 | Amitriptyline, 50–150 mg/day for 2 mos | - | - | 30* | - | 429.4 | p<0.05 (amitriptyline better) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Placebo | - | - | 30* | - | 510.8 | p<0.05 (amitriptyline better) HI
Clomipramine
Langohr, Gerber, Koletzki, et al., 1985 | Clomipramine, 100 mg/day (max) for 1 mo | 5/20* (24%) | 0.95 (0.25 to 3.6) > 50% reduction in HF | 20* | - | - | n.s. (no p-value reported) HF
Langohr, Gerber, Koletzki, et al., 1985 | Placebo | 7/27* (26%) | 0.95 (0.25 to 3.6) > 50% reduction in HF | 27* | - | - | n.s. (no p-value reported) HF
Noone, 1980 | Clomipramine, 30 mg/day for 2 mos | - | - | 10* | 6 (median) | 3 (median) | p=0.46 (n.s) HF
Noone, 1980 | Placebo | - | - | 10* | 6 (median) | 3.5 (median) | p=0.46 (n.s) HF
Femoxetine
Orholm, Honoré, and Zeeberg, 1986 | Femoxetine, 200–600 mg/day for 4 mos | - | - | 25 | 7.3 (median) | 6.3 (median) | n.s. (no p-value reported) HI
Orholm, Honoré, and Zeeberg, 1986 | Placebo | - | - | 28 | 6.8 (median) | 4.5 (median) | n.s. (no p-value reported) HI
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Femoxetine, 200–300 mg/day for 3 mos | - | - | 20 | - | - | p>0.10 (n.s.) HI
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Placebo | - | - | 25 | - | - | p>0.10 (n.s.) HI
Fluoxetine
Adly, Straumanis, and Chesson, 1992 | Fluoxetine, 20 mg every other day − 40 mg/day for 2 mos | - | - | 9 | 32 (median) | 6 (median) | p<0.05 (fluoxetine better) HI
Adly, Straumanis, and Chesson, 1992 | Placebo | - | - | 9 | 35 (median) | 24 (median) | p<0.05 (fluoxetine better) HI
Saper, Silberstein, Lake, et al., 1994 | Fluoxetine, 20 – 40 mg/day for 3 mos | - | - | 31 | - | - | n.s. (no p-value reported) HI
Saper, Silberstein, Lake, et al., 1994 | Placebo | - | - | 26 | - | - | n.s. (no p-value reported) HI
Mianserin
Monro, Swade, and Coppen, 1985 | Mianserin, 30–60 mg/day for 4 mos | - | - | 16 | - | - | n.s. (no p-value reported) HI
Monro, Swade, and Coppen, 1985 | Placebo | - | - | 18 | - | - | n.s. (no p-value reported) HI
Opipramol
Jacobs, 1972 | Opipramol for 1.5 mos (6 wks) | - | - | 13 | - | 2.8 | 0.05>p>0.02 (opipramol better) HF
Jacobs, 1972 | Placebo | - | - | 12 | - | −0.1 | 0.05>p>0.02 (opipramol better) HF
COMPARISONS AMONG ANTIDEPRESSANTS
Amitriptyline VS. fluvoxamine
Bánk, 1994 | Amitriptyline, 25 mg/day for 3 mos | - | - | 20 | 0.41 (median) | 0.24 (median) | - HS
Bánk, 1994 | Fluvoxamine, 50 mg/day for 3 mos | - | - | 24 | 0.43 (median) | 0.18 (median) | - HS
COMPARISONS WITH BETA-BLOCKERS
Amitriptyline vs. propranolol
Mathew, 1981 (Migraine-only) | Amitriptyline, 25–75 mg/day for 6 mos | - | - | 32 | 3.93 | 2.28 | −0.15 (−0.62 to 0.32) HI
Mathew, 1981 (Migraine-only) | Propranolol, 60–160 mg/day for 6 mos | - | - | 38 | 4.12 | 1.57 | −0.15 (−0.62 to 0.32) HI
Mathew, 1981 (Mixed HA) | Amitriptyline, 25–75 mg/day for 6 mos | - | - | 31 | 7.78 | 3.12 | 0.02 (−0.46 to 0.49) HI
Mathew, 1981 (Mixed HA) | Propranolol, 60–160 mg/day for 6 mos | - | - | 38 | 6.70 | 3.24 | 0.02 (−0.46 to 0.49) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Amitriptyline, 50–150 mg/day for 2 mos (See ET 1) | 12/30* (40%) | 1.33 (0.47 to 3.8) ≥50% reduction in HI vis-à-vis placebo | 30* | - | 429.4 | p>0.05 (n.s) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Propranolol, 80–240 mg/day for 2 mos (See ET 1) | 10/30* (33%) | 1.33 (0.47 to 3.8) ≥50% reduction in HI vis-à-vis placebo | 30* | - | 404.6 | p>0.05 (n.s) HI
Femoxetine vs. propranolol
Andersson and Petersen, 1981 | Femoxetine, 200–400 mg/day for 3 mos | 6/28* (21%) | 0.49 (0.15 to 1.6) > 50% reduction in HI | 28* | 24.5 | 17.9 | −0.17 (−0.70 to 0.35) HI
Andersson and Petersen, 1981 | Propranolol, 80–160 mg/day for 3 mos | 10/28* (36%) | 0.49 (0.15 to 1.6) > 50% reduction in HI | 28* | 24.5 | 16.0 | −0.17 (−0.70 to 0.35) HI
Kangasniemi, Nyrke, Lang, et al., 1983 | Femoxetine, 200–400 mg/day for 3 mos | - | - | 24* | 10.30 | 9.68 | −0.34 (−0.91 to 0.23) HI
Kangasniemi, Nyrke, Lang, et al., 1983 | Propranolol, 80–160 mg/day for 3 mos | - | - | 24* | 10.30 | 7.07 | −0.34 (−0.91 to 0.23) HI
Clomipramine vs. metoprolol
Langohr, Gerber, Koletzki, et al., 1985 | Clomipramine, 100 mg/day (max) for 2 mos | 5/20* (24%) | 0.45 (0.12 to 1.7) > 50% reduction in HF | 20* | - | - | p<0.05 (metoprolol better) HF
Langohr, Gerber, Koletzki, et al., 1985 | Metoprolol, 100 mg/day (max) for 2 mos | 9/21* (44%) | 0.45 (0.12 to 1.7) > 50% reduction in HF | 21* | - | - | p<0.05 (metoprolol better) HF
COMPARISONS WITH OTHER AGENTS
Amitriptyline vs. timed-release DHE
Bonuso, Di Stasio, Barone, et al., 1983 | Amitriptyline, 75 mg/day for 2 mos | - | - | 15 | 17.0 | 5.4 | 0.82 (0.08 to 1.6) HS
Bonuso, Di Stasio, Barone, et al., 1983 | DHE (timed-release), 10 mg/day for 2 mos | - | - | 15 | 18.7 | 10.7 | 0.82 (0.08 to 1.6) HS

1 Key to abbreviations: DHE = dihydroergotamine; ET = Evidence Table; HA = headache; HF = headache frequency; HI = headache index; HS = headache severity; max. = maximum; mg = milligram; N = population studied (n = sample size); n.s. = not (statistically) significant

2 An asterisk denotes a crossover trial.

Evidence Table 5 Efficacy of Beta-Blockers^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO
Propranolol
Ahuja and Verma, 1985 | Propranolol, 120 mg/day for 2 mos | - | - | 26* | - | 20.69 | 0.58 (0.02 to 1.1) HI
Ahuja and Verma, 1985 | Placebo | - | - | 26* | - | 38.00 | 0.58 (0.02 to 1.1) HI
Al-Qassab and Findley, 1993 | Propranolol (long-acting), 160 mg/day for 2 mos | - | - | 30* | - | 3.8 (median) | n.s. (p > 0.96) HF
Al-Qassab and Findley, 1993 | Placebo | - | - | 30* | - | 3.2 (median) | n.s. (p > 0.96) HF
Al-Qassab and Findley, 1993 | Propranolol (long-acting), 80 mg/day for 2 mos | - | - | 30* | - | 3.8 (median) | n.s. (p > 0.63) HF
Al-Qassab and Findley, 1993 | Placebo | - | - | 30* | - | 3.2 (median) | n.s. (p > 0.63) HF
Børgesen, Nielsen, and Møller, 1974 | Propranolol, 120 mg/day for 8 wks | 15/30 (50%) | 2.3 (0.81 to 6.7) ≥ 50% reduction in HF | 30* | 1.77 | 1.03 | 0.44 (0.09 to 0.80) HF
Børgesen, Nielsen, and Møller, 1974 | Placebo | 9/30 (30%) | 2.3 (0.81 to 6.7) ≥ 50% reduction in HF | 30* | 1.77 | 1.33 | 0.44 (0.09 to 0.80) HF
Dahlöf, 1987 | Propranolol, 120 mg/day for 1 mo | - | - | 28* | - | 3.2 | 0.52 (−0.01 to 1.1) HF^†^
Dahlöf, 1987 | Placebo | - | - | 28* | - | 4.3 | 0.52 (−0.01 to 1.1) HF^†^
Diamond and Medina, 1976 | Propranolol, 80– 160 mg/day for 4 – 8 wks (patients preference) | - | - | 62* | - | - | -
Diamond and Medina, 1976 | Placebo | - | - | 62* | - | - | -
Forssman, Henriksson, Johannsson, et al., 1976 | Propranolol, 240 mg/day (dosage gradually increased to this level) for 10 wks | - | - | 32* | 5.14 | 3.00 | 0.56 (0.06 to 1.1) HI
Forssman, Henriksson, Johannsson, et al., 1976 | Placebo | - | - | 32* | 5.14 | 4.77 | 0.56 (0.06 to 1.1) HI
Johnson, Hornabrook, and Lambie, 1986 | Propranolol, 240 mg/day for 3 mos | - | - | 17* | - | 13.8 | 0.45 (−0.23 to 1.1) HF
Johnson, Hornabrook, and Lambie, 1986 | Placebo | - | - | 17* | - | 20.1 | 0.45 (−0.23 to 1.1) HF
Kuritzky and Hering, 1987 | Propranolol (long-acting), 160 mg/day for 1 mo | - | - | 31* | - | 3.23 | p=0.014 (propranolol better) HF
Kuritzky and Hering, 1987 | Placebo | - | - | 31* | - | 5.56 | p=0.014 (propranolol better) HF
Malvea, Gwon, and Graham, 1973 | Propranolol, dose N/S, for 6 wks | - | - | 29* | 25.4 | 18.6 | - HI
Malvea, Gwon, and Graham, 1973 | Placebo | - | - | 29* | 25.4 | 23.3 | - HI
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Propranolol, 120 mg/day for 3 mos | - | - | 31* | - | - | 0.52 (0.17 to 0.88) HF
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Placebo | - | - | 31* | - | - | 0.52 (0.17 to 0.88) HF
Palferman, Gibberd, and Simmonds, 1983 | Propranolol, 120 mg/day for 2 mos | - | - | 10* | - | 47 | n.s. (p>0.05) HI
Palferman, Gibberd, and Simmonds, 1983 | Placebo | - | - | 10* | - | 52 | n.s. (p>0.05) HI
Pita, Higueras, Bolaños, et al., 1977 | Propranolol, 160 mg/day for 2 mos | - | - | 8* | - | 2.25 | 1.1 (0.33 to 1.8) HF
Pita, Higueras, Bolaños, et al., 1977 | Placebo | - | - | 8* | - | 7.5 | 1.1 (0.33 to 1.8) HF
Pradalier, Serratrice, Collard, et al., 1989b | Propranolol (long-acting), 160 mg/day for 12 wks | - | - | 31 | 6.11 | 3.15 | 0.38 (−0.16 to 0.91) HF^‡^
Pradalier, Serratrice, Collard, et al., 1989b | Placebo | - | - | 24 | 6.00 | 6.41 | 0.38 (−0.16 to 0.91) HF^‡^
Sargent, Solbach, Damasio, et al., 1985 | Propranolol, 120 mg/day for 3 mos | - | - | 44 | - | 0.21 (difference from baseline) | 0.25 (−0.17 to 0.67) HF
Sargent, Solbach, Damasio, et al., 1985 | Placebo | - | - | 43 | - | −0.25 (difference from baseline) | 0.25 (−0.17 to 0.67) HF
Solomon, 1986 | Propranolol (long-acting), 120 mg/day for 2 mos | - | - | 15* | - | 4.5 | p<0.05 (propranolol better) HF
Solomon, 1986 | Placebo | - | - | 15* | - | 6.0 | p<0.05 (propranolol better) HF
Stensrud and Sjaastad, 1976b | Propranolol (Inderal®), 160 mg/day for 4 wks | - | - | 19* | - | 7.47 | 0.61 (0.17 to 1.05) HF
Stensrud and Sjaastad, 1976b | Placebo | - | - | 19* | - | 12.32 | 0.61 (0.17 to 1.05) HF
Stensrud and Sjaastad, 1980a | Propranolol, 160 mg/day for 6 wks | - | - | 28* | - | - | n.s. (no p-value reported) HI
Stensrud and Sjaastad, 1980a | Placebo | - | - | 28* | - | - | n.s. (no p-value reported) HI
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Propranolol, 160 mg/day for 12 wks | 48/80* (60%) | 3.5 (1.8 to 6.7) ≥ 50% reduction in HF | 80* | - | 6.66 | 0.38 (0.07 to 0.70) HI
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Placebo | 24/80* (30%) | 3.5 (1.8 to 6.7) ≥ 50% reduction in HF | 80* | - | 9.03 | 0.38 (0.07 to 0.70) HI
Weber and Reinmuth, 1972 | Propranolol, 80 mg/day for 3 mos | 15/19 (79%) | 31.5 (5.1 to 195) ≥ 50% reduction in HF | 19* | - | - | -
Weber and Reinmuth, 1972 | Placebo | 2/19 (11%) | 31.5 (5.1 to 195) ≥ 50% reduction in HF | 19* | - | - | -
Widerøe and Vigander, 1974 | Propranolol, 160 mg/day for 3 mos | - | - | 26* | 3.0 | 0.4 | 1.1 (0.68 to 1.4) HF
Widerøe and Vigander, 1974 | Placebo | - | - | 26* | 3.0 | 1.7 | 1.1 (0.68 to 1.4) HF
Ziegler, Hurwitz, Hassanein, et al., 1987 | Propranolol, 80–240 mg/day for 2 mos | - | - | 30* | - | 404.6 | p<0.05 (propranolol better) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Placebo | - | - | 30* | - | 510.8 | p<0.05 (propranolol better) HI
Combined | Test for homogeneity: Chi-square =6.5, d.f.=2, p=0.04 | | | Test for homogeneity: Chi-square =15.0, d.f.=11, p=0.18 | | | 0.55 (0.43 to 0.68)
Metoprolol
Andersson, Dahl, Hansen, et al., 1983 | Metoprolol, 200 mg/day (controlled release) for 2 mos | 10/30 (33%) | 3.9 (1.1 to 14) ≥ 50% reduction in HI | 30 | 17.63 | 11.95 | 0.58 (0.08 to 1.1) HI
Andersson, Dahl, Hansen, et al., 1983 | Placebo | 4/35 (11%) | 3.9 (1.1 to 14) ≥ 50% reduction in HI | 35 | 16.33 | 16.51 | 0.58 (0.08 to 1.1) HI
Kangasniemi, Andersen, Andersson, et al., 1987 | Metoprolol, 200 mg/day (slow-release tabs) for 2 mos | - | - | 73* | 3.8 (median) | 1.8 (median) | p = 0.004 (metoprolol better) HF
Kangasniemi, Andersen, Andersson, et al., 1987 | Placebo | - | - | 73* | 3.8 (median) | 2.5 (median) | p = 0.004 (metoprolol better) HF
Langohr, Gerber, Koletzki, et al., 1985 | Metoprolol, 100 mg/day (max) for 1 mo | 9/21* (44%) | 2.1 (0.63 to 7.2) >50% reduction in HF | 21* | - | - | n.s. (no p-value reported) HF
Langohr, Gerber, Koletzki, et al., 1985 | Placebo | 7/27* (26%) | 2.1 (0.63 to 7.2) >50% reduction in HF | 27* | - | - | n.s. (no p-value reported) HF
Steiner, Joseph, Hedman, et al., 1988 | Metoprolol, 100 mg/day for 2 mos | - | - | 28 | 11.2 | 8.2 | 0.16 (−0.36 to 0.67) HI
Steiner, Joseph, Hedman, et al., 1988 | Placebo | - | - | 31 | 10.8 | 9.4 | 0.16 (−0.36 to 0.67) HI
Atenolol
Forssman, Lindblad, and Zbornikova, 1983 | Atenolol, 100 mg/day for 3 mos | - | - | 20* | - | 0.17 | - HF
Forssman, Lindblad, and Zbornikova, 1983 | Placebo | - | - | 20* | - | 0.23 | - HF
Johannsson, Nilsson, Widelius, et al., 1987 | Atenolol, 100 mg/day for 3 mos | - | - | 63* | - | - | p=0.004 (atenolol better) HI
Johannsson, Nilsson, Widelius, et al., 1987 | Placebo | - | - | 63* | - | - | p=0.004 (atenolol better) HI
Stensrud and Sjaastad, 1980a | Atenolol, 100 mg/day for 6 wks | - | - | 28* | - | - | p<0.05 (atenolol better) HI
Stensrud and Sjaastad, 1980a | Placebo | - | - | 28* | - | - | p<0.05 (atenolol better) HI
Nadolol
Freitag and Diamond, 1984 | Nadolol, 80, 160, or 240 mg/day for 4 mos (3 groups combined) | 7/22 (32%) | 26.6 (0.30 to 2395.0) ≥ 50% reduction in HI | 24 | - | - | -
Freitag and Diamond, 1984 | Placebo | 0/8 (0%) | 26.6 (0.30 to 2395.0) ≥ 50% reduction in HI | 8 | - | - | -
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 240 mg/day for 3 mos | - | - | 20 | 8.45 | 3.28 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Placebo | - | - | 20 | 6.9 | 4.25 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 160 mg/day for 3 mos | - | - | 20 | 6.8 | 2.10 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Placebo | - | - | 20 | 6.9 | 4.25 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 80 mg/day for 3 mos | - | - | 20 | 6.73 | 4.05 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Placebo | - | - | 20 | 6.9 | 4.25 | - HF
Sudilovsky, Stern, and Meyer, 1986b | Nadolol, 240 mg/day or 160 mg/day or 80 mg/day (results not reported separately by dose) | - | - | (Total n=154) | - | - | p<0.05 (nadolol better) HI
Sudilovsky, Stern, and Meyer, 1986b | Placebo | - | - | (Total n=154) | - | - | p<0.05 (nadolol better) HI
Timolol
Briggs and Millac, 1979 | Timolol, 20 mg/day for 3 mos | - | - | 13* | - | 4.4 | 0.93 (0.39 to 1.5) HF
Briggs and Millac, 1979 | Placebo | - | - | 13* | - | 6.8 | 0.93 (0.39 to 1.5) HF
Stellar, Ahrens, Meibohm, et al., 984 | Timolol, 20–30 mg/day for 2 mos | 40/94* (43%) | 2.0 (1.1 to 3.8) ≥ 50% reduction in HF | 94* | 6.8 | 4.3 | p<0.01 (timolol better) HF
Stellar, Ahrens, Meibohm, et al., 984 | Placebo | 25/94* (27%) | 2.0 (1.1 to 3.8) ≥ 50% reduction in HF | 94* | 6.8 | 5.0 | p<0.01 (timolol better) HF
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Timolol, 20 mg/day for 12 wks | 44/80* (55%) | 2.9 (1.5 to 5.5) ≥ 50% reduction in HF | 80* | - | 5.71 | 0.54 (0.22 to 0.85) HI
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Placebo | 24/80* (30%) | 2.9 (1.5 to 5.5) ≥ 50% reduction in HF | 80* | - | 9.03 | 0.54 (0.22 to 0.85) HI
Pindolol
Ekbom and Lundberg, 1972 | Pindolol, 15 mg/day for 1 mo | - | - | 9 | - | - | n.s. (no p-value reported) HI
Ekbom and Lundberg, 1972 | Placebo | - | - | 10 | - | - | n.s. (no p-value reported) HI
Ekbom and Lundberg, 1972 | Pindolol, 7.5 mg/day for 1 mo | - | - | 7 | - | - | n.s. (no p-value reported) HI
Ekbom and Lundberg, 1972 | Placebo | - | - | 10 | - | - | n.s. (no p-value reported) HI
Sjaastad and Stensrud, 1972 | Pindolol, 7.5 or 15 mg/day for 1 mo (results not reported separately by dose) | - | - | 24* | - | - | 0.024 (−0.38 to 0.43) HI
Sjaastad and Stensrud, 1972 | Placebo | - | - | 24* | - | - | 0.024 (−0.38 to 0.43) HI
Other beta-blockers
Nanda, Johnson, Gray, et al., 1978 | Acebutolol, 800 mg/day for 3 mos | - | - | 33* | - | - | n.s. (no p-value reported) HF
Nanda, Johnson, Gray, et al., 1978 | Placebo | - | - | 33* | - | - | n.s. (no p-value reported) HF
Ekbom, 1975 | Alprenolol, 400 mg/day for 6 wks | - | - | 28* | - | 4.0 | −0.05 (−0.58 to 0.47) HI
Ekbom, 1975 | Placebo | - | - | 28* | - | 3.8 | −0.05 (−0.58 to 0.47) HI
Ekbom and Zetterman, 1977 | Oxprenolol, 240 mg/day for 2 mos | - | - | 30* | - | 30.9 | 0.15 (−0.36 to 0.65) HI
Ekbom and Zetterman, 1977 | Placebo | - | - | 30* | - | 33.9 | 0.15 (−0.36 to 0.65) HI
DOSING STUDIES
Propranolol
Al-Qassab and Findley, 1993 | Propranolol, 160 mg/day for 2 mos | - | - | 30* | - | 3.8 (median) | n.s. (p> 0.75) HF
Al-Qassab and Findley, 1993 | Propranolol, 80 mg/day for 2 mos | - | - | 30* | - | 3.8 (median) | n.s. (p> 0.75) HF
Carroll, Reidy, Savundra, et al., 1990 | Propranolol (long-acting), 160 mg/day for 12 wks | - | - | 37* | 6.10 (median) | 3.4 (median) | p =0.03 (propranolol LA 160 mg better) HF
Carroll, Reidy, Savundra, et al., 1990 | Propranolol (long-acting), 80 mg/day for 12 wks | - | - | 37* | 6.10 (median) | 3.70 (median) | p =0.03 (propranolol LA 160 mg better) HF
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Propranolol (long-acting), 160 mg/day for 3 mos | 17/21 (81%) | 0.71 (0.14 to 3.6) ≥ 50% reduction in HF (no. of attacks) | 21 | 5.4 | 4.4 | −0.16 (−0.76 to 0.45) HF (no. of HA days)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Propranolol (long-acting), 80 mg/day for 3 mos | 18/21 (86%) | 0.71 (0.14 to 3.6) ≥ 50% reduction in HF (no. of attacks) | 21 | 6.2 | 5.2 | −0.16 (−0.76 to 0.45) HF (no. of HA days)
Nadolol
Ryan, 1984 | Nadolol, 160 mg/day for 3 mos | - | - | 16 | 10.43 | 5.83 | - HI
Ryan, 1984 | Nadolol, 80 mg/day for 3 mos | - | - | 15 | 12.73 | 4.84 | - HI
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 240 mg/day for 3 mos | - | - | 20 | 8.45 | 3.28 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 160 mg/day for 3 mos | - | - | 20 | 6.8 | 2.10 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 240 mg/day for 3 mos | - | - | 20 | 8.45 | 3.28 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 80 mg/day for 3 mos | - | - | 20 | 6.73 | 4.05 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 160 mg/day for 3 mos | - | - | 20 | 6.8 | 2.10 | - HF
Ryan, Ryan, and Sudilovsky, 1983 | Nadolol, 80 mg/day for 3 mos | - | - | 20 | 6.73 | 4.05 | - HF
Sudilovsky, Elkind, Ryan, et al., 1987 | Nadolol, 160 mg/day for 2 mos | 21/33 (64%) | 3.5 (1.3 to 9.6) ≥ 50% reduction in HI | - | - | - | -
Sudilovsky, Elkind, Ryan, et al., 1987 | Nadolol, 80 mg/day for 2 mos | 11/33 (33%) | 3.5 (1.3 to 9.6) ≥ 50% reduction in HI | - | - | - | -
Pindolol
Ekbom and Lundberg, 1972 | Pindolol, 15 mg/day for 1 mo | - | - | 9 | - | - | n.s. (no p-value reported) HI
Ekbom and Lundberg, 1972 | Pindolol, 7.5 mg/day for 1 mo | - | - | 7 | - | - | n.s. (no p-value reported) HI
COMPARISONS AMONG BETA-BLOCKERS
Nadolol vs. propranolol
Olerud, Gustavsson, and Furberg, 1986 | Nadolol, 40–160 mg/day for 6 mos | 5/13 (38%) | 0.47 (0.10 to 2.2) HF | 13 | 5.6 (median) | 2.7 (median) | - HF
Olerud, Gustavsson, and Furberg, 1986 | Propranolol, 80–160 mg/day for 6 mos | 81/4 (57%) | 0.47 (0.10 to 2.2) HF | 14 | 3.6 (median) | 1.9 (median) | - HF
Ryan, 1984 | Nadolol, 160 mg/day for 3 mos | - | - | 16 | 10.43 | 5.83 | - HI
Ryan, 1984 | Propranolol, 160 mg/day for 3 mos | - | - | 14 | 14.71 | 8.01 | - HI
Ryan, 1984 | Nadolol, 80 mg/day for 3 mos | - | - | 15 | 12.73 | 4.84 | - HI
Ryan, 1984 | Propranolol, 160 mg/day for mos | - | - | 14 | 14.71 | 8.01 | - HI
Sudilovsky, Elkind, Ryan, et al., 1987 | Nadolol, 160 mg/day for 2 mos | 21/33 (64%) | 3.0 (1.04 to 8.5) ≥ 50% reduction in HI | - | - | - | -
Sudilovsky, Elkind, Ryan, et al., 1987 | Propranolol, 160 mg/day for 2 mos | 10/27 (37%) | 3.0 (1.04 to 8.5) ≥ 50% reduction in HI | - | - | - | -
Sudilovsky, Elkind, Ryan, et al., 1987 | Nadolol, 80 mg/day for 2 mos | 11/33 (33%) | 0.85 (0.29 to 2.5) ≥ 50% reduction in HI | - | - | - | -
Sudilovsky, Elkind, Ryan, et al., 1987 | Propranolol, 160 mg/day for 2 mos | 10/27 (37%) | 0.85 (0.29 to 2.5) ≥ 50% reduction in HI | - | - | - | -
Metoprolol vs. propranolol
Gerber, Diener, Scholz, et al., 1991 | Metoprolol, 50–200 mg/day (see ET 1) for 6 mos | - | - | 22? | - | - | p>0.05 (n.s) HF
Gerber, Diener, Scholz, et al., 1991 | Propranolol, 40–160 mg/day (see ET 1) for 6 mos | - | - | 19? | - | - | p>0.05 (n.s) HF
Kangasniemi and Hedman, 1984 | Metoprolol (controlled-release), 200 mg/day for 8 wks | 17/34* (50%) | 1.2 (0.46 to 3.1) HI | 34* | 9.7 | 4.9 | 0.15 (−0.33 to 0.63) HI
Kangasniemi and Hedman, 1984 | Propranolol, 160 mg/day for 8 wks | 15/33* (45%) | 1.2 (0.46 to 3.1) HI | 33* | 9.7 | 5.4 | 0.15 (−0.33 to 0.63) HI
Olsson, Behring, Forssman, et al., 1984 | Metoprolol, 100 mg/day for 8 wks | 21/56* (37%) | 1.4 (0.62 to 3.1) HI | 56* | - | - | -
Olsson, Behring, Forssman, et al., 1984 | Propranolol, 80mg/day for 8 wks | 16/53* (30%) | 1.4 (0.62 to 3.1) HI | 53* | - | - | -
Steardo, Bonuso, Di Stasio, et al., 1982 | Metoprolol, 300 mg/day for 6 mos | 1/16 (6%) | 0.03 (0.004 to 0.29) ≥50% reduction in HF | 16 | - | 16.13 | −1.3 (−2.0 to 0.62) HF
Steardo, Bonuso, Di Stasio, et al., 1982 | Propranolol, 120 mg/day for 6 mos | 16/24 (67%) | 0.03 (0.004 to 0.29) ≥50% reduction in HF | 24 | - | 7.67 | −1.3 (−2.0 to 0.62) HF
Atenolol vs. propranolol
Stensrud and Sjaastad, 1980a | Atenolol, 100 mg/day for 6 wks | - | - | 28* | - | - | n.s. (no p-value reported) HI
Stensrud and Sjaastad, 1980a | Propranolol, 160 mg/day for 6 wks | - | - | 28* | - | - | n.s. (no p-value reported) HI
Timolol vs. propranolol
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Timolol, 20 mg/day for 12 wks | 44/80* (55%) | 0.81 (0.43 to 1.5) ≥50% reduction in HF | 80* | - | 5.71 | 0.15 (−0.16 to 0.46) HI
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Propranolol, 160 mg/day for 12 wks | 48/80* (60%) | 0.81 (0.43 to 1.5) ≥50% reduction in HF | 80* | - | 6.66 | 0.15 (−0.16 to 0.46) HI
Bisoprolol vs. metoprolol
Wörz, Reinhardt- Benmalek, Foeh, et al., 1992 | Bisoprolol, 5 mg/day for 3 mos | 41/78* (53%) | 1.05 (0.56 to 2.0) ≥50% reduction in HF | 78* | 4.0 | 2.05 | −0.04 (−0.35 to 0.28) HF
Wörz, Reinhardt- Benmalek, Foeh, et al., 1992 | Metoprolol, 100 mg/day for 3 mos | 40/78* (51%) | 1.05 (0.56 to 2.0) ≥50% reduction in HF | 78* | 4.0 | 1.99 | −0.04 (−0.35 to 0.28) HF
COMPARISONS WITH CALCIUM ANTAGONISTS
Propranolol vs. flunarizine
Gawel, Kreeft, Nelson, et al., 1992 | Propranolol, 160 mg/day (max) for 4 mos | - | - | 45 | - | −0.20 (difference from baseline) | 0.064 (−0.35 to 0.48) HS
Gawel, Kreeft, Nelson, et al., 1992 | Flunarizine, 10 mg/day for 4 mos | - | - | 44 | - | −0.02 (difference from baseline) | 0.064 (−0.35 to 0.48) HS
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Propranolol, 120 mg/day for 4 mos | - | - | 170 | 6 | 4 | 0 (−0.21 to 0.21) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Flunarizine, 10 mg/day for 4 mos | - | - | 166 | 6 | 4 | 0 (−0.21 to 0.21) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Propranolol, 120 mg/day for 4 mos | - | - | 34 | 5 | 3 | −0.13 (−0.60 to 0.34) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Flunarizine, 10 mg/day for 4 mos | - | - | 35 | 6 | 4 | −0.13 (−0.60 to 0.34) HF
Ludin, 1989 | Propranolol, 120 mg/day for 4 mos | - | - | 32 | 121.4 | 66.9 | 0.16 (−0.68 to 1.0) HI
Ludin, 1989 | Flunarizine, 10 mg/day for 4 mos | - | - | 27 | 92.9 | 93.0 | 0.16 (−0.68 to 1.0) HI
Shimell, Fritz, and Levien, 1990 | Propranolol, 180 mg/day for 4 mos | - | - | 29 | 5.71 | 1.17 | n.s. (no p-value reported) HF
Shimell, Fritz, and Levien, 1990 | Flunarizine, 10 mg/day for 4 mos | - | - | 28 | 4.57 | 1.35 | n.s. (no p-value reported) HF
Propranolol vs. nifedipine
Albers, Simon, Hamik, et al., 1989 | Propranolol, 120–180 mg/day for 6 mos | - | - | 12 | 6.1 | 2.2 | 0.68 (−0.27 to 1.64) HF
Albers, Simon, Hamik, et al., 1989 | Nifedipine, 60–90 mg/day for 6 mos | - | - | 7 | 3.6 | 1.5 | 0.68 (−0.27 to 1.64) HF
Gerber, Diener, Scholz, et al., 1991 | Propranolol, 40–160 mg/day (see ET 1) for 6 mos | - | - | 19? | - | - | p>0.05 (n.s.) HF
Gerber, Diener, Scholz, et al., 1991 | Nifedipine, 10–40 mg/day (see ET 1) for 6 mos | - | - | 17? | - | - | p>0.05 (n.s.) HF
Propranolol vs. cyclandelate
Gerber, Schellenberg, Thom, et al., 1995 | Propranolol, 120–160 mg/day (see ET 1) for 4 mos | 18/34 (53%) | 0.45 (0.16 to 1.3) ≥50% reduction in HF | 34 | 5.7 | 3.1 | n.s. (no p-value reported) HF
Gerber, Schellenberg, Thom, et al., 1995 | Cyclandelate, 1200–1600 mg/day (see ET 1) for 4 mos | 20/28 (71%) | 0.45 (0.16 to 1.3) ≥50% reduction in HF | 28 | 6.3 | 2.7 | n.s. (no p-value reported) HF
Propranolol vs. nimodipine
Formisano, Falaschi, Cerbo, et al., 1991 | Propranolol, 120 mg/day for 4 mos | - | - | 8 | 5.0 | 2.6 | 0.13 (−0.78 to 1.0) HF
Formisano, Falaschi, Cerbo, et al., 1991 | Nimodipine, 120 mg/day for 4 mos | - | - | 11 | 4.0 | 2.9 | 0.13 (−0.78 to 1.0) HF
Propranolol vs. verapamil
Solomon, 1986 | Propranolol (long-acting), 120 mg/day for 2 mos | - | - | 15* | - | 4.5 | n.s. (no p-value reported) HF
Solomon, 1986 | Verapamil, 240 mg/day for 2 mos | - | - | 15* | - | 5.0 | n.s. (no p-value reported) HF
Metoprolol vs. flunarizine
Grotemeyer, Schlake, Husstedt, et al., 1987 | Metoprolol, 200 mg/day for 3 mos | 12/24* (50%) | 2.4 (0.74 to 8.0) ≥50% reduction in HF | - | - | - | -
Grotemeyer, Schlake, Husstedt, et al., 1987 | Flunarizine, 10 mg/day for 3 mos | 7/24* (29%) | 2.4 (0.74 to 8.0) ≥50% reduction in HF | - | - | - | -
Sørensen, Larsen, Rasmussen, et al., 1991 | Metoprolol, 200 mg/day for 5 mos | - | - | 69 | - | −1.5 (change from baseline) | −0.22 (−0.57 to 0.13) HF
Sørensen, Larsen, Rasmussen, et al., 1991 | Flunarizine, 10 mg/day for 5 mos | - | - | 58 | - | −2.2 (change from baseline) | −0.22 (−0.57 to 0.13) HF
Metoprolol vs. nifedipine
Gerber, Diener, Scholz, et al., 1991 | Metoprolol, 50–200 mg/day (see ET 1) for 6 mos | - | - | 22? | - | - | p<0.05 (metoprolol better) HF
Gerber, Diener, Scholz, et al., 1991 | Nifedipine, 10–40 mg/day (see ET 1) for 6 mos | - | - | 17? | - | - | p<0.05 (metoprolol better) HF
COMPARISONS WITH ANTIDEPRESSANTS
Propranolol vs. amitriptyline
Mathew, 1981 (Migraine-only) | Propranolol, 60–160 mg/day for 6 mos | - | - | 38 | 4.12 | 1.57 | 0.15 (−0.32 to 0.62) HI
Mathew, 1981 (Migraine-only) | Amitriptyline, 25–75 mg/day for 6 mos | - | - | 32 | 3.93 | 2.28 | 0.15 (−0.32 to 0.62) HI
Mathew, 1981 (Mixed HA) | Propranolol, 60–160 mg/day for 6 mos | - | - | 38 | 6.70 | 3.24 | −0.0016 (−0.49 to 0.46) HI
Mathew, 1981 (Mixed HA) | Amitriptyline, 25–75 mg/day for 6 mos | - | - | 31 | 7.78 | 3.12 | −0.0016 (−0.49 to 0.46) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Propranolol, 80–240 mg/day for 2 mos | 10/30* (33%) | 0.75 (0.26 to 2.2) ≥50% reduction in HI compared to placebo | 30* | - | 404.6 | p>0.05 (n.s.) HI
Ziegler, Hurwitz, Hassanein, et al., 1987 | Amitriptyline, 50–150 mg/day for 2 mos | 12/30* (40%) | 0.75 (0.26 to 2.2) ≥50% reduction in HI compared to placebo | 30* | - | 429.4 | p>0.05 (n.s.) HI
Propranolol vs. femoxetine
Andersson and Petersen, 1981 | Propranolol, 80–160 mg/day for 3 mos | 10/28* (36%) | 2.0 (0.62 to 6.7) >50% reduction in HI | 28* | 24.5 | 16.0 | 0.17 (−0.35 to 0.70) HI
Andersson and Petersen, 1981 | Femoxetine, 200–400 mg/day for 3 mos | 6/28* (21%) | 2.0 (0.62 to 6.7) >50% reduction in HI | 28* | 24.5 | 17.9 | 0.17 (−0.35 to 0.70) HI
Kangasniemi, Nyrke, Lang, et al., 1983 | Propranolol, 80–160 mg/day for 3 mos | - | - | 24* | 10.30 | 7.07 | 0.34 (−0.23 to 0.91) HI
Kangasniemi, Nyrke, Lang, et al., 1983 | Femoxetine, 200–400 mg/day for 3 mos | - | - | 24* | 10.30 | 9.68 | 0.34 (−0.23 to 0.91) HI
Metoprolol vs. clomipramine
Langohr, Gerber, Koletzki, et al., 1985 | Metoprolol, 100 mg/day (max) for 1 mo | 9/21* (44%) | 2.2 (0.59 to 8.5) >50% reduction in HF | 21* | - | - | p<0.05 (metoprolol better) HF
Langohr, Gerber, Koletzki, et al., 1985 | Clomipramine, 100 mg/day (max) for 1 mo | 5/20* (24%) | 2.2 (0.59 to 8.5) >50% reduction in HF | 20* | - | - | p<0.05 (metoprolol better) HF
COMPARISONS WITH NSAIDs
Metoprolol vs. aspirin
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Metoprolol, 200 mg/day for 3 mos | 14/21* (67%) | 12 (2.6 to 54) > 50% reduction in HF | 21* | 2.0 | 1.6 | −0.33 (−0.94 to 0.28) HS
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Aspirin, 1500 mg/day | 3/21* (14%) | 12 (2.6 to 54) > 50% reduction in HF | 21* | 2.0 | 104 | −0.33 (−0.94 to 0.28) HS
Propranolol vs. tolfenamic acid
Kjærsgård- Rasmussen, Holt- Larsen, Borg, et al., 1994 | Propranolol, 120 mg/day for 3 mos | - | - | 29 | - | −6.9 (difference from baseline) | 0.24 (−0.76 to 0.29) HI
Kjærsgård- Rasmussen, Holt- Larsen, Borg, et al., 1994 | Tolfenamic acid, 300 mg/day for 3 mos | - | - | 27 | - | −15.7 (difference from baseline) | 0.24 (−0.76 to 0.29) HI
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Propranolol, 120 mg/day for 3 mos | - | - | 31* | - | - | 0.05 (−0.30 to 0040) HF
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Tolfenamic acid, 300 mg/day for 3 mos | - | - | 31* | - | - | 0.05 (−0.30 to 0040) HF
Propranolol vs. aspirin
Baldrati, Cortelli, Procaccianti, et al., 1983 | Propranolol, approx. 120 mg/day (avg) for 3 mos | 9/12* (75%) | 1.0 (0.16 to 6.3) > 50% reduction in HI | 12* | - | - | 0.01 (−0.55 to 0.58) HI
Baldrati, Cortelli, Procaccianti, et al., 1983 | Aspirin, approx. 975 mg/day (avg) for 3 mos | 9/12* (75%) | 1.0 (0.16 to 6.3) > 50% reduction in HI | 12* | - | - | 0.01 (−0.55 to 0.58) HI
Propranolol vs. mefenamic acid
Johnson, Hornabrook, and Lambie, 1986 | Propranolol,240 mg/day for 3 mos | - | - | 17* | - | 13.8 | −0.06 (−0.74 to 0.61) HF
Johnson, Hornabrook, and Lambie, 1986 | Mefenamic acid, 1500 mg/day for 3 mos | - | - | 17* | - | 12.9 | −0.06 (−0.74 to 0.61) HF
Propranolol vs. naproxen sodium
Sargent, Solbach, Damasio, et al., 1985 | Propranolol, 120 mg/day for 3 mos | - | - | 44 | - | 0.21 (difference from baseline) | 0.37 (−0.05 to 0.80) HF
Sargent, Solbach, Damasio, et al., 1985 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 42 | - | −0.48 (difference from baseline) | 0.37 (−0.05 to 0.80) HF
COMPARISONS WITH ANTICONVULSANTS
Propranolol vs. divalproex sodium
Klapper, 1994 | Propranolol, 140 mg/day (avg) for 2 mos | - | - | 12* | - | 20.4 | - HF
Klapper, 1994 | Divalproex sodium, 1100 mg/day (avg) for 2 mos | - | - | 12* | - | 10.9 | - HF
Prindolol vs. carbamazepine
Anthony, Lance, and Somerville, 1972 | Prindolol, 10 mg/day for 1 mo | 21/33 (64%) | 3.5 (1.2 to 9.9) ≥ 50% reduction in HF | - | - | - | -
Anthony, Lance, and Somerville, 1972 | Carbamazepine, 600 mg/day for 1 mo | 10/30 (33%) | 3.5 (1.2 to 9.9) ≥ 50% reduction in HF | - | - | - | -
COMPARISONS WITH METHYSERGIDE
Propranolol vs. methysergide
Behan and Reid, 1980 | Propranolol, 120 mg/day for 3 mos | 19/36* (53%) | 1.7 (0.68 to 4.3) ≥ 50% reduction in HF | - | - | - | -
Behan and Reid, 1980 | Methysergide, 3 mg/day for 3 mos | 15/38* (39%) | 1.7 (0.68 to 4.3) ≥ 50% reduction in HF | - | - | - | -
Steardo, Bonuso, Di Stasio, et al., 1982 | Propranolol, 120 mg/day for 6 mos | 16/24 (67%) | 1.6 (0.49 to 5.0) ≥ 50% reduction in HF | 24 | - | 7.67 | 0.51 (−0.06 to 1.1) HF
Steardo, Bonuso, Di Stasio, et al., 1982 | Methysergide, 6–10 mg/day for 6 mos | 14/25 (56%) | 1.6 (0.49 to 5.0) ≥ 50% reduction in HF | 25 | - | 10.92 | 0.51 (−0.06 to 1.1) HF
Metoprolol vs. methysergide
Steardo, Bonuso, Di Stasio, et al., 1982 | Metoprolol, 300 mg/day for 6 mos | 1/16 (6%) | 0.05 (0.01 to 0.45) ≥ 50% reduction in HF | 16 | - | 16.13 | −0.81 (−1.5 to −0.16) HF
Steardo, Bonuso, Di Stasio, et al., 1982 | Methysergide, 6–10 mg/day for 6 mos | 14/25 (56%) | 0.05 (0.01 to 0.45) ≥ 50% reduction in HF | 25 | - | 10.92 | −0.81 (−1.5 to −0.16) HF
COMPARISONS WITH ALPHA 2 AGONISTS
Metoprolol vs. clonidine
Louis, Schoenen, and Hedman, 1985a | Metoprolol, 100 mg/day for 8 wks | 10/27* (37%) | 1.5 (0.50 to 4.8) >50% reduction in HF | 31* | 11.2 (median) | 8.4 (median) | p<0.05 (metoprolol better) HI
Louis, Schoenen, and Hedman, 1985a | Clonidine, 100 μg/day for 8 wks | 8/29* (28%) | 1.5 (0.50 to 4.8) >50% reduction in HF | 31* | 11.2 (median) | 10.2 (median) | p<0.05 (metoprolol better) HI
Practolol vs. clonidine
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 2) | Practolol, 150 mg/day for 8 wks | - | - | 50* | 4.0 | 2.49 | −0.21 (−0.60 to 0.19) HF
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 (Study 2) | Clonidine 150 μg/day for 8 wks | - | - | 50* | 4.0 | 1.88 | −0.21 (−0.60 to 0.19) HF
Prindolol vs. clonidine
Anthony, Lance, and Somerville, 1972 | Prindolol, 10 mg/day for 1 mo | 21/33 (64%) | 1.5 (0.56 to 4.2) ≥ 50% reduction in HF | - | - | - | -
Anthony, Lance, and Somerville, 1972 | Clonidine, 225 μg/day for 1 mo | 16/30 (53%) | 1.5 (0.56 to 4.2) ≥ 50% reduction in HF | - | - | - | -
Propranolol vs. clonidine
Kåss and Nestvold, 1980 | Propranolol (Inderal®), 160 mg/day for 4 mos | 13/21* (62%) | 2.6 (0.76 to 9.2) >50% reduction in HF | 21* | - | - | n.s. (no p-value reported) HF
Kåss and Nestvold, 1980 | Clonidine (Catapresan®), 100 mg/day for 4 mos | 8/21* (38%) | 2.6 (0.76 to 9.2) >50% reduction in HF | 21* | - | - | n.s. (no p-value reported) HF
COMPARISONS WITH SEROTONIN ANTAGONISTS
Metoprolol vs. pizotifen
Vilming, Standnes, and Hedman, 1985 | Metoprolol, 100 mg/day for 8 wks | 10/34* (29%) | 0.57 (0.21 to 1.6) ≥ 50% reduction in HI | 30* | 13.0 (median) | 8.6 (median) | n.s. (p>0.05) HI
Vilming, Standnes, and Hedman, 1985 | Pizotifen, 0.5 mg/day, gradually increased to 1.5 mg/day for 8 wks | 14/33* (42%) | 0.57 (0.21 to 1.6) ≥ 50% reduction in HI | 30* | 13.0 (median) | 7.1 (median) | n.s. (p>0.05) HI

1 Key to abbreviations: avg = average; d.f. = degrees of freedom; ET = Evidence Table; HA = headache; HF = headache frequency; HI = headache index; HS = headache severity; LA = long-acting; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not (statistically) significant; N/S = not specified; wk = week; μg = microgram

2 An asterisk denotes a crossover trial.

† Effect size calculations are based on the assumption that the data reported in the article (unlabeled) represent mean ± standard error of the mean. Under the assumption that the reported figures are standard deviations, the resulting effect size of 2.75 (95% CI: 2.1 to 3.4) makes this study an outlier.

‡ Effect size calculations are based upon the assumption that the data reported as standard deviations actually represent mean ± standard error of the mean. Under the assumption that the reported figures are standard deviations, the resulting effect size of 1.9 (1.2 to 2.55) makes this study an outlier.

Evidence Table 6 Efficacy of Calcium Anfagonisfs^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO (AND DOSING STUDIES)
Flunarizine
Al Deeb, Biary, Bahou, et al., 1992 | Flunarizine, 10 mg/day for 3 mos | 6/21 (29%) | 1.3 (0.32 to 5.1) ≥ 50% reduction in HS | 21 | 13.75 | 9.9 | 0.24 (−0.37 to 0.84) HF
Al Deeb, Biary, Bahou, et al., 1992 | Placebo | 5/21 (24%) | 1.3 (0.32 to 5.1) ≥ 50% reduction in HS | 21 | 9.83 | 7.86 | 0.24 (−0.37 to 0.84) HF
Diamond and Freitag, 1993 | Flunarizine, 10 mg/day for 5 mos | 20/50 (40%) | 1.3 (0.59 to 3.0) ≥ 50% reduction in HF or HS | 50 | - | −2.083 (change from baseline) | 0.37 (−0.02 to 0.77) HI
Diamond and Freitag, 1993 | Placebo | 17/51 (33%) | 1.3 (0.59 to 3.0) ≥ 50% reduction in HF or HS | 51 | - | −0.640 (change from baseline) | 0.37 (−0.02 to 0.77) HI
Frenken and Nuijten, 1984 | Flunarizine, 10 mg/day for 3 mos | - | - | 17 | 3.3 | 0.8 | n.s. (p=0.029) HF
Frenken and Nuijten, 1984 | Placebo | - | | 18 | 3.8 | 2.6 | n.s. (p=0.029) HF
Louis, 1981 | Flunarizine, 10 mg/day for 3 mos | - | - | 29 | - | - | 1.2 (0.69 to 1.7) HF
Louis, 1981 | Placebo | - | - | 29 | - | - | 1.2 (0.69 to 1.7) HF
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Flunarizine, 10 mg/day for 3 mos | | - | 9 | 34.7 | 6.2 | 0.99 (0.05 to 1.92) HI
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Placebo | - | - | 11 | 37.0 | 61.6 | 0.99 (0.05 to 1.92) HI
Pini, Ferrari, Guidetti, et al., 1985 | Flunarizine, 20 mg/day for 2 wks; then 10 mg/day for "up to 120 days" | - | - | 14 | 0.54 | 0.31 | 0.02 (−0.72 to 0.76) HI
Pini, Ferrari, Guidetti, et al., 1985 | Placebo | - | - | 14 | 0.33 | 0.30 | 0.02 (−0.72 to 0.76) HI
Sørensen, Hansen, and Olesen, 1986 | Flunarizine, 10 mg/day for 5 mos | - | - | 29* | - | - | 0.26 (−0.11 to 0.63) HI
Sørensen, Hansen, and Olesen, 1986 | Placebo | - | - | 29* | | | 0.26 (−0.11 to 0.63) HI
Thomas, Behari, and Ahuja, 1991 | Flunarizine, 10 mg/day for 3 mos | 12/15* (80%) | 6.0 (1.2 to 30) ≥ 50% reduction in HI | 15* | 8.10 | 2.84 | 0.87 (0.12 to 1.61) HI
Thomas, Behari, and Ahuja, 1991 | Placebo | 6/15* (40%) | 6.0 (1.2 to 30) ≥ 50% reduction in HI | 15* | 8.10 | 6.30 | 0.87 (0.12 to 1.61) HI
Bassi, Brunati, Rapuzzi, et al., 1992 | Flunarizine, 10 mg/day for 4 mos | - | - | 14 | | | n.s. (no p-value reported) HI
Bassi, Brunati, Rapuzzi, et al., 1992 | Flunarizine, 10 mg/day for 1 wk, then 3 mg/day for 4 mos | - | - | 15 | - | - | n.s. (no p-value reported) HI
Nimodipine
Ansell, Fazzone, Festenstein, et al., 1983 | Nimodipine, 120 mg/day for 4 mos | - | - | 30 | - | - | n.s. (no p-value reported) HI
Ansell, Fazzone, Festenstein, et al., 1983 | Placebo | - | - | 27 | - | - | n.s. (no p-value reported) HI
Gelmers, 1983 | Nimodipine, 120 mg/day for 3 mos | - | - | 28 | 56 | 19 | 0.78 (0.20 to 1.4) HI
Gelmers, 1983 | Placebo | - | - | 22 | 72 | 53 | 0.78 (0.20 to 1.4) HI
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Nimodipine, 120 mg/day for 2 mos | - | - | 29* | - | 10.3 | 0.85 (0.31 to 1.4) HI
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Placebo | - | - | 29* | - | 13.7 | 0.85 (0.31 to 1.4) HI
Migraine-Nimodipine European Study Group (MINES), 1989a | Nimodipine, 120 mg/day for 3 mos | - | - | 43 | 7.7 | 2.1 | n.s. (no p-value reported) HI
Migraine-Nimodipine European Study Group (MINES), 1989a | Placebo | - | - | 46 | 8.1 | 0.9 | n.s. (no p-value reported) HI
Migraine-Nimodipine European Study Group (MINES), 1989b | Nimodipine, 120 mg/day for 3 mos | - | - | 94 | 9.27 | 4.19 | p=0.91 (n.s.) HI
Migraine-Nimodipine European Study Group (MINES), 1989b | Placebo | - | - | 98 | 8.78 | 3.87 | p=0.91 (n.s.) HI
Meyer and Hardenberg, 1983 | Nimodipine, 120 mg/day for 2 mos | - | - | 27* | - | - | n.s. (no p-value reported) HF
Meyer and Hardenberg, 1983 | Nimodipine, 60 mg/day for 2 mos | - | - | 27* | - | - | n.s. (no p-value reported) HF
Verapamil
Markley, Cheronis, and Piepho, 1984 | Verapamil, 240 mg/day for 2 mos | - | - | 14* | - | 72.6 | 1.14 (0.34 to 1.94) HI
Markley, Cheronis, and Piepho, 1984 | Placebo | - | - | 14* | - | 116.4 | 1.14 (0.34 to 1.94) HI
Solomon, Steel, and Spaccavento, 1983 | Verapamil, 320 mg/day for 3 mos | - | - | 12* | - | 0.44 | 0.38 (−0.43 to 1.18) HI
Solomon, Steel, and Spaccavento, 1983 | Placebo | - | - | 12* | - | 0.61 | 0.38 (−0.43 to 1.18) HI
Solomon, 1986 | Verapamil, 240 mg/day for 2 mos | - | - | 15* | - | 5.0 | n.s. (p>0.05) HF
Solomon, 1986 | Placebo | - | - | 15* | - | 6.0 | n.s. (p>0.05) HF
Nifedipine
McArthur, Marek, Pestronk, et al., 1989 | Nifedipine, 60–90 mg/day for 3 mos | - | - | 14* | - | 1.9 | 0.12 (−0.62 to 0.86) HF
McArthur, Marek, Pestronk, et al., 1989 | Placebo | - | - | 14* | - | 2.1 | 0.12 (−0.62 to 0.86) HF
Shukla, Garg, Nag, et al., 1995 | Nifedipine, 15 mg/day for 2 mos | - | - | 28* | 808.6 | 616.4 | 0.17 (−0.35 to 0.70) HI
Shukla, Garg, Nag, et al., 1995 | Placebo | - | - | 28* | 808.6 | 750.6 | 0.17 (−0.35 to 0.70) HI
Nicardipine
Leandri, Rigardo, Schizzi, et al., 1990 | Nicardipine, 40 mg/day for 2 mos | - | - | 30* | 12.61 | 2.35 | 0.47 (−0.05 to 0.98) HI
Leandri, Rigardo, Schizzi, et al., 1990 | Placebo | - | - | 30* | 12.61 | 8.09 | 0.47 (−0.05 to 0.98) HI
COMPARISONS AMONG CALCIUM ANTAGONISTS
Nimodipine vs. flunarizine
Bussone, Baldini, D'Andrea, et al., 1987 | Nimodipine, 120 mg/day for 3 mos | 61/4 (43%) | 1.3 (0.29 to 5.4) ≥50% reduction in HI | 12 | 258.4 | 116.9 | 0.22 (−0.56 to 1.01) HI
Bussone, Baldini, D'Andrea, et al., 1987 | Flunarizine, 10 mg/day for 3 mos | 6/16 (38%) | 1.3 (0.29 to 5.4) ≥50% reduction in HI | 13 | 286.6 | 200.4 | 0.22 (−0.56 to 1.01) HI
Nifedipine vs. flunarizine
Lamsudin and Sadjimin, 1993 | Nifedipine, 20 mg/day for 3 mos | - | - | 38 | 26.28 | 9.07 | −0.082 (−0.66 to 0.50) HI
Lamsudin and Sadjimin, 1993 | Flunarizine, 10 mg/day for 3 mos | - | - | 40 | 26.41 | 6.69 | −0.082 (−0.66 to 0.50) HI
Cyclandelate VS. flunarizine
Nappi, Sandrini, Savoini, et al., 1987 | Cyclandelate, 1600 mg/day for 3 mos | - | - | 19 | - | - | p<0.02 (flunarizine better) HI
Nappi, Sandrini, Savoini, et al., 1987 | Flunarizine, 5 mg/day for 3 mos | - | - | 18 | - | - | p<0.02 (flunarizine better) HI
COMPARISONS WITH BETA-BLOCKERS
Flunarizine vs. propranolol
Gawel, Kreeft, Nelson, et al., 1992 | Flunarizine, 10 mg/day for 4 mos | - | - | 44 | - | −0.02 (difference from baseline) | −0.064 (−0.48 to 0.35) HS
Gawel, Kreeft, Nelson, et al., 1992 | Propranolol, 160 mg/day (max) for 4 mos | - | - | 45 | - | −0.20 (difference from baseline) | −0.064 (−0.48 to 0.35) HS
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Flunarizine, 10 mg/day for 4 mos | - | - | 166 | 6 | 4 | 0 (−0.21 to 0.21) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Propranolol, 120 mg/day for 4 mos | - | - | 170 | 6 | 4 | 0 (−0.21 to 0.21) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Flunarizine, 10 mg/day for 4 mos | - | - | 35 | 6 | 4 | 0.13 (−0.34 to 0.60) HF
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Propranolol, 120 mg/day for 4 mos | - | - | 34 | 5 | 3 | 0.13 (−0.34 to 0.60) HF
Ludin, 1989 | Flunarizine, 10 mg/day for 4 mos | - | - | 27 | 92.9 | 93.0 | −0.16 (−1.0 to 0.68) HI
Ludin, 1989 | Propranolol, 120 mg/day for 4 mos | - | - | 32 | 121.4 | 66.9 | −0.16 (−1.0 to 0.68) HI
Shimell, Fritz, and Levien, 1990 | Flunarizine, 10 mg/day for 4 mos | - | - | 28 | 4.57 | 1.35 | n.s. (no p-value reported) HF
Shimell, Fritz, and Levien, 1990 | Propranolol, 180 mg/day for 4 mos | - | - | 29 | 5.71 | 1.17 | n.s. (no p-value reported) HF
Flunarizine vs. metoprolol
Grotemeyer, Schlake, Husstedt, et al., 1987 | Flunarizine, 10 mg/day for 3 mos | 7/24* (29%) | 0.41 (0.13 to 1.4) ≥50% reduction in HF | - | - | - | -
Grotemeyer, Schlake, Husstedt, et al., 1987 | Metoprolol, 200 mg/day for 3 mos | 12/24* (50%) | 0.41 (0.13 to 1.4) ≥50% reduction in HF | - | - | - | -
Sørensen, Larsen, Rasmussen, et al., 1991 | Flunarizine, 10 mg/day for 5 mos | - | - | 58 | - | −2.2 (change from baseline) | 0.22 (−0.13 to 0.57) HF
Sørensen, Larsen, Rasmussen, et al., 1991 | Metoprolol, 200 mg/day for 5 mos | - | - | 69 | - | −1.5 (change from baseline) | 0.22 (−0.13 to 0.57) HF
Nifedipine vs. propranolol
Albers, Simon, Hamik, et al., 1989 | Nifedipine, 60–90 mg/day for 6 mos | - | - | 7 | 3.6 | 1.5 | −0.68 (−1.64 to 0.27) HF
Albers, Simon, Hamik, et al., 1989 | Propranolol, 120–180 mg/day for 6 mos | - | - | 12 | 6.1 | 2.2 | −0.68 (−1.64 to 0.27) HF
Gerber, Diener, Scholz, et al., 1991 | Nifedipine, 10–40 mg/day for 6 mos (See ET 1) mg/day | - | - | 17? | - | - | p>0.05 (n.s.) HF
Gerber, Diener, Scholz, et al., 1991 | Propranolol, 40–160 for 6 mos (See ET 1) | - | - | 19? | - | - | p>0.05 (n.s.) HF
Nifedipine vs. metoprolol
Gerber, Diener, Scholz, et al., 1991 | Nifedipine, 10–40 mg/day for 6 mos (See ET 1) | - | - | 17? | - | - | p<0.05 (metoprolol better) HF
Gerber, Diener, Scholz, et al., 1991 | Metoprolol, 50–200 mg/day for 6 mos (See ET 1) | - | - | 22? | - | - | p<0.05 (metoprolol better) HF
Nimodipine vs. propranolol
Formisano, Falaschi, Cerbo, et al., 1991 | Nimodipine, 120 mg/day for 4 mos | - | - | 11 | 4.0 | 2.9 | −0.13 (−1.0 to 0.78) HF
Formisano, Falaschi, Cerbo, et al., 1991 | Propranolol, 120 mg/day for 4 mos | - | - | 8 | 5.0 | 2.6 | −0.13 (−1.0 to 0.78) HF
Verapamil vs. propranolol
Solomon, 1986 | Verapamil, 240 mg/day for 2 mos | - | - | 15* | - | 5.0 | n.s. (no p-value reported) HF
Solomon, 1986 | Propranolol, 120 mg/day for 2 mos | - | - | 15* | - | 4.5 | n.s. (no p-value reported) HF
Cyclandelate vs. propranolol
Gerber, Schellenberg, Thom, et al., 1995 | Cyclandelate, 1200–1600 mg/day for 2 mos (See ET 1) | 20/28 (71%) | 2.2 (0.77 to 6.4) ≥50% reduction in HF | 28 | 6.3 | 2.7 | n.s. (no p-value reported) HF
Gerber, Schellenberg, Thom, et al., 1995 | Propranolol, 120–160 mg/day for 2 mos (See ET 1) | 18/34 (53%) | 2.2 (0.77 to 6.4) ≥50% reduction in HF | 34 | 5.7 | 3.1 | n.s. (no p-value reported) HF
COMPARISONS WITH SEROTONIN ANTAGONISTS
Flunarizine vs. pizotifen
Cerbo, Casacchia, Formisano, et al., 1986 | Flunarizine, 15 mg/day for 2 mos | - | - | 21* | - | - | n.s. (no p-value reported) HI
Cerbo, Casacchia, Formisano, et al., 1986 | Pizotifen, 1.5 mg/day for 2 mos | - | - | 21* | - | - | n.s. (no p-value reported) HI
Louis and Spierings, 1982 | Flunarizine, 10 mg/day for 4 mos | - | - | 36 | - | - | n.s. (no p-value reported) HF
Louis and Spierings, 1982 | Pizotifen, 2–3 mg/day for 4 mos | - | - | 30 | - | - | n.s. (no p-value reported) HF
Rascol, Montastruc, and Rascol, 1986 | Flunarizine, 10 mg/day for 4 mos | - | - | 21 | - | - | n.s. (no p-value reported) HF
Rascol, Montastruc, and Rascol, 1986 | Pizotifen, 2.19 mg/day for 4 mos | - | - | 14 | - | - | n.s. (no p-value reported) HF
Nimodipine vs. pizotifen
Gawel, 1987 | Nimodipine, 120 mg/day for 3 mos | - | - | 25 | 7.56 | 6.04 | −0.11 (−0.64 to 0.42) HF
Gawel, 1987 | Pizotifen, 3 mg/day for 3 mos | - | - | 29 | 7.55 | 6.65 | −0.11 (−0.64 to 0.42) HF
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Nimodipine, 120 mg/day for 3 mos | - | - | 43* | 6.2 | 2.3 | 0.11 (−0.31 to 0.54) HF
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 43* | 6.2 | 2.6 | 0.11 (−0.31 to 0.54) HF
Micieli, Trucco, Agostinis, et al., 1985 | Nimodipine, 120 mg/day for 3 mos | - | - | 20* | - | - | n.s. (no p-value reported) HI
Micieli, Trucco, Agostinis, et al., 1985 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 20* | - | - | n.s. (no p-value reported) HI
Cyclandelate vs. pizotifen
Mastrosimone, laccarino, and de Caterina, 1992 | Cyclandelate, 1600 mg/day for 3 mos | - | - | 35 | - | - | p<0.001 (cyclandelate better) HI
Mastrosimone, laccarino, and de Caterina, 1992 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 26 | | | p<0.001 (cyclandelate better) HI
COMPARISONS WITH OTHER (MISCELLANEOUS) AGENTS
Flunarizine vs. dihydroergokryptine (DEK)
Agnoli, Bussone, Mailland, et al., 1991 | Flunarizine, 5 mg/day for 6 mos | 4/41 (10%) | 1.4 (0.30 to 6.7) ≥50% reduction in HF | 41 | 6.4 | - | p<0.025 (DEK better) HF
Agnoli, Bussone, Mailland, et al., 1991 | DEK, 20 mg/day for 6 mos | 3/42 (7%) | 1.4 (0.30 to 6.7) ≥50% reduction in HF | 42 | 6.4 | - | p<0.025 (DEK better) HF
Flunarizine vs. methysergide
Steardo, Marano, Barone, et al., 1986 | Flunarizine, 10 mg/day for 5 mos | - | - | 53? | - | - | n.s. (no p-value reported) HF
Steardo, Marano, Barone, et al., 1986 | Methysergide, 6 mg/day for 5 mos | - | - | 51? | - | - | n.s. (no p-value reported) HF
Flunarizine vs. etilefrine pivalate
Grotemeyer, Schlake, and Husstedt, 1989 | Flunarizine, 5 mg/day for 2 mos; then for 3 mos both treatments are compared (See ET 1) | - | - | ? | - | - | -
Grotemeyer, Schlake, and Husstedt, 1989 | Etilefrine pivalate, 20 mg/day for 3 mos, during which both treatments are compared (See ET 1) | - | - | ? | - | - | -

1 Key to abbreviations: DEK = dihydroergokryptine; ET = Evidence Table; HF = headache frequency; HI = headache index; HS = headache severity; max. = maximum; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not (statistically) significant; N/S = not specified; wk = week; μg = microgram

2 An asterisk denotes a crossover trial.

Evidence Table 7 Efficacy of Ergots^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO
Cafergot comp.® (1 cap = ergotamine 1 mg + caffeine 100 mg + butalbital 50 mg + belladonna alkaloids 0.125 mg):
Kallos and Kallos- Deffner, 1971 | Cafergot comp.®, 2 caps/day, perimenstrually, for 2 menstrual cycles (see Evidence Table 1 for details). | - | - | 20* | - | 0.35 | - HF
Kallos and Kallos- Deffner, 1971 | Placebo | - | - | 20* | - | 1.55 | - HF
Dihydroergotamine (DHE)
Autret and de Chasteigner, 1987 | DHE (timed-release), 10 mg/day for 2 mos | - | - | 58 | - | 1.98 (reduction from baseline) | 0.60 (0.23 to 0.98) HI
Autret and de Chasteigner, 1987 | Placebo | - | - | 57 | - | 0.058 (reduction from baseline) | 0.60 (0.23 to 0.98) HI
Martucci, Manna, Mattesi, et al., 1983 | DHE (timed-release), 10 mg/day for 45 days | - | - | 79* | - | - | - HI
Martucci, Manna, Mattesi, et al., 1983 | Placebo | - | - | 79* | - | - | - HI
Neuman, Demarez, Harmey, et al., 1986 | DHE (timed-release), 10 mg/day for 1 mo | - | - | 20 | 3.3 | 1.3 | 2.1 (1.3 to 2.8) HF
Neuman, Demarez, Harmey, et al., 1986 | Placebo | - | - | 20 | 3.3 | 3.0 | 2.1 (1.3 to 2.8) HF
DHE + aspirin
Bousser, Chick, Fuseau, et al., 1988 | DHE + aspirin (timed-release), 10 mg + 80 mg/day for 2 mos | - | - | 38* | - | 11.5 | 0.62 (0.16 to 1.1) HF
Bousser, Chick, Fuseau, et al., 1988 | Placebo | - | - | 38* | - | 16.6 | 0.62 (0.16 to 1.1) HF
Dihydroergokryptine (DEK)
Canonico, Scapagnini, Genazzani, et al., 1989 | DEK, 20 mg/day for 2 mos | - | - | 102* | - | - | - HI
Canonico, Scapagnini, Genazzani, et al., 1989 | Placebo | - | - | 102* | - | - | - HI
Fiorini, Sances, Martignoni, et al., 1991 | DEK, 20 mg/day for 2 menstrual cycles | - | - | 10 | - | 32.9 | 0.93 (−0.02 to 1.9) HI
Fiorini, Sances, Martignoni, et al., 1991 | Placebo | - | - | 9 | - | 60.8 | 0.93 (−0.02 to 1.9) HI
DOSING STUDIES
DHE
Buscaino, Sorge, Bussone, et al., 1991 | DHE, 10 mg/day (1 x 10 mg) for 2 mos | - | - | 45 | - | - | n.s. (no p-value reported) HI
Buscaino, Sorge, Bussone, et al., 1991 | DHE, 10 mg/day (2 x 5 mg) for 2 mos | - | - | 45 | - | - | n.s. (no p-value reported) HI
Ergotamine
Barrie, Fox, Weatherall, et al., 1968 | Ergotamine, 1 mg/day for 1 mo | - | - | 15 | - | - | -
Barrie, Fox, Weatherall, et al., 1968 | Ergotamine, 0.5 mg/day for 1 mo | - | - | 17 | - | - | -
COMPARISONS AMONG ERGOTS
DEK vs. DHE
Frediani, Grazzi, Zanotti, et al., 1991 | DEK, 20 mg/day for 4 mos | - | - | - | - | - | - HI
Frediani, Grazzi, Zanotti, et al., 1991 | DHE (timed-release), 10 mg/day for 4 mos | - | - | - | - | - | - HI
COMPARISONS WITH ANTIDEPRESSANTS
DHE vs. amitriptyline
Bonuso, Di Stasio, Barone, et al., 1983 | DHE (timed-release), 10 mg/day for 2 mos | - | - | 15 | 18.7 | 10.7 | −0.82 (−1.6 to −0.08) HS
Bonuso, Di Stasio, Barone, et al., 1983 | Amitriptyline, 75 mg/day for 2 mos | - | - | 15 | 17.0 | 5.4 | −0.82 (−1.6 to −0.08) HS
COMPARISONS WITH CALCIUM ANTAGONISTS
DEK vs. flunarizine
Agnoli, Bussone, Mailland, et al., 1991 | DEK, 20 mg/day for 6 mos | 3/42 (7%) | 0.71 (0.15 to 3.4) ≥50% reduction in HF | 42 | - | - | p=0.025 (DEK better) HF
Agnoli, Bussone, Mailland, et al., 1991 | Flunarizine, 5 mg/day for 6 mos | 4141 (10%) | 0.71 (0.15 to 3.4) ≥50% reduction in HF | 41 | - | - | p=0.025 (DEK better) HF
COMPARISONS WITH METHYSERGIDE
DEK vs. methysergide
Cangi, Boccuni, Zanotti, et al., 1989 | DEK, 20 mg/day for 2 mos | - | - | 11 | 9.8 | 6.8 | −0.22 (−1.1 to 0.61) HF
Cangi, Boccuni, Zanotti, et al., 1989 | Methysergide, 2 mg/day for 2 mos | - | - | 11 | 8.6 | 6.0 | −0.22 (−1.1 to 0.61) HF
Ergotamine vs. methysergide
Barrie, Fox, Weatherall, et al., 1968 | Ergotamine, 0.5 mg/day or 1 mg/day for 1 mo | - | - | 17 or 15 | - | - | -
Barrie, Fox, Weatherall, et al., 1968 | Methysergide, 3 mg/day or 6 mg/day for 1 mo | - | - | 16 or 11 | - | - | -

1 Key to abbreviations: cap = capsule; caps = capsules; DEK = dihydroergokryptine; DHE = dihydroergotamine; HF = headache frequency; HI = headache index; HS = headache severity; mg = milligram; mo = month; mos = months; N or n = sample size; n.s. = not (statistically) significant

2 An asterisk denotes a crossover trial.

Evidence Table 8 Efficacy of Methysergide^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO
Lance, Fine, and Curran, 1963 | Methysergide, 6 mg/day for 4 wks | 38/56 (68%) | 8.1 (3.0 to 22) ≥ 50% reduction in HF | - | - | - | -
Lance, Fine, and Curran, 1963 | Placebo | 7/34 (21%) | 8.1 (3.0 to 22) ≥ 50% reduction in HF | - | - | - | -
Pedersen and Møller, 1966 | Methysergide (prolonged-action), 6 mg/day for 6 wks | 34/60* (57%) | 3.6 (1.7 to 7.7) ≥ 50% reduction in HF | 60* | - | - | 0.22 (−0.04 to 0.47)
Pedersen and Møller, 1966 | Placebo | 16/60* (27%) | 3.6 (1.7 to 7.7) ≥ 50% reduction in HF | 60* | - | - | Mean Within-patient difference in HF
Ryan, 1968 | Methysergide, 4 mg/day for 4 wks | - | - | 62* | - | 11.3 | - HI
Ryan, 1968 | Placebo | - | - | 62* | - | 17.0 | - HI
Shekelle and Ostfeld, 1964 | Methysergide, 6 mg/day for 5 wks | - | - | 13* | - | - | 1.02 (0.48 to 1.6)
Shekelle and Ostfeld, 1964 | Placebo | - | - | 13* | - | - | Mean within-patient difference in HF
Barrie, Fox, Weatherall, et al., 1968 | Methysergide, 6 mg/day for 1 mo | - | - | - | - | - | -
Barrie, Fox, Weatherall, et al., 1968 | Methysergide, 3 mg/day for 1 mo | - | - | - | - | - | -
COMPARISONS WITH SEROTONIN ANTAGONISTS
Vs. pizotifen
Andersson, 1973 | Methysergide, 4 mg/day for 3 mos | 15/48* (31%) | 0.73 (0.31 to 1.7) > 50% reduction in HF | 48* | 5.9 | 4.1 | −0.17 (−0.57 to 0.23) HF
Andersson, 1973 | Pizotifen, 2 mg/day for 3 mos | 18/47* (38%) | 0.73 (0.31 to 1.7) > 50% reduction in HF | 47* | 5.9 | 3.5 | −0.17 (−0.57 to 0.23) HF
Forssman, Henriksson, and Kihlstrand, 1972 | Methysergide, 4–6 mg/day for 10 wks | - | - | 17* | 3.5 | 1.8 | n.s. (no p-value reported) HI
Forssman, Henriksson, and Kihlstrand, 1972 | Pizotifen, 2–3 mg/day for 10 wks | - | - | 17* | 3.5 | 2.1 | n.s. (no p-value reported) HI
Presthus, 1971 | Methysergide, 3 mg/day for 5 wks | - | - | 19* | - | - | −0.29 (−0.76 to 0.17) Mean within-patient difference in HF
Presthus, 1971 | Pizotifen, 1.5 mg/day for 5 wks | - | - | 19* | - | - | −0.29 (−0.76 to 0.17) Mean within-patient difference in HF
Ryan, 1968 | Methysergide, 4 mg/day for 4 wks | - | - | 62* | - | 11.3 | - HI
Ryan, 1968 | Pizotifen, 4 mg/day for 4 wks | - | - | 62* | - | 8.9 | - HI
Vs. Oxitriptan
Sicuteri, 1973 | Methysergide, 2 mg/day for 40 days | - | - | 20 | - | 5.9 (mean within- patient difference, pre- to post- treatment) | 0.09 (−0.53 to 0.71) HI
Sicuteri, 1973 | Oxitriptan, 200 mg/day for 40 days | - | - | 20 | - | 5.6 (mean within- patient difference, pre- to post- treatment) | 0.09 (−0.53 to 0.71) HI
Titus, Dávalos, Alom, et al., 1986 | Methysergide, 3 mg/day for 6 mos | 30/40 (75%) | 1.2 (0.47 to 3.2) ≥ 50% reduction in HF or frequency of severe HAs | - | - | - | -
Titus, Dávalos, Alom, et al., 1986 | Oxitriptan, 600 mg/day for 6 mos | 32/45 (71%) | 1.2 (0.47 to 3.2) ≥ 50% reduction in HF or frequency of severe HAs | - | - | | -
Vs. lisuride
Herrmann, Horowski, Dannehl, et al., 1977 | Methysergide, 6 mg/day for 3 mos | 27/53 (51%) | 0.93 (0.46 to 1.9) ≥ 50% reduction in HF | - | - | - | -
Herrmann, Horowski, Dannehl, et al., 1977 | Lisuride, 75 mcg/day for 3 mos | 38/72 (53%) | 0.93 (0.46 to 1.9) ≥ 50% reduction in HF | - | - | | -
COMPARISONS WITH BETA-BLOCKERS
Vs. propranolol
Behan and Reid, 1980 | Methysergide, 3 mg/day for 3 mos | 15/38* (39%) | 0.58 (0.23 to 1.5) ≥ 50% reduction in HF | - | - | - | -
Behan and Reid, 1980 | Propranolol, 120 mg/day for 3 mos | 19/36* (53%) | 0.58 (0.23 to 1.5) ≥ 50% reduction in HF | - | - | - | -
Steardo, Bonuso, Di Stasio, et al.. 1982 | Methysergide, 6–10 mg/day for 6 mos | 14/25 (56%) | 0.64 (0.20 to 2.0) ≥50% reduction in HF | 25 | - | 10.92 | −0.51 (−1.1 to 0.06) HF
Steardo, Bonuso, Di Stasio, et al.. 1982 | Propranolol, 120 mg/day for 6 mos | 16/24 (67%) | 0.64 (0.20 to 2.0) ≥50% reduction in HF | 24 | - | 7.67 | −0.51 (−1.1 to 0.06) HF
Vs. metoprolol
Steardo, Bonuso, Di Stasio, et al., 1982 | Methysergide, 6–10 mg/day for 6 mos | 14/25 (56%) | 18 (2.2 to 153) ≥ 50% reduction in HF | 25 | - | 10.92 | 0.81 (0.16 to 1.5) HF
Steardo, Bonuso, Di Stasio, et al., 1982 | Metoprolol, 300 mg/day for 6 mos | 1/16 (6%) | 18 (2.2 to 153) ≥ 50% reduction in HF | 16 | - | 16.13 | 0.81 (0.16 to 1.5) HF
COMPARISONS WITH OTHER AGENTS
Vs. flumedroxone (Demigran®)
Hudgson, Foster, and Newell, 1967 | Methysergide, 3 mg/day for 4 mos | - | - | 33* | - | 2.8 | - HF
Hudgson, Foster, and Newell, 1967 | Flumedroxone (Demigran®), 15 mg/day for 4 mos | - | - | 33* | - | 4.3 | - HF
Vs. dihydroergokryptine (DEK)
Cangi, Boccuni, Zanotti, et al., 1989 | Methysergide, 2 mg/day for 2 mos | - | - | 11 | 8.6 | 6.0 | 0.22 (−0.61 to 1.1) HF
Cangi, Boccuni, Zanotti, et al., 1989 | DEK, 20 mg/day for 2 mos | - | - | 11 | 9.8 | 6.8 | 0.22 (−0.61 to 1.1) HF
Vs. ergotamine
Barrie, Fox, Weatherall, et al., 1968 | Methysergide, 3 mg/day or 6 mg/day for 1 mo | - | - | - | - | - | -
Barrie, Fox, Weatherall, et al., 1968 | Ergotamine, 0.5 mg/day or 1 mg/day for 1 mo | - | - | - | - | - | -
Vs. flunarizine
Steardo, Marano, Barone, et al., 1986 | Methysergide, 6 mg/day for 5 mos | - | - | 51? | - | - | n.s. (no p-value reported) HF
Steardo, Marano, Barone, et al., 1986 | Flunarizine, 10 mg/day for 5 mos | - | - | 53? | - | - | n.s. (no p-value reported) HF

1 Key to abbreviations: DEK = dihydroergokryptine; HF = headache frequency; HI = headache index; mcg = microgram; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not (statistically) significant; N/S = not specified; wk = week

2 An asterisk denotes a crossover trial.

Evidence Table 9 Efficacy of NSAIDs^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO (AND DOSING STUDIES)
Naproxen or naproxen sodium
Bellavance and Meloche, 1990 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 56 | 5.32 | 2.85 | p<0.0166 (naproxen better) HI
Bellavance and Meloche, 1990 | Placebo | - | - | 52 | 5.56 | 5.08 | p<0.0166 (naproxen better) HI
Lindegaard, Ovrelid, and Sjaastad, 1980 | Naproxen, 500 mg/day for 6 wks | - | - | 15 | - | 3.4 | 0.20 (−0.54 to 0.95) HI
Lindegaard, Ovrelid, and Sjaastad, 1980 | Placebo | - | - | 13 | - | 4.0 | 0.20 (−0.54 to 0.95) HI
Sances, Martignoni, Fioroni, et al., 1990 | Naproxen sodium, 1100 mg/day for 3 mos | 6/18 (33%) | 7.7 (0.87 to 69) ≥ 50% improvement in HI | 18 | 75.1 | 49.4 | 0.35 (−0.32 to 1.0) HI
Sances, Martignoni, Fioroni, et al., 1990 | Placebo | 1/17 (6%) | 7.7 (0.87 to 69) ≥ 50% improvement in HI | 17 | 78.6 | 69.1 | 0.35 (−0.32 to 1.0) HI
Sargent. Solbach, Damasio, et al., 1985 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 42 | - | −0.48 (difference from baseline) | −0.13 (−0.55 to 0.30) HF
Sargent. Solbach, Damasio, et al., 1985 | Placebo | - | - | 43 | - | −0.25 (difference from baseline) | −0.13 (−0.55 to 0.30) HF
Szekely, Merryman, Croft, et al., 1989 | Naproxen sodium, 1100 mg/day for 2 mos | - | - | 22* | - | - | p=0.03 (naproxen better) HI
Szekely, Merryman, Croft, et al., 1989 | Placebo | - | - | 22* | - | - | p=0.03 (naproxen better) HI
Welch, Ellis, and Keenan, 1985 | Naproxen sodium, 1100 mg/day for 2 mos | - | - | 31* | - | 2.61 | 0.41 (−0.09 to 0.91) HI
Welch, Ellis, and Keenan, 1985 | Placebo | - | - | 31* | - | 3.47 | 0.41 (−0.09 to 0.91) HI
Ziegler and Ellis, 1985 | Naproxen sodium, 1100 mg/day for 2 mos | - | - | 34* | - | 2.79 | 0.40 (−0.08 to 0.88) HI
Ziegler and Ellis, 1985 | Placebo | - | - | 34* | - | 3.82 | 0.40 (−0.08 to 0.88) HI
Aspirin
O'Neill and Mann, 1978 | Aspirin, 1300 mg/day for 3 mos | - | - | 12* | - | - | 1.7 (1.1 to 2.2) HF
O'Neill and Mann, 1978 | Placebo | - | - | 12* | - | - | 1.7 (1.1 to 2.2) HF
Ryan and Ryan, 1981 | Aspirin, 1300 mg/day for 2 mos | - | - | 40 | 8.15 | 7.13 | - HF
Ryan and Ryan, 1981 | Placebo | - | - | 40 | 7.79 | 7.64
Aspirin + dipyridamole
Masel, Chesson, Peters, et al., 1980 | Aspirin + dipyridamole, 975 + 75 mg/day for 3 mos | - | - | 25* | 2.00 (median) | 1.33 (median) | p<0.01 (aspirin + dipyridamole better) HF
Masel, Chesson, Peters, et al., 1980 | Placebo | - | - | 25* | 2.00 (median) | 2.33 (median) | p<0.01 (aspirin + dipyridamole better) HF
Ryan and Ryan, 1981 | Aspirin + dipyridamole, 1300 + 75 mg/day for 2 mos | - | - | 40 | 9.15 | 7.15 | - HF
Ryan and Ryan, 1981 | Placebo | - | - | 40 | 7.79 | 7.64 | - HF
Ryan and Ryan, 1981 | Aspirin + dipyridamole, 1300 + 75 mg/day for 2 mos | - | - | 40 | 9.15 | 7.15 | - HF
Ryan and Ryan, 1981 | Aspirin, 1300 mg/day for 2 mos | - | - | 40 | 8.15 | 7.13 | - HF
Fenoprofen
Couch, Bearss, and Verhulst, 1987 | Fenoprofen, 1800 mg/day for 3 mos | - | - | 24 | 216 | 161 | n.s. (no p-value reported) HI
Couch, Bearss, and Verhulst, 1987 | Placebo | - | - | 26 | 222 | 168 | n.s. (no p-value reported) HI
Couch, Bearss, and Verhulst, 1987 | Fenoprofen, 600 mg/day for 3 mos | - | - | 23 | 140 | 95 | n.s. (no p-value reported) HI
Couch, Bearss, and Verhulst, 1987 | Placebo | - | - | 26 | 222 | 168 | n.s. (no p-value reported) HI
Couch, Bearss, and Verhulst, 1987 | Fenoprofen, 1800 mg/day for 3 mos | - | - | 24 | 216 | 161 | n.s. (no p-value reported) HI
Couch, Bearss, and Verhulst, 1987 | Fenoprofen, 600 mg/day for 3 mos | - | - | 23 | 140 | 95 | n.s. (no p-value reported) HI
Diamond, Solomon, Freitag, et al., 1987 | Fenoprofen, 1800 mg/day for 3 mos | 16/27 (59%) | 3.2 (1.1 to 9.0) > 50% reduction in HI | 27 | - | - | -
Diamond, Solomon, Freitag, et al., 1987 | Placebo | 11/35 (31%) | 3.2 (1.1 to 9.0) > 50% reduction in HI | 35 | - | - | -
Diamond, Solomon, Freitag, et al., 1987 | Fenoprofen, 600 mg/day for 3 mos | 11/34 (32%) | 1.0 (0.38 to 2.9) >50% reduction in HI | 34 | - | - | -
Diamond, Solomon, Freitag, et al., 1987 | Placebo | 11/35 (31%) | 1.0 (0.38 to 2.9) >50% reduction in HI | 35 | - | - | -
Diamond, Solomon, Freitag, et al., 1987 | Fenoprofen, 1800 mg/day for 3 mos | 16/27 (59%) | 3.0 (1.1 to 8.8) | 27 | - | - | -
Diamond, Solomon, Freitag, et al., 1987 | Fenoprofen, 600 mg/day for 3 mos | 11/34 (32%) | 3.0 (1.1 to 8.8) | 34 | - | - | -
Tolfenamic acid
Mikkelsen and Falk, 1982 | Tolfenamic acid, 300 mg/day for 10 wks | - | - | 31* | - | - | 0.38 (−0.12 to 0.88) HF
Mikkelsen and Falk, 1982 | Placebo | - | - | 31* | | | 0.38 (−0.12 to 0.88) HF
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Tolfenamic acid, 300 mg/day for 12 wks | - | - | 31* | - | - | 0.44 (0.17 to 0.79) HF
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Placebo | - | - | 31* | - | - | 0.44 (0.17 to 0.79) HF
Flurbiprofen
Solomon and Kunkel, 1993 | Flurbiprofen, 200 mg/day for 2 mos | - | - | 23* | - | 4.39 | 0.70 (−0.12 to 1.5) HF
Solomon and Kunkel, 1993 | Placebo | - | - | 23* | - | 5.73 | 0.70 (−0.12 to 1.5) HF
Indobufen
Carrieri, Orefice, and Sorge, 1988 | Indobufen, 400 mg/day for 3 mos | - | - | 18 | 10.4 | 6.1 | 0.66 (−0.02 to 1.3) HI
Carrieri, Orefice, and Sorge, 1988 | Placebo | - | - | 17 | 10.6 | 10.4 | 0.66 (−0.02 to 1.3) HI
Indomethacin
Anthony and Lance, 1968 | Indomethacin, 75 mg/day for 1 mo | 7/19 (37%) | 1.0 (0.27 to 3.7) > 50% reduction in HF or HS | - | - | - | -
Anthony and Lance, 1968 | Placebo | 7/19 (37%) | 1.0 (0.27 to 3.7) > 50% reduction in HF or HS | - | - | - | -
Ketoprofen
Stensrud and Sjaastad, 1974 | Ketoprofen, 150 mg/day for 6 wks | - | - | 24* | - | - | p<0.05 (ketoprofen better) HI
Stensrud and Sjaastad, 1974 | Placebo | - | - | 24* | - | - | p<0.05 (ketoprofen better) HI
Lornoxicam
Sternieri, Bussone, Manzoni, et al., 1991 | Lornoxicam, 12 mg/day for 2 mos | - | - | 46 | 7.8 | 5.3 | 0.52 (0.11 to 0.93) HF
Sternieri, Bussone, Manzoni, et al., 1991 | Placebo | - | - | 50 | 7.8 | 7.3 | 0.52 (0.11 to 0.93) HF
Mefenamic acid
Johnson, Hornabrook, and Lambie, 1986 | Mefenamic acid, 1500 mg/day for 3 mos | - | - | 17* | - | 12.9 | 0.52 (−0.17 to 1.2) HF
Johnson, Hornabrook, and Lambie, 1986 | Placebo | - | - | 17* | - | 20.1 | 0.52 (−0.17 to 1.2) HF
COMPARISONS WITH BETA-BLOCKERS
Aspirin vs. metoprolol
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Aspirin, 1500 mg/day for 3 mos | 3/21* (14%) | 0.084 (0.018 to 0.38) > 50% reduction in HF | 21* | 2.0 | 1.4 | 0.33 (−0.28 to 0.94) HS
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Metoprolol, 200 mg/day for 3 mos | 14/21* (67%) | 0.084 (0.018 to 0.38) > 50% reduction in HF | 21* | 2.0 | 1.6 | 0.33 (−0.28 to 0.94) HS
Aspirin vs. propranolol
Baldrati, Cortelli, Procaccianti, et al., 1983 | Aspirin, approx. 975 mg/day (avg) for 3 mos | 9/12* (75%) | 1.0 (0.16 to 6.3) > 50% reduction in HI | 12* | - | - | −0.01 (−0.58 to 0.55) HI
Baldrati, Cortelli, Procaccianti, et al., 1983 | Propranolol, approx. 120 mg/day (avg) for 3 mos | 9/12* (75%) | 1.0 (0.16 to 6.3) > 50% reduction in HI | 12* | - | - | −0.01 (−0.58 to 0.55) HI
Mefenamic acid vs. propranolol
Johnson, Hornabrook, and Lambie, 1986 | Mefenamic acid, 1500 mg/day for 3 mos | - | - | 17* | - | 12.9 | 0.06 (−0.61 to 0.74) HF
Johnson, Hornabrook, and Lambie, 1986 | Propranolol, 240 mg/day for 3 mos | - | - | 17* | - | 13.8 | 0.06 (−0.61 to 0.74) HF
Naproxen sodium vs. propranolol
Sargent, Solbach, Damasio, et al., 1985 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 42 | - | −0.48 (difference from baseline) | −0.37 (−0.80 to 0.05) HF
Sargent, Solbach, Damasio, et al., 1985 | Propranolol, 120 mg/day for 3 mos | - | - | 44 | - | 0.21 (difference from baseline) | −0.37 (−0.80 to 0.05) HF
Tolfenamic acid vs. propranolol
Kjærsgård-Rasmussen, Holt-Larsen, Borg, et al., 1994 | Tolfenamic acid, 300 mg/day for 3 mos | - | - | 27 | - | −15.7 (difference from baseline) | −0.24 (−0.76 to 0.29) HI
Kjærsgård-Rasmussen, Holt-Larsen, Borg, et al., 1994 | Propranolol, 120 mg/day for 3 mos | - | - | 29 | - | −6.9 (difference from baseline) | −0.24 (−0.76 to 0.29) HI
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Tolfenamic acid, 300 mg/day for 3 mos | - | - | 31* | - | - | −0.05 (−0.40 to 0.30) HF
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Propranolol, 120 mg/day for 3 mos | - | - | 31* | - | - | −0.05 (−0.40 to 0.30) HF
COMPARISONS WITH SEROTONIN ANTAGONISTS
Naproxen sodium vs. pizotifen
Bellavance and Meloche, 1990 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 56 | 5.32 | 2.85 | n.s. (no p-value reported) HI
Bellavance and Meloche, 1990 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 58 | 5.77 | 3.27 | n.s. (no p-value reported) HI

1 Key to abbreviations: avg = average; HF = headache frequency; HI = headache index; HS = headache severity; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not (statistically) significant; N/S = not specified; wk = week

2 An asterisk denotes a crossover trial.

Evidence Table 10 Efficacy of Other Serotoninergic Agents^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
COMPARISONS WITH PLACEBO (AND DOSING STUDIES)
Pizotifen
Arthur and Hornabrook, 1971 | Pizotifen, 3 mg/day for 1 mo | 21/52 (40%) | 5.2 (1.9 to 14.3) ≥ 50% reduction in HF | 52* | - | - | p < 0.005 (pizotifen better) HF
Arthur and Hornabrook, 1971 | Placebo | 6/52 (12%) | 5.2 (1.9 to 14.3) ≥ 50% reduction in HF | 52* | - | - | p < 0.005 (pizotifen better) HF
Bellavance and Meloche, 1990 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 58 | 5.77 | 3.27 | n.s. (no p-value reported) HI
Bellavance and Meloche, 1990 | Placebo | - | - | 52 | 5.56 | 5.08 | n.s. (no p-value reported) HI
Carroll and Maclay, 1975 | Pizotifen, 1.5 to 3 mg/day for 2 mos | - | - | 14* | - | - | -
Carroll and Maclay, 1975 | Placebo | - | - | 14* | - | - | -
Hughes and Foster, 1971 | Pizotifen, 3 mg/day for 6 wks | - | - | 26* | 18.1 | 18.5 | n.s. (no p-value reported) HF
Hughes and Foster, 1971 | Placebo (lactose) | - | - | 26* | 18.1 | 20.3 | n.s. (no p-value reported) HF
Krakowski and Engisch, 1973 | Pizotifen, 6 mg/day for 12 wks | - | - | 13 | 31.8 | 16.8 | 0.90 (0.01 to 1.8) HI
Krakowski and Engisch, 1973 | Placebo | - | - | 9 | 36.2 | 32.8 | 0.90 (0.01 to 1.8) HI
Lance and Anthony, 1968 | Pizotifen, 3 mg/day for 1 mo | 12/25 (48%) | 1.6 (0.53 to 5.1) ≥ 50% reduction in either HF or HA intensity | 25 | - | - | n.s. (p = 0.4) HF or HA intensity
Lance and Anthony, 1968 | Placebo | 9/25 (36%) | 1.6 (0.53 to 5.1) ≥ 50% reduction in either HF or HA intensity | 25 | - | - | n.s. (p = 0.4) HF or HA intensity
Lawrence, Hossain, and Littlestone, 1977 | Pizotifen, 3 mg/day for 10 wks | - | - | 14 | - | 8.6 | 0.62 (−0.14 to 1.4) HI
Lawrence, Hossain, and Littlestone, 1977 | Placebo | - | - | 14 | - | 14.9 | 0.62 (−0.14 to 1.4) HI
Osterman, 1977 | Pizotifen, 3 mg/day for 8 wks | 12/27 (44%) | - | 27* | - | 1.6 | 0.95 (0.38 to 1.5) HI
Osterman, 1977 | Placebo | - | - | 27* | - | 2.4 | 0.95 (0.38 to 1.5) HI
Ryan, 1968 | Pizotifen, 4 mg/day | - | - | 62* | - | 8.9 | - HI
Ryan, 1968 | Placebo | - | - | 62* | - | 17.0 | - HI
Ryan, 1971 | Pizotifen, dose increased from 0.5 mg/day to 3 mg/day for 2 wks; after 2 wks, and at 4-wk intervals, dosage adjusted according to a protocol for 10 wks | - | - | 25 | 21.53 | 15.68 | - HI
Ryan, 1971 | Placebo | - | - | 20 | 10.00 | 6.65 | - HI
Sjaastad and Stensrud, 1969 | Pizotifen, 4 mg/day for 8 wks | 9/20 (45%) | - | 20* | - | 5.6 | 1.1 (0.36 to 1.7) HF
Sjaastad and Stensrud, 1969 | Placebo | - | - | 20* | - | 9.9 | 1.1 (0.36 to 1.7) HF
Tropisetron
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Tropisetron, 50 mg/day for 3 mos | 13/45 (29%) | 0.60 (0.25 to 1.4) ≥ 50% reduction in either HF or HI | 45 | - | - | n.s. (p > 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Placebo | 19/47 (40%) | 0.60 (0.25 to 1.4) ≥ 50% reduction in either HF or HI | 47 | - | - | n.s. (p > 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Tropisetron, 25 mg/day for 3 mos | 16/43 (37%) | 0.87 (0.37 to 2.0) ≥ 50% reduction in either HF or HI | 43 | - | - | n.s. (p > 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Placebo | 19/47 (40%) | 0.87 (0.37 to 2.0) ≥ 50% reduction in either HF or HI | 47 | - | - | n.s. (p > 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Tropisetron, 15 mg/day for 3 mos | 17/30 (57%) | 2.4 (0.70 to 8.2) ≥ 50% reduction in either HF or HI | 30 | - | - | n.s. (p> 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Placebo | 6/17 (35%) | 2.4 (0.70 to 8.2) ≥ 50% reduction in either HF or HI | 17 | - | - | n.s. (p> 0.05) HF
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Tropisetron, 50 mg/day for 3 mos | 13/45 (29%) | 0.69 (0.28 to 1.7) ≥ 50% reduction in either HF or HI | 45 | - | - | -
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Tropisetron, 25 mg/day for 3 mos | 16/43 (37%) | 0.69 (0.28 to 1.7) ≥ 50% reduction in either HF or HI | 43 | - | - | -
Lisuride
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Lisuride, 0.075 mg/day for 6 mos | - | - | 103 | - | - | p = 0.05 (lisuride better) HF
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Placebo | - | - | 111 | - | - | p = 0.05 (lisuride better) HF
Sances, Martignoni, Rosettino, et al., 1989 | Lisuride, 0.15 mg/day for 3 mos | - | - | 20 | 81.7 | 47.3 | 0.76 (0.12 to 1.4) HI
Sances, Martignoni, Rosettino, et al., 1989 | Placebo | - | - | 20 | 102 | 95.8 | 0.76 (0.12 to 1.4) HI
Somerville and Herrmann, 1978 | Lisuride, 0.075 mg/day for 3 mos | - | - | 58 | - | - | p < 0.05 (lisuride better) HF
Somerville and Herrmann, 1978 | Placebo | - | - | 52 | - | - | p < 0.05 (lisuride better) HF
Zuddas, Mulas, Del Zompo, et al., 1985 | Lisuride, 0.075 mg/day for 3 mos | - | - | 15 | - | - | -
Zuddas, Mulas, Del Zompo, et al., 1985 | Placebo | - | - | 15 | - | - | -
Wilkinson, Agnoli, Gerber, et al., 1989 | Lisuride, 0.15 mg/day for 3 mos | 18/49 (37%) | 0.98 (0.42 to 2.3) ≥ 50% reduction in HF | 49 | - | - | n.s. (p > 0.05) HI
Wilkinson, Agnoli, Gerber, et al., 1989 | Lisuride, 0.075 mg/day for 3 mos | 16/43 (37%) | 0.98 (0.42 to 2.3) ≥ 50% reduction in HF | 43 | - | - | n.s. (p > 0.05) HI
Oxitriptan
De Benedittis and Massei, 1986 | Oxitriptan, 400 mg/day for 2 mos | - | - | 31* | 43.8 | 25.1 | 0.08 (−0.42 to 0.58) HI
De Benedittis and Massei, 1986 | Placebo | - | - | 31* | 43.8 | 26.5 | 0.08 (−0.42 to 0.58) HI
Kangasniemi, Falck, Långvik, et al., 1978 | Oxitriptan, 2000 mg/day for 3 mos | - | - | 8* | - | 16.0 | −0.45 (−0.54 to 1.4) HI
Kangasniemi, Falck, Långvik, et al., 1978 | Placebo (levoleucine), 1280 mg/day for 3 mos | - | - | 8* | - | 23.8 | −0.45 (−0.54 to 1.4) HI
Mathew, 1978 | Oxitriptan, 300 mg/day for 8 wks | - | - | 12* | - | - | -
Mathew, 1978 | Placebo | - | - | 12* | - | - | -
Iprazochrome
Osterman, 1977 | Iprazochrome, 15 mg/day for 8 wks | 6/27 (22%) | - | 27* | - | 2.1 | n.s. (no p-value reported) HI
Osterman, 1977 | Placebo | - | - | 27* | - | 2.4 | n.s. (no p-value reported) HI
COMPARISONS AMONG SEROTONIN ANTAGONISTS
Pizotifen VS. iprazochrome
Osterman, 1977 | Pizotifen, 3 mg/day for 8 wks | 12/27 (44%) | 2.8 (0.86 to 9.1) ≥ 50% reduction in HF | 27* | - | 1.6 | 0.73 (0.18 to 1.3) HI
Osterman, 1977 | Iprazochrome, 15 mg/day for 8 wks | 6/27 (22%) | 2.8 (0.86 to 9.1) ≥ 50% reduction in HF | 27* | - | 2.1 | 0.73 (0.18 to 1.3) HI
Kangasniemi, 1979 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 34* | - | 2.7 | 0.26 (−0.22 to 0.73) HI
Kangasniemi, 1979 | Iprazochrome, 15 mg/day for 3 mos | - | - | 34* | - | 3.2 | 0.26 (−0.22 to 0.73) HI
Pizotifen vs. lisuride
Nattero, Biale, Savi, et al., 1991 | Pizotifen, 4.5 mg/day for 16 wks | 10/43 (23%) | 0.57 (0.22 to 1.5) ≥ 50% reduction in HF | 43* | - | - | - HF
Nattero, Biale, Savi, et al., 1991 | Lisuride, 0.225 mg/day for 16 wks | 15/43 (35%) | 0.57 (0.22 to 1.5) ≥ 50% reduction in HF | 43* | - | - | - HF
Pizotifen vs. oxitriptan
Bono, Criscuoli, Martignoni, et al., 1982 | Pizotifen, 1.40 mg/day for 2 mos | - | - | 34 | - | - | p < 0.02 (pizotifen better) HI
Bono, Criscuoli, Martignoni, et al., 1982 | Oxitriptan, 400 mg/day for 2 mos | - | - | 33 | - | - | p < 0.02 (pizotifen better) HI
COMPARISONS WITH CALCIUM ANTAGONISTS
Pizotifen vs. flunarizine
Cerbo, Casacchia, Formisano, et al., 1986 | Pizotifen, 1.5 mg/day for 2 mos | - | - | 21* | - | - | n.s. (no p-value reported) HF
Cerbo, Casacchia, Formisano, et al., 1986 | Flunarizine, 15 mg/day for 2 mos | - | - | 21* | - | - | n.s. (no p-value reported) HF
Louis and Spierings, 1982 | Pizotifen, 2–3 mg/day for 4 mos | - | - | 30 | - | - | n.s. (no p-value reported) HF
Louis and Spierings, 1982 | Flunarizine, 10 mg/day for 4 mos | - | - | 36 | - | - | n.s. (no p-value reported) HF
Rascol, Montastruc, and Rascol, 1986 | Pizotifen, 2.19 mg/day for 4 mos | - | - | 14 | - | - | n.s. (no p-value reported) HF
Rascol, Montastruc, and Rascol, 1986 | Flunarizine, 10 mg/day for 4 mos | - | - | 21 | - | - | n.s. (no p-value reported) HF
Pizotifen vs. nimodipine
Gawel, 1987 | Pizotifen, 3 mg/day for 3 mos | - | - | 54* | 7.55 | 6.65 | 0.11 (−0.42 to 0.64) HF
Gawel, 1987 | Nimodipine, 120 mg/day for 3 mos | - | - | 54* | 7.56 | 6.04 | 0.11 (−0.42 to 0.64) HF
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 43* | 6.2 | 2.6 | −0.11 (−0.54 to 0.31) HF
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Nimodipine, 120 mg/day for 3 mos | - | - | 43* | 6.2 | 2.3 | −0.11 (−0.54 to 0.31) HF
Micieli, Trucco, Agostinis, et al., 1985 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 20* | - | - | n.s. (no p-value reported) HI
Micieli, Trucco, Agostinis, et al., 1985 | Nimodipine, 120 mg/day for 3 mos | - | - | 20* | - | - | n.s. (no p-value reported) HI
Pizotifen vs. cyclandelate
Mastrosimone, laccarino, and de Caterina, 1992 | Pizotifen, 1.5 mg/day for 3 mos | - | - | 26 | - | - | p < 0.001 (cyclandelate better) Total pain index
Mastrosimone, laccarino, and de Caterina, 1992 | Cyclandelate, 1600 mg/day for 3 mos | - | - | 35 | - | - | p < 0.001 (cyclandelate better) Total pain index
COMPARISONS WITH METHYSERGIDE
Pizotifen vs. methysergide
Andersson, 1973 | Pizotifen, 2.0 mg/day for 3 mos | 18/47 (38%) | 1.4 (0.59 to 3.2) > 50% reduction in HF | 49* | 5.9 | 3.5 | 0.17 (−0.23 to 0.57) HF
Andersson, 1973 | Methysergide, 4 mg/day for 3 mos | 15/48 (31%) | 1.4 (0.59 to 3.2) > 50% reduction in HF | 49* | 5.9 | 4.1 | 0.17 (−0.23 to 0.57) HF
Forssman, Henriksson, and Kihlstrand, 1972 | Pizotifen, 2–3 mg/day for 10 wks | - | - | 17* | 3.5 | 2.1 | n.s. (no p-value reported) HI
Forssman, Henriksson, and Kihlstrand, 1972 | Methysergide, 4–6 mg/day for 10 wks | - | - | 17* | 3.5 | 1.8 | n.s. (no p-value reported) HI
Presthus, 1971 | Pizotifen, 1.5 mg/day for 5 wks | - | - | 19* | - | - | 0.29 (−0.17 to 0.76) HF
Presthus, 1971 | Methysergide, 3 mg/day for 5 wks | - | - | 19* | - | - | 0.29 (−0.17 to 0.76) HF
Ryan, 1968 | Pizotifen, 4 mg/day for 4 wks | - | - | 62* | - | 8.9 | - HI
Ryan, 1968 | Methysergide, 4 mg/day for 4 wks | | - | 62* | - | 11.3 | - HI
Oxitriptan vs. methysergide
Sicuteri, 1973 | Oxitriptan, 200 mg/day for 40 days | - | - | 20 | - | 5.6 (mean within- patient, pre- to - post-treatment) | −0.09 (−0.71 to 0.53) HI
Sicuteri, 1973 | Methysergide, 2 mg/day for 40 days | - | - | 20 | - | 5.9 (mean within- patient, pre- to - post-treatment) | −0.09 (−0.71 to 0.53) HI
Titus, Davalos, Alom, et al., 1986 | Oxitriptan, 600 mg/day for 6 mos | 32/45 (71%) | 0.82 (0.31 to 2.2) ≥50% reduction in HF or frequency of severe HAs | 45 | - | - | -
Titus, Davalos, Alom, et al., 1986 | Methysergide, 3 mg/day for 6 mos | 30/40 (75%) | 0.82 (0.31 to 2.2) ≥50% reduction in HF or frequency of severe HAs | 40 | - | - | -
Lisuride vs. methysergide
Herrmann, Horowski, Dannehl, et al., 1977 | Lisuride, 75 mcg/day for 3 mos | 38/72 (53%) | 1.1 (0.53 to 2.2) ≥50% reduction in HF | 72 | - | - | -
Herrmann, Horowski, Dannehl, et al., 1977 | Methysergide, 6 mg/day for 3 mos | 27/53 (51%) | 1.1 (0.53 to 2.2) ≥50% reduction in HF | 53 | - | - | -
COMPARISON WITH ALPHA-2 AGONIST
Pizotifen vs. clonidine
Behan, 1985 | Pizotifen (Sanomigran®), 1.5 mg/night for 1 mo; 1.5 – 3.0 mg/night for 2d mo | - | - | 18 | - | - | -
Behan, 1985 | Clonidine (Dixarit®), 100 μg/day for 1 mo; 100–150 μg/day for 2d mo | - | - | 26 | - | - | -
COMPARISON WITH ANTINAUSEANT
Pizotifen vs. prochlorperazine
Hübbe, 1973 | Pizotifen, 3 mg/day for 2 mos | - | - | 40* | - | - | n.s. (no p-value reported) HF
Hübbe, 1973 | Prochlorperazine, 15 mg/day for 2 mos | - | - | 40* | - | - | n.s. (no p-value reported) HF
COMPARISON WITH BETA-BLOCKER
Pizotifen vs. metoprolol
Vilming, Standnes, and Hedman, 1985 | Pizotifen, 0.5 mg/day, gradually increased to 1.5 mg/day for 8 wks | 14/33 (42%) | 1.8 (0.64 to 4.9) ≥50% reduction in HI | 30* | 13.0 (median) | 7.1 (median) | n.s. (p > 0.05) HI
Vilming, Standnes, and Hedman, 1985 | Metoprolol, 100 mg/day for 8 wks | 10/34 (29%) | 1.8 (0.64 to 4.9) ≥50% reduction in HI | 30* | 13.0 (median) | 8.6 (median) | n.s. (p > 0.05) HI
COMPARISON WITH NSAID
Pizotyline vs. naproxen sodium
Bellavance and Meloche, 1990 | Pizotyline, 1.5 mg/day for 3 mos | - | - | 58 | 5.77 | 3.27 | n.s. (no p-value reported) HI
Bellavance and Meloche, 1990 | Naproxen sodium, 1100 mg/day for 3 mos | - | - | 56 | 5.32 | 2.85 | n.s. (no p-value reported) HI

1 Key to abbreviations: HA = headache; HF = headache frequency; HI = headache index; mog = microgram; mg = milligram; mo = month; N = population studied (n = sample size); n.s. = not (statistically) significant; N/S = not specified; wk = week; μg = microgram

2 An asterisk denotes a crossover trial.

Evidence Table 11 Efficacy of Other Treatments^1,2^

Study | Treatment | # of patients improved/N (%) | Odds ratio | Mean Values | | | Effect size or p-value
Study | Treatment | # of patients improved/N (%) | Odds ratio | N | Before Treatment | After Treatment | Effect size or p-value
HORMONAL TREATMENTS
Estradiol vs. placebo
Dennerstein, Morse, Burrows, et al., 1988 | Estradiol (percutaneous gel), 1.5 mg/day, 7 days, for 2 menstrual cycles | - | - | 19* | - | - | 0.71 (0.26 to 1.2) HF(within-patients difference)
Dennerstein, Morse, Burrows, et al., 1988 | Placebo | - | - | 19* | - | - | 0.71 (0.26 to 1.2) HF(within-patients difference)
Smits, van der Meer, Pfeil, et al., 1993 | Estradiol (Estraderm TTS® patch), 50 μg/day for 8 days during 1–2 menstrual cycles (see Evidence Table 1) | - | - | 19* | - | - | n.s. (no p-value reported) HF
Smits, van der Meer, Pfeil, et al., 1993 | Placebo | - | - | 19* | - | - | n.s. (no p-value reported) HF
Flumedroxone vs. placebo
Bradley, Hudgson, Foster, et al., 1968 (Men) | Flumedroxone, 30 mg/day for 3 mos | - | - | 14* | - | - | n.s. (no p-value reported) HI (within-patients difference)
Bradley, Hudgson, Foster, et al., 1968 (Men) | Placebo | - | - | 14* | - | - | n.s. (no p-value reported) HI (within-patients difference)
Bradley, Hudgson, Foster, et al., 1968 (Women w/o menstrual exacerbation of HA) | Flumedroxone, 30 mg/day for 3 mos | - | - | 7* | - | - | n.s. (no p-value reported) HI (within-patients difference)
Bradley, Hudgson, Foster, et al., 1968 (Women w/o menstrual exacerbation of HA) | Placebo | - | - | 7* | - | - | n.s. (no p-value reported) HI (within-patients difference)
Bradley, Hudgson, Foster, et al., 1968 (Women with menstrual exacerbation of HA) | Flumedroxone, mos 30 mg/day for 3 | - | - | 18* | - | - | p<0.05 (flumedroxone better) HI (within-patients difference)
Bradley, Hudgson, Foster, et al., 1968 (Women with menstrual exacerbation of HA) | Placebo | - | - | 18* | - | - | p<0.05 (flumedroxone better) HI (within-patients difference)
Lundberg, 1969 | Flumedroxone, 10 mg/day for 1 mo | - | - | 21 | - | - | p<0.0005 (flumedroxone better) HF
Lundberg, 1969 | Placebo | - | - | 23 | - | - | p<0.0005 (flumedroxone better) HF
Flumedroxone vs. methysergide
Hudgson, Foster, and Newell, 1967 | Flumedroxone, 15 mg/day for 4 mos | - | - | 33* | - | 4.3 | - HF
Hudgson, Foster, and Newell, 1967 | Methysergide, 3 mg/day for 4 mos | - | - | 33* | - | 2.8 | - HF
Ovral® (norgestrel 0.5 mg + ethinyl estradiol 0.005 mg) vs. no treatment
Ryan, 1978 | Ovral®, as prescribed, for 2 mos | - | - | 40* | - | 48.70 | - HI
Ryan, 1978 | No treatment | - | - | 40* | - | 32.85 | - HI
FEVERFEW
Johnson, Kadam, Hylands, et al., 1985 | 50 mg/day for 6 mos | - | - | 8 | - | 1.50 | 2.3 (1.0 to 3.6) HF
Johnson, Kadam, Hylands, et al., 1985 | Placebo | - | - | 7 | - | 3.43 | 2.3 (1.0 to 3.6) HF
Murphy, Heptinstall, and Mitchell, 1988 | Feverfew, ≈82 mg/day (mean dose) for 4 mos | - | - | 59* | - | 3.6 | 0.56 (0.19 to 0.93) HF
Murphy, Heptinstall, and Mitchell, 1988 | Placebo | - | - | 59* | - | 4.7 | 0.56 (0.19 to 0.93) HF

1 Key to abbreviations: ES = effect size; Freq = frequency; HA = headache; HF = headache frequency; HI = headache index; HS = headache severity; Imprv'd = improved; MD = medical doctor; med = medication; mo = month or months; N or n = number of patients; normo = normobaric; n.s. = not (statistically) significant; OC = outcome; OR = odds ratio

2 An asterisk denotes a crossover trial.

Evidence Table 12 Adverse events^1, 2^

Report | Adverse events | Interventions | | | | Notes; Difference in proportion of patients reporting adverse events (95% CI)
Adam, Gore, and Price, 1978 | | Clonidine (Dixarit®), 0.025 mg, 3x/day for 6 mos (could be increased to max. of 0.050 mg, 3x/day for 6 mos) | | Placebo | | Information on AEs provided only on the 26 patients who withdrew from trial.
Adam, Gore, and Price, 1978 | Number of patients evaluable for AEs: | N/S (See note) | | N/S (See note) | | Information on AEs provided only on the 26 patients who withdrew from trial.
Adam, Gore, and Price, 1978 | Number of patients reporting AEs: | N/S | | N/S | | Information on AEs provided only on the 26 patients who withdrew from trial.
Adam, Gore, and Price, 1978 | Total number of AEs reported: | N/S | | N/S | | Information on AEs provided only on the 26 patients who withdrew from trial.
Adam, Gore, and Price, 1978 | Withdrawals due to AEs: | 2 (palpitations & dyspnoea; nausea, epigastric discomfort, abdominal distension) | | 1 (nausea, vomiting, flatulence, skin irritation) | | Information on AEs provided only on the 26 patients who withdrew from trial.
Adly, Straumanis, and Chesson, 1992 | | Fluoxetine, doses ranged from 20 mg every other day to 40 mg/day | | Placebo | | Data at left are only for those patients who completed the trial (18/32). One patient in the fluoxetine group withdrew prematurely due to AEs (anxiety and insomnia). No patients withdrew from the placebo group due to AEs.
Adly, Straumanis, and Chesson, 1992 | Number of patients evaluable for AEs: | 9 | | 9
Adly, Straumanis, and Chesson, 1992 | Number of patients reporting AEs: | 3 (33%) | | 3 (33%)
Adly, Straumanis, and Chesson, 1992 | Total number of AEs reported: | 6 | | 4
Adly, Straumanis, and Chesson, 1992 | Number of patients reporting: | n (%) | | n (%)
Adly, Straumanis, and Chesson, 1992 | Insomnia | 2 (22%) | | 2 (22%)
Adly, Straumanis, and Chesson, 1992 | Anxiety | 1 (11 %) | | 1 (11 %)
Adly, Straumanis, and Chesson, 1992 | Excitement | 1 (11 %) | | 0
Adly, Straumanis, and Chesson, 1992 | Strange skin sensations | 1 (11 %) | | 0
Adly, Straumanis, and Chesson, 1992 | Floating sensation | 1 (11 %) | | 0
Adly, Straumanis, and Chesson, 1992 | Weakness/fatigue | 0 | | 1 (11 %)
Adly, Straumanis, and Chesson, 1992 | Withdrawals due to AEs: | (See note) | | (See note)
Agnoli, Bussone, Mailland, et al., 1991 | | Dihydroergokryptine (DEK), 10 mg/day for 6 mos | | Flunarizine, 5 mg/day for 6 mos | | Abstract reporting limited results. Investigators stated only that the overall rate of AEs was similar in the two groups.
Agnoli, Bussone, Mailland, et al., 1991 | Number of patients evaluable for AEs: | 54 | | 48 | | Abstract reporting limited results. Investigators stated only that the overall rate of AEs was similar in the two groups.
Agnoli, Bussone, Mailland, et al., 1991 | Number of patients reporting AEs: | N/S | | N/S | | Abstract reporting limited results. Investigators stated only that the overall rate of AEs was similar in the two groups.
Agnoli, Bussone, Mailland, et al., 1991 | Total number of AEs reported: | N/S | | N/S | | Abstract reporting limited results. Investigators stated only that the overall rate of AEs was similar in the two groups.
Agnoli, Bussone, Mailland, et al., 1991 | Withdrawals due to AEs: | 4 (causative AEs N/S) | | 0 | | Abstract reporting limited results. Investigators stated only that the overall rate of AEs was similar in the two groups.
Ahuja and Verma, 1985 | | Propranolol 40 mg, 3x/day for 8 wks | | Placebo | | Regarding AEs, investigators reported only that there were "no significant side effects of propranolol observed during the trial period." No information was provided on AEs that might have resulted from the placebo treatment.
Ahuja and Verma, 1985 | Number of patients evaluable for AEs: | 26* (See note) | | 26* (See note)
Ahuja and Verma, 1985 | Number of patients reporting AEs: | N/S | | N/S
Ahuja and Verma, 1985 | Total number of AEs reported: | N/S | | N/S
Ahuja and Verma, 1985 | Withdrawals due to AEs: | N/S | | N/S
Albers, Simon, Hamik, et al., 1989 | | Nifedipine, 60–90 mg/day for 6 mos | | Propranolol, 120–180 mg/day for 6 mos | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Number of patients evaluable for AEs: | 20 | | 18 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Number of patients reporting AEs: | 20 (100%) | | 15 (83%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Total number of AEs reported: | 52 | | 17 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Number of patients reporting: | n (%) | | n(%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Dizziness | 13 (65%) | | 3 (17%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Warm, swollen, red legs | 9 (45%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Fatigue | 0 | | 8 (44%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Increased HA frequency | 4 (20%) | | 3 (17%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Tachycardia | 6 (30%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Facial flushing | 6 (30%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Nausea | 6 (30%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Decrease in concentration | 4 (20%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Shakiness | 4 (20%) | | 0 | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Depression | 0 | | 3 (17%) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Albers, Simon, Hamik, et al., 1989 | Withdrawals due to AEs: | 13 (causative AEs N/S) | | 5 (causative AEs N/S) | | Nifedipine vs. propranolol: 0.16 (−0.025 to 0.34)
Al Deeb, Biary, Bahou, et al., 1992 | | Flunarizine, 10 mg/day for 3 mos | | Placebo | | Limited information provided on AEs. Four of 50 patients (8%) withdrew due to AEs "such as tiredness or weight-gain, depression or giddiness." The investigators did not report from which treatment group these withdrawals came.
Al Deeb, Biary, Bahou, et al., 1992 | Number of patients evaluable for AEs: | N/S | | N/S
Al Deeb, Biary, Bahou, et al., 1992 | Number of patients reporting AEs: | N/S | | N/S
Al Deeb, Biary, Bahou, et al., 1992 | Total number of AEs reported: | N/S | | N/S
Al Deeb, Biary, Bahou, et al., 1992 | Withdrawals due to AEs: | (See note) | | (See note)
Al-Qassab and Findley, 1993 | | Propranolol (long-acting), 160 mg, 1x/day for 2 mos | Propranolol (long-acting), 80 mg, 1x/day for 2 mos | Placebo | | Of the 45 patients randomized to treatment, 1 was withdrawn due to AEs. Investigators did not describe the AE or report the treatment group from which the patient withdrew. Authors reported only that "reported side effects during the three treatment periods were similar and were not statistically significant." It was also reported that the incidence of side effects were similar on the active drug as on placebo.
Al-Qassab and Findley, 1993 | Number of patients evaluable for AEs: | N/S (See note) | N/S (See note) | N/S (See note)
Al-Qassab and Findley, 1993 | Number of patients reporting AEs: | N/S | N/S | N/S
Al-Qassab and Findley, 1993 | Total number of AEs reported: | N/S | N/S | N/S
Al-Qassab and Findley, 1993 | Withdrawals due to AEs: | N/S (See note) | N/S (See note) | N/S (See note)
Andersson, 1973 | | Methysergide, 1 mg, 4x/day for 3 mos | | Pizotifen, 0.5 mg, 4x/day for 3 mos | | Limited information reported on AEs. Among patients who experienced AEs but did not withdraw from the trial, restlessness and pain in the legs were the most common AEs associated with methysergide; weight gain was the most common AE associated with pizotifen.
Andersson, 1973 | Number of patients evaluable for AEs: | N/S | | N/S
Andersson, 1973 | Number of patients reporting AEs: | N/S | | N/S
Andersson, 1973 | Total number of AEs reported: | N/S | | N/S
Andersson, 1973 | Withdrawals due to AEs: | 4 (muscle pain in legs [3], severe phlebitis [1]) | | 9 (weight gain [4], drowsiness [2], vertigo and drowsiness [2], muscle pains in legs [1])
Andersson, Dahl, Hansen, et al., 1983 | | Metoprolol, 200 mg, 1x/day for 8 wks | | Placebo | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Number of patients evaluable for AEs: | 30 (See note) | | 35 (See note) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Number of patients reporting AEs: | 16 (53%) | | 10 (29%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Total number of AEs reported: | 31 | | 32 | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Number of AEs reported: | n (%) | | n (%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Sleep disturbances | 11 (35%) | | 9 (28%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Fatigue | 9 (29%) | | 1 (3%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Gastrointestinal | 3 (10%) | | 6 (19%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Bradycardia | 0 | | 1 (3%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Paraesthesia | 2 (6%) | | 4 (13%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Depression | 2 (6%) | | 2 (6%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Others | 3 (10%) | | 10 (31%) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson, Dahl, Hansen, et al., 1983 | Withdrawals due to AEs: | 1 (N/S) | | 1 (N/S) | | Data at left appear to concern only the 65/71 patients included in the efficacy analyses, but this is not clear. Metoprolol vs. placebo: 0.24 (0.0049 to 0.46)
Andersson and Petersen, 1981 | | Femoxetine, 200 mg, 2x/day for 3 mos; dose reduced by half during first week | | Propranolol, 80 mg, 2x/day for 3 mos; dose reduced by half during first week | | The data reported at left appear to include only those patients who completed the trial (37/49 patients randomized to treatment), though this is not entirely clear. Two patients withdrew prematurely due to unspecified AEs associated with femoxetine; two withdrew due to unspecified AEs associated with propranolol.
Andersson and Petersen, 1981 | Number of patients evaluable for AEs: | 37* | | 37*
Andersson and Petersen, 1981 | Number of patients reporting AEs: | N/S | | N/S
Andersson and Petersen, 1981 | Total number of AEs reported: | 14 | | 30
Andersson and Petersen, 1981 | Number of patients reporting: | n (%) | | n (%)
Andersson and Petersen, 1981 | Tiredness | 4(11%} | | 8 (22%)
Andersson and Petersen, 1981 | Menstrual disorder | 1 (3%) | | 10 (27%)
Andersson and Petersen, 1981 | Depression | 1 (3%) | | 3 (8%)
Andersson and Petersen, 1981 | Nausea | 1 (3%) | | 2 (5%)
Andersson and Petersen, 1981 | Feeling unwell | 2 (5%) | | 0
Andersson and Petersen, 1981 | Insomnia | 1 (3%) | | 1 (3%)
Andersson and Petersen, 1981 | Dizziness | 1 (3%) | | 1 (3%)
Andersson and Petersen, 1981 | Exanthema | 1 (3%) | | 1 (3%)
Andersson and Petersen, 1981 | Precordial pain | 1 (3%) | | 0
Andersson and Petersen, 1981 | Gastric distress | 1 (3%) | | 0
Andersson and Petersen, 1981 | Palpitations | 0 | | 1 (3%)
Andersson and Petersen, 1981 | Unrest of the legs | 0 | | 1 (3%)
Andersson and Petersen, 1981 | Paresthesia | 0 | | 1 (3%)
Andersson and Petersen, 1981 | Irritability | 0 | | 1 (3%)
Andersson and Petersen, 1981 | Withdrawals due to AEs: | (See note) | | (See note)
Ansell, Fazzone, Festenstein, et al., 1988 | | Nimodipine, 120 mg/day for 4 mos | | Placebo | | Investigators reported only that no patients withdrew due to AEs and that no "serious" AEs were reported. AEs were recorded at monthly clinic visits.
Ansell, Fazzone, Festenstein, et al., 1988 | Number of patients evaluable for AEs: | 34 | | 34 | | Investigators reported only that no patients withdrew due to AEs and that no "serious" AEs were reported. AEs were recorded at monthly clinic visits.
Ansell, Fazzone, Festenstein, et al., 1988 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported only that no patients withdrew due to AEs and that no "serious" AEs were reported. AEs were recorded at monthly clinic visits.
Ansell, Fazzone, Festenstein, et al., 1988 | Total number of AEs reported: | N/S | | N/S | | Investigators reported only that no patients withdrew due to AEs and that no "serious" AEs were reported. AEs were recorded at monthly clinic visits.
Ansell, Fazzone, Festenstein, et al., 1988 | Withdrawals due to AEs: | 0 | | 0 | | Investigators reported only that no patients withdrew due to AEs and that no "serious" AEs were reported. AEs were recorded at monthly clinic visits.
Anthony and Lance, 1968 | | Indomethacin, 25 mg, 3x/day for 1–9 mos | | Placebo, 3x/day for 1 rno | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Number of patients evaluable for AEs: | 38 (See note) | | 19 (See note) | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Number of patients reporting AEs: | 15 (39%) | | N/S | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Total number of AEs reported: | 35 | | 7 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Number of patients reporting: | n (%) | | n (%) | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Full head | 5 (13%) | | 4 (21%) | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Indigestion | 7(18%) | | 1 (5%) | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Lightheadedness | 5 (13%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Insomnia | 5 (13%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Dizziness | 2 (5%) | | 2 (11%) | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Poor concentration | 3 (8%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Bifrontal headache | 2 (5%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Depression | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Irritability | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Tiredness | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Unsteadiness | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Nausea | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Epigastric pain | 1 (3%) | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony and Lance, 1968 | Withdrawals due to AEs: | 0 | | 0 | | See Evidence Table 1 on study design. Investigators stated that no patients withdrew due to AEs.
Anthony, Lance, and Somerville, 1972 | | Prindolol, 2.5 mg, 4x/day for 1– 20 mos | Clonidine, 75 μg, 3x/day for 1–18 mos | Carbamazepine, 200 mg, 3x/day for 1–4 mas | | AEs reported for entire (partial crossover) trial (see Evidence Table 1 for details of trial design). Withdrawals from the prindolol group were due to increasing headache (2); and dizziness, nausea, vomiting, paraesthesiae, lassitude and exhaustion, and cramps (1 each). Carbamazepine vs. prindolol: 0.34 (0.17 to 0.49) Carbamazepine VS. clonidine: 0.12 (−0.060 to 0.29) Clonidine vs. prindolol: 0.22 (0.074 to 0.36)
Anthony, Lance, and Somerville, 1972 | Number of patients evaluable for AEs: | 79* | 73* | 51*
Anthony, Lance, and Somerville, 1972 | Number of patients reporting AEs: | 15 (19%) | 30 (41%) | 27 (53%)
Anthony, Lance, and Somerville, 1972 | Total number of AEs reported: | 21 | 41 | 40
Anthony, Lance, and Somerville, 1972 | Number of patients reporting: | n (%) | n (%) | n (%)
Anthony, Lance, and Somerville, 1972 | Drowsiness, tiredness, weakness | 2 (3%) | 15(21%) | 7 (14%)
Anthony, Lance, and Somerville, 1972 | Nausea | 2 (3%) | 5 (7%) | 6 (12%)
Anthony, Lance, and Somerville, 1972 | Giddiness, ataxia | 1 (1%) | 0 | 10 (20%)
Anthony, Lance, and Somerville, 1972 | Faintness, dizziness | 3 (4%) | 5 (7%) | 3 (6%)
Anthony, Lance, and Somerville, 1972 | Dry mouth, sore tongue, bad taste | 0 | 10 (14%) | 0
Anthony, Lance, and Somerville, 1972 | Cramps, limb pains | 6 (8%) | 1 (1%) | 2 (4%)
Anthony, Lance, and Somerville, 1972 | Irritability, agitation | 4 (5%) | 2 (3%) | 2 (4%)
Anthony, Lance, and Somerville, 1972 | Epigastric discomfort | 0 | 1 (1%) | 1 (2%)
Anthony, Lance, and Somerville, 1972 | Insomnia, nightmares | 0 | 1 (1%) | 1 (2%)
Anthony, Lance, and Somerville, 1972 | Itching skin, rash | 0 | 0 | 2 (4%)
Anthony, Lance, and Somerville, 1972 | Blurred vision | 0 | 0 | 2 (4%)
Anthony, Lance, and Somerville, 1972 | Lack of concentration | 0 | 0 | 2 (4%)
Anthony, Lance, and Somerville, 1972 | Vomiting | 1 (1%) | 0 | 0
Anthony, Lance, and Somerville, 1972 | Increased appetite | 0 | 0 | 1 (2%)
Anthony, Lance, and Somerville, 1972 | Bruising, prominent veins | 0 | 1 (1%) | 0
Anthony, Lance, and Somerville, 1972 | Swelling of throat | 0 | 0 | 1 (2%)
Anthony, Lance, and Somerville, 1972 | Paraesthesiae | 1 (1%) | 0 | 0
Anthony, Lance, and Somerville, 1972 | Jaundice | 1 (1%) | 0 | 0
Anthony, Lance, and Somerville, 1972 | Withdrawals due to AEs: | 8 (See note) | 8 (causative AEs N/S) | 12 (causative AEs N/S)
Arthur and Hornabrook, 1971 | | Pizotifen (BC 105), 3 mg/day for 1 mo | | Placebo | | Information on AEs provided only on the 52/63 patients from whom efficacy data were obtained, which included the three patients who withdrew due to severe AEs. Of patients treated with pizotifen, weight gain was reported by 26 of the 44 patients (59%) for whom data were available. Fifteen of 46 patients (33%) treated with placebo reported weight gain. Pizotifen VS. placebo: 0.30 (0.14 to 0.45)
Arthur and Hornabrook, 1971 | Number of patients evaluable for AEs: | 52* (See note) | | 52* (See note)
Arthur and Hornabrook, 1971 | Number of patients reporting AEs: | 22 (42%) | | 6 (12%)
Arthur and Hornabrook, 1971 | Total number of AEs reported: | 22 | | 6
Arthur and Hornabrook, 1971 | Number of patients reporting: | n (%) | | n (%)
Arthur and Hornabrook, 1971 | Bizarre feelings in head | 0 | | 1 (2%)
Arthur and Hornabrook, 1971 | “Dead” feelings in legs | 0 | | 1 (2%)
Arthur and Hornabrook, 1971 | Depression | 4 (8%) | | N/S
Arthur and Hornabrook, 1971 | Dizziness | 1 (2%) | | N/S
Arthur and Hornabrook, 1971 | Drowsiness | 11 (21%) | | N/S
Arthur and Hornabrook, 1971 | Enuresis | 1 (2%) | | N/S
Arthur and Hornabrook, 1971 | Faintness | 0 | | 1 (2%)
Arthur and Hornabrook, 1971 | Fatigue | 2 (4%) | | 2 (4%)
Arthur and Hornabrook, 1971 | Increased appetite | 1 (2%) | | N/S
Arthur and Hornabrook, 1971 | Nausea | 0 | | 1 (2%)
Arthur and Hornabrook, 1971 | Wakefulness | 2 (4%) | | N/S
Arthur and Hornabrook, 1971 | Withdrawals due to AEs: | 3 (drowsiness [2 – 1 with diplopia & blurred vision], dizziness [1]) | | N/S
Autret and de Chasteigner, 1987 | | DHE (timed-release), 5 mg, 2x/day for 2 mos | | Placebo | | Abstract providing limited information. Investigators stated that all 115 patients who started the treatment phase of the trial completed it. No information was provided on AEs reported during the trial.
Autret and de Chasteigner, 1987 | Number of patients evaluable for AEs: | 58 | | 57
Autret and de Chasteigner, 1987 | Number of patients reporting AEs: | N/S | | N/S
Autret and de Chasteigner, 1987 | Total number of AEs reported: | N/S | | N/S
Autret and de Chasteigner, 1987 | Withdrawals due to AEs: | 0 | | 0
Baldrati, Cortelli, Procaccianti, et al., 1983 | | Aspirin, mean dose (± SD) 13.5 ± 1.2 mg/kg/day, for 3 mos | | Propranolol, mean dose (± SD) 1.8 ± 0.1 mg/kg/day, for 3 mos | | Overall AE rates were reported only for those patients who completed the trial (12/18). AEs associated with aspirin were gastric distress, palpitations, weight gain, and constipation (number of patients reporting these N/S). AEs associated with propranolol were palpitations, gastric distress, dizziness, insomnia, and constipation number of patients reporting these N/S). Three patients withdrew before completing the trial due to AEs associated with aspirin (gastric distress in all three cases); two withdrew due to AEs associated with propranolol (hypotension, worsening of HA). Aspirin vs. propranolol: 0.00 (−0.37 to 0.37)
Baldrati, Cortelli, Procaccianti, et al., 1983 | Number of patients evaluable for AEs: | 12* | | 12*
Baldrati, Cortelli, Procaccianti, et al., 1983 | Number of patients reporting AEs: | 6 (50%) | | 6 (50%)
Baldrati, Cortelli, Procaccianti, et al., 1983 | Total number of AEs reported: | N/S | | N/S
Baldrati, Cortelli, Procaccianti, et al., 1983 | Withdrawals due to AEs: | (See note) | | (See note)
Bánk, 1994 | | Amitriptyline, 25 mg, 1x/day for 12 wks | | Fluvoxamine, 50 mg, 1x/day for 12 wks | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Number of patients evaluable for AEs: | 29 | | 30 | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Number of patients reporting AEs: | 12 (41%) | | 7 (23%) | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Total number of AEs reported: | 12 | | N/S | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Number of patients reporting: | n (%) | | n (%) | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Drowsiness | 12 (41%) | | N/S | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Dry mouth | 0 | | N/S | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Nausea | 0 | | N/S | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | General weakness | 0 | | N/S | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Bánk, 1994 | Withdrawals due to AEs: | 7 (all due to drowsiness) | | 3 (drowsiness, severe constipation, feeling of pressure in abdomen) | | Fluvoxamine vs. amitriptyline: −0.18 (−0.40 to 0.060)
Barrie, Fox, Weatherall, et al., 1968 | | Ergotamine, 0.17 mg, 3x/day for up to 2 mos | Ergotamine, 0.33 mg, 3x/day for up to 2 mos | Methysergide,1 mg, 3x/day for up to 2 mos | Methysergide, 2 mg, 3x/day for up to 2 mos | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Number of patients evaluable for AEs: | 73 | 68 | 76 | 54 | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Number of patients reporting AEs: | N/S | N/S | N/S | N/S | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Total number of AEs reported: | 23 | 25 | 53 | 61 | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Number of patients reporting: | n (%) | n (%) | n (%) | n (%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Drowsiness | 6 (8%) | 7 (10%) | 9 (12%) | 9 (17%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Depression | 3 (4%) | 6 (9%) | 7 (9%) | 8 (15%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Nausea, vomiting | 1 (1%) | 3 (4%) | 11 (14%) | 8 (15%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Vertigo, “muzzy head” | 3 (4%) | 4 (6%) | 4 (5%) | 9 (17%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Swollen joints, stiffness or cramps | 6 (8%) | 0 | 5 (7%) | 7 (13%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Digestive disturbance | 0 | 2 (3%) | 7 (9%) | 7 (13%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Swollen eyes, visual disturbance | 0 | 1 (1%) | 1 (1%) | 4 (7%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Other | 4 (5%) | 2 (3%) | 9 (12%) | 9 (17%) | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Barrie, Fox, Weatherall, et al., 1968 | Withdrawals due to AEs: | N/S | N/S | N/S | N/S | Data on AEs were reported only for the four treatment arms at left (of six), and only for all four treatment periods combined.
Bassi, Brunati, Rapuzzi, et al., 1992 | | Flunarizine, 10 mg, 1x/day for 4 mos | | Flunarizine, 10 mg, 1x/day for one wk, then 3 mg, 1x/day for total of 4 mos | | The data reported at left are for those patients who completed the trial (29/40). Two patients, one from each treatment group, withdrew prematurely due to unspecified AEs. Flunarizine, 10 mg vs. 3 mg: 0.49 (0.16 to 0.74)
Bassi, Brunati, Rapuzzi, et al., 1992 | Number of patients evaluable for AEs: | 15 | | 14
Bassi, Brunati, Rapuzzi, et al., 1992 | Number of patients reporting AEs: | 13 (86%) | | 5 (38%)
Bassi, Brunati, Rapuzzi, et al., 1992 | Total number of AEs reported: | 13 | | 5
Bassi, Brunati, Rapuzzi, et al., 1992 | Number of patients reporting: | n (%) | | n (%)
Bassi, Brunati, Rapuzzi, et al., 1992 | Sleepiness | 5 (33%) | | 2 (14%)
Bassi, Brunati, Rapuzzi, et al., 1992 | Weight gain | 5 (33%) | | 2 (14%)
Bassi, Brunati, Rapuzzi, et al., 1992 | Depression | 2 (13%) | | 1 (7%)
Bassi, Brunati, Rapuzzi, et al., 1992 | Rash | 1 (7%) | | 0
Bassi, Brunati, Rapuzzi, et al., 1992 | Withdrawals due to AEs: | (See note) | | (See note)
Behan, 1985 | | Clonidine (Dixarit®), 50 μg, 2x/day for 1 mo; 50–75 μg, 2x/day for 2d mo | | Pizotifen (Sanomigran®), 1.5 mg, 1x/night for 1 mo; 1.5–3.0 mg, 1x/night for 2d mo | | Five patients taking pizotifen experienced weight gain, and one reported drowsiness. Four patients in the pizotifen group and 7 in the clonidine group withdrew from the study, but investigators did not state whether or not withdrawals resulted from AEs.
Behan, 1985 | Number of patients evaluable for AEs: | N/S (See note) | | N/S (See note)
Behan, 1985 | Number of patients reporting AEs: | N/S | | N/S
Behan, 1985 | Total number of AEs reported: | N/S | | N/S
Behan, 1985 | Withdrawals due to AEs: | N/S | | 1 (weight gain)
Behan and Reid, 1980 | | Propranolol, 40 mg, 3x/day for 3 mos | | Methysergide, 1 mg, 3x/day for 3 mos | | Data at left concern only the 36 patients who completed the trial. AEs reported by these patients in association with methysergide included nausea, vomiting, dizziness, nightmares, circumoral numbness, and abdominal cramps (number of patients reporting each of these symptoms not given). AEs associated with propranolol included generalized weakness and dizziness (9 patients), coldness of hands and circumoral paraesthesia (1), excessive tearing (1), and depression (1). 3 patients withdrew prematurely from the trial due to AEs associated with methysergide (severe chest pains and intermittent claudication [2], bilateral spasm of brachial arteries [1]). No patients withdrew due to AEs associated with propranolol Propranolol vs. methysergide: −0.11 (−0.32 to 0.11)
Behan and Reid, 1980 | Number of patients evaluable for AEs: | 36* | | 36*
Behan and Reid, 1980 | Number of patients reporting AEs: | 12 (33%) | | 16 (44%)
Behan and Reid, 1980 | Total number of AEs reported: | N/S | | N/S
Behan and Reid, 1980 | Withdrawals due to AEs: | (See note) | | (See note)
Bellavance and Meloche, 1990 | | Naproxen sodium, 550 mg, 2x/day for 12 wks | Pizotyline, 0.5 mg, 3x/day for 12 wks | Placebo | | Patients questioned about AEs At monthly clinic visits. Naproxen sodium vs. placebo: 0.061 (−0.092 to 0.21) Pizotyline vs. placebo: 0.078 (−0.077 to 0.23) Naproxen sodium vs. pizotyline: −0.017 (−0.18 to 0.14)
Bellavance and Meloche, 1990 | Number of patients evaluable for AEs: | 58 | 58 | 56
Bellavance and Meloche, 1990 | Number of patients reporting AEs: | 15 (26%) | 16 (28%) | 11 (20%)
Bellavance and Meloche, 1990 | Total number of AEs reported: | N/S | N/S | N/S
Bellavance and Meloche, 1990 | Number of patients reporting: | n (%) | n (%) | n (%)
Bellavance and Meloche, 1990 | Gastrointestinal symptoms | 8 (14%) | 7 (12%) | 3 (5%)
Bellavance and Meloche, 1990 | Central nervous system symptoms | 4 (7%) | 4 (7%) | 5 (9%)
Bellavance and Meloche, 1990 | Skin symptoms | 2 (3%) | 0 | 1 (2%)
Bellavance and Meloche, 1990 | Weight gain | 0 | 6 (10%) | 1 (2%)
Bellavance and Meloche, 1990 | Other AEs | 4 (7%) | 2 (3%) | 4 (7%)
Bellavance and Meloche, 1990 | Withdrawals due to AEs: | 3 (gastric ulcer [1], epigastric burning [2]) | 2 (weight gain [1], sleepiness [1]) | 2 (hematoma and epigastric pain [1], parasthesia [1])
Boisen, Deth, Hübbe, et al., 1978 | | Clonidine, 0.05 mg (in 2 tabs), 2x/day for 8 wks | | Placebo | | Data at left concern only those 49 patients (of 71) who completed the crossover. In this group, the most common AEs reported were drowsiness, dizziness, and nausea. Two patients withdrew prematurely due to AEs associated with clonidine (fainting, severe vomiting). Clonidine VS. placebo: 0.14 (−0.02 to 0.29)
Boisen, Deth, Hübbe, et al., 1978 | Number of patients evaluable for AEs: | 49* (See note) | | 49* (See note)
Boisen, Deth, Hübbe, et al., 1978 | Number of patients reporting AEs: | 13 (26%) | | 6 (12%)
Boisen, Deth, Hübbe, et al., 1978 | Total number of AEs reported: | N/S | | N/S
Boisen, Deth, Hübbe, et al., 1978 | Withdrawals due to AEs: | (See note) | | (See note)
Bono, Criscuoli, Martignoni, et al., 1982 | | Pizotifen, 1.40 mg/day for 2 mos | | Oxitriptan, 400 mg/day for 2 mos | | Limited data were provided on AEs, but appear to have been drawn from all 80 patients randomized to treatment. Figures at left are from the 13/80 patients (16%) who withdrew from the trial. Data from these patients were not included in the efficacy analyses. Of the 67 patients completing the trial and included in the efficacy analyses, weight gain was reported by 22/34 (65%) who took pizotifen and by 9/33 (27%) who took oxitriptan.
Bono, Criscuoli, Martignoni, et al., 1982 | Number of patients evaluable for AEs: | (See note) | | (See note)
Bono, Criscuoli, Martignoni, et al., 1982 | Number of patients reporting AEs: | N/S | | N/S
Bono, Criscuoli, Martignoni, et al., 1982 | Total number of AEs reported: | N/S | | N/S
Bono, Criscuoli, Martignoni, et al., 1982 | Withdrawals due to AEs: | N/S | | 5 (nausea, diarrhea, pyrosis, drowsiness)
Bonuso, Di Stasio, Barone, et al., 1983 | | DHE (timed-release), 5 mg, 2x/day for 2 mos | | Amitriptyline, 75 mg/day (dosing schedule not described) for 2 mos | | Investigators reported only that the most common AEs reported with DHE were nausea and stomach ache; the most common AEs associated with amitriptyline were drowsiness and dry mouth.
Bonuso, Di Stasio, Barone, et al., 1983 | Number of patients evaluable for AEs: | N/S | | N/S | | Investigators reported only that the most common AEs reported with DHE were nausea and stomach ache; the most common AEs associated with amitriptyline were drowsiness and dry mouth.
Bonuso, Di Stasio, Barone, et al., 1983 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported only that the most common AEs reported with DHE were nausea and stomach ache; the most common AEs associated with amitriptyline were drowsiness and dry mouth.
Bonuso, Di Stasio, Barone, et al., 1983 | Total number of AEs reported: | N/S | | N/S | | Investigators reported only that the most common AEs reported with DHE were nausea and stomach ache; the most common AEs associated with amitriptyline were drowsiness and dry mouth.
Bonuso, Di Stasio, Barone, et al., 1983 | Withdrawals due to AEs: | 2 | | 3 | | Investigators reported only that the most common AEs reported with DHE were nausea and stomach ache; the most common AEs associated with amitriptyline were drowsiness and dry mouth.
Børgesen, Nielsen, and Møller, 1974 | | Propranolol, 40 mg, 3x/day for 12 wks | | Placebo | | Little information was provided on AEs from the 45 patients randomized to treatment in this crossover trial. Investigators reported that patients had been informed before the trial began that they might experience AEs such as fatigue, drowsiness, and diarrhea. Many patients reported such side effects, both when receiving propranolol and when receiving placebo. Investigators reported that "none of the side effects were persistent or intolerable."
Børgesen, Nielsen, and Møller, 1974 | Number of patients evaluable for AEs: | N/S (See note) | | N/S (See note)
Børgesen, Nielsen, and Møller, 1974 | Number of patients reporting AEs: | N/S | | N/S
Børgesen, Nielsen, and Møller, 1974 | Total number of AEs reported: | N/S | | N/S
Børgesen, Nielsen, and Møller, 1974 | Withdrawals due to AEs: | 0 | | 2 (N/S)
Bousser, Chick, Fuseau, et al., 1988 | | DHE + aspirin (timed-release), 5 mg + 40 mg, 2x/day for 2 mos | | Placebo | | Data on AEs were reported only for those patients who completed the trial (38/45). Six patients treated with DHE + aspirin and one treated with placebo reported such symptoms as nausea, sleepiness, gastralgia, and abdominal discomfort (numbers reporting each symptom N/S). Four patients on placebo temporarily suspended treatment due to AEs (diarrhea, vomiting, gastralgia), as did one of the same patients on DHE + aspirin (diarrhea).
Bousser, Chick, Fuseau, et al., 1988 | Number of patients evaluable for AEs: | 38* | | 38*
Bousser, Chick, Fuseau, et al., 1988 | Number of patients reporting AEs: | 7 (18%) | | 5 (13%)
Bousser, Chick, Fuseau, et al., 1988 | Total number of AEs reported: | N/S | | N/S
Bousser, Chick, Fuseau, et al., 1988 | Withdrawals due to AEs: | (See note) | | (See note)
Bradley, Hudgson, Foster, et al., 1968 | | Flumedroxone, 10 mg, 3x/day for 3 mos | | Placebo | | Data at left concern only those patients who completed the trial (39/48). Two patients withdrew prematurely due to AEs associated with flumedroxone (severe polymenorrhagia and nausea; mastitis and glandular-fever-like syndrome). AEs reported by male patients in association with flumedroxone included drowsiness, dyspepsia, and decreased libido (no n's reported). Six of 14 women of reproductive age reported polymenorrhagia. One of these six also reported engorgement of the breasts and varicose veins. Flumedroxone vs. placebo: 0.28 (0.078 to 0.46)
Bradley, Hudgson, Foster, et al., 1968 | Number of patients evaluable for AEs: | 39* | | 39*
Bradley, Hudgson, Foster, et al., 1968 | Number of patients reporting AEs: | 17 (44%) | | 6 (15%)
Bradley, Hudgson, Foster, et al., 1968 | Total number of AEs reported: | N/S | | N/S
Bradley, Hudgson, Foster, et al., 1968 | Withdrawals due to AEs: | (See note) | | (See note)
Bredfeldt, Sutherland, and Kruse, 1989 | | Clonidine (Dixarit®), ≈ 0.2 mg/day via 1 transdermal (Catapres TTS-2®) patch/wk for 6 wks | | Placebo | | Investigators reported that "[i]n general, both patches were well tolerated by study participants." Of patients completing the trial, 6 reported skin irritation under clonidine patch; 1 experienced fatigue (treatment N/S); and "several" experienced dry mouth (treatment N/S). No AEs were reported for patients taking placebo. Some patients (number N/S) were also taking OTC meds containing acetaminophen or narcotic preparations prescribed by physicians.
Bredfeldt, Sutherland, and Kruse, 1989 | Number of patients evaluable for AEs: | N/S (See note) | | N/S (See note)
Bredfeldt, Sutherland, and Kruse, 1989 | Number of patients reporting AEs: | N/S | | N/S
Bredfeldt, Sutherland, and Kruse, 1989 | Total number of AEs reported: | N/S | | N/S
Bredfeldt, Sutherland, and Kruse, 1989 | Withdrawals due to AEs: | 3 (overtired) | | 0
Briggs and Millac, 1979 | | Timolol, 10 mg, 2x/day for 12 wks | | Placebo | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Number of patients evaluable for AEs: | 14* (See note) | | 14* (See note) | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Number of patients reporting AEs: | N/S | | N/S | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Total number of AEs reported: | N/S | | N/S | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Number of patients reporting: | n (%) | | n (%) | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Cold extremities | 1 (7%) | | 0 | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Visual disturbance | 0 | | 1 (7%) | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Briggs and Millac, 1979 | Withdrawals due to AEs: | 0 | | 1 (constipation & fluid retention) | | Limited data were provided on AEs. The data at left concern all 14 patients randomized to treatment in this crossover trial.
Buscaino, Sorge, Bussone, et al., 1991 | | DHE (timed-release), 10 mg, 1x/day for 2 mos | | DHE (timed-release), 5 mg, 2x/day for 2 mos | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Number of patients evaluable for AEs: | 45 | | 45 | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Number of patients reporting AEs: | 6 (13%) | | 7 (16%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Total number of AEs reported: | 6 | | | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Number of patients reporting: | n (%) | | n (%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Epigastralgia | 1 (2%) | | 4 (9%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Heartburn | 1 (2%) | | 1 (2%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Nausea | 1 (2%) | | 0 | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Increase in appetite | 1 (2%) | | 1 (2%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Auricular tinnitus | 0 | | 1 (2%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Polyphagism | 0 | | 1 (2%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Paresthesia | 1 (2%) | | 0 | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Rise in diastolic BP | 1 (2%) | | 0 | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Headache | 0 | | 1 (2%) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Buscaino, Sorge, Bussone, et al., 1991 | Withdrawals due to AEs: | 1 (heartburn) | | 4 (epigastralgia [2]; epigastralgia, auricular tinnitus, and polyphagism [1]; heartburn [1]) | | 10 mg, 1x/day vs. 5 mg, 2x/day: −0.022 (−0.17 to 0.12)
Bussone, Baldini, D'Andrea, et al., 1987 | | Nimodipine, 120 mg/day for 12 wks | | Flunarizine, 10 mg/day for 12 wks | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Number of patients evaluable for AEs: | 14 | | 16 | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Number of patients reporting AEs: | 2 (14%) | | 7 (44%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Total number of AEs reported: | 2 | | 9 | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Number of patients reporting: | n (%) | | n (%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Weight increase | 0 | | 5 (31%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Erythema | 0 | | 2 (13%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Abdominal discomfort | 1 (7%) | | 0 | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Exacerbation of insomnia | 1 (7%) | | 0 | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Drowsiness/daytime sedation | 0 | | 1 (6%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Depression | 0 | | 1 (6%) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Bussone, Baldini, D'Andrea, et al., 1987 | Withdrawals due to AEs: | 1 (causative AEs N/S) | | 2 (causative AEs N/S) | | Nimodipine vs. flunarizine: −0.28 (−0.55 to 0.030)
Cangi, Boccuni, Zanotti, et al., 1989 | | Dihydroergokryptine (DEK), 10 mg, 2x/day for 2 mos | | Methysergide, 1 mg, 2x/day for 2 mos | | This was an abstract reporting interim results of a longer-term trial. Regarding AEs, investigators reported only that "both drugs have been well tolerated by patients" (p. 449).
Cangi, Boccuni, Zanotti, et al., 1989 | Number of patients evaluable for AEs: | N/S | | N/S | | This was an abstract reporting interim results of a longer-term trial. Regarding AEs, investigators reported only that "both drugs have been well tolerated by patients" (p. 449).
Cangi, Boccuni, Zanotti, et al., 1989 | Number of patients reporting AEs: | N/S | | N/S | | This was an abstract reporting interim results of a longer-term trial. Regarding AEs, investigators reported only that "both drugs have been well tolerated by patients" (p. 449).
Cangi, Boccuni, Zanotti, et al., 1989 | Total number of AEs reported: | N/S | | N/S | | This was an abstract reporting interim results of a longer-term trial. Regarding AEs, investigators reported only that "both drugs have been well tolerated by patients" (p. 449).
Cangi, Boccuni, Zanotti, et al., 1989 | Withdrawals due to AEs: | N/S | | N/S | | This was an abstract reporting interim results of a longer-term trial. Regarding AEs, investigators reported only that "both drugs have been well tolerated by patients" (p. 449).
Canonico, Scapagnini, Genazzani, et al., 1989 | | Dihydroergokryptine (DEK), 10 mg, 2x/day for 2 mos | | Placebo | | Abstract providing limited information. Dropouts were not described. DEK vs. placebo: 0.039 (−0.0027 to 0.080)
Canonico, Scapagnini, Genazzani, et al., 1989 | Number of patients evaluable for AEs: | 102* | | 102* | | Abstract providing limited information. Dropouts were not described. DEK vs. placebo: 0.039 (−0.0027 to 0.080)
Canonico, Scapagnini, Genazzani, et al., 1989 | Number of patients reporting AEs: | 4 (4%) | | 0 | | Abstract providing limited information. Dropouts were not described. DEK vs. placebo: 0.039 (−0.0027 to 0.080)
Canonico, Scapagnini, Genazzani, et al., 1989 | Total number of AEs reported: | N/S | | 0 | | Abstract providing limited information. Dropouts were not described. DEK vs. placebo: 0.039 (−0.0027 to 0.080)
Canonico, Scapagnini, Genazzani, et al., 1989 | Withdrawals due to AEs: | (See note) | | (See note) | | Abstract providing limited information. Dropouts were not described. DEK vs. placebo: 0.039 (−0.0027 to 0.080)
Carrieri, Orefice, and Sorge, 1988 | | Indobufen, 200 mg, 2x/day for 3 mos | | Placebo | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Number of patients evaluable for AEs: | 18 | | 17 | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Number of patients reporting AEs: | 2 (11%) | | 1 (6%) | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Total number of AEs reported: | 2 | | 1 | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Number of patients reporting: | n (%) | | n (%) | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Transient heartburn | 2 (11%) | | 1 (6%) | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carrieri, Orefice, and Sorge, 1988 | Withdrawals due to AEs: | 0 | | 0 | | Data at left appears to be for those patients who completed 3 mos of treatment (35/40). None of the 5 patients who withdrew prematurely did so due to AEs. Indobufen vs. placebo: 0.049 (−0.15 to 0.24)
Carroll and Maclay, 1975 | | Pizotifen (Sanomigran®), inc'd from 0.5 mg, 1x/day to 0.5 mg, 3x/day for 2 wks or until end of trial -- if relief insufficient, dose increased to 1 mg, 3x/day until end of 2-mo trial | | Placebo | | Investigators reported that of all 27 patients randomized to treatment, 4 reported weight gain (treatment N/S); 2 reported having hemiparaesthesia and apprehension, as well as other (unspecified) AEs, after being treated with placebo. Of 27 patients, several withdrew from the trial. One withdrew after treatment with pizotifen for feeling "drugged, dazed, hungry, and depressed"; 2 withdrew for weight gain (treatment N/S); 1 withdrew because of depression (treatment N/S); and 1 withdrew because of "worsening HA" (treatment N/S).
Carroll and Maclay, 1975 | Number of patients evaluable for AEs: | (See note) | | (See note)
Carroll and Maclay, 1975 | Number of patients reporting AEs: | N/S | | N/S
Carroll and Maclay, 1975 | Total number of AEs reported: | N/S | | N/S
Carroll and Maclay, 1975 | Withdrawals due to AEs: | (See note) | | (See note)
Carroll, Reidy, Savundra, et al., 1990 | | Propranolol (long-acting), 160 mg/day for 12 wks | | Propranolol (long-acting), 80 mg/day for 12 wks | | Four patients reported "tiredness" during the placebo washout period, one of whom withdrew for this reason. Three additional patients withdrew after failure to respond to the trial medication, and five withdrew for unspecified reasons. Propranolol (long-acting) 160 mg vs. propranolol (long-acting) 80 mg: 0.17 (−0.017 to 0.35)
Carroll, Reidy, Savundra, et al., 1990 | Number of patients evaluable for AEs: | 51* (See note) | | 51* (See note)
Carroll, Reidy, Savundra, et al., 1990 | Number of patients reporting AEs: | 27 (53%) | | 18 (35%)
Carroll, Reidy, Savundra, et al., 1990 | Total number of AEs reported: | N/S | | N/S
Carroll, Reidy, Savundra, et al., 1990 | Number of patients reporting: | n (%) | | n (%)
Carroll, Reidy, Savundra, et al., 1990 | Tiredness | 9 (18%) | | 11 (22%)
Carroll, Reidy, Savundra, et al., 1990 | Withdrawals due to AEs: | 3 (dizziness, visual disturbance, insomnia & depression) | | 1 (nausea & drowsiness)
Cerbo, Casacchia, Formisano, et al., 1986 | | Flunarizine, 15 mg/day for 2 mos | | Pizotifen, 1.5 mg/day for 2 mos
Cerbo, Casacchia, Formisano, et al., 1986 | Number of patients evaluable for AEs: | 21* | | 21*
Cerbo, Casacchia, Formisano, et al., 1986 | Number of patients reporting AEs: | N/S | | N/S
Cerbo, Casacchia, Formisano, et al., 1986 | Total number of AEs reported: | 17 | | 24
Cerbo, Casacchia, Formisano, et al., 1986 | Number of patients reporting: | n (%) | | n (%)
Cerbo, Casacchia, Formisano, et al., 1986 | Drowsiness | 9 (43%) | | 10 (48%)
Cerbo, Casacchia, Formisano, et al., 1986 | Weight gain | 4 (19%) | | 11 (52%)
Cerbo, Casacchia, Formisano, et al., 1986 | Asthenia | 2 (10%) | | 2 (10%)
Cerbo, Casacchia, Formisano, et al., 1986 | Constipation | 1 (5%) | | 0
Cerbo, Casacchia, Formisano, et al., 1986 | Xerostomia | 1 (5%) | | 0
Cerbo, Casacchia, Formisano, et al., 1986 | Decrease of libido | 0 | | 1 (5%)
Cerbo, Casacchia, Formisano, et al., 1986 | Withdrawals due to AEs: | 0 | | 4 (weight gain [1], reasons for other three withdrawals N/S)
Couch, Bearss, and Verhulst, 1987 | | Fenoprofen, 600 mg, 3x/day for 12 wks | Fenoprofen, 200 mg, 3x/day for 12 wks | Placebo | | No information provided on AEs.
Couch, Bearss, and Verhulst, 1987 | Number of patients evaluable for AEs: | N/S | N/S | N/S | | No information provided on AEs.
Couch, Bearss, and Verhulst, 1987 | Number of patients reporting AEs: | N/S | N/S | N/S | | No information provided on AEs.
Couch, Bearss, and Verhulst, 1987 | Total number of AEs reported: | N/S | N/S | N/S | | No information provided on AEs.
Couch, Bearss, and Verhulst, 1987 | Withdrawals due to AEs: | N/S | N/S | N/S | | No information provided on AEs.
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 | | Amitriptyline, 50–100 mg/day for 4–8 wks | | Placebo | | Limited information reported (none in interim report [1976]). Patients were questioned about specific AEs. "Dry mouth," "bad taste," and "drowsiness" were significantly more common with amitriptyline. There were no significant differences in the occurrence of other AEs.
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 | Number of patients evaluable for AEs: | 55 | | 61
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 | Number of patients reporting AEs: | N/S | | N/S
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 | Total number of AEs reported: | N/S | | N/S
Couch and Hassanein, 1979 and Couch and Hassanein, 1976 | Withdrawals due to AEs: | 5 (rash [2], hypertension [1], nausea [1], numbness in hands and feet [1]) | | 2 (both chest pain)
Dahlöf, 1987 | | Propranolol, 40 mg, 3x/day for 1 mo | | Placebo | | Limited information was provided on AEs. Patients had been asked to record any central nervous system-related AEs on a visual analog scale. Investigators reported that such AEs were "significantly more frequent during the month of propranolol treatment in comparison to placebo."
Dahlöf, 1987 | Number of patients evaluable for AEs: | 28* (See note) | | 28* (See note)
Dahlöf, 1987 | Number of patients reporting AEs: | N/S | | N/S
Dahlöf, 1987 | Total number of AEs reported: | N/S | | N/S
Dahlöf, 1987 | Withdrawals due to AEs: | 0 | | 0
Das, Ahuja, and Narainaswamy, 1979 | | Clonidine, 25 μg, 2x/day for 6 wks | | Placebo | | Investigators did not report information on withdrawals (for any reason), so data at left concern only those patients who completed the crossover. Investigators reported that "[n]o side effects of clonidine were observed" but did not report whether or not patients taking placebo experienced AEs.
Das, Ahuja, and Narainaswamy, 1979 | Number of patients evaluable for AEs: | 20* | | 20*
Das, Ahuja, and Narainaswamy, 1979 | Number of patients reporting AEs: | N/S | | N/S
Das, Ahuja, and Narainaswamy, 1979 | Total number of AEs reported: | 0 | | N/S
Das, Ahuja, and Narainaswamy, 1979 | Withdrawals due to AEs: | 0 (See note) | | N/S (See note)
De Benedittis and Massei, 1986 | | Oxitriptan, 400 mg/day orally for 2 mos | | Placebo | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Number of patients evaluable for AEs: | 31* | | 31* | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Number of patients reporting AEs: | 5 (16%) | | 6 (19%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Total number of AEs reported: | N/S | | N/S | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Number of patients reporting: | n (%) | | n (%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Gastric distress: | 2 (6%) | | 3 (10%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Drowsiness: | 1 (3%) | | 0 | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Pyrosis: | 1 (3%) | | 0 | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Weight gain: | 1 (3%) | | 0 | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Dizziness: | 0 | | 1 (3%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Palpitations: | 0 | | 1 (3%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Unspecified: | 0 | | 2 (6%) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
De Benedittis and Massei, 1986 | Withdrawals due to AEs: | 0 | | 1 (N/S) | | Data on AEs at left are from the 31/40 patients from whom efficacy data were obtained. Oxitriptan vs. placebo: −0.032 (−0.22 to 0.16)
Dennerstein, Morse, Burrows, et al., 1988 | | Estradiol gel, 1.5 mg/day, 7 days/mo for 2 mos | | Placebo | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Number of patients evaluable for AEs: | 22* | | 22* | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Number of patients reporting AEs: | 4 (18%) | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Total number of AEs reported: | 4 | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Number of patients reporting: | n (%) | | n (%) | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Amenorrhea | 2 (9%) | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Skin rash | 1 (5%) | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Ache in leg | 1 (5%) | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Dennerstein, Morse, Burrows, et al., 1988 | Withdrawals due to AEs: | 2 (skin rash, ache in leg) | | 0 | | Estradiol vs. placebo: 0.18 (0.0013 to 0.34)
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | | Flunarizine, 10 mg/day for 5 mos | | Placebo | | No further information provided on AEs.
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | Number of patients evaluable for AEs: | N/S | | N/S | | No further information provided on AEs.
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | Number of patients reporting AEs: | N/S | | N/S | | No further information provided on AEs.
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | Total number of AEs reported: | N/S | | N/S | | No further information provided on AEs.
Diamond and Freitag, 1993 and Freitag, Diamond, and Diamond, 1991 | Withdrawals due to AEs: | 5 (causative AEs N/S) | | 3 (causative AEs N/S) | | No further information provided on AEs.
Diamond and Medina, 1976 | | Propranolol, 80 (or up to mg 160 mg/day) for 4 wks (or up to 8 wks) | | Placebo | | The data at left concern all patients randomized to treatment in this crossover trial. Investigators reported that “most side effects were transient and clinically unimportant.” AEs occurring on both treatments were nausea, light-headedness, fatigue, difficulty catching breath, mild depression, and heartburn. AEs occurring only after treatment with propranolol were diarrhea, abdominal cramps, irritability, insomnia, and sleepiness. Investigators did not report AEs occurring only after treatment with placebo. One patient treated with the active drug had precordial pain, with a normal electrocardiogram, and blood in sputum and stools. The relationship of these symptoms to propranolol was not proven. Propranolol vs. placebo: 0.072 (−0.036 to 0.18)
Diamond and Medina, 1976 | Number of patients evaluable for AEs: | 83* | | 83*
Diamond and Medina, 1976 | Number of patients reporting AEs: | 15(18%) | | 9 (11 %)
Diamond and Medina, 1976 | Total number of AEs reported: | N/S | | N/S
Diamond and Medina, 1976 | Withdrawals due to AEs: | 6 (N/S) | | 1 (N/S)
Diamond, Solomon, Freitag, et al., 1987 | | Fenoprofen, 600 mg, 3x/day for 12 wks | Fenoprofen, 200 mg, 3x/day for 12 wks | Placebo
Diamond, Solomon, Freitag, et al., 1987 | Number of patients evaluable for AEs: | N/S | N/S | N/S
Diamond, Solomon, Freitag, et al., 1987 | Number of patients reporting AEs: | N/S | N/S | N/S
Diamond, Solomon, Freitag, et al., 1987 | Total number of AEs reported: | N/S | N/S | N/S
Diamond, Solomon, Freitag, et al., 1987 | Number of patients reporting: | n(%) | n (%) | n (%)
Diamond, Solomon, Freitag, et al., 1987 | Gastrointestinal symptoms | N/S (13.5%) | N/S (10%) | N/S (4%)
Diamond, Solomon, Freitag, et al., 1987 | Fatigue and/or somnolence | N/S (4%) | N/S (16%) | N/S (3.3%)
Diamond, Solomon, Freitag, et al., 1987 | Withdrawals due to AEs: | 4 (GI symptoms, 3; fatigue, 1) | 3 (GI symptoms, 3) | 4 GI symptoms, 1; fatigue, 1; photosensitivity, 1; blurred vision, 1)
Ekbom, 1975 | | Alprenolol, 200 mg, 2x/day for 6 wks | | Placebo | | The data at left appear to concern all patients randomized to treatment, but this is not clear. Investigators reported that two additional patients withdrew from treatment with the active drug “because of illness,” but did not clarify whether the illness was considered an AE.
Ekbom, 1975 | Number of patients evaluable for AEs: | 33* (See note) | | 33* (See note)
Ekbom, 1975 | Number of patients reporting AEs: | N/S | | N/S
Ekbom, 1975 | Total number of AEs reported: | N/S | | N/S
Ekbom, 1975 | Number of patients reporting: | n (%) | | n (%)
Ekbom, 1975 | Retrosternal burning sensations on swallowing | 3 (9%) | | 0
Ekbom, 1975 | Perspiration | 2 (6%) | | 0
Ekbom, 1975 | Dryness of mouth | 1 (3%) | | 0
Ekbom, 1975 | Dizziness | 1 (3%) | | 0
Ekbom, 1975 | Tiredness and dizziness | 1 (3%) | | 0
Ekbom, 1975 | Withdrawals due to AEs: | 1 (depression and palpitation) | | N/S
Ekbom and Lundberg, 1972 | | Pindolol, 2.5–5 mg, 3x/day for 1 mo | | Placebo | | No further information provided. Data on withdrawals due to AEs were not reported separately for the two doses of pindolol.
Ekbom and Lundberg, 1972 | Number of patients evaluable for AEs: | 20 | | 10 | | No further information provided. Data on withdrawals due to AEs were not reported separately for the two doses of pindolol.
Ekbom and Lundberg, 1972 | Number of patients reporting AEs: | N/S | | N/S | | No further information provided. Data on withdrawals due to AEs were not reported separately for the two doses of pindolol.
Ekbom and Lundberg, 1972 | Total number of AEs reported: | N/S | | N/S | | No further information provided. Data on withdrawals due to AEs were not reported separately for the two doses of pindolol.
Ekbom and Lundberg, 1972 | Withdrawals due to AEs: | 4 (orthostatic hypotension [2], increased HA [1], dizziiness and cystopyelitis [1]) | | 0 | | No further information provided. Data on withdrawals due to AEs were not reported separately for the two doses of pindolol.
Ekbom and Zetterman, 1977 | | Oxprenolol, 80 mg, 3x/day for 2 mos | | Placebo | | Investigators stated only that “no serious side-effects were noted” (p. 183).
Ekbom and Zetterman, 1977 | Number of patients evaluable for AEs: | 34* | | 34* | | Investigators stated only that “no serious side-effects were noted” (p. 183).
Ekbom and Zetterman, 1977 | Number of patients reporting AEs: | N/S | | N/S | | Investigators stated only that “no serious side-effects were noted” (p. 183).
Ekbom and Zetterman, 1977 | Total number of AEs reported: | N/S | | N/S | | Investigators stated only that “no serious side-effects were noted” (p. 183).
Ekbom and Zetterman, 1977 | Withdrawals due to AEs: | 0 | | 0 | | Investigators stated only that “no serious side-effects were noted” (p. 183).
Elkind, Webster, Herbertson, et al., 1989a | | Guanfacine, 1.0 mg/day for 12 wks | Guanfacine, 0.5 mg/day for 12 wks | Placebo | | Three patients withdrew due to unspecified AEs. Investigators did not identify treatment groups from which patients withdrew, but reported that no AEs were “serious.”
Elkind, Webster, Herbertson, et al., 1989a | Number of patients evaluable for AEs: | 12 | 13 | 12 | | Three patients withdrew due to unspecified AEs. Investigators did not identify treatment groups from which patients withdrew, but reported that no AEs were “serious.”
Elkind, Webster, Herbertson, et al., 1989a | Number of patients reporting AEs: | N/S | N/S | N/S | | Three patients withdrew due to unspecified AEs. Investigators did not identify treatment groups from which patients withdrew, but reported that no AEs were “serious.”
Elkind, Webster, Herbertson, et al., 1989a | Total number of AEs reported: | N/S | N/S | N/S | | Three patients withdrew due to unspecified AEs. Investigators did not identify treatment groups from which patients withdrew, but reported that no AEs were “serious.”
Elkind, Webster, Herbertson, et al., 1989a | Withdrawals due to AEs: | N/S (See note) | N/S (See note) | N/S (See note) | | Three patients withdrew due to unspecified AEs. Investigators did not identify treatment groups from which patients withdrew, but reported that no AEs were “serious.”
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | | Tropisetron 50 mg/day for 3 mos | Tropisetron, 25 mg/day for 3 mos | Placebo | | Investigators reported that they assessed all patients randomized to treatment for AEs. Data at left concern the 7/146 patients (5%) who withdrew due to AEs, who were excluded from efficacy analyses. Additional AEs reported were constipation in 54, 55, and 9 cases occurring in the tropisetron 50 mg, tropisetron 25 mg, and placebo groups, respectively. “Other” unspecified AEs were reported in 33, 19, and 24 cases in patients treated with tropisetron 50 mg, tropisetron 25 mg, and placebo, respectively. In 13 patients (tropisetron 50 mg, 7; tropisetron 25 mg, 5; placebo, 1), constipation led to the reduction of the dose by 0.5–1 capsule every other day.
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Number of patients evaluable for AEs: | 50 (See note) | 47 (See note) | 49 (See note)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Number of patients reporting AEs: | N/S | N/S | N/S
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Total number of AEs reported: | 87 | 74 | 33
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Number of patients withdrawing due to: | n (%) | n (%) | n (%)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Constipation | 2 (4%) | 2 (4%) | 0
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Skin reaction | 2 (4%) | 0 | 0
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Tremor (hands/foot) | 0 | 0 | 1 (2%)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 1 | Withdrawals due to AEs: | 4 (listed above) | 2 (listed above) | 1 (listed above)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | | Tropisetron, 15 mg/day for 3 mos | | Placebo | | Investigators reported that they assessed all patients randomized to treatment for AEs. Data at left concern the 3/58 patients (5%) who withdrew due to AEs, who were excluded from efficacy analyses. Additional AEs reported were constipation in 42 cases occurring in the group treated with tropisetron 15 mg. No cases of constipation were reported in the placebo group. “Other” unspecified AEs were reported in 37 and 35 cases in patients treated with tropisetron 15 mg and placebo, respectively.
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Number of patients evaluable for AEs: | 38 (See note) | | 20 (See note)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Number of patients reporting AEs: | N/S | | N/S
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Total number of AEs reported: | 79 | | 35
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Number of patients withdrawing due to: | n (%) | | n (%)
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Constipation | 1 (3%) | | 0
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Hypoglycemia | 1 (3%) | | 0
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Nausea/vomiting | 1 (3%) | | 0
Ferrari, Wilkinson, Hirt, et al., 1991 Study 2 | Withdrawals due to AEs: | 3 (listed above) | | 0
Fiorini, Sances, Martignoni, et al., 1991 | | Dihydroergokryptine (DEK), 10 mg, 2x/day for 2 mos | | Placebo | | Abstract reporting limited information. No data reported on AEs.
Fiorini, Sances, Martignoni, et al., 1991 | Number of patients evaluable for AEs: | 20* | | 20* | | Abstract reporting limited information. No data reported on AEs.
Fiorini, Sances, Martignoni, et al., 1991 | Number of patients reporting AEs: | N/S | | N/S | | Abstract reporting limited information. No data reported on AEs.
Fiorini, Sances, Martignoni, et al., 1991 | Total number of AEs reported: | N/S | | N/S | | Abstract reporting limited information. No data reported on AEs.
Fiorini, Sances, Martignoni, et al., 1991 | Withdrawals due to AEs: | 0 | | 0 | | Abstract reporting limited information. No data reported on AEs.
Formisano, Falaschi, Cerbo, et al., 1991 | | Nimodipine, 120 mg/day for 4 mos | | Propranolol, 120 mg/day for 4 mos
Formisano, Falaschi, Cerbo, et al., 1991 | Number of patients evaluable for AEs: | 12 | | 10
Formisano, Falaschi, Cerbo, et al., 1991 | Number of patients reporting AEs: | N/S | | N/S
Formisano, Falaschi, Cerbo, et al., 1991 | Total number of AEs reported: | 12 | | 6
Formisano, Falaschi, Cerbo, et al., 1991 | Number of patients reporting: | n (%) | | n (%)
Formisano, Falaschi, Cerbo, et al., 1991 | Gastric discomfort | 4 (33%) | | 0
Formisano, Falaschi, Cerbo, et al., 1991 | Paraesthesia | 2 (17%) | | 1 (10%)
Formisano, Falaschi, Cerbo, et al., 1991 | Weight gain | 2(17%) | | 0
Formisano, Falaschi, Cerbo, et al., 1991 | Flushing | 2(17%) | | 0
Formisano, Falaschi, Cerbo, et al., 1991 | Menstrual irregularities | 1 (8%) | | 1 (10%)
Formisano, Falaschi, Cerbo, et al., 1991 | Dizziness | 0 | | 2 (20%)
Formisano, Falaschi, Cerbo, et al., 1991 | Insomnia | 1 (8%) | | 0
Formisano, Falaschi, Cerbo, et al., 1991 | Arterial hypotension | 0 | | 1 (10%)
Formisano, Falaschi, Cerbo, et al., 1991 | Asthma | 0 | | 1 (10%)
Formisano, Falaschi, Cerbo, et al., 1991 | Withdrawals due to AEs: | 1(flushing) | | 2(arterial hypotension [1], asthma [1])
Forssman, Henriksson, Johannsson, et al., 1976 | | Propranolol, 80 mg, 3x/day for 10 wks (gradually increased) | | Placebo
Forssman, Henriksson, Johannsson, et al., 1976 | Number of patients evaluable for AEs: | 38* | | 38*
Forssman, Henriksson, Johannsson, et al., 1976 | Number of patients reporting AEs: | N/S | | N/S
Forssman, Henriksson, Johannsson, et al., 1976 | Total number of AEs reported: | 22 | | 9
Forssman, Henriksson, Johannsson, et al., 1976 | Number of patients reporting: | n (%) | | n (%)
Forssman, Henriksson, Johannsson, et al., 1976 | Increase in weight > 2 kg | 5 (13%) | | 0
Forssman, Henriksson, Johannsson, et al., 1976 | Insomnia | 5 (13%) | | 1 (3%)
Forssman, Henriksson, Johannsson, et al., 1976 | Tiredness | 4 (11%) | | 3 (8%)
Forssman, Henriksson, Johannsson, et al., 1976 | Uncharacteristic dizziness | 3 (8%) | | 2 (5%)
Forssman, Henriksson, Johannsson, et al., 1976 | Feeling of numbness, paraesthesiae | 2 (5%) | | 1 (3%)
Forssman, Henriksson, Johannsson, et al., 1976 | Nausea | 2 (5%) | | 1 (3%)
Forssman, Henriksson, Johannsson, et al., 1976 | Increased appetite | 1 (3%) | | 0
Forssman, Henriksson, Johannsson, et al., 1976 | Palpitations | 1 (3%) | | 1 (3%)
Forssman, Henriksson, Johannsson, et al., 1976 | Withdrawals due to AEs: | 2 (tiredness, dizziness) | | 2 (tiredness, dizziness)
Forssman, Henriksson, and Kihlstrand, 1972 | | Pizotifen, 2–3 mg/day for 10 wks | | Methysergide, 4–6 mg/day For 10 wks | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Number of patients evaluable for AEs: | 22* | | 22* | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Number of patients reporting AEs: | 20 (91%) | | 20 (91%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Total number of AEs reported: | 19 | | 25 | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Number of patients reporting: | n (%) | | n (%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Drowsiness | 9 (41%) | | 8 (36%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Increased appetite and weight gain | 6 (27%) | | 3 (14%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Nausea | 0 | | 5 (23%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Dizziness | 2 (9%) | | 1 (5%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Diarrhea | 1 (5%) | | 2 (9%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Depression | 0 | | 3 (14%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Feelings of irritation | 1 (5%) | | 1 (5%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Feeelings of tightness | 0 | | 2 (9%) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Henriksson, and Kihlstrand, 1972 | Withdrawals due to AEs: | 1 (See note) | | 1 (See note) | | One patient suspended treatment during both treatment periods due to AEs (drowsiness and irritation). Pizotifen vs. methysergide: 0(−0.18 to 0.18)
Forssman, Lindblad, and Zbornikova, 1983 | | Atenolol, 100 mg/day for 3 mos | | Placebo | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Number of patients evaluable for AEs: | 24* (See note) | | 24* (See note) | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Number of patients reporting AEs: | N/S | | N/S | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Total number of AEs reported: | N/S | | N/S | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Number of patients reporting: | n (%) | | n (%) | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Slight dizziness of orthostatic type | 6 (25%) | | 1 (4%) | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Diffuse tiredness | 2 (8%) | | 0 | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Forssman, Lindblad, and Zbornikova, 1983 | Withdrawals due to AEs: | 1 (mood alterations) | | N/S | | The data at left appear to concern all 24 patients randomized to treatment in this crossover trial, but this is not clear.
Frediani, Grazzi, Zanotti, et al., 1991 | | Dihydroergokryptine (DEK), 10 mg, 2x/day for 4 mos | | DHE (timed-release), 5 mg, 2x/day for 4 mos | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Number of patients evaluable for AEs: | 29* | | 29* | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Number of patients reporting AEs: | 7 (24%) | | 5 (17%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Total number of AEs reported: | 8 | | 6 | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Number of patients reporting: | n (%) | | n (%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Gastric pain | 3 (10%) | | 1 (3%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Constipation | 2 (7%) | | 2 (7%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Nausea | 2 (7%) | | 1 (3%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Dizziness | 1 (3%) | | 0 | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Malaise | 0 | | 1 (3%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Skin rash | 0 | | 1 (3%) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Frediani, Grazzi, Zanotti, et al., 1991 | Withdrawals due to AEs: | 3 (gastric pain and/or nausea) | | 1 (skin rash) | | DEK vs. DHE: 0.067 (−0.14 to 0.27)
Freitag and Diamond, 1984 | | Nadolol, up to 240 mg/day (3 groups combined) for 3 mos | | Placebo | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Number of patients evaluable for AEs: | 24 | | 8 | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Number of patients reporting AEs: | 4 (17%) | | N/S | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Total number of AEs reported: | 5 (21%) | | N/S | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Fatigue | 3 (13%) | | N/S | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Bradycardia | 1 (4%) | | N/S | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Freitag and Diamond, 1984 | Withdrawals due to AEs: | 1 (See note) | | N/S | | Investigators reported that one patient developed a significant bradycardia (≤ 45 beats per minute). Medication was discontinued and the patient was subsequently dropped from the study.
Frenken and Nuijten, 1984 | | Flunarizine, 10 mg/day for 12 wks | | Placebo | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Number of patients evaluable for AEs: | 17 | | 18 | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Number of patients reporting AEs: | 10 (59%) | | 8 (44%) | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Total number of AEs reported: | 12 | | 8 | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Number of patients reporting: | n (%) | | n (%) | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Daytime sedation | 7 41%) | | 3 (17%) | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Weight gain | 3 (18%) | | 0 | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Stomach complaints | 0 | | 4 (22%) | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Other | 2 (12%) | | 1 (6%) | | Flunarizine vs. placebo: 0.14 (− 0.44)
Frenken and Nuijten, 1984 | Withdrawals due to AEs: | 0 | | 0 | | Flunarizine vs. placebo: 0.14 (− 0.44)
Gawel, 1987 | | Nimodipine, 120 mg/day for 3 mos | | Pizotifen, 3 mg/day for 3 mos | | Abstract reporting limited results. The most common AEs associated with nimodipine were nausea and flushing, and with pizotifen, weight gain and sedation. Six patients overall withdrew prematurely, but it is not clear how many (if any) of these were due to AEs. Nimodipine vs. pizotifen: 0.099 (−0.26)
Gawel, 1987 | Number of patients evaluable for AEs: | 60* | | 60*
Gawel, 1987 | Number of patients reporting AEs: | 21 (35%) | | 15 (25%)
Gawel, 1987 | Total number of AEs reported: | N/S | | N/S
Gawel, 1987 | Withdrawals due to AEs: | N/S | | N/S
Gawel, Kreeft, Nelson, et al, 1992 | | Flunarizine, 10 mg/day for 4 mos | | Propranolol, 160 mg/day for mos | | Investigators did not provide a numerical breakdown of specific AEs, but reported that propranolol was associated with a greater incidence of dizziness, hypoaesthesia, insomnia, agitation, nausea, diarrhea, and dyspepsia. Fatigue and weight gain were more common in the flunarizine group. The incidence of depression was comparable in the two groups (3.3%).
Gawel, Kreeft, Nelson, et al, 1992 | Number of patients evaluable for AEs: | 44 | | 45
Gawel, Kreeft, Nelson, et al, 1992 | Number of patients reporting AEs: | 33 (75%) | | 36 (80%)
Gawel, Kreeft, Nelson, et al, 1992 | Total number of AEs reported: | N/S | | N/S
Gawel, Kreeft, Nelson, et al, 1992 | Withdrawals due to AEs: | 3 (depression, weight gain, fatigue) | | 5 (bloating, weight gain; bloating; rash; increased HA; increased HA, depression)
Gelmers, 1983 | | Nimodipine, 40 mg, 3x/day for 3 mos | | Placebo | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Number of patients evaluable for AEs: | 30 | | 30 | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Number of patients reporting AEs: | 6 (20%) | | 9 (30%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Total number of AEs reported: | 6 | | 19 | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Number of patients reporting: | n (%) | | n (%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Vertigo and/or dizziness | 0 | | 6 (20%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Abdominal discomfort | 5 (17%) | | 0 | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Weight loss | 1 (3%) | | 0 | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Back pain | 0 | | 1 (3%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Blurred vision | 0 | | 1 (3%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Derealization | 0 | | 1 (3%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Bifrontal HA | 0 | | 1 (3%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Total body pruritus | 0 | | 1 (3%) | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gelmers, 1983 | Withdrawals due to AEs: | 0 | | 0 | | Nimodipine vs. placebo: −0.098 (−0.31 to 0.12)
Gerber, Diener, Scholz, et al., 1991 | | Nifedipine, 40 mg/day for 2 mos | Metoprolol, 200 mg/day for 2 mos | Propranolol, 160 mg/day for 2 mos | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Number of patients evaluable for AEs: | N/S | N/S | N/S | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Number of patients reporting AEs: | N/S | N/S | N/S | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Total number of AEs reported: | N/S | N/S | N/S | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Number of patients reporting: | n (%) | n (%) | n (%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Fatigue | (38%) | (60%) | (33%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Vertigo | (32%) | (20%) | (22%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Sleep disorders | (9%) | (10%) | (11%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Body weight increase | (15%) | (5%) | (11%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Circulatory disturbances | (8%) | (5%) | (28%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Swollen legs | (31%) | 0 | (5%) | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Diener, Scholz, et al., 1991 | Withdrawals due to AEs: | N/S | 0 | N/S | | AEs reported for high-dosage phase of trial only. Percentages at left are estimated from graph.
Gerber, Schellenberg, Thom, et al., 1995 | | Cyclandelate, 1200 mg/day for 8 wks, 1600 mg/day for 8 wks | | Propranolol, 120 mg/day for 8 wks, 160 mg/day for 8 wks | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Number of patients evaluable for AEs: | 42 | | 42 | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Number of patients reporting AEs: | 4 (10%) | | 6 (14%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Total number of AEs reported: | 6 | | 8 | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Number of patients reporting: | n (%) | | n (%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Allergic reaction/exanthema | 1 (2%) | | 3 (7%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | GI or cardiovascular problems | 1 (2%) | | 3 (7%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Dizziness | 2 (5%) | | 1 (2%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Worsening of HA | 1 (2%) | | 0 | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Tiredness/loss of motivation | 0 | | 1 (2%) | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Excessive thirst | 1 (2%) | | 0 | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gerber, Schellenberg, Thom, et al., 1995 | Withdrawals due to AEs: | N/S | | N/S | | The only AEs described were those deemed by the investigators to be drug-related. Cyclandelate vs. propranolol: −0.047 (−0.18 to 0.093)
Gomersall and Stuart, 1973 | | Amitriptyline, 30–60 mg/day for 27 wks | | Placebo | | Data reported at left are for the 20 patients (of 26) who completed the trial. One patient withdrew prematurely due to increased HAs while taking placebo. Amitriptyline vs. placebo: 0.15 (−0.13 to 0.40)
Gomersall and Stuart, 1973 | Number of patients evaluable for AEs: | 20* | | 20*
Gomersall and Stuart, 1973 | Number of patients reporting AEs: | 16 (80%) | | 13 (65%)
Gomersall and Stuart, 1973 | Total number of AEs reported: | 26 | | 15
Gomersall and Stuart, 1973 | Number of patients reporting: | n (%) | | n (%)
Gomersall and Stuart, 1973 | Drowsiness | 10 (50%) | | 4 (20%)
Gomersall and Stuart, 1973 | Dry mouth | 7 (35%) | | 2 (10%)
Gomersall and Stuart, 1973 | Nausea | 2 (10%) | | 2 (10%)
Gomersall and Stuart, 1973 | Increased HAs | 1 (5%) | | 3 (15%)
Gomersall and Stuart, 1973 | Weight gain | 1 (5%) | | 2 (10%)
Gomersall and Stuart, 1973 | Depression | 1 (5%) | | 1 (5%)
Gomersall and Stuart, 1973 | Hypertension | 1 (5%) | | 1 (5%)
Gomersall and Stuart, 1973 | Constipation | 1 (5%) | | 0
Gomersall and Stuart, 1973 | Disturbing dreams | 1 (5%) | | 0
Gomersall and Stuart, 1973 | Dizziness | 1 (5%) | | 0
Gomersall and Stuart, 1973 | Withdrawals due to AEs: | 0 | | (See note)
Grotemeyer, Scharafinski, Schlake, et al., 1990 | | Aspirin, 500 mg, 3x/day for 3 mos | | Metoprolol, 200 mg, 1x/day for 3 mos | | Investigators reported data only on those patients who withdrew from the trial due to AEs.
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Number of patients evaluable for AEs: | 28* | | 28* | | Investigators reported data only on those patients who withdrew from the trial due to AEs.
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported data only on those patients who withdrew from the trial due to AEs.
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Total number of AEs reported: | N/S | | N/S | | Investigators reported data only on those patients who withdrew from the trial due to AEs.
Grotemeyer, Scharafinski, Schlake, et al., 1990 | Withdrawals due to AEs: | 5 (gastrointestinal AEs) | | 2 (drowsiness) | | Investigators reported data only on those patients who withdrew from the trial due to AEs.
Grotemeyer, Schlake, and Husstedt, 1989 | | Etilefrene pivalate, 20 mg/day for 3 mos | | Flunarizine, 5 mg/day for 3 mos | | Abstract reporting limited results.
Grotemeyer, Schlake, and Husstedt, 1989 | Number of patients evaluable for AEs: | N/S | | N/S | | Abstract reporting limited results.
Grotemeyer, Schlake, and Husstedt, 1989 | Number of patients reporting AEs: | N/S | | N/S | | Abstract reporting limited results.
Grotemeyer, Schlake, and Husstedt, 1989 | Total number of AEs reported: | N/S | | N/S | | Abstract reporting limited results.
Grotemeyer, Schlake, and Husstedt, 1989 | Withdrawals due to AEs: | 0 | | 1 (gastritis) | | Abstract reporting limited results.
Grotemeyer, Schlake, Husstedt, et al., 1987 | | Flunarizine, 10 mg/day for 3 mos | | Metoprolol, 200 mg/day for 3 mos | | Abstract reporting limited results. Some (unspecified number of) patients in both groups reported weight gain, which was more pronounced with flunarizine than with metoprolol (2.6% vs. 0.8% on average).
Grotemeyer, Schlake, Husstedt, et al., 1987 | Number of patients evaluable for AEs: | 28* | | 28*
Grotemeyer, Schlake, Husstedt, et al., 1987 | Number of patients reporting AEs: | N/S | | N/S
Grotemeyer, Schlake, Husstedt, et al., 1987 | Total number of AEs reported: | N/S | | N/S
Grotemeyer, Schlake, Husstedt, et al., 1987 | Withdrawals due to AEs: | 0 | | 2 (hypotonic reaction)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | | Nimodipine, 120 mg/day for 8 wks | | Placebo | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Number of patients evaluable for AEs: | 33* | | 33* | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Number of patients reporting AEs: | N/S | | N/S | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Total number of AEs reported: | N/S | | N/S | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Number of patients reporting: | n (%) | | n (%) | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Vertigo | 3 (9%) | | N/S | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Flushing | 2 (6%) | | N/S | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Itching | 1 (3%) | | N/S | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1985b | Withdrawals due to AEs: | 0 | | 0 | | Limited information was provided on AEs. Investigators reported that "no marked side effects were reported." Patients recorded possible AEs in their HA diaries.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | | Nimodipine, 120 mg/day for 3 mos | | Plzotifen, 1.5 mg/day for 3 mos
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Number of patients evaluable for AEs: | 50* | | 50*
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Number of patients reporting AEs: | N/S | | N/S
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Total number of AEs reported: | N/S | | N/S
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Number of patients reporting: | n (%) | | n (%)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Weight gain | 0 | | 16 (32%)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Fatigue | 0 | | 5 (10%)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Vertigo | 0 | | 4 (8%)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Nausea | 0 | | 4 (8%)
Havanka-Kanniainen, Hokkanen, and Myllylä, 1987 | Withdrawals due to AEs: | 0 | | 0
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | | Propranolol (long-acting), 160 mg, 1x/day for 3 mos | | Propranolol (long-acting), 80 mg, 1x/day for 3 mos | | Limited information reported on AEs. 1 patient withdrew due to AEs (nausea, vomiting, tiredness, and insomnia) associated with propranolol (dose N/S). Other side effects reported included cold hands and feet, fatigue, and vivid dreams.
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Number of patients evaluable for AEs: | 48* | | 48*
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Number of patients reporting AEs: | N/S | | N/S
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Total number of AEs reported: | N/S | | N/S
Havanka-Kanniainen, Hokkanen, and Myllylä, 1988 | Withdrawals due to AEs: | (See note) | | (See note)
Hering and Kuritzky, 1992 | | Sodium valproate, 400 mg, 2x/day for 8 wks | | Placebo | | Figures at left are for those patients who completed the trial (29/32). Three patients withdrew prematurely due to unspecified AEs, one while taking sodium valproate and two while taking placebo. Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.13 (−0.044 to 0.30)
Hering and Kuritzky, 1992 | Number of patients evaluable for AEs: | 29* | | 29*
Hering and Kuritzky, 1992 | Number of patients reporting AEs: | 6 (21%) | | 2 (7%)
Hering and Kuritzky, 1992 | Total number of AEs reported: | N/S | | N/S
Hering and Kuritzky, 1992 | Number of patients reporting: | n (%) | | n (%)
Hering and Kuritzky, 1992 | Dyspepsia | 2 (7%) | | 0
Hering and Kuritzky, 1992 | Nausea | 2 (7%) | | 0
Hering and Kuritzky, 1992 | Mild weariness | 2 (7%) | | 0
Hering and Kuritzky, 1992 | Constipation | 0 | | 1 (3%)
Hering and Kuritzky, 1992 | Dizziness | 0 | | 1 (3%)
Hering and Kuritzky, 1992 | Withdrawals due to AEs: | (See note) | | (See note)
Herrmann, Horowski, Dannehl, et al., 1977 | | Lisuride, 25 mcg, 3x/day for 3 mos | | Methysergide, 2 mg, 3x/day for 3 mos | | Detailed information was provided only about those AEs that led patients to withdraw from the trial. Investigators reported that the difference in the number of patients withdrawing due to AEs was significant (p<0.05). Data on AEs were collected at monthly clinic visits, where patients were specifically asked about AEs commonly associated with ergot therapy. Investigators acknowledged that this may have had the effect of increasing the overall frequency of reported AEs.
Herrmann, Horowski, Dannehl, et al., 1977 | Number of patients evaluable for AEs: | 130 | | 123
Herrmann, Horowski, Dannehl, et al., 1977 | Number of patients reporting AEs: | N/S | | N/S
Herrmann, Horowski, Dannehl, et al., 1977 | Total number of AEs reported: | N/S | | N/S
Herrmann, Horowski, Dannehl, et al., 1977 | Number of patients withdrawing due to: | n (%) | | n (%)
Herrmann, Horowski, Dannehl, et al., 1977 | Nausea | 7 (5%) | | 21 (17%)
Herrmann, Horowski, Dannehl, et al., 1977 | Vomiting | 2 (2%) | | 18 (15%)
Herrmann, Horowski, Dannehl, et al., 1977 | Dizziness | 3 (2%) | | 16 (13%)
Herrmann, Horowski, Dannehl, et al., 1977 | Gastrointestinal complaints | 6 (5%) | | 10 (8%)
Herrmann, Horowski, Dannehl, et al., 1977 | Drowsiness | 4 (3%) | | 5 (4%)
Herrmann, Horowski, Dannehl, et al., 1977 | Myalgia and neuralgia | 0 | | 6 (5%)
Herrmann, Horowski, Dannehl, et al., 1977 | Paraesthesia | 0 | | 5 (4%)
Herrmann, Horowski, Dannehl, et al., 1977 | Tachycardia | 0 | | 4 (3%)
Herrmann, Horowski, Dannehl, et al., 1977 | Angina-like symptoms | 0 | | 3 (2%)
Herrmann, Horowski, Dannehl, et al., 1977 | Eye pain | 0 | | 3 (2%)
Herrmann, Horowski, Dannehl, et al., 1977 | Tiredness | 0 | | 3 (2%)
Herrmann, Horowski, Dannehl, et al., 1977 | Withdrawals due to AEs: | 22 (See note) | | 48 (See note)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | | Lisuride, dose gradually increased during first wk of trial up to 0.075 mg/day for 6 mos | | Placebo | | The data at left appear to concern all 240 patients randomized to treatment, not just the 214 from whom efficacy data were obtained; however, this is not clear. The AEs at left are those for which significant differences were found between the treatments. Investigators stated that significant differences had also been noted between the two treatments for these AEs prior to treatment. Investigators reported having "examined" other AEs both prior to and during the trial, but it is not clear whether or not those AEs were reported by patients. The other AEs were: euphoria, nausea, sleep disturbances, dryness of mouth, dysphoric mood, diarrhea, stenocardial complaints, numbness, hallucinations, hot flushes, muscular weakness and pains, and vomiting.
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Number of patients evaluable for AEs: | 103 (See note) | | 111 (See note)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Number of patients reporting AEs: | N/S | | N/S
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Total number of AEs reported: | N/S | | N/S
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Number of patients reporting: | n (%) | | n (%)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Cold feelings in extremities | 44 (43%) | | 13 (12%)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Skin manifestations | 14 (14%) | | 6 (5%)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Tachycardia | 12 (12%) | | 6 (5%)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Vertigo | 25 (24%) | | 7 (6%)
Herrmann, Krištof, and Sastre y Hernandez, 1978 | Withdrawals due to AEs: | 2 (N/S) | | 0
Hübbe, 1973 | | Pizotifen, 1 mg, 3x/day for 8 wks | | Prochlorperazine, 5 mg, 3x/day for 8 wks | | Data at left are for those patients who completed the trial and were included in the efficacy analysis. Three patients withdrew before completing the trial, one due to lack of efficacy and two for unknown reasons.
Hübbe, 1973 | Number of patients evaluable for AEs: | 40* | | 40*
Hübbe, 1973 | Number of patients reporting AEs: | N/S | | N/S
Hübbe, 1973 | Total number of AEs reported: | 76 | | 33
Hübbe, 1973 | Number of patients reporting: | n (%) | | n (%)
Hübbe, 1973 | Weight gain | 29 (73%) | | 16 (40%)
Hübbe, 1973 | Drowsiness | 19 (48%) | | 9 (23%)
Hübbe, 1973 | Increased appetite | 8 (20%) | | 1 (3%)
Hübbe, 1973 | Irritability | 6 (15%) | | 2 (5%)
Hübbe, 1973 | Dizziness | 5 (13%) | | 3 (8%)
Hübbe, 1973 | Dyspepsia | 3 (8%) | | o
Hübbe, 1973 | Hot flushes | 1 (3%) | | 2 (5%)
Hübbe, 1973 | Edema | 2 (5%) | | o
Hübbe, 1973 | Paresthesia | 2 (5%) | | o
Hübbe, 1973 | Palpitations | 1 (3%) | | o
Hübbe, 1973 | Withdrawals due to AEs: | (See note) | | (See note)
Hudgson, Foster, and Newell, 1967 | | Flumedroxone, 5 mg, 3x/day for 4 mos | | Methysergide, 1 mg, 3x/day for 4 mos | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Number of patients evaluable for AEs: | 40* | | 40* | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Number of patients reporting AEs: | 9 (23%) | | 1 (3%) | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Total number of AEs reported: | 15 | | 0 | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Number of patients reporting: | n(%) | | n (%) | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Polymenorrhea | 5(13%) | | 0 | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Worsening of HA | 3 (8%) | | o | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Nausea, vomiting, and vertigo | 0 | | 1 (3%) | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hudgson, Foster, and Newell, 1967 | Withdrawals due to AEs: | 4 (worsening of HA [3], syncope [1]) | | 1 nausea, vomiting, and vertigo) | | Flumedroxone vs. methysergide: 0.20 (0.053 to 0.33)
Hughes and Foster. 1971 | | Pizotifen (BC105), inc'd from 0.5 mg, 1x/day to 0.5 mg. 3x/day for 10 days; then 1 mg, 3x/day for 6 wks | | Placebo
Hughes and Foster. 1971 | Number of patients evaluable for AEs: | 26* | | 26*
Hughes and Foster. 1971 | Number of patients reporting AEs: | N/S | | N/S
Hughes and Foster. 1971 | Total number of AEs reported: | N/S | | N/S
Hughes and Foster. 1971 | Number of patients reporting: | n (%) | | n (%)
Hughes and Foster. 1971 | Facial flushing | 1 (4%) | | N/S
Hughes and Foster. 1971 | Increased appetite (voracious) | 2 (8%) | | 0
Hughes and Foster. 1971 | Increased tiredness | 5 (19%) | | N/S
Hughes and Foster. 1971 | Increased vomiting | 1 (4%) | | N/S
Hughes and Foster. 1971 | Increased weight gain | 10 (38%) | | 0
Hughes and Foster. 1971 | Withdrawals due to AEs: | 0 | | 0
Jacobs, 1972 | | Opipramol. 50 mg. 3x/day for 12 wks | | Placebo | | No patients known to have withdrawn due to AEs; no further information provided.
Jacobs, 1972 | Number of patients evaluable for AEs: | N/S | | N/S | | No patients known to have withdrawn due to AEs; no further information provided.
Jacobs, 1972 | Number of patients reporting AEs: | N/S | | N/S | | No patients known to have withdrawn due to AEs; no further information provided.
Jacobs, 1972 | Total number of AEs reported: | N/S | | N/S | | No patients known to have withdrawn due to AEs; no further information provided.
Jacobs, 1972 | Withdrawals due to AEs: | 0 | | 0 | | No patients known to have withdrawn due to AEs; no further information provided.
Jensen, Brinck, and Olesen, 1994 | | Sodium valproate (slow-release), 1000–1500 mg/day for 12 wks | | Placebo | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Number of patients evaluable for AEs: | 43* | | 43* | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Number of patients reporting AEs: | 14 (33%) | | 7 (16%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Total number of AEs reported: | N/S | | N/S | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Number of patients reporting: | n (%) | | n (%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Nausea | 5 (12%) | | 2 (5%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Drowsiness | 5 (12%) | | 2 (5%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Weight gain | 3 (7%) | | 1 (2%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Vertigo | 3 (7%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Abdominal pain | 2 (5%) | | 1 (2%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Increased appetite | 1 (2%) | | 1 (2%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Diarrhea | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Restless legs | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Dry mouth | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Tremor | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Pain in neck/shoulders | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Dyspnea | 1 (2%) | | 0 | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Tinnitus | 0 | | 1 (2%) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Jensen, Brinck, and Olesen, 1994 | Withdrawals due to AEs: | 4 (nausea [3], vertigo [2]. weight gain [1]. dry mouth [1], tremor [1]) | | 2 (abdominal pain [1], weight gain [1], increased appetite [1]) | | Data on AEs were collected during monthly clinic visits. Sodium valproate vs. placebo: 0.16 (−0.020 to 0.33)
Johannsson, Nilsson, Widelius, et al., 1987 | | Atenolol, 100 mg, 1x/day for 3 mos | | Placebo | | No further information provided on AEs.
Johannsson, Nilsson, Widelius, et al., 1987 | Number of patients evaluable for AEs: | 63* | | 63* | | No further information provided on AEs.
Johannsson, Nilsson, Widelius, et al., 1987 | Number of patients reporting AEs: | N/S | | N/S | | No further information provided on AEs.
Johannsson, Nilsson, Widelius, et al., 1987 | Total number of AEs reported: | N/S | | N/S | | No further information provided on AEs.
Johannsson, Nilsson, Widelius, et al., 1987 | Withdrawals due to AEs: | 0 | | 3 (intolerable HA [1], nausea and fatigue [1], sleep disturbances [1]) | | No further information provided on AEs.
Johnson, Hornabrook, and Lambie, 1986 | | Mefenamic acid, 250 mg, 3x/day for 3 mos | Propranolol, 40 mg, 3x/day for 3 mos | Placebo | | Investigators described only those AEs they believed could be attributed to the study medication. Mefenamic acid vs. placebo: 0.049 (−0.11 to 0.20) Propranolol vs. placebo: 0.044 (−0.11 to 0.19) Mefenamic acid vs. propranolol: 0.0046 (−0.17 to 0.18)
Johnson, Hornabrook, and Lambie, 1986 | Number of patients evaluable for AEs: | 22* | 23* | 24*
Johnson, Hornabrook, and Lambie, 1986 | Number of patients reporting AEs: | 2 (9%) | 2 (9%) | 1 (4%)
Johnson, Hornabrook, and Lambie, 1986 | Total number of AEs reported: | 2 | 2 | 1
Johnson, Hornabrook, and Lambie, 1986 | Number of patients reporting: | n (%) | n (%) | n (%)
Johnson, Hornabrook, and Lambie, 1986 | GI symptoms/diarrhea | 2 (9%) | 1 (4%) | 0
Johnson, Hornabrook, and Lambie, 1986 | Depression | 0 | 1 (4%) | 0
Johnson, Hornabrook, and Lambie, 1986 | Dizziness | 0 | 0 | 1 (4%)
Johnson, Hornabrook, and Lambie, 1986 | Withdrawals due to AEs: | 1 (diarrhea) | 1 (N/S) | 1 (dizziness)
Johnson, Kadam, Hylands, et al., 1985 | | Continuation of feverfew, 50 mg/day for 6 mos | | Withdrawal of feverfew (placebo) | | The data at left appear to concern all 17 patients randomized to treatment rather than the 15 who completed treatment, but this is not clear. Investigators noted that all patients taking placebo reported at least one AE, whereas four patients taking feverfew reported none. Two patients taking placebo withdrew because they experienced recurring headaches after having been in remission prior to the trial. (Note: In this report, “worsening headaches” are not considered AEs.) The two patients taking feverfew who reported stiffness or pain in joints had always had these symptoms. Continuation vs. withdrawal: −0.46 (−0.75 to −0.086)
Johnson, Kadam, Hylands, et al., 1985 | Number of patients evaluable for AEs: | 8 (See note) | | 9 (See note)
Johnson, Kadam, Hylands, et al., 1985 | Number of patients reporting AEs: | 4 (50%) | | 9 (100%)
Johnson, Kadam, Hylands, et al., 1985 | Total number of AEs reported: | 9 | | 19
Johnson, Kadam, Hylands, et al., 1985 | Number of patients reporting: | n (%) | | n (%)
Johnson, Kadam, Hylands, et al., 1985 | Nervousness, tension, less calm, jumpy | 0 | | 5 (56%)
Johnson, Kadam, Hylands, et al., 1985 | Tension or frequent non-migrainous HAs | 0 | | 3 (33%)
Johnson, Kadam, Hylands, et al., 1985 | Insomnia, disturbed sleep, nocturnal restlessness | 0 | | 2 (22%)
Johnson, Kadam, Hylands, et al., 1985 | Stiffness or pain in joints | 2 (25%) | | 3 (33%)
Johnson, Kadam, Hylands, et al., 1985 | Tiredness | 0 | | 2 (22%)
Johnson, Kadam, Hylands, et al., 1985 | Nausea | 0 | | 1 (11 %)
Johnson, Kadam, Hylands, et al., 1985 | Lighter, irregular periods | 0 | | 1 (11%)
Johnson, Kadam, Hylands, et al., 1985 | Slightly heavier periods | 1 (13%) | | 1 (11%)
Johnson, Kadam, Hylands, et al., 1985 | Palpitations | 1 (13%) | | 0
Johnson, Kadam, Hylands, et al., 1985 | Colicky abdominal pain | 1 (13%) | | 0
Johnson, Kadam, Hylands, et al., 1985 | Urinary frequency | 0 | | 1 (11%)
Johnson, Kadam, Hylands, et al., 1985 | Withdrawals due to AEs: | 0 (See note) | | 1 (disturbed sleep & stiffness in joints) (See note)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | | (Study 1) Clonidine, 75 μg/day for 4 wks | (Study 1) Placebo | (Study 2) Clonidine, 150 μg/day for 8 wks | (Study 2) Practolol, 150 mg/day for 8 wks | No information was provided for withdrawals (for any reason). Investigators stated that “increased clonidine use was associated with increased side effects, especially nausea and sedation.” Clonidine vs. placebo (Study 1): 0(−0.14 to 0.14) Clonidine vs. practolol (Study 2): −0.16 (−0.34 to 0.03)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Number of patients evaluable for AEs: | 50* | 50* | 50* | 50*
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Number of patients reporting AEs: | 8 (16%) | 8 (16%) | 15 (30%) | 23 (46%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Total number of AEs reported: | 8 | 8 | 18 | 27
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Number of patients reporting: | n (%) | n (%) | n (%) | n (%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Dry mouth | 1 (2%) | 3 (6%) | 0 | 0
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Nausea | 2 (4%) | 1 (2%) | 7 (14%) | 9 (18%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Sedation | 1 (2%) | 2 (4%) | 6 (12%) | 13 (26%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Vertigo | 0 | 1 (2%) | 4 (8%) | 4 (8%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Weight gain | 1 (2%) | 0 | 1 (2%) | 0
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Other (mood changes, skin irritations) | 3 (6%) | 1 (2%) | 0 | 1 (2%)
Kallanranta, Hakkarainen, Hokkanen, et al., 1977 | Withdrawals due to AEs: | N/S (See note) | N/S (See note) | N/S (See note) | N/S (See note)
Kallos and Kallos-Deffner, 1971 | | Cafergot comp.®, 1 cap, 2x/day for 2 menstrual periods | | Placebo
Kallos and Kallos-Deffner, 1971 | Number of patients evaluable for AEs: | 20* | | 20*
Kallos and Kallos-Deffner, 1971 | Number of patients reporting AEs: | N/S | | N/S
Kallos and Kallos-Deffner, 1971 | Total number of AEs reported: | N/S | | N/S
Kallos and Kallos-Deffner, 1971 | Number of reports of (NB: a single patient may have reported a given symptom twice): | n (%) | | n (%)
Kallos and Kallos-Deffner, 1971 | Nausea/vomiting | 11 | | 24
Kallos and Kallos-Deffner, 1971 | Muscle pain | 9 | | 5
Kallos and Kallos-Deffner, 1971 | Visual disturbances | 0 | | 0
Kallos and Kallos-Deffner, 1971 | Withdrawals due to AEs: | N/S | | N/S
Kangasniemi, 1979 | | Pizotifen (Sandomigrin®), inc’d from 0.5 mg, 1x/day to 0.5 mg, 3x/day for 3 mos (or 14 wks, not clear) | | Iprazochrome (Migrenon®), inc’d from 5 mg, 1x/day to 5 mg, 3x/day for 3 mos (or 14 wks, not clear) | | Data at left concern only the 34/50 patients who completed the trial and from whom efficacy data were obtained. An additional 3 patients, excluded from efficacy analyses, withdrew from the trial due to unspecified AEs (2 from pizotifen, 1 from iprazochrome).
Kangasniemi, 1979 | Number of patients evaluable for AEs: | 34* | | 34*
Kangasniemi, 1979 | Number of patients reporting AEs: | N/S | | N/S
Kangasniemi, 1979 | Total number of AEs reported: | 31 | | 5
Kangasniemi, 1979 | Number of patients reporting: | n (%) | | n (%)
Kangasniemi, 1979 | Weight gain | 25 (74%) | | 4 (12%)
Kangasniemi, 1979 | Tiredness | 5 (15%) | | 0
Kangasniemi, 1979 | Palpitations | 1 (3%) | | 0
Kangasniemi, 1979 | Vertigo, dizziness | 0 | | 1 (3%)
Kangasniemi, 1979 | Withdrawals due to AEs: | (See note) | | (See note)
Kangasniemi, Andersen, Andersson, et al., 1987 | | Metoprolol 200 mg/day for 8 wks | | Placebo | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Number of patients evaluable for AEs: | 73* (See note) | | 73* (See note) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Number of patients reporting AEs: | 26 (36%) | | 13(18%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Total number of AEs reported: | 52 | | 25 | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Number of AEs reported: | n (%) | | n (%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Gastrointestinal | 16(31%) | | 3 (6%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Others | 16(31%) | | 15 (29%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Fatigue/tiredness | 13 (25%) | | 4 (8%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Sleep disturbances | 4 (8%) | | 0 | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Cardiovascular | 3 (6%) | | 3 (6%) | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Andersen, Andersson, et al., 1987 | Withdrawals due to AEs: | 1 (bradycardia) | | 0 | | The data at left are for the 73 of 77 patients included in the efficacy analyses.
Kangasniemi, Falck, Långvik, et al., 1978 | | Oxitriptan, 500 mg, 4x/day for 3 mos | | Placebo (Ievoleucine), 320 mg, 4x/day for 3 mos | | Investigators reported that no AEs were reported from pts taking oxitriptan. No information was provided on AEs resulting from the placebo treatment.
Kangasniemi, Falck, Långvik, et al., 1978 | Number of patients evaluable for AEs: | 8* | | 8* | | Investigators reported that no AEs were reported from pts taking oxitriptan. No information was provided on AEs resulting from the placebo treatment.
Kangasniemi, Falck, Långvik, et al., 1978 | Number of patients reporting AEs: | 0 | | 0 | | Investigators reported that no AEs were reported from pts taking oxitriptan. No information was provided on AEs resulting from the placebo treatment.
Kangasniemi, Falck, Långvik, et al., 1978 | Total number of AEs reported: | 0 | | 0 | | Investigators reported that no AEs were reported from pts taking oxitriptan. No information was provided on AEs resulting from the placebo treatment.
Kangasniemi, Falck, Långvik, et al., 1978 | Withdrawals due to AEs: | 0 | | 0 | | Investigators reported that no AEs were reported from pts taking oxitriptan. No information was provided on AEs resulting from the placebo treatment.
Kangasniemi and Hedman, 1984 | | Metoprolol (controlled-release), 200 mg/day, 1x/day for 8 wks | | Propranolol, 80 mg, 2x/day for 8 wks
Kangasniemi and Hedman, 1984 | Number of patients evaluable for AEs: | 36* | | 36*
Kangasniemi and Hedman, 1984 | Number of patients reporting AEs: | N/S | | N/S
Kangasniemi and Hedman, 1984 | Total number of AEs reported: | 54 | | 65
Kangasniemi and Hedman, 1984 | Number of patients reporting: | n (%) | | n (%)
Kangasniemi and Hedman, 1984 | Fatigue | 14 (39%) | | 11 (31%)
Kangasniemi and Hedman, 1984 | CNS symptoms | 11 (31%) | | 14 (39%)
Kangasniemi and Hedman, 1984 | GI symptoms | 8 (22%) | | 9 (25%)
Kangasniemi and Hedman, 1984 | Sleep disturbances | 3 (8%) | | 10 (28%)
Kangasniemi and Hedman, 1984 | CV or respiratory symptoms | 2 (6%) | | 5 (14%)
Kangasniemi and Hedman, 1984 | Others | 16 (44%) | | 16 (44%)
Kangasniemi and Hedman, 1984 | Withdrawals due to AEs: | 0 | | 2 (causative AEs N/S)
Kangasniemi, Nyrke, Lang, et al., 1983 | | Femoxetine, 200 mg, 2x/day for 3 mos; dose reduced by half during first week | | Propranolol, 80 mg, 2x/day for 3 mos; dose reduced by half during first week | | Data at left are (apparently) for the 24 patients who completed the trial. Three other patients withdrew due to AEs associated with propranolol (tiredness, dizziness, increase in weight). There were no withdrawals due to AEs associated with femoxetine.
Kangasniemi, Nyrke, Lang, et al., 1983 | Number of patients evaluable for AEs: | 24* | | 24*
Kangasniemi, Nyrke, Lang, et al., 1983 | Number of patients reporting AEs: | N/S | | N/S
Kangasniemi, Nyrke, Lang, et al., 1983 | Total number of AEs reported: | 14 | | 38
Kangasniemi, Nyrke, Lang, et al., 1983 | Number of patients reporting: | n (%) | | n (%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Dizziness | 3 (13%) | | 10 (42%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Tiredness | 1 (4%) | | 9 (38%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Sleep disturbances | 1 (4%) | | 5 (21%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Feeling unwell | 2 (8%) | | 3 (13%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Exanthema | 1 (4%) | | 3 (13%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Palpitations | 1 (4%) | | 3 (13%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Increase in weight | 0 | | 3 (13%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Gastric distress | 1 (4%) | | 1 (4%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Sweating | 1 (4%) | | 1 (4%)
Kangasniemi, Nyrke, Lang, et al., 1983 | Decrease in weight | 2 (8%) | | 0
Kangasniemi, Nyrke, Lang, et al., 1983 | Dry mouth | 1 (4%) | | 0
Kangasniemi, Nyrke, Lang, et al., 1983 | Withdrawals due to AEs: | (See note) | | (See note)
Kåss and Nestvold, 1980 | | Clonidine (Catapresan®), 50 μg, 2x/day for 16 wks | | Propranolol (Inderal®), 80 mg, 2x/day for 16 wks | | Data at left appear to concern those 21 patients (of 23) who completed the crossover, but this is unclear. Prior to trial, patients given a test dose of 40 mg propranolol followed by testing of blood pressure and pulse rate after 30 min and 3 hrs to "exclude unwanted immediate side effects." Investigators reported that 2 patients taking propranolol received reduced daily dosage due to dizziness. Clonidine vs. propranolol: −0.09 (−0.37 to 0.20)
Kåss and Nestvold, 1980 | Number of patients evaluable for AEs: | 21* (See note) | | 21* (See note)
Kåss and Nestvold, 1980 | Number of patients reporting AEs: | 11 (52%) | | 13 (62%)
Kåss and Nestvold, 1980 | Total number of AEs reported: | 11 | | 15
Kåss and Nestvold, 1980 | Number of patients reporting: | n (%) | | n (%)
Kåss and Nestvold, 1980 | Anxiety | 0 | | 1 (5%)
Kåss and Nestvold, 1980 | Dizziness | 1 (5%) | | 5 (24%) (See note)
Kåss and Nestvold, 1980 | Fatigue | 8 (38%) | | 4 (19%)
Kåss and Nestvold, 1980 | Gastrointestinal | 1 (5%) | | 0
Kåss and Nestvold, 1980 | Insomnia | 0 | | 5 (24%)
Kåss and Nestvold, 1980 | Hair loss | 1 (5%) | | 0
Kåss and Nestvold, 1980 | Withdrawals due to AEs: | 0 | | 0
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | | Tolfenamic acid, 100 mg, 3x/day for 12 wks | | Propranolol, 40 mg, 3x/day for 12 wks | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Number of patients evaluable for AEs: | 62* | | 67* | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Number of patients reporting AEs: | 26 (42%) | | 28 (42%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Total number of AEs reported: | 28 | | 20 | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Number of patients reporting: | n (%) | | n (%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Gastrointestinal symptoms | 11 (18%) | | 11 (16%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Dysuria | 6 (10%) | | 1 (1%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Dizziness, fatigue, tremor, drop in BP | 8 (13%) | | 7 (10%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Weight gain | 2 (3%) | | 1 (1%) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Rash | 1 (2%) | | 0 | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Kjærsgård Rasmussen, Holt-Larsen, Borg, et al., 1994 | Withdrawals due to AEs: | 5 (GI symptoms [4], rash [1]) | | 9 (GI symptoms [4]; dizziness, etc. [5]) | | Tolfenamic acid vs. propranolol: 0.0015 (minus;0.17 to 0.17)
Klapper, 1994 | | Divalproex sodium, average dose 1100 mg/day, for 2 mos | | Propranolol, average dose 140 mg/day, for 2 mos | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Number of patients evaluable for AEs: | 24* | | 24* | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Number of patients reporting AEs: | N/S | | N/S | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Total number of AEs reported: | N/S | | N/S | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Number of patients withdrawing due to: | n (%) | | n (%) | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Fatigue | 2 (8%) | | 2 (8%) | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Gastrointenstinal symptoms | 3 (13%) | | 0 | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Increasing HAs | 1 (4%) | | 1 (4%) | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Low white blood count | 2 (8%) | | 0 | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Rash | 1 (4%) | | 0 | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1994 | Withdrawals due to AEs: | 9 (See note) | | 3 (See note) | | Investigator reported data on AEs only for those patients who withdrew due to AEs.
Klapper, 1996 | | Divalproex sodium, 1500 mg/day for 12 wks | Divalproex sodium, 1000 mg/day for 12 wks | Divalproex sodium, 500 mg/day for 12 wks | Placebo | "Gastrointestinal events" were the primary cause of withdrawal from the divalproex sodium groups (3 in the 500- mg group, 2 in the 1000-mg group, and six in the 1500-mg group). No other details were provided. Divalproex sodium 1500 mg vs. placebo: 0.067 (−0.090 to 0.22) Divalproex sodium 1000 mg vs. placebo: −0.051 (−0.22 to 0.12) Divalproex sodium 500 mg vs. placebo: −0.039 (−0.21 to 0.13)
Klapper, 1996 | Number of patients evaluable for AEs: | 44 | 43 | 45 | 44
Klapper, 1996 | Number of patients reporting AEs: | 38 (86%) | 32 (74%) | 34 (76%) | 35 (80%)
Klapper, 1996 | Total number of AEs reported: | N/S | N/S | N/S | N/S
Klapper, 1996 | Number of patients reporting most common AEs (> 10% of pts treated with active med): | n (%) | n (%) | n (%) | n (%)
Klapper, 1996 | Nausea | 34 (77%) | 9 (21%) | 27 (60%) | 7 (16%)
Klapper, 1996 | Infection | 20 (45%) | 16 (37%) | 18 (40%) | 18 (41%)
Klapper, 1996 | Dyspepsia | 16 (36%) | 19 (44%) | 7 (16%) | 9 (20%)
Klapper, 1996 | Asthenia | 23 (52%) | 9 (21 %) | 9 (20%) | 9 (20%)
Klapper, 1996 | Dizziness | 20 (45%) | 7 (16%) | 7 (16%) | 5 (11%)
Klapper, 1996 | Somnolence | 18 (41%) | 7 (16%) | 7 (16%) | 5 (11%)
Klapper, 1996 | Back pain | 14 (32%) | 5 (12%) | 7 (16%) | 9 (20%)
Klapper, 1996 | Diarrhea | 18 (41%) | 5 (12%) | 7 (16%) | 5 (11%)
Klapper, 1996 | Pain | 11 (25%) | 7 (16%) | 9 (20%) | 7 (16%)
Klapper, 1996 | Tremor | 16 (36%) | 7 (16%) | 0 | 0
Klapper, 1996 | Vomiting | 11 (25%) | 5 (12%) | 4 (9%) | 2 (5%)
Klapper, 1996 | Withdrawals due to AEs: | 12 (See note) | 6 (See note) | 7 (See note) | 2 (See note)
Krakowski and Engisch, 1973 | | Pizotifen, 2 mg, 3x/day for 12 wks | | Placebo | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Number of patients evaluable for AEs: | 15 (See note) | | 14 (See note) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Number of patients reporting AEs: | 7 (47%) | | 9 (64%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Total number of AEs reported: | 39 | | 33 | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Number of patients reporting: | n (%) | | n (%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Swelling of feet | 12 (80%) | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Drowsiness | 8 (53%) | | 4 (29%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Dizziness | 4 (27%) | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Dry mouth | 4 (27%) | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Nervousness | 3 (20%) | | 9 (64%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Depressed | 2 (13%) | | 5 (36%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Nausea | 2 (13%) | | 5 (36%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Bloated feeling | 1 (7%) | | 2 (14%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Febrile feeling | 1 (7%) | | 0 | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Backache | 0 | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Muscle cramps | 1 (7%) | | 0 | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Pruritis | 1 (7%) | | 0 | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Stimulated | 0 | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Tremor | 0 | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Twitching | 0 | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Weight gain | 0 | | 1 (7%) | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Krakowski and Engisch, 1973 | Withdrawals due to AEs: | 0 | | N/S | | Data at left are for all 29 patients randomized to treatment and include the 7 patients who withdrew early and for whom efficacy data were not analyzed. Pizotifen vs. placebo: 0.20 (−0.048 to 0.43)
Kuritzky and Herlng, 1987 | | Propranolol (long-acting), 160 mg, 1x/day for 1 mo | | Placebo | | Abstract reporting limited information. Investigators stated that the most common AEs associated with propranolol were tiredness, insomnia, and dizziness.
Kuritzky and Herlng, 1987 | Number of patients evaluable for AEs: | 38* | | 38* | | Abstract reporting limited information. Investigators stated that the most common AEs associated with propranolol were tiredness, insomnia, and dizziness.
Kuritzky and Herlng, 1987 | Number of patients reporting AEs: | N/S | | N/S | | Abstract reporting limited information. Investigators stated that the most common AEs associated with propranolol were tiredness, insomnia, and dizziness.
Kuritzky and Herlng, 1987 | Total number of AEs reported: | N/S | | N/S | | Abstract reporting limited information. Investigators stated that the most common AEs associated with propranolol were tiredness, insomnia, and dizziness.
Kuritzky and Herlng, 1987 | Withdrawals due to AEs: | 2 (dizziness, somnolence) | | 0 | | Abstract reporting limited information. Investigators stated that the most common AEs associated with propranolol were tiredness, insomnia, and dizziness.
Lamsudin and Sadjimin, 1993 | | Nifedipine, 20 mg/day for 3 mos | | Flunarizine, 10 mg/day for 3 mos | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Number of patients evaluable for AEs: | 38 | | 40 | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Total number of AEs reported: | N/S | | N/S | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Tachycardia | 12 (32%) | | 6 (15%) | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Sedation | 6 (16%) | | 8 (20%) | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lamsudin and Sadjimin, 1993 | Withdrawals due to AEs: | 0 | | 0 | | Investigators reported figures for tachycardia and sedation only, broken down by treatment month. Figures at left are for the last month of treatment (3).
Lance and Anthony, 1968 | | Pizotifen inc'd from 0.025 mg, 3x/day to 1 mg, 3x/day for 1 mo | | Placebo | | Data at left for pizotifen appear to include not only the 25 patients in this trial, but an additional 15 patients treated with pizotifen from another study described in the article. Two patients who were included in efficacy analyses withdrew due to AEs, one because of aching in the legs and one because of a continual feeling of unsteadiness and heaviness in the head "like a drunken hangover." Investigators did not specify from which treatment groups the patients withdrew.
Lance and Anthony, 1968 | Number of patients evaluable for AEs: | 40 (See note) | | 25 (See note)
Lance and Anthony, 1968 | Number of patients reporting AEs: | 19 (48%) | | N/S
Lance and Anthony, 1968 | Total number of AEs reported: | 29 | | 7
Lance and Anthony, 1968 | Number of patients reporting: | n (%) | | n (%)
Lance and Anthony, 1968 | Drowsiness, languour | 12 (30%) | | 0
Lance and Anthony, 1968 | Increased appetite, craving for sweets, gain in weight | 7 (18%) | | 0
Lance and Anthony, 1968 | Aching of legs | 2 (5%) | | 0
Lance and Anthony, 1968 | Swelling of ankles | 2 (5%) | | 0
Lance and Anthony, 1968 | Swelling of abdomen | 2 (5%) | | 0
Lance and Anthony, 1968 | Depression, irritability | 2 (5%) | | 3 (12%)
Lance and Anthony, 1968 | Nausea | 2 (5%) | | 1 (4%)
Lance and Anthony, 1968 | Blurred vision | 1 (3%) | | 0
Lance and Anthony, 1968 | Dizziness | 0 | | 2 (8%)
Lance and Anthony, 1968 | Skin rash | 0 | | 1 (4%)
Lance and Anthony, 1968 | Withdrawals due to AEs: | (See note) | | (See note)
Lance, Fine, and Curran, 1963 | | Methysergide, 2 mg, 3x/day for 1 mo | | Placebo | | This report described results of treatment of patients with several different types of HA, and from controlled and uncontrolled portions of the trial. The data on AEs were not reported separately for migraine patients participating in the controlled portion of the trial; thus, the data at left are for all patients included in all phases of the trial. It was reported that 6 of 56 migraine patients taking methysergide during the controlled portion of the trial withdrew due to AEs. Methysergide vs. placebo: 0.23 (0.12 to 0.35)
Lance, Fine, and Curran, 1963 | Number of patients evaluable for AEs: | 183 | | 50
Lance, Fine, and Curran, 1963 | Number of patients reporting AEs: | 66 (36%) | | 6 (12%)
Lance, Fine, and Curran, 1963 | Total number of AEs reported: | 128 | | 6
Lance, Fine, and Curran, 1963 | Number of patients reporting: | n (%) | | n (%)
Lance, Fine, and Curran, 1963 | Nausea | 29 (16%) | | 1 (2%)
Lance, Fine, and Curran, 1963 | Giddiness | 12 (7%) | | 1 (2%)
Lance, Fine, and Curran, 1963 | Drowsiness | 9 (5%) | | 0
Lance, Fine, and Curran, 1963 | Lassitude | 9 (5%) | | 0
Lance, Fine, and Curran, 1963 | Anxiety, insomnia, vivid dreams | 4 (2%) | | 3 (6%)
Lance, Fine, and Curran, 1963 | Abdominal pain | 5 (3%) | | 0
Lance, Fine, and Curran, 1963 | Aching in legs | 5 (3%) | | 0
Lance, Fine, and Curran, 1963 | Blocked nose | 5 (3%) | | 0
Lance, Fine, and Curran, 1963 | More frequent periods | 5 (3%) | | 0
Lance, Fine, and Curran, 1963 | Sensation of swelling of throat, tongue | 5 (3%) | | 0
Lance, Fine, and Curran, 1963 | Diarrhea | 4 (2%) | | 1 (2%)
Lance, Fine, and Curran, 1963 | Depression | 4 (2%) | | 0
Lance, Fine, and Curran, 1963 | Uncoordination, ataxia of gait | 4 (2%) | | 0
Lance, Fine, and Curran, 1963 | Blurred vision | 3 (2%) | | 0
Lance, Fine, and Curran, 1963 | Paresthesia | 3 (2%) | | 0
Lance, Fine, and Curran, 1963 | Faintness | 3 (2%) | | 0
Lance, Fine, and Curran, 1963 | Skin rash | 3 (2%) | | 0
Lance, Fine, and Curran, 1963 | Epistaxis | 3 (2%) | | 0
Lance, Fine, and Curran, 1963 | Vomiting | 2 (1%) | | 0
Lance, Fine, and Curran, 1963 | Tightness in chest | 2 (1%) | | 0
Lance, Fine, and Curran, 1963 | Palpitations | 2 (1%) | | 0
Lance, Fine, and Curran, 1963 | Hot flushes | 2 (1%) | | 0
Lance, Fine, and Curran, 1963 | Constipation | 1 (< 1%) | | 0
Lance, Fine, and Curran, 1963 | Flatulence | 1 (< 1%) | | 0
Lance, Fine, and Curran, 1963 | Dyspnea | 1 (< 1%) | | 0
Lance, Fine, and Curran, 1963 | Sensation of swelling of face | 1 (< 1%) | | 0
Lance, Fine, and Curran, 1963 | Sensation of swelling of legs | 1 (< 1%) | | 0
Lance, Fine, and Curran, 1963 | Withdrawals due to AEs: | 16 | | 0
Langohr, Gerber, Koletzki, et al., 1985 | | Clomipramine, dose gradually increased to 100 mg/day for total of 4 wks | Metoprolol, gradually increased to 100 mg/day for total of 4 wks | Placebo | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Number of patients evaluable for AEs: | N/S | N/S | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Number of patients reporting AEs: | N/S | N/S | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Total number of AEs reported: | 79 | 30 | 16 | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Number of patients reporting: | n (%) | n (%) | n (%) | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Insomnia | 15 | 2 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Sweating | 9 | 1 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Tiredness | 7 | 9 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Constipation | 6 | 1 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Nausea | 5 | 2 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Dizziness | 4 | 1 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Loss of appetite | 3 | 1 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Restlessness | 2 | 2 | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Langohr, Gerber, Koletzki, et al., 1985 | Withdrawals due to AEs: | 18 | N/S | N/S | | Little information provided on AEs. Individual AEs listed at left were the most common AEs in the two active treatment groups.
Lawrence, Hossain, and Littlestone, 1977 | | Pizotifen, inc’d from 0.5 mg, 1x/day to 0.5 mg, 3x/day for 10 days; then 1.0 mg, 3x/day for 10 wks | | Placebo | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Number of patients evaluable for AEs: | 14 (See note) | | 14 (See note) | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Number of patients reporting AEs: | N/S | | N/S | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Total number of AEs reported: | N/S | | N/S | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Number of patients reporting: | n (%) | | n (%) | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Weight gain | 4 (29%) | | 2 (14%) | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Nausea and vomiting | 1 (7%) | | 1 (7%) | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Lawrence, Hossain, and Littlestone, 1977 | Withdrawals due to AEs: | 0 | | 1 (dizziness) | | Data at left concern only those 28/36 patients from whom efficacy data were obtained.
Leandri, Rigardo, Schizzi, et al., 1990 | | Nicardipine, 40 mg/day for 2 mos | | Placebo | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Number of patients evaluable for AEs: | 36* | | 36* | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Total number of AEs reported: | 16 | | 16 | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Gastralgia | 5 (14%) | | 8 (22%) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Dizziness | 6 (17%) | | 5 (14%) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | HA precipitated (once) | 4 (11%) | | 1 (3%) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Dyspepsia | 1 (3%) | | 2 (6%) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Leandri, Rigardo, Schizzi, et al., 1990 | Withdrawals due to AEs: | 1 (dyspepsia) | | 2 (dyspepsia) | | Investigators reported that no patients complained of symptoms related to low blood pressure. No significant changes in weight were observed.
Lindegaard, Övrelid, and Sjaastad, 1980 | | Naproxen(Naprosyn®),250 mg, 2x/day for 6 wks | | Placebo | | The article did not describe dropouts. On AEs, the authors stated only that “there was no difference between naproxen and placebo with regard to side-effects.”
Lindegaard, Övrelid, and Sjaastad, 1980 | Number of patients evaluable for AEs: | 28* | | 28* | | The article did not describe dropouts. On AEs, the authors stated only that “there was no difference between naproxen and placebo with regard to side-effects.”
Lindegaard, Övrelid, and Sjaastad, 1980 | Number of patients reporting AEs: | N/S | | N/S | | The article did not describe dropouts. On AEs, the authors stated only that “there was no difference between naproxen and placebo with regard to side-effects.”
Lindegaard, Övrelid, and Sjaastad, 1980 | Total number of AEs reported: | N/S | | N/S | | The article did not describe dropouts. On AEs, the authors stated only that “there was no difference between naproxen and placebo with regard to side-effects.”
Lindegaard, Övrelid, and Sjaastad, 1980 | Withdrawals due to AEs: | (See note) | | (See note) | | The article did not describe dropouts. On AEs, the authors stated only that “there was no difference between naproxen and placebo with regard to side-effects.”
Louis, 1981 | | Flunarizine, 10 mg/day for 3 mos | | Placebo | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Number of patients evaluable for AEs: | 29 | | 29 | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Number of patients reporting AEs: | 2 (7%) | | 2 (7%) | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Total number of AEs reported: | 2 | | 2 | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Number of patients reporting: | n (%) | | n (%) | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Daytime sedation | 2 (7%) | | 0 | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Dry mouth | 0 | | 2 (7%) | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, 1981 | Withdrawals due to AEs: | 0 | | 0 | | Possible AEs recorded at monthly clinic visits. Flunarizine vs. placebo: 0(−0.14 to 0.14)
Louis, Schoenen, and Hedman, 1985a | | Clonidine, 50 μg, 2x/day for 8 wks | | Metoprolol, 50 mg, 2x/day for 8 wks | | Data at left appear to concern all patients, including those who withdrew prematurely from study. Three patients withdrew after treatment with clonidine (subjective toxic effect, lack of effect; nervousness, lack of effect; dizziness, lack of effect). One additional patient withdrew during the washout period due to thrombosis in superior retinal half of left eye. No patients withdrew because of AEs associated with metoprolol. Following the baseline period but prior to treatment, 8 patients in addition to those at left reported 12 AEs: cardiovascular (1); CNS-related (3); fatigue (3); gastrointestinal (4); others (1). Clonidine vs. metoprolol: −0.03 (−0.25 to 0.19)
Louis, Schoenen, and Hedman, 1985a | Number of patients evaluable for AEs: | 31* (See note) | | 31* (See note)
Louis, Schoenen, and Hedman, 1985a | Number of patients reporting AEs: | 21 (68%) | | 22 (71%)
Louis, Schoenen, and Hedman, 1985a | Total number of AEs reported: | 42 | | 41
Louis, Schoenen, and Hedman, 1985a | Number of patients reporting: | n (%) | | n (%)
Louis, Schoenen, and Hedman, 1985a | Cardiovascular | 2 (6%) | | 0
Louis, Schoenen, and Hedman, 1985a | CNS-related | 14 (45%) | | 16 (52%)
Louis, Schoenen, and Hedman, 1985a | Fatigue | 7 (23%) | | 10 (32%)
Louis, Schoenen, and Hedman, 1985a | Gastrointestinal | 9 (29%) | | 7 (23%)
Louis, Schoenen, and Hedman, 1985a | Others | 10 (32%) | | 8 (26%)
Louis, Schoenen, and Hedman, 1985a | Withdrawals due to AEs: | (See note) | | 0 (See note)
Louis and Spierings, 1982 | | Flunarizine, 10 mg/day for 4 mos | | Pizotifen, 2–3 mg/day for 4 mos
Louis and Spierings, 1982 | Number of patients evaluable for AEs: | 38 | | 34
Louis and Spierings, 1982 | Number of patients reporting AEs: | N/S | | N/S
Louis and Spierings, 1982 | Total number of AEs reported: | 20 | | 15
Louis and Spierings, 1982 | Number of patients reporting: | n (%) | | n (%)
Louis and Spierings, 1982 | Weight gain | 8(21%) | | 7 (21%)
Louis and Spierings, 1982 | Daytime sedation | 6 (16%) | | 4 (12%)
Louis and Spierings, 1982 | Gastric discomfort | 6 (16%) | | 4 (12%)
Louis and Spierings, 1982 | Withdrawals due to AEs: | 1 (weight gain) | | 1 (weight gain)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | | Flunarizine, 10 mg/day for 4 mos | | Propranolol, 120 mg/day for 4 mos | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Number of patients evaluable for AEs: | 211 | | 223 | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Number of patients reporting AEs: | 52 (25%) | | 66 (30%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Total number of AEs reported: | N/S | | N/S | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Number of patients reporting: | n (%) | | n (%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | GI disorders | 15 (7%) | | 22 (10%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Sedation/fatigue | 17 (8%) | | 18 (8%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Vertigo | 11 (5%) | | 16 (7%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Weight gain | 6 (3%) | | 8 (4%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Hyposthenia | 5 (2%) | | 5 (2%) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 1) | Withdrawals due to AEs: | 6 (nausea, sedation, gastric pain, vertigo [numbers with each N/S]) | | 11 (nausea, changes in heart rate, hallucinations, sedation, vertigo, GI disorders, weight gain, eczema) | | Flunarizine VS. propranolol: −0.049 (−0.13 to 0.034)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | | Flunarizine, 10 mg/day for 4 mos | | Propranolol, 120 mg/day for 4 mos | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Number of patients evaluable for AEs: | 43 | | 44 | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Number of patients reporting AEs: | 16 (37%) | | 21 (48%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Total number of AEs reported: | N/S | | N/S | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Number of patients reporting: | n (%) | | n (%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Sedation/fatigue | 10 (23%) | | 4 (9%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | GI disorders | 0 | | 9 (21%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Weight gain | 5 (12%) | | 3 (7%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Vertigo | 1 (2%) | | 2 (5%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Hyposthenia | 1 (2%) | | 2 (5%) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Lücking, Oestreich, Schmidt, et al., 1988 (Study 2) | Withdrawals due to AEs: | 2 (causative AEs N/S) | | 4 (causative AEs N/S) | | Flunarizine VS. propranolol: −0.10 (−0.30 to 0.10)
Ludin, 1989 | | Flunarizine, 10 mg/day for 4 mos | | Propranolol, 120 mg/day for 4 mos | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Number of patients evaluable for AEs: | 27 | | 32 | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Number of patients reporting AEs: | 13 (48%) | | 15 (47%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Total number of AEs reported: | 18 | | 23 | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Number of patients reporting: | n (%) | | n (%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Tiredness/sleepiness | 7 (26%) | | 3 (9%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | GI symptoms | 2 (7%) | | 6 (19%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Dizziness | 3 (11%) | | 2 (6%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Weight gain | 2 (7%) | | 3 (9%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Increased appetite | 0 | | 4 (13%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Insomnia | 1 (4%) | | 2 (6%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Hair loss | 0 | | 2 (6%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Dyspnoea | 1 (4%) | | 0 | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Urticaria/pruritus | 1 (4%) | | 0 | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Oedema | 1 (4%) | | 0 | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Nausea | 0 | | 1 (3%) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Ludin, 1989 | Withdrawals due to AEs: | 2 (tiredness/sleepiness, insomnia) | | 3 (hair loss, GI symptoms, tiredness/sleepiness) | | Flunarizine vs. propranolol: 0.013 (−0.23 to 0.26)
Lundberg, 1969 | | Flumedroxone, 5 mg, 2x/day for 1 mo | | Placebo | | Limited information provided on AEs. 8/30 women completing the trial (apparently some in each treatment group) reported "menstrual disturbances: Other AEs were characterized as "infrequent” and "mild."
Lundberg, 1969 | Number of patients evaluable for AEs: | 25 | | 25
Lundberg, 1969 | Number of patients reporting AEs: | N/S | | N/S
Lundberg, 1969 | Total number of AEs reported: | N/S | | N/S
Lundberg, 1969 | Withdrawals due to AEs: | 0 | | 0
Malvea, Gwon, and Graham, 1973 | | Propranolol, dose N/S, for 6 wks | | Placebo
Malvea, Gwon, and Graham, 1973 | Number of patients evaluable for AEs: | 31* | | 31*
Malvea, Gwon, and Graham, 1973 | Number of patients reporting AEs: | N/S | | N/S
Malvea, Gwon, and Graham, 1973 | Total number of AEs reported: | 17 | | N/S
Malvea, Gwon, and Graham, 1973 | Number of patients reporting: | n (%) | | n (%)
Malvea, Gwon, and Graham, 1973 | Nausea | 5 (16%) | | N/S
Malvea, Gwon, and Graham, 1973 | Fatigue | 5 (16%) | | N/S
Malvea, Gwon, and Graham, 1973 | Numbness | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Heartburn | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Heaviness in leg and arm | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Light-headedness | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Vomiting | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Tingling in leg and arm | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Depression | 1 (3%) | | N/S
Malvea, Gwon, and Graham, 1973 | Withdrawals due to AEs: | 0 | | 0
Markley, Cheronis, and Piepho, 1984 | | Verapamil, 240 mg/day for 8 wks | | Placebo
Markley, Cheronis, and Piepho, 1984 | Number of patients evaluable for AEs: | 14* | | 14*
Markley, Cheronis, and Piepho, 1984 | Number of patients reporting AEs: | 6 (43%) | | N/S
Markley, Cheronis, and Piepho, 1984 | Total number of AEs reported: | 6 | | N/S
Markley, Cheronis, and Piepho, 1984 | Number of patients reporting: | n (%) | | n (%)
Markley, Cheronis, and Piepho, 1984 | Constipation | 6 (43%) | | 0
Markley, Cheronis, and Piepho, 1984 | Withdrawals due to AEs: | 1 (severe constipation) | | 0
Martucci, Manna, Mattesi, et al., 1983 | | DHE (timed-release), 5 mg, 2x/day for 45 days | | Placebo | | Limited information provided on AEs.
Martucci, Manna, Mattesi, et al., 1983 | Number of patients evaluable for AEs: | 90* | | 90* | | Limited information provided on AEs.
Martucci, Manna, Mattesi, et al., 1983 | Number of patients reporting AEs: | N/S | | N/S | | Limited information provided on AEs.
Martucci, Manna, Mattesi, et al., 1983 | Total number of AEs reported: | N/S | | N/S | | Limited information provided on AEs.
Martucci, Manna, Mattesi, et al., 1983 | Withdrawals due to AEs: | 6 (pyrosis and epigastralgia [4], insomnia [1], allergic skin reaction [1]) | | 0 | | Limited information provided on AEs.
Masel, Chesson, Peters, et al., 1980 | | Aspirin + dipyridamole, 325 + 25 mg, 3x/day, for 3 mos | | Placebo | | The data at left appear to refer only to the 25/40 patients who completed the trial. None of the 15 patients who withdrew prematurely did so due to AEs.
Masel, Chesson, Peters, et al., 1980 | Number of patients evaluable for AEs: | 25* | | 25* | | The data at left appear to refer only to the 25/40 patients who completed the trial. None of the 15 patients who withdrew prematurely did so due to AEs.
Masel, Chesson, Peters, et al., 1980 | Number of patients reporting AEs: | 0 | | 0 | | The data at left appear to refer only to the 25/40 patients who completed the trial. None of the 15 patients who withdrew prematurely did so due to AEs.
Masel, Chesson, Peters, et al., 1980 | Total number of AEs reported: | 0 | | 0 | | The data at left appear to refer only to the 25/40 patients who completed the trial. None of the 15 patients who withdrew prematurely did so due to AEs.
Masel, Chesson, Peters, et al., 1980 | Withdrawals due to AEs: | 0 | | 0 | | The data at left appear to refer only to the 25/40 patients who completed the trial. None of the 15 patients who withdrew prematurely did so due to AEs.
Mastrosimone, laccarino, and de Caterina, 1992 | | Cyclandelate, 1600 mg/day for 3 mos | | Pizotifen, 1.5 mg/day for 3 mos | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Number of patients evaluable for AEs: | 35 | | 26 | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Number of patients reporting AEs: | 8 (23%) | | 19 (73%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Total number of AEs reported: | 8 | | 19 | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Number of patients reporting: | n (%) | | n (%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Weight gain | 1 (3%) | | 6 (23%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Asthenia | 2 (6%) | | 3 (12%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | GI disturbances | 2 (6%) | | 2 (8%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Somnolence | 1 (3%) | | 2 (8%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Visual disturbances | 0 | | 3 (12%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Vertigo | 1 (3%) | | 1 (4%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Other | 1 (3%) | | 2 (8%) | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mastrosimone, laccarino, and de Caterina, 1992 | Withdrawals due to AEs: | 0 | | 0 | | Cyclandelate vs. pizotifen: −0.49 (−0.69 to −0.26)
Mathew, 1978 | | Oxitriptan, 300 mg/day for 8 wks | | Placebo | | Limited information was provided on AEs. Investigators only reported that "slight drowsiness and mild diarrhea" were the most common AEs from oxitriptan. They did not report the number of AEs from placebo.
Mathew, 1978 | Number of patients evaluable for AEs: | 12* (See note) | | 12* (See note)
Mathew, 1978 | Number of patients reporting AEs: | N/S | | N/S
Mathew, 1978 | Total number of AEs reported: | N/S | | N/S
Mathew, 1978 | Withdrawals due to AEs: | N/S | | N/S
Mathew, 1981 | | See notes column, at right. Trial reported results separately for migraine-only and mixed HA patients. | | | | Very limited data were reported on AEs. Among migraine-only patients, the incidence of AEs was "more or less comparable" in the.various treatment groups; 18/340 patients (5%) withdrew due to AEs. Among patients with mixed HAs, 29/375 (8%) withdrew due to AEs; AEs were highest in the control (ergotamine) group. In both HA groups, no unusual AEs were reported when propranolol and amitriptyline were used simultaneously.
Mathew, 1981 | | Eight interventions were tested over 6 mos:
Mathew, 1981 | | Ergotamine + analgesics, used abortively (control)
Mathew, 1981 | | Propranolol, 60–160 mg/day
Mathew, 1981 | | Amitriptyline, 25–75 mg/day
Mathew, 1981 | | Biofeedback (+ relaxation)
Mathew, 1981 | | Propranolol + amitriptyline
Mathew, 1981 | | Propranolol + biofeedback
Mathew, 1981 | | Amitriptyline + biofeedback
Mathew, 1981 | | Propranolol + amitriptyline + biofeedback
Mathew, Saper, Silberstein, et al., 1995 | | Divalproex sodium, average dose 1087 mg/day, for 12 wks | | Placebo | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Number of patients evaluable for AEs: | 70 | | 37 | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Number of patients reporting AEs: | N/S | | N/S | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Total number of AEs reported: | N/S | | N/S | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Nausea | 32 (46%) | | 5 (14%) | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Asthenia | 22 (31%) | | 3 (8%) | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Somnolence | 21 (30%) | | 2 (5%) | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Vomiting | 13 (19%) | | 0 | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Tremor | 9(13%) | | 0 | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Alopecia | 9(13%) | | 0 | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
Mathew, Saper, Silberstein, et al., 1995 | Withdrawals due to AEs: | 9 (nausea [2], rash [1], vomiting [1], decreased mental acuity [1], fatigue [1], elevated liver function test results [1], chest/GI pain [1], weight gain [1 ]) | | 2 (rash [1], depression [1]) | | Investigators reported data only on those AEs for which there was a significant difference between the two groups.
McArthur, Marek, Pestronk, et al., 1989 | | Nifedipine, 60–90 mg/day for 3 mos | | Placebo
McArthur, Marek, Pestronk, et al., 1989 | Number of patients evaluable for AEs: | 24* | | −24*
McArthur, Marek, Pestronk, et al., 1989 | Number of patients reporting AEs: | N/S | | N/S
McArthur, Marek, Pestronk, et al., 1989 | Total number of AEs reported: | 46 | | 10
McArthur, Marek, Pestronk, et al., 1989 | Number of patients reporting: | n (%) | | n (%)
McArthur, Marek, Pestronk, et al., 1989 | Dizziness | 11 (46%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Edema | 11 (46%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Gastric symptoms | 4 (17%) | | 6 (25%)
McArthur, Marek, Pestronk, et al., 1989 | Flushing | 7 (29%) | | 2 (8%)
McArthur, Marek, Pestronk, et al., 1989 | Exacerbation of HA severity | 4 (17%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Mental symptoms | 3 (13%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Acute onset of HA w/dose titration | 2 (8%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Weight gain | 2 (8%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Fatigue | 2 (8%) | | 0
McArthur, Marek, Pestronk, et al., 1989 | Diarrhea | 0 | | 1 (4%)
McArthur, Marek, Pestronk, et al., 1989 | Leg cramps | 0 | | 1 (4%)
McArthur, Marek, Pestronk, et al., 1989 | Withdrawals due to AEs: | 5 (causative AEs N/S) | | 1 (causative AEs N/S)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | | Flunarizine, 10 mg/day for 3–4 mos | | Placebo | | No indication of how data on AEs were gathered. Flunarizine VS. placebo: 0.0084 (−0.16 to 0.18)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Number of patients evaluable for AEs: | 9 | | 11 | | No indication of how data on AEs were gathered. Flunarizine VS. placebo: 0.0084 (−0.16 to 0.18)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Number of patients reporting AEs: | 0 | | 0 | | No indication of how data on AEs were gathered. Flunarizine VS. placebo: 0.0084 (−0.16 to 0.18)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Total number of AEs reported: | 0 | | 0 | | No indication of how data on AEs were gathered. Flunarizine VS. placebo: 0.0084 (−0.16 to 0.18)
Mendenopoulos, Manafi, Logothetis, et al., 1985 | Withdrawals due to AEs: | 0 | | 0 | | No indication of how data on AEs were gathered. Flunarizine VS. placebo: 0.0084 (−0.16 to 0.18)
Meyer and Hardenberg, 1983 | | Nimodipine, 60 mg/day for 8 wks and 120 mg/day for 8 wks | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Number of patients evaluable for AEs: | 27* | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Number of patients reporting AEs: | 11 (40%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Total number of AEs reported: | 28 | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Number of patients reporting: | n (%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Muscular complaints | 12 (44%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | GI complaints | 5 (19%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Behavioral changes | 5 (19%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Other CNS symptoms | 3 (11%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Vascular complaints | 2 (7%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Dermatological changes | 1 (1%) | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Meyer and Hardenberg, 1983 | Withdrawals due to AEs: | N/S | | | | This was a dose-comparison trial, but AEs were not reported separately for the two doses.
Micieli, Trucco, Agostinis, et al., 1985 | | Nimodipine, 120 mg/day for 3 mos | | Pizotifen, 1.5 mg/day for 3 mos | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Number of patients evaluable for AEs: | 20* | | 20* | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Number of patients reporting AEs: | N/S | | N/S | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Total number of AEs reported: | N/S | | N/S | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Number of patients reporting: | n (%) | | n (%) | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Drowsiness | 0 | | 9 (45%) | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Weight gain (1–3 kg) | 0 | | 6 (30%) | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Micieli, Trucco, Agostinis, et al., 1985 | Withdrawals due to AEs: | N/S | | N/S | | Abstract reporting limited information. Authors stated that no significant AEs were reported with nimodipine.
Migraine-Nimodipine European Study Group (MINES), 1989a | | Nimodipine, 120 mg/day for 12 wks | | Placebo | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Number of patients evaluable for AEs: | 43 | | 46 | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Number of patients reporting AEs: | 12 (28%) | | 8 (17%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Total number of AEs reported: | 12 | | 8 | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Number of patients reporting: | n (%) | | n (%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Increased HA | 4 (9%) | | 2 (4%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Dizziness | 1 (2%) | | 3 (6%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Vasodilatation | 2 (5%) | | 1 (2%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Asthenia | 2 (5%) | | 0 | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Myalgia | 2 (5%) | | 0 | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Depression | 0 | | 2 (4%) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Tachycardia | 1 (2%) | | 0 | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989a | Withdrawals due to AEs: | 3 (increased HA [2], tachycardia [1]) | | 4 (causative AEs N/S) | | Nimodipine vs. placebo: 0.10 (−0.070 to 0.27)
Migraine-Nimodipine European Study Group (MINES), 1989b | | Nimodipine, 120 mg/day for 12 wks | | Placebo | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Number of patients evaluable for AEs: | 94 | | 98 | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Number of patients reporting AEs: | 24 (26%) | | 13 (13%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Total number of AEs reported: | 24 | | 13 | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Number of patients reporting: | n (%) | | n (%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Increased HA | 8 (9%) | | 2 (2%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | GI problems | 4 (4%) | | 4 (4%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Vasodilatation | 5 (5%) | | 1 (1%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Nausea | 2 (2%) | | 1 (1%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Palpitation | 2 (2%) | | 1 (1%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Dizziness | 1 (1%) | | 2 (2%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Tachycardia | 2 (2%) | | 0 | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Rash | 0 | | 2 (2%) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Migraine-Nimodipine European Study Group (MINES), 1989b | Withdrawals due to AEs: | 5 (4 due to increased HA; 1 due to unspecified AEs) | | 3 (causative AEs N/S) | | Nimodipine vs. placebo: 0.12 (0.010 to 0.23)
Mikkelsen and Falk, 1982 | | Tolfenamic acid, 100 mg, 3x/day for 10 wks | | Placebo | | Gastrointestinal symptoms are said to have included mild dyspepsia, gaseous abdominal distension, constipation, diarrhea, and bloating. "Other" AEs included difficulty breathing, insomnia, failure of impressing ability, and a pressing feeling in the head.
Mikkelsen and Falk, 1982 | Number of patients evaluable for AEs: | 38* | | 38*
Mikkelsen and Falk, 1982 | Number of patients reporting AEs: | N/S | | N/S
Mikkelsen and Falk, 1982 | Total number of AEs reported: | 21 | | 19
Mikkelsen and Falk, 1982 | Number of patients reporting: | n (%) | | n (%)
Mikkelsen and Falk, 1982 | Gastrointestinal symptoms (see note) | 13 (34%) | | 12 (32%)
Mikkelsen and Falk, 1982 | Increase in weight and oedema | 4 (11%) | | 5 (13%)
Mikkelsen and Falk, 1982 | Dysuria | 1 (2%) | | 1 (2%)
Mikkelsen and Falk, 1982 | Other AEs (see note) | 3 (6%) | | 1 (2%)
Mikkelsen and Falk, 1982 | Withdrawals due to AEs: | 2 (increase in weight, diarrhea) | | 1 (tingling in hands and feet)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | | Propranolol, 40 mg, 3x/day for 12 wks | Tolfenamic acid, 100 mg, 3x/day for 12 wks | Placebo | | Data at left are for those patients who completed the trial (31/39). Three patients withdrew due to AEs before completing the trial: two due to AEs associated with propranolol (fatigue and difficulty working; fatigue, tremor, and general indisposition), and one due to AEs associated with tolfenamic acid ("indistinct psychical symptoms"). Propranolol vs. placebo: 0(−0.15 to 0.15) Tolfenamic acid vs. placebo: −0.031 (−0.17 to 0.11) Propranolol vs. tolfenamic acid: 0.031 (−0.11 to 0.17)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Number of patients evaluable for AEs: | 31* | 31* | 31*
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Number of patients reporting AEs: | 3 (10%) | 2 (6%) | 3 (10%)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Total number of AEs reported: | 3 | 2 | 3
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Number of patients reporting: | n (%) | n (%) | n (%)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Diarrhea | 0 | 1 (3%) | 1 (3%)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Fatigue | 1 (3%) | 0 | 0
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Polyuria | 1 (3%) | 0 | 0
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Low back pain | 1 (3%) | 0 | 0
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Slight sedation | 0 | 1 (3%) | 0
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Slight neurological symptoms | 0 | 0 | 1 (3%)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Hot flushes | 0 | 0 | 1 (3%)
Mikkelsen, Kjærsgaard-Pedersen, and Christiansen, 1986 | Withdrawals due to AEs: | (See note) | (See note) | (See note)
Mondrup and Møller, 1977 | | Clonidine, 50–75 μg, 2x/day for 12 wks | | Placebo, 2–3 tabs, 2x/day for 12 wks | | Data at left appear to concern only the 21 patients (of 32) who completed the crossover, but it is unclear. No patients withdrew due to AEs. However, 5 patients (2 on clonidine and 3 on placebo) were withdrawn from the study because of "unacceptable worsening of the headaches." One patient (on placebo) became HA free and withdrew.
Mondrup and Møller, 1977 | Number of patients evaluable for AEs: | 21* (See note) | | 21* (See note)
Mondrup and Møller, 1977 | Number of patients reporting AEs: | N/S | | NIS
Mondrup and Møller, 1977 | Total number of AEs reported: | 18 (86%) | | 8 (38%)
Mondrup and Møller, 1977 | Number of patients reporting: | n (%) | | n (%)
Mondrup and Møller, 1977 | Dryness of mouth | 3 (14%) | | 1 (5%)
Mondrup and Møller, 1977 | Dyspepsia | 3 (14%) | | 1 (5%)
Mondrup and Møller, 1977 | Slight dizziness | 4 (19%) | | 1 (5%)
Mondrup and Møller, 1977 | Slight tiredness | 8 (38%) | | 5 (24%)
Mondrup and Møller, 1977 | Withdrawals due to AEs: | 0 (See note) | | 0 (See note)
Monro, Swade, and Coppen, 1985 | | Mianserin, 30 mg/day for 1 wk, 60 mg/day for 15 wks | | Placebo | | No information provided on AEs.
Monro, Swade, and Coppen, 1985 | Number of patients evaluable for AEs: | N/S | | N/S | | No information provided on AEs.
Monro, Swade, and Coppen, 1985 | Number of patients reporting AEs: | N/S | | N/S | | No information provided on AEs.
Monro, Swade, and Coppen, 1985 | Total number of AEs reported: | N/S | | N/S | | No information provided on AEs.
Monro, Swade, and Coppen, 1985 | Withdrawals due to AEs: | N/S | | N/S | | No information provided on AEs.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | | Feverfew, ≈82 mg/day (mean dose) for 4 mos | | Placebo | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Number of patients evaluable for AEs: | 72* (See note) | | 72* (See note) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Number of patients reporting AEs: | N/S | | N/S | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Total number of AEs reported: | 28 | | 36 | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Number of patients reporting: | n (%) | | n (%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Mouth ulceration | 10 (14%) | | 16 (22%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Indigestion | 4 (6%) | | 2 (3%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Heartburn | 3 (4%) | | 3 (4%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Dizziness/lightheadedness | 2 (3%) | | 2 (3%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Skin rash | 1 (1%) | | 3 (4%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Diarrhea | 1 (1%) | | 2 (3%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Abdominal bloating | 1 (1%) | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Sore mouth | 1 (1%) | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Nausea | 1 (1%) | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Flatulence | 1 (1%) | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Weight gain | 2 (3%) | | 0 | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Constipation | 1 (1%) | | 0 | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Night sweats | 0 | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Paraesthesiae in legs | 0 | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Bleeding per rectum | 0 | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Somnolence | 0 | | 1 (1%) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Murphy, Heptinstall, and Mitchell, 1988 #4580 | Withdrawals due to AEs: | 2 (heartburn [1], dizziness/lightheadedness [1]) | | 3 (paraesthesiae in legs [1], skin rash [1], bleeding per rectum [1]) | | Data at left appear to concern all 72 patients randomized to treatment, but this is not clear.
Nanda, Johnson, Gray, et al., 1978 | | Acebutolol, 400 mg, 2x/day for 12 wks | | Placebo | | Limited information provided on AEs. Investigators stated that “no serious side-effects were reported” during the trial (p. 21).
Nanda, Johnson, Gray, et al., 1978 | Number of patients evaluable for AEs: | 43* | | 43* | | Limited information provided on AEs. Investigators stated that “no serious side-effects were reported” during the trial (p. 21).
Nanda, Johnson, Gray, et al., 1978 | Number of patients reporting AEs: | N/S | | N/S | | Limited information provided on AEs. Investigators stated that “no serious side-effects were reported” during the trial (p. 21).
Nanda, Johnson, Gray, et al., 1978 | Total number of AEs reported: | N/S | | N/S | | Limited information provided on AEs. Investigators stated that “no serious side-effects were reported” during the trial (p. 21).
Nanda, Johnson, Gray, et al., 1978 | Withdrawals due to AEs: | 0 | | 0 | | Limited information provided on AEs. Investigators stated that “no serious side-effects were reported” during the trial (p. 21).
Nappi, Sandrini, Savoini, et al., 1987 | | Cyclandelate, 1600 mg/day for 3 mos | | Flunarizine, 5 mg/day for 3 mos | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Number of patients evaluable for AEs: | 20 | | 20 | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Number of patients reporting AEs: | N/S | | N/S | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Total number of AEs reported: | N/S | | N/S | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Number of patients reporting: | n (%) | | n (%) | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Weight gain | N/S | | 9 (45%) | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Drowsiness | N/S | | 5 (25%) | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Gastric complaints | 3 (15%) | | N/S | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Asthenia | N/S | | 2 (10%) | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nappi, Sandrini, Savoini, et al., 1987 | Withdrawals due to AEs: | 1 (gastric complaints) | | 2 (drowsiness) | | Limited information provided on AEs. Incidence of specific AEs reported at left is for the third month of treatment only.
Nattero, Biale, Savi, et al., 1991 | | Pizotifen, 1.5 mg, 3x/day for 16 wks | | Lisuride, 0.075 mg, 3x/day for 16 wks | | Data at left are for the “most common” AEs reported and appear to concern only those 47/110 patients who completed both cycles of the crossover trial, but this is not clear. No information was provided on other AEs or on the number of patients who withdrew due to AEs.
Nattero, Biale, Savi, et al., 1991 | Number of patients evaluable for AEs: | N/S (See note) | | N/S (See note)
Nattero, Biale, Savi, et al., 1991 | Number of patients reporting AEs: | N/S | | N/S
Nattero, Biale, Savi, et al., 1991 | Total number of AEs reported: | N/S | | N/S
Nattero, Biale, Savi, et al., 1991 | Number of patients reporting: | n (%) | | n (%)
Nattero, Biale, Savi, et al., 1991 | Weight gain | 38% | | N/S
Nattero, Biale, Savi, et al., 1991 | Gastrointestinal disorders | 32% | | 50%
Nattero, Biale, Savi, et al., 1991 | Somnolence | 12% | | 12%
Nattero, Biale, Savi, et al., 1991 | Withdrawals due to AEs: | N/S | | N/S
Neuman, Demarez, Harmey, et al., 1986 | | DHE (timed-release), 5 mg, 2x/day for 1 mo | | Placebo | | Investigators stated only that “no notable side-effects were registered in either of the two groups” (p. 13).
Neuman, Demarez, Harmey, et al., 1986 | Number of patients evaluable for AEs: | 20 | | 20 | | Investigators stated only that “no notable side-effects were registered in either of the two groups” (p. 13).
Neuman, Demarez, Harmey, et al., 1986 | Number of patients reporting AEs: | N/S | | N/S | | Investigators stated only that “no notable side-effects were registered in either of the two groups” (p. 13).
Neuman, Demarez, Harmey, et al., 1986 | Total number of AEs reported: | N/S | | N/S | | Investigators stated only that “no notable side-effects were registered in either of the two groups” (p. 13).
Neuman, Demarez, Harmey, et al., 1986 | Withdrawals due to AEs: | 0 | | 0 | | Investigators stated only that “no notable side-effects were registered in either of the two groups” (p. 13).
Noone, 1980 | | Clomipramine, 10 mg, 3x/day for B wks | | Placebo | | These data are for those patients who completed the trial (10/21 randomized to treatment). Two patients withdrew before completing due to unspecified AEs; both were taking clomipramine at the time. Clomipramine vs. placebo: 0.47 (0.086 to 0.76)
Noone, 1980 | Number of patients evaluable for AEs: | 10* | | 10*
Noone, 1980 | Number of patients reporting AEs: | 6 (60%) | | 1 (10%)
Noone, 1980 | Total number of AEs reported: | N/S | | N/S
Noone, 1980 | Withdrawals due to AEs: | (See note) | | 0
Olerud, Gustavsson, and Furberg, 1986 | | Nadolol, 40–160 mg, 1x/day for 6 mos | | Propranolol, 40–80 mg, 2x/day for 6 mos | | Limited information provided. Investigators stated that “most” reported AEs were typical of beta-blockers. Nadolol vs. propranolol: 0.12 (−0.22 to 0.45)
Olerud, Gustavsson, and Furberg, 1986 | Number of patients evaluable for AEs: | 13 | | 15 | | Limited information provided. Investigators stated that “most” reported AEs were typical of beta-blockers. Nadolol vs. propranolol: 0.12 (−0.22 to 0.45)
Olerud, Gustavsson, and Furberg, 1986 | Number of patients reporting AEs: | 6 (46%) | | 5 (33%) | | Limited information provided. Investigators stated that “most” reported AEs were typical of beta-blockers. Nadolol vs. propranolol: 0.12 (−0.22 to 0.45)
Olerud, Gustavsson, and Furberg, 1986 | Total number of AEs reported: | N/S | | N/S | | Limited information provided. Investigators stated that “most” reported AEs were typical of beta-blockers. Nadolol vs. propranolol: 0.12 (−0.22 to 0.45)
Olerud, Gustavsson, and Furberg, 1986 | Withdrawals due to AEs: | 1 (cold fingers, tiredness) | | 0 | | Limited information provided. Investigators stated that “most” reported AEs were typical of beta-blockers. Nadolol vs. propranolol: 0.12 (−0.22 to 0.45)
Olsson, Behring, Forssman, et al., 1984 | | Metoprolol, 50 mg, 2x/day for 8 wks | | Propranolol, 40 mg, 2x/day for 8 wks
Olsson, Behring, Forssman, et al., 1984 | Number of patients evaluable for AEs: | 56* | | 56*
Olsson, Behring, Forssman, et al., 1984 | Number of patients reporting AEs: | N/S | | N/S
Olsson, Behring, Forssman, et al., 1984 | Total number of AEs reported: | 158 | | 141
Olsson, Behring, Forssman, et al., 1984 | Number of patients reporting: | n (%) | | n (%)
Olsson, Behring, Forssman, et al., 1984 | CNS symptoms | 36 (64%) | | 24 (43%)
Olsson, Behring, Forssman, et al., 1984 | GI symptoms | 24 (43%) | | 16 (29%)
Olsson, Behring, Forssman, et al., 1984 | Sleep disturbances | 17 (30%) | | 22 (39%)
Olsson, Behring, Forssman, et al., 1984 | Fatigue | 14 (25%) | | 17 (30%)
Olsson, Behring, Forssman, et al., 1984 | Cardiovascular symptoms | 12 (21%) | | 12 (21%)
Olsson, Behring, Forssman, et al., 1984 | Other | 55 (98%) | | 50 (89%)
Olsson, Behring, Forssman, et al., 1984 | Withdrawals due to AEs: | 0 | | 0
O’Neill and Mann, 1978 | | Aspirin, 650 mg, 2x/day for 3 mos | | Placebo | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Number of patients evaluable for AEs: | 12* | | 12* | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Number of patients reporting AEs: | 3 (25%) | | 0 | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Total number of AEs reported: | 3 | | 0 | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Number of patients reporting: | n (%) | | n (%) | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Gastritis | 3 (25%) | | 0 | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
O’Neill and Mann, 1978 | Withdrawals due to AEs: | 1 (gastritis) | | 0 | | Aspirin vs. placebo: 0.24 (−0.033 to 0.47)
Orholm, Honoré, and Zeeberg, 1986 | | Femoxetine, 200 mg/day initially, increasing over first nine days to 600 mg/day for total of 16 wks | | Placebo | | These data appear to include only those patients who completed the trial or were known to have withdrawn due to AEs (59/65 patients randomized to treatment), though this is not entirely clear. Femoxetine vs. placebo: 0.17 (−0.027 to 0.36)
Orholm, Honoré, and Zeeberg, 1986 | Number of patients evaluable for AEs: | 29 | | 30
Orholm, Honoré, and Zeeberg, 1986 | Number of patients reporting AEs: | 8 (28%) | | 3 (10%)
Orholm, Honoré, and Zeeberg, 1986 | Total number of AEs reported: | 14 | | 3
Orholm, Honoré, and Zeeberg, 1986 | Number of patients reporting: | n (%) | | n (%)
Orholm, Honoré, and Zeeberg, 1986 | Tremor | 3 (10%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Nausea | 3 (10%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Palpitation | 1 (3%) | | 1 (3%)
Orholm, Honoré, and Zeeberg, 1986 | Vomiting | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Stomach pain | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Orthostatic dizziness | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Tiredness | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Lack of appetite | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Constipation | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Perspiration | 1 (3%) | | 0
Orholm, Honoré, and Zeeberg, 1986 | Edema | 0 | | 1 (3%)
Orholm, Honoré, and Zeeberg, 1986 | Urticarial exanthema | 0 | | 1 (3%)
Orholm, Honoré, and Zeeberg, 1986 | Withdrawals due to AEs: | 4 (nausea, orthostatic dizziness; tiredness, stomach pain; tremor, nausea, palpitation, lack of appetite; tremor) | | 2 (edema, palpitation)
Osterman, 1977 | | Pizotifen, inc’d from 0.5 mg, 1x/day to 1 mg, 3x/day for 8 wks | Iprazochrome, inc’d from 2.5 mg, 1x/day to 5 mg, 3x/day for 8 wks | Placebo | | The data at left appear to concern only those 27 patients who completed all three treatments of the crossover trial, plus one patient who only completed treatment with iprazochrome and placebo. These were the patients (of the 30 originally randomized to treatment) for whom efficacy data were analyzed. One patient, not included in efficacy analyses, withdrew due to “abdominal problems due to both placebo and pizotifen.” Investigators stated that AEs were frequent during treatment with pizotifen, with drowsiness and weight gain being the most common. Investigators also reported that there was no difference between iprazochrome and placebo with respect to AEs.
Osterman, 1977 | Number of patients evaluable for AEs: | 27* (See note) | 27* (See note) | 27* (See note)
Osterman, 1977 | Number of patients reporting AEs: | N/S | N/S | N/S
Osterman, 1977 | Total number of AEs reported: | 68 | 12 | 11
Osterman, 1977 | Number of patients reporting: | n (%) | n (%) | n (%)
Osterman, 1977 | Weight gain > 1.5 kg | 21 (78%) | 1 (4%) | 2 (7%)
Osterman, 1977 | Weight gain > 4 kg | 8 (30%) | 0 | 0
Osterman, 1977 | Drowsiness | 15 (56%) | 6 (22%) | 4 (15%)
Osterman, 1977 | Of above “drowsiness,” those which were “severe” | 9 (33%) | 1 (4%) | 1 (4%)
Osterman, 1977 | Increased appetite and hunger | 12 (44%) | 2 (7%) | 3 (11%)
Osterman, 1977 | Depression | 3 (11%) | 2 (7%) | 1 (4%)
Osterman, 1977 | Withdrawals due to AEs: | 1 (N/S) | 0 | 0
Palferman, Gibberd, and Simmonds, 1983 | | Propranolol, 40 mg, 3x/day for 2 mos | | Placebo | | Investigators stated that, among patients completing the trial, minor AEs, most commonly fatigue, were reported exclusively in association with propranolol.
Palferman, Gibberd, and Simmonds, 1983 | Number of patients evaluable for AEs: | 16* | | 16* | | Investigators stated that, among patients completing the trial, minor AEs, most commonly fatigue, were reported exclusively in association with propranolol.
Palferman, Gibberd, and Simmonds, 1983 | Number of patients reporting AEs: | N/S | | N/S | | Investigators stated that, among patients completing the trial, minor AEs, most commonly fatigue, were reported exclusively in association with propranolol.
Palferman, Gibberd, and Simmonds, 1983 | Total number of AEs reported: | N/S | | N/S | | Investigators stated that, among patients completing the trial, minor AEs, most commonly fatigue, were reported exclusively in association with propranolol.
Palferman, Gibberd, and Simmonds, 1983 | Withdrawals due to AEs: | 0 | | 1 (dizziness) | | Investigators stated that, among patients completing the trial, minor AEs, most commonly fatigue, were reported exclusively in association with propranolol.
Pedersen and Møller, 1966 | | Methysergide (prolonged-action), 6 mg/day for 6 wks | | Placebo | | Data at left are for those patients who completed the trial (60/102). Seven patients withdrew prematurely due to AEs associated with methysergide (intermittent claudication [3]; cardiac symptoms [2]; severe dizziness, nausea, and vomiting [2], in one case accompanied by generalized edema and an increase in body weight). No patients withdrew due to AEs associated with placebo. Methysergide vs. placebo: 0.15 (−0.0075 to 0.30)
Pedersen and Møller, 1966 | Number of patients evaluable for AEs: | 60* | | 60*
Pedersen and Møller, 1966 | Number of patients reporting AEs: | 20 (33%) | | 11 (18%)
Pedersen and Møller, 1966 | Total number of AEs reported: | 31 | | 16
Pedersen and Møller, 1966 | Number of patients reporting: | n (%) | | n (%)
Pedersen and Møller, 1966 | Leg symptoms | 12 (20%) | | 5 (8%)
Pedersen and Møller, 1966 | Fatigue | 6 (10%) | | 4 (7%)
Pedersen and Møller, 1966 | Cardiac symptoms | 4 (7%) | | 4 (7%)
Pedersen and Møller, 1966 | Dizziness | 3 (5%) | | 1 (2%)
Pedersen and Møller, 1966 | Nausea | 3 (5%) | | 1 (2%)
Pedersen and Møller, 1966 | Edema | 3 (5%) | | 1 (2%)
Pedersen and Møller, 1966 | Withdrawals due to AEs: | (See note) | | (See note)
Pini, Ferrari, Guidetti, et al., 1985 | | Flunarizine, 20 mg/day for 14 days, then 10 mg/day for up to 106 days | | Placebo | | Limited information provided on AEs. No patients experienced AEs requiring them to withdraw or impairing their usual activities. Significant weight gain was reported by 29% of patients on flunarizine. Motor disturbances such as extra-pyramidal reactions were not observed.
Pini, Ferrari, Guidetti, et al., 1985 | Number of patients evaluable for AEs: | 14 or 15 | | 14 or 15
Pini, Ferrari, Guidetti, et al., 1985 | Number of patients reporting AEs: | N/S | | N/S
Pini, Ferrari, Guidetti, et al., 1985 | Total number of AEs reported: | N/S | | N/S
Pini, Ferrari, Guidetti, et al., 1985 | Withdrawals due to AEs: | 0 | | 0
Pita, Higueras, Bolaños, et al., 1977 | | Propranolol, 40 mg, 4x/day for 2 mos | | Placebo | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Number of patients evaluable for AEs: | 9* | | 9* | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Number of patients reporting AEs: | 3 (33%) | | 0 | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Total number of AEs reported: | 3 | | 0 | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Number of patients reporting: | n (%) | | n (%) | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Orthostatic hypotension | 1 (11 %) | | 0 | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Light pyrosis | 2 (22%) | | 0 | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pita, Higueras, Bolaños, et al., 1977 | Withdrawals due to AEs: | 1 (orthostatic hypotension) | | 0 | | Propranolol vs. placebo: 0.31 (−0.024 to 0.59)
Pradalier, Serratrice, Collard, et al., 1989b | | Propranolol (long-acting) 160 mg, 1x/day for 3 mos | | Placebo
Pradalier, Serratrice, Collard, et al., 1989b | Number of patients evaluable for AEs: | 31 | | 24
Pradalier, Serratrice, Collard, et al., 1989b | Number of patients reporting AEs: | N/S | | N/S
Pradalier, Serratrice, Collard, et al., 1989b | Total number of AEs reported: | N/S | | N/S
Pradalier, Serratrice, Collard, et al., 1989b | Number of patients reporting (in response to questionnaire): | n (%) | | n (%)
Pradalier, Serratrice, Collard, et al., 1989b | Tiredness | 8 (26%) | | 7 (29%)
Pradalier, Serratrice, Collard, et al., 1989b | Insomnia | 5 (16%) | | 5 (21%)
Pradalier, Serratrice, Collard, et al., 1989b | Constipation | 3 (10%) | | 7 (29%)
Pradalier, Serratrice, Collard, et al., 1989b | Dyspnea | 6 (19%) | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Depression | 2 (6%) | | 5 (21 %)
Pradalier, Serratrice, Collard, et al., 1989b | Dizziness | 3 (10%) | | 2 (8%)
Pradalier, Serratrice, Collard, et al., 1989b | Dyspepsia | 2 (6%) | | 3 (13%)
Pradalier, Serratrice, Collard, et al., 1989b | Diarrhea | 3 (10%) | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Cold extremities | 0 | | 4 (17%)
Pradalier, Serratrice, Collard, et al., 1989b | Headache | 1 (3%) | | 2 (8%)
Pradalier, Serratrice, Collard, et al., 1989b | Nausea | 1 (3%) | | 0
Pradalier, Serratrice, Collard, et al., 1989b | Eye troubles | 0 | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Rash | 0 | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Wheezing | 0 | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Impotence | 0 | | 1 (4%)
Pradalier, Serratrice, Collard, et al., 1989b | Withdrawals due to AEs: | 0 | | 0
Presthus, 1971 | | Pizotifen, 0.5 mg. 3x/day for 5 wks | | Methysergide, 1 mg, 3x/day for 5 wks
Presthus, 1971 | Number of patients evaluable for AEs: | 21* | | 21*
Presthus, 1971 | Number of patients reporting AEs: | N/S | | 1 (5%)
Presthus, 1971 | Total number of AEs reported: | 20 | | 1
Presthus, 1971 | Number of patients reporting: | n (%) | | n (%)
Presthus, 1971 | Weight gain | 14 (67%) | | 0
Presthus, 1971 | Fatigue | 3 (14%) | | 0
Presthus, 1971 | Drowsiness | 1 (5%) | | 0
Presthus, 1971 | Dysphoria | 1 (5%) | | 0
Presthus, 1971 | Restless legs | 1 (5%) | | 0
Presthus, 1971 | Exanthema | 0 | | 1 (5%)
Presthus, 1971 | Withdrawals due to AEs: | 0 | | 1 (exanthema accompained by fatigue, nausea, vomiting, and diarrhea)
Rascol, Montastruc, and Rascol, 1986 | | Flunarizine, 10 mg/day for 2 mas | | Pizotifen, 2.19 mg/day for 2 mos (lower during 1st wk) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Number of patients evaluable for AEs: | 21 | | 14 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Number of patients reporting AEs: | 6 (29%) | | 4 (29%) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Total number of AEs reported: | 10 | | 5 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Number of patients reporting: | n (%) | | n (%) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Weight gain | 6 (29%) | | 4 (29%) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Oversleeping | 1 (5%) | | 0 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Dreaming | 1 (5%) | | 0 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Hot flushes | 1 (5%) | | 0 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Drowsiness | 1 (5%) | | 0 | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Asthenia | 0 | | 1 (7%) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rascol, Montastruc, and Rascol, 1986 | Withdrawals due to AEs: | 1 (weight gain and drowsiness) | | 1 (weight gain and asthenia) | | Flunarizine vs. pizotifen: −0.0047 (−0.29 to 0.29)
Rompel and Bauermeister, 1970 | | Carbamazepine, 600 mg/day for 6 wks | | Placebo | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Number of patients evaluable for AEs: | 48* | | 48* | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Number of patients reporting AEs: | 30 (63%) | | 11 (23%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Total number of AEs reported: | N/S | | N/S | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Number of patients reporting: | n (%) | | n (%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Vertigo or giddiness | 23 (48%) | | 2 (4%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Drowsiness | 5 (10%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Nausea | 4 (8%) | | 3 (6%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Dry mouth | 2 (4%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Heavy eyes | 2 (4%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Constipation | 2 (4%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Vomiting | 1 (2%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Weight gain | 1 (2%) | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Sweating | 1 (2%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Rash | 1 (2%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Dysuria | 1 (2%) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Blocked nose | 0 | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Lack of drive | 0 | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Flushing | 0 | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Blunted feeling | 0 | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Heavy head | 0 | | 1 (2%) | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Rompel and Bauermeister, 1970 | Withdrawals due to AEs: | 1 (causative AEs N/S) | | 0 | | Carbamazepine vs placebo: 0.39 (0.20 to 0.56)
Ryan, 1968 | | Pizotifen, 2 mg, 2x/day for 4 wks | Methysergide, 2 mg, 2x/day for 4 wks | Placebo | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Number of patients evaluable for AEs: | 62* | 62* | 62* | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Number of patients reporting AEs: | N/S | N/S | N/S | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Total number of AEs reported: | 34 | 24 | 10 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Number of patients reporting | n (%) | n (%) | n (%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Drowsiness | 14 (23%) | 4 (6%) | 3 (5%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Weight gain | 8 (13%) | 1 (2%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Nausea | 2 (3%) | 4 (6%) | 2 (3%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Dry mucous membranes | 4 (6%) | 1 (2%) | 2 (3%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Nervousness | 1 (2%) | 3 (5%) | 1 (2%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Vertigo | 1 (2%) | 2 (3%) | 1 (2%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Abdominal cramps | 2 (3%) | 1 (2%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Bloated sensation | 1 (2%) | 2 (3%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Leg cramps | 0 | 2 (3%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Insomnia | 0 | 2 (3%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Increased appetite | 1 (2%) | 0 | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Vomiting | 0 | 1 (2%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Floating sensation | 0 | 0 | 1 (2%) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Edema in extremities | 0 | 1 (2%) | 0 | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1968 | Withdrawals due to AEs: | (See note) | (See note) | (See note) | | This article says nothing about dropouts and therefore appears to be reporting only on those patients who completed the trial.
Ryan, 1971 | | Pizotifen (BC105), inc’d from 0.5 mg, 1x/day to 1.0 mg. 3x/day for 2 wks; then dosage adjusted according to a protocol for 10 wks | | Placebo | | Data at left on AEs appear to concern all patients randomized to treatment, but this is unclear. Investigators reported that one patient withdrew from pizotifen treatment due to increased blood pressure. Three others withdrew for unspecified reasons (pizotifen 1, placebo 2).
Ryan, 1971 | Number of patients evaluable for AEs: | 27 (See note) | | 24 (See note)
Ryan, 1971 | Number of patients reporting AEs: | N/S | | N/S
Ryan, 1971 | Total number of AEs reported: | 54 | | 14
Ryan, 1971 | Number of patients reporting | n (%) | | n (%)
Ryan, 1971 | Increased appetite | 17 (63%)) | | 0
Ryan, 1971 | Drowsy | 16 (60%) | | 6 (25%)
Ryan, 1971 | Weight gain | 7 (26%) | | 0
Ryan, 1971 | Nausea | 6 (22%) | | 5 (21%)
Ryan, 1971 | Ankle edema | 2 (7%) | | 0
Ryan, 1971 | Nervous | 2 (7%) | | 1 (4%)
Ryan, 1971 | Vertigo | 2 (7%) | | 0
Ryan, 1971 | Dry mouth | 1 (4%) | | 0
Ryan, 1971 | Vomiting | 1 (4%) | | 2 (8%)
Ryan, 1971 | Withdrawals due to AEs: | 1 (increased blood pressure) | | N/S (See note)
Ryan, 1978 | | Ovral® (norgestrel 0.5 mg + ethinyl estradiol 0.05 mg), 1x/day for 2 mos | | No treatment | | Limited information provided on AEs. AEs reported with Ovral® included nausea and/or vomiting, abdominal cramping, depression, drowsiness, dry mouth, and pigmented skin (no n’s reported).
Ryan, 1978 | Number of patients evaluable for AEs: | 40* | | 40* | | Limited information provided on AEs. AEs reported with Ovral® included nausea and/or vomiting, abdominal cramping, depression, drowsiness, dry mouth, and pigmented skin (no n’s reported).
Ryan, 1978 | Number of patients reporting AEs: | 28 (70%) | | N/S | | Limited information provided on AEs. AEs reported with Ovral® included nausea and/or vomiting, abdominal cramping, depression, drowsiness, dry mouth, and pigmented skin (no n’s reported).
Ryan, 1978 | Total number of AEs reported: | N/S | | N/S | | Limited information provided on AEs. AEs reported with Ovral® included nausea and/or vomiting, abdominal cramping, depression, drowsiness, dry mouth, and pigmented skin (no n’s reported).
Ryan, 1978 | Withdrawals due to AEs: | 0 | | 0 | | Limited information provided on AEs. AEs reported with Ovral® included nausea and/or vomiting, abdominal cramping, depression, drowsiness, dry mouth, and pigmented skin (no n’s reported).
Ryan, 1984 | | Nadolol, 160 mg/day for 3 mos | Nadolol, 80 mg/day for 3 mos | Propranolol, 160 mg/day for 3 mos | | No further information provided on AEs.
Ryan, 1984 | Number of patients evaluable for AEs | 16 | 16 | 16 | | No further information provided on AEs.
Ryan, 1984 | Number of patients reporting AEs | N/S | N/S | N/S | | No further information provided on AEs.
Ryan, 1984 | Total number of AEs reported: | N/S | N/S | N/S | | No further information provided on AEs.
Ryan, 1984 | Withdrawals due to AEs: | 0 | 1 (gastric symptoms) | 0 | | No further information provided on AEs.
Ryan, Diamond, and Ryan, 1975 | | Clonidine, 0.025 – 0.075 mg, 2x/day for 8 wks | | Placebo | | Investigators did not provide the number of patients affected, the number of AEs reported, or the treatment groups associated with AEs. Authors only reported that the same number of AEs were experienced with each treatment and that no AEs incapacitated patients. The most common AEs were nausea, nervousness, and tiredness. Other rare AEs were dry mouth, drowsiness, vertigo, sleepiness, insomnia, and an increased number of HAs.
Ryan, Diamond, and Ryan, 1975 | Number of patients evaluable for AEs: | 133* | | 133*
Ryan, Diamond, and Ryan, 1975 | Number of patients reporting AEs: | N/S (See note) | | N/S (See note)
Ryan, Diamond, and Ryan, 1975 | Total number of AEs reported: | N/S | | N/S
Ryan, Diamond, and Ryan, 1975 | Withdrawals due to AEs: | 0 | | 0
Ryan and Ryan, 1981 | | Aspirin + dipyridamole. 325 + 75 mg. 4x/day for 8 wks | Aspirin, 325 mg, 4x/day for 8 wks | Dipyridamole 75 mg. 4x/day for 8 wks | Placebo | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Number of patients evaluable for AEs: | 40 | 40 | 40 | 40 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Number of patients reporting AEs: | N/S | N/S | N/S | N/S | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Total number of AEs reported: | 20 | 2 | 16 | 5 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Number of patients reporting: | n (%) | n (%) | n (%) | n (%) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Increased HA | 5 (13%) | 0 | 6 (15%) | 2 (5%) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Nausea | 6 (15%) | 1 (3%) | 4 (10%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Vomiting | 2 (5%) | 0 | 1 (3%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Vertigo | 1 (3%) | 0 | 2 (5%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Cramps | 2 (5%) | .0 | 0 | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Head pressure | 2 (5%) | 0 | 0 | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Skin bruises | 1 (3%) | 0 | 0 | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Frequent urination | 1 (3%) | 0 | 0 | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Hot flashes | 0 | 1 (3%) | 0 | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Diarrhea | 0 | 0 | 1 (3%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Chest pain | 0 | 0 | 1 (3%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Tinnitus | 0 | 0 | 1 (3%) | 0 | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Sensitivity to odors | 0 | 0 | 0 | 1 (3%) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Chills | 0 | 0 | 0 | 1 (3%) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Rapid heart beat | 0 | 0 | 0 | 1 (3%) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan and Ryan, 1981 | Withdrawals due to AEs: | (See note) | (See note) | (See note) | (See note) | No information on dropouts was provided. Data at left may be for those patients who completed the trial only; this is unclear.
Ryan, Ryan, and Sudilovsky, 1983 | | Nadolol, 240 mg/day for 3 mos | Nadolol, 160 mg/day for 3 mos | Nadolol, 80 mg/day for 3 mos | Placebo | Data at left on AEs concern all 80 patients randomized to treatment. One patient dropped out. Investigators did not report the treatment group from which the patient withdrew or the reason for withdrawal.
Ryan, Ryan, and Sudilovsky, 1983 | Number of patients evaluable for AEs: | 20 | 20 | 20 | 20
Ryan, Ryan, and Sudilovsky, 1983 | Number of patients reporting AEs: | 10 (50%) | 5 (25%) | 5 (25%) | 5 (25%)
Ryan, Ryan, and Sudilovsky, 1983 | Total number of AEs reported: | N/S | N/S | N/S | N/S
Ryan, Ryan, and Sudilovsky, 1983 | Number of patients reporting: | n (%) | n (%) | n (%) | n (%)
Ryan, Ryan, and Sudilovsky, 1983 | Drowsiness | 1 | 1 | 3 | 1
Ryan, Ryan, and Sudilovsky, 1983 | Vertigo | 1 | 2 | 1 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Insomnia | 2 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Sweaty | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Blurred vision | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Tinitus | 0 | 0 | 0 | 1
Ryan, Ryan, and Sudilovsky, 1983 | Kidney stone | 0 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Bloating | 0 | 1 | 1 | 1
Ryan, Ryan, and Sudilovsky, 1983 | General weakness | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Nausea | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Chest pain | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Weak extremities | 0 | 0 | 0 | 1
Ryan, Ryan, and Sudilovsky, 1983 | Decreased sex | 0 | 1 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Numbness in extremities | 1 | 0 | 0 | 0
Ryan, Ryan, and Sudilovsky, 1983 | Withdrawals due to AEs: | (See note) | (See note) | (See note) | (See note)
Sances, Martignoni, Fioroni, et al., 1990 | | Naproxen sodium, 550 mg, 2x/day for 3 (n= 17) or 6 (n = 18) mos | | Placebo, for 3 mos | | The article appears to report data on AEs only for those patients who completed the trial (35/40), and does not separately report data from the controlled (mos 1–3) and uncontrolled (mos 4–6) portions of the trial. Two patients withdrew due to AEs (severe gastralgia and nausea) before completing the controlled trial; it is not stated which treatment they were using at the time they withdrew. On the trial design, see Evidence Table 1.
Sances, Martignoni, Fioroni, et al., 1990 | Number of patients evaluable for AEs: | 35 (See note) | | 17 (See note)
Sances, Martignoni, Fioroni, et al., 1990 | Number of patients reporting AEs: | N/S | | N/S
Sances, Martignoni, Fioroni, et al., 1990 | Total number of AEs reported: | N/S | | N/S
Sances, Martignoni, Fioroni, et al., 1990 | Number of patients reporting: | n (%) | | n (%)
Sances, Martignoni, Fioroni, et al., 1990 | Mild-mod nausea and epigastric distress | 9 (26%) | | N/S
Sances, Martignoni, Fioroni, et al., 1990 | Withdrawals due to AEs: | (See note) | | (See note)
Sances, Martignoni, Rosettino, et al., 1989 | | Lisuride, 0.05 mg, 3x/day for 3 mos | | Placebo | | Limited data on AEs were provided. Investigators reported that 4/40 patients (10%) dropped out due to nausea, vomiting, and hypotension, but did not specify from which treatment groups they withdrew or whether or not dropouts were included in efficacy analyses.
Sances, Martignoni, Rosettino, et al., 1989 | Number of patients evaluable for AEs: | 20 | | 20
Sances, Martignoni, Rosettino, et al., 1989 | Number of patients reporting AEs: | N/S | | N/S
Sances, Martignoni, Rosettino, et al., 1989 | Total number of AEs reported: | N/S | | N/S
Sances, Martignoni, Rosettino, et al., 1989 | Withdrawals due to AEs: | (See note) | | (See note)
Saper, Silberstein, Lake, et al., 1994 | | Fluoxetine, doses ranging from 20–40 mg/day, for 12 wks | | Placebo | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Number of patients evaluable for AEs: | 61 (See note) | | 50 (See note) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Number of patients reporting AEs: | 51 (84%) | | 33 (66%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Number of patients reporting severe AEs: | 5 (8%) | | 2 (4%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Total number of AEs reported: | N/S | | N/S | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Number of patients reporting: | n (%) | | n (%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Fatigue | 15 (25%) | | 13 (26%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Sleeping problems | 17 (28%) | | 4 (8%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Tremors | 12 (20%) | | 3 (6%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Stomach pain | 8 (13%) | | 0 | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Weight loss (5–15 Ibs) | 5 (8%) | | 1 (2%) | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Saper, Silberstein, Lake, et al., 1994 | Withdrawals due to AEs: | 0 | | 0 | | Combined AE data were reported for migraine (n = 57) and CDH (n = 54) patients. List of specific AEs does not represent all AEs reported by patients. Fluoxetine vs. placebo: 0.18 (0.012 to 0.33)
Sargent, Solbach, Damasio, et al., 1985 | | Naproxen sodium, 550 mg, 2x/day for 15 wks | Propranolol, 40 mg, 2x/day for 2 wks, 3x/day for 12 wks, 2x/day for 1 wk | Placebo | | AE data were reported for the 149 patients who started the first active treatment period, but investigators did not report how these patients were distributed among the three treatment groups. The authors reported that patients in the naproxen sodium group reported more GI complaints than patients in the other two groups, and that the incidence and severity of non-GI AEs were comparable in the naproxen sodium and propranolol groups.
Sargent, Solbach, Damasio, et al., 1985 | Number of patients evaluable for AEs: | N/S | N/S | N/S
Sargent, Solbach, Damasio, et al., 1985 | Number of patients reporting AEs: | 38 | 30 | 28
Sargent, Solbach, Damasio, et al., 1985 | Total number of AEs reported: | N/S | N/S | N/S
Sargent, Solbach, Damasio, et al., 1985 | Withdrawals due to AEs: | 3 (rash) | 0 | 0
Shafar, Tallett, and Knowlson, 1972 | | Clonidine, 50 μg, 2x/day for 16 wks | | Placebo | | AEs reported at left are for the 50 patients (of 65) included in efficacy analyses only. Of those dropping out of study, 2 withdrew after being treated with clonidine (1 for “general malaise,” 1 because HAs worsened). Three others withdrew for reasons unrelated to AES, and 10 withdrew for reasons unknown to investigators. Clonidine vs. placebo: 0.16 (−0.02 to 0.33)
Shafar, Tallett, and Knowlson, 1972 | Number of patients evaluable for AEs: | 50* (See note) | | 50* (See note)
Shafar, Tallett, and Knowlson, 1972 | Number of patients reporting AEs: | 20 (40%) | | 12 (24%)
Shafar, Tallett, and Knowlson, 1972 | Total number of AEs reported: | 36 | | 17
Shafar, Tallett, and Knowlson, 1972 | Number of patients reporting (complete list:) | n (%) | | n (%)
Shafar, Tallett, and Knowlson, 1972 | Anxiety: | 6 (12%) | | 2
Shafar, Tallett, and Knowlson, 1972 | Depression: | 0 | | 1 (2%)
Shafar, Tallett, and Knowlson, 1972 | Dry mouth: | 8 (16%) | | 2 (4%)
Shafar, Tallett, and Knowlson, 1972 | Fatigue: | 1 (2%) | | 0
Shafar, Tallett, and Knowlson, 1972 | Gastrointestinal: | 12 (24%) | | 9 (18%)
Shafar, Tallett, and Knowlson, 1972 | Palpitation, flushes: | 5 (10%) | | 2 (4%)
Shafar, Tallett, and Knowlson, 1972 | Rash: | 1 (2%) | | 0
Shafar, Tallett, and Knowlson, 1972 | Others (trivial): | 3 (6%) | | 1 (2%)
Shafar, Tallett, and Knowlson, 1972 | Withdrawals due to AEs: | (See note) | | (See note)
Shekelle and Ostfeld, 1964 | | Methysergide, 2 mg, 3x/day for 5 wks | | Placebo | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Number of patients evaluable for AEs: | 13* | | 13* | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Number of patients reporting AEs: | 2 (15%) | | 1 (8%) | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Total number of AEs reported: | 2 | | 1 | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Number of patients reporting: | n (%) | | n (%) | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Mild ache in calves | 1 (8%) | | 1 (8%) | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Hair loss | 1 (8%) | | 0 | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shekelle and Ostfeld, 1964 | Withdrawals due to AEs: | (See note) | | (See note) | | Data at left are for those patients who completed the trial (13/16). None of the three patients who withdrew prematurely did so due to AEs. Methysergide vs. placebo: 0.073 (−0.18 to 0.32)
Shimell, Fritz, and Levien, 1990 | | Flunarizine, 10 mg/day (dose achieved gradually over 4 days) for 4 mos | | Propranolol, 180 mg/day (dose achieved gradually over 20 days) for 4 mos
Shimell, Fritz, and Levien, 1990 | Number of patients evaluable for AEs: | 28 | | 29
Shimell, Fritz, and Levien, 1990 | Number of patients reporting AEs: | N/S | | N/S
Shimell, Fritz, and Levien, 1990 | Total number of AEs reported: | 17 | | 31
Shimell, Fritz, and Levien, 1990 | Number of patients reporting: | n (%) | | n (%)
Shimell, Fritz, and Levien, 1990 | Sleepiness/tiredness | 6 (21%) | | 8 (28%)
Shimell, Fritz, and Levien, 1990 | Weight gain | 9 (32%) | | 4 (14%)
Shimell, Fritz, and Levien, 1990 | Nightmares | 2 (7%) | | 3 (10%)
Shimell, Fritz, and Levien, 1990 | Drowsiness | 0 | | 3 (10%)
Shimell, Fritz, and Levien, 1990 | Irritability | 0 | | 3 (10%)
Shimell, Fritz, and Levien, 1990 | Disturbed sleep | 0 | | 3 (10%)
Shimell, Fritz, and Levien, 1990 | Lethargy | 0 | | 2 (7%)
Shimell, Fritz, and Levien, 1990 | Skin rash | 0 | | 1 (3%)
Shimell, Fritz, and Levien, 1990 | Bitter taste | 0 | | 1 (3%)
Shimell, Fritz, and Levien, 1990 | Tingling sensation | 0 | | 1 (3%)
Shimell, Fritz, and Levien, 1990 | Hot flushes | 0 | | 1 (3%)
Shimell, Fritz, and Levien, 1990 | Excessive diuresis | 0 | | 1 (3%)
Shimell, Fritz, and Levien, 1990 | Withdrawals due to AEs: | 2 (weight gain) | | 3 (nightmares [2], rash [1])
Shukla, Garg, Nag, et al., 1995 | | Nifedipine, 15 mg/day for 4 wks | | Placebo | | Data reported appear to be for those patients who completed the trial (28/36), though this is unclear. Investigators stated that they did not observe any cases of worsening of HA or hypotension associated with nifedipine. Patients were asked about AEs at end of each treatment period. Nifedipine vs. placebo: 0.035 (−0.058 to 0.13)
Shukla, Garg, Nag, et al., 1995 | Number of patients evaluable for AEs: | 28* | | 28*
Shukla, Garg, Nag, et al., 1995 | Number of patients reporting AEs: | 1 (4%) | | 0
Shukla, Garg, Nag, et al., 1995 | Total number of AEs reported: | 1 | | 0
Shukla, Garg, Nag, et al., 1995 | Number of patients reporting: | n (%) | | n (%)
Shukla, Garg, Nag, et al., 1995 | Nervousness | 1 (4%) | | 0
Shukla, Garg, Nag, et al., 1995 | Withdrawals due to AEs: | 0 | | 0
Sicuteri, 1973 | | Oxitriptan (L-5-hydroxytryptophan or 5-HTP), 100 mg, 2x/day for 40 days | | Methysergide,1 mg, 2x/day for 40 days | | Very limited information was provided about AEs. Authors reported that oxitriptan was very well tolerated: an increase in appetite and/or body weight was reported in a few cases, but no patients withdrew due to AEs.
Sicuteri, 1973 | Number of patients evaluable for AEs: | 20 | | 20
Sicuteri, 1973 | Number of patients reporting AEs: | N/S | | N/S
Sicuteri, 1973 | Total number of AEs reported: | N/S | | N/S
Sicuteri, 1973 | Withdrawals due to AEs: | 0 | | N/S
Sjaastad and Stensrud, 1969 | | Pizotifen, 1 mg, 4x/day for 8 wks | | Placebo | | Limited data on AEs were provided for this crossover trial, and investigators did not report whether information on AEs were from all 24 patients randomized to treatment or from the 20 from whom efficacy data were obtained. Fourteen patients treated with pizotifen gained weight and all had “tremendous appetites.” An unspecified number of patients were drowsy and easily fatigued (treatment N/S). Two patients (treatment N/S) also experienced vertigo.
Sjaastad and Stensrud, 1969 | Number of patients evaluable for AEs: | (See note) | | (See note)
Sjaastad and Stensrud, 1969 | Number of patients reporting AEs: | N/S | | N/S
Sjaastad and Stensrud, 1969 | Total number of AEs reported: | N/S | | N/S
Sjaastad and Stensrud, 1969 | Withdrawals due to AEs: | (thrombophlebitis [1]) | | 0
Sjaastad and Stensrud, 1971 | | Clonidine (Catapresan®), 25 μg, 3x/day for 3 wks | | Placebo | | Data at left appear to concern only those patients who completed the crossover. Investigators reported that a few patients experienced the throbbing, pounding sensation of a HA attack, but without any accompanying pain. Investigators stated that 4 patients withdrew for unknown reasons.
Sjaastad and Stensrud, 1971 | Number of patients evaluable for AEs: | 26* (See note) | | 26* (See note)
Sjaastad and Stensrud, 1971 | Number of patients reporting AEs: | N/S | | N/S
Sjaastad and Stensrud, 1971 | Total number of AEs reported: | 12 (46%) | | 0
Sjaastad and Stensrud, 1971 | Number of patients reporting: | n (%) | | n (%)
Sjaastad and Stensrud, 1971 | Drowsiness | 8 (31%) | | 0
Sjaastad and Stensrud, 1971 | Dryness of mouth | 3 (12%) | | 0
Sjaastad and Stensrud, 1971 | Thirst | 1 (4%) | | 0
Sjaastad and Stensrud, 1971 | Withdrawals due to AEs: | N/S (See note) | | N/S (See note)
Sjaastad and Stensrud, 1972 | | Pindolol, 2.5 or 5 mg, 3x/day for 4 wks | | Placebo
Sjaastad and Stensrud, 1972 | Number of patients evaluable for AEs: | 28* | | 28*
Sjaastad and Stensrud, 1972 | Number of patients reporting AEs: | N/S | | N/S
Sjaastad and Stensrud, 1972 | Total number of AEs reported: | 22 | | 2
Sjaastad and Stensrud, 1972 | Number of patients reporting: | n (%) | | n (%)
Sjaastad and Stensrud, 1972 | Dizziness or faintness | 6 (21%) | | 0
Sjaastad and Stensrud, 1972 | Nausea | 3 (11%) | | 0
Sjaastad and Stensrud, 1972 | Lethargy | 3(11%) | | 0
Sjaastad and Stensrud, 1972 | Chest discomfort | 1 (4%) | | 1 (4%)
Sjaastad and Stensrud, 1972 | Increased appetite, weight gain | 1 (4%) | | 1 (4%)
Sjaastad and Stensrud, 1972 | Flushing | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Palpitations | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Restlessness | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Dryness of mouth | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Dyspnea | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Reduced ability to concentrate | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | “Feeling of unreality” | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Feeling of inability to judge distance | 1 (4%) | | 0
Sjaastad and Stensrud, 1972 | Withdrawals due to AEs: | 3 (causative AEs N/S) | | 0
Smits, van der Meer, Pfeil, et al., 1993 | | Estradiol (Estraderm TTS® patch), 50 μg/day for 8 days during 1–2 menstrual cycles | | Placebo | | Limited information reported on AEs. Itching in the area of the patch was reported in 9% of menstrual cycles during which Estraderm TTS® was used and in no cycles during which the placebo patch was used. Breast tenderness and bleeding pattern changes were no more common with Estraderm TTS® than with placebo.
Smits, van der Meer, Pfeil, et al., 1993 | Number of patients evaluable for AEs: | 20* | | 20*
Smits, van der Meer, Pfeil, et al., 1993 | Number of patients reporting AEs: | N/S | | N/S
Smits, van der Meer, Pfeil, et al., 1993 | Total number of AEs reported: | N/S | | N/S
Smits, van der Meer, Pfeil, et al., 1993 | Withdrawals due to AEs: | 0 | | 0
Stensrud and Sjaastad, 1976a | | Clonidine (Catapresan®), 75–150 μg/day for 7 wks | | Placebo | | Investigators provided no information on AEs. Two patients withdrew from the study, one for a reason unrelated to AEs. No explanation was given for the other’s withdrawal.
Stensrud and Sjaastad, 1976a | Number of patients evaluable for AEs: | 27* (See note) | | 27* (See note) | | Investigators provided no information on AEs. Two patients withdrew from the study, one for a reason unrelated to AEs. No explanation was given for the other’s withdrawal.
Stensrud and Sjaastad, 1976a | Number of patients reporting AEs: | N/S | | N/S | | Investigators provided no information on AEs. Two patients withdrew from the study, one for a reason unrelated to AEs. No explanation was given for the other’s withdrawal.
Stensrud and Sjaastad, 1976a | Total number of AEs reported: | N/S | | N/S | | Investigators provided no information on AEs. Two patients withdrew from the study, one for a reason unrelated to AEs. No explanation was given for the other’s withdrawal.
Stensrud and Sjaastad, 1976a | Withdrawals due to AEs: | N/S (See note) | | N/S (See note) | | Investigators provided no information on AEs. Two patients withdrew from the study, one for a reason unrelated to AEs. No explanation was given for the other’s withdrawal.
Solomon, 1986 | | Verapamil, 240 mg/day for 2 mos | Propranolol (long-acting), 120 mg/day for 2 mos | Placebo | | Abstract reporting limited results. Data at left are for those patients who completed the trial (15/?). Investigators reported that, apart from the specific AEs listed at left, AEs were “similar” in the three groups. Three patients withdrew before completing the trial due to AEs associated with verapamil (1 rash, 2 headache). Two withdrew due to AEs associated with propranolol (1 wheezing, 1 fatigue).
Solomon, 1986 | Number of patients evaluable for AEs: | 15* | 15* | 15*
Solomon, 1986 | Number of patients reporting AEs: | N/S | N/S | N/S
Solomon, 1986 | Total number of AEs reported: | N/S | N/S | N/S
Solomon, 1986 | Number of patients reporting: | n (%) | n (%) | n (%)
Solomon, 1986 | Constipation | 5 | N/S | N/S
Solomon, 1986 | Lightheadedness/fatigue | N/S | 3 | N/S
Solomon, 1986 | Withdrawals due to AEs: | (See note) | (See note) | (See note)
Solomon and Kunkel, 1993 | | Flurbiprofen, 100 mg, 2x/day for 8 wks | | Placebo | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Number of patients evaluable for AEs: | 31* | | 31* | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Number of patients reporting drug-related AEs: | 5 (16%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Total number of drug-related AEs reported: | 8 | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Blood in stool | 2 (6%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Burning (no further specification) | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Drop in hemoglobin | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Drop in hematocrit | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Abdominal cramps with diarrhea | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Epigastric pain with emesis | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Cold sores in mouth | 1 (3%) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon and Kunkel, 1993 | Withdrawals due to AEs: | 2 (abdominal pain and burning) | | 0 | | Investigators reported only AEs they considered to be “drug-related.” Flurbiprofen vs. placebo: 0.16 (0.019 to 0.29)
Solomon, Steel, and Spaccavento, 1983 | | Verapamil, 320 mg/day for 3 mos | | Placebo | | Limited information provided on AEs. Investigators reported that there were no major side effects with verapamil. One patient had symptomatic hypotension during last month of trial.
Solomon, Steel, and Spaccavento, 1983 | Number of patients evaluable for AEs: | N/S | | N/S | | Limited information provided on AEs. Investigators reported that there were no major side effects with verapamil. One patient had symptomatic hypotension during last month of trial.
Solomon, Steel, and Spaccavento, 1983 | Number of patients reporting AEs: | N/S | | N/S | | Limited information provided on AEs. Investigators reported that there were no major side effects with verapamil. One patient had symptomatic hypotension during last month of trial.
Solomon, Steel, and Spaccavento, 1983 | Total number of AEs reported: | N/S | | N/S | | Limited information provided on AEs. Investigators reported that there were no major side effects with verapamil. One patient had symptomatic hypotension during last month of trial.
Solomon, Steel, and Spaccavento, 1983 | Withdrawals due to AEs: | 0 | | 2 (causative AEs N/S) | | Limited information provided on AEs. Investigators reported that there were no major side effects with verapamil. One patient had symptomatic hypotension during last month of trial.
Somerville and Herrmann, 1978 | | Lisuride, dose gradually increased to 0.025 mg, 3x/day, on Day 5 and used thereafter for 3 mos | | Placebo | | Data at left are for 17/150 patients (11 %) who withdrew due to AEs and were included in efficacy analyses. Investigators reported that other less severe AEs were “encountered frequently” by patients in both treatment groups. These AEs, all of which occurred more frequently in the lisuride- treated group, were muscle aches and pains, dizziness, cold feelings in the extremities, and palpitations. Lisuride vs. placebo: 0.10 (−0.0097 to 0.22)
Somerville and Herrmann, 1978 | Number of patients evaluable for AEs: | 66 (See note) | | 66 (See note)
Somerville and Herrmann, 1978 | Number of patients withdrawing due to AEs: | 12(18%) | | 5 (8%)
Somerville and Herrmann, 1978 | Total number of AEs reported: | 18 | | 8
Somerville and Herrmann, 1978 | Number of patients reporting: | n (%) | | n (%)
Somerville and Herrmann, 1978 | Fatigue, weakness | 3 (5%) | | 0
Somerville and Herrmann, 1978 | Nausea | 2 (3%) | | 2 (3%)
Somerville and Herrmann, 1978 | Chest pains | 2 (3%) | | 1 (2%)
Somerville and Herrmann, 1978 | Back pains | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Blurred vision | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Depersonalization | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Depression | 1 (2%) | | 1 (2%)
Somerville and Herrmann, 1978 | Drowsiness | 1 (2%) | | 1 (2%)
Somerville and Herrmann, 1978 | Eye irritation | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Hallucinations | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Impotence | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Muscle aches and pains | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Numbness of tongue | 0 | | 1 (2%)
Somerville and Herrmann, 1978 | Subcutaneous hemorrhage | 1 (2%) | | 2 (3%)
Somerville and Herrmann, 1978 | Vertigo | 1 (2%) | | 0
Somerville and Herrmann, 1978 | Withdrawals due to AEs: | 12 (for reasons listed above) | | 5 (for reasons listed above)
Sørensen, Hansen, and Olesen, 1986 | | Flunarizine, 10 mg/day for 4 mos | Placebo | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Number of patients evaluable for AEs: | 29* | 29* | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Number of patients reporting AEs: | 3 (10%) | 1 (3%) | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Total number of AEs reported: | 3 | 1 | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Number of patients reporting: | n (%) | n (%) | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Daytime sedation | 3 (10%) | 1 (3%) | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Hansen, and Olesen, 1986 | Withdrawals due to AEs: | 1 (daytime sedation) | 0 | | | Data on AEs collected at monthly clinic visits. Flunarizine vs. placebo: 0.067 (−0.071 to 0.20)
Sørensen, Larsen, Rasmussen, et al., 1991 | | Flunarizine, 10 mg/day for 5 mos | | Metoprolol (slow-release), 200 mg/day for 5 mos
Sørensen, Larsen, Rasmussen, et al., 1991 | Number of patients evaluable for AEs: | 72 | | 75
Sørensen, Larsen, Rasmussen, et al., 1991 | Number of patients reporting AEs: | N/S | | N/S
Sørensen, Larsen, Rasmussen, et al., 1991 | Total number of AEs reported: | 72 | | 69
Sørensen, Larsen, Rasmussen, et al., 1991 | Number of patients reporting: | n (%) | | n (%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Drowsiness/sedation | 26 (36%) | | 21 (28%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Weight gain | 23 (32%) | | 9 (12%)
Sørensen, Larsen, Rasmussen, et al., 1991 | GI symptoms | 5 (7%) | | 10 (13%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Sleep disturbances/vivid dreams | 4 (6%) | | 10(13%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Muscle fatigue/cold paresthesia | 3 (4%) | | 10 (13%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Depression | 6 (8%) | | 2 (3%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Dizziness/vertigo | 1 (1%) | | 4 (5%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Cardiovascular symptoms/hypotension | 2 (3%) | | 1 (1%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Extrapyramidal symptoms | 2 (3%) | | 1 (1 %)
Sørensen, Larsen, Rasmussen, et al., 1991 | Respiratory symptoms | 0 | | 1 (1%)
Sørensen, Larsen, Rasmussen, et al., 1991 | Withdrawals due to AEs: | 10 (depression [4], weight gain [4]. drowsiness/sedation [1], unknown [1]) | | 1 (depression)
Steardo, Bonuso, Di Stasio, et al., 1982 | | Propranolol, 40 mg, 3x/day for 6 mos | Metoprolol, 100 mg, 3x/day for 6 mos | Methysergide, 6–10 mg/day for 6 mos | | Limited information provided on AEs.
Steardo, Bonuso, Di Stasio, et al., 1982 | Number of patients evaluable for AEs: | 33 | 30 | 36 | | Limited information provided on AEs.
Steardo, Bonuso, Di Stasio, et al., 1982 | Number of patients reporting AEs: | N/S | N/S | N/S | | Limited information provided on AEs.
Steardo, Bonuso, Di Stasio, et al., 1982 | Total number of AEs reported: | N/S | N/S | N/S | | Limited information provided on AEs.
Steardo, Bonuso, Di Stasio, et al., 1982 | Withdrawals due to AEs: | 4 | 8 | 6 | | Limited information provided on AEs.
Steardo, Bonuso, Di Stasio, et al., 1982 | | (dizziness [2], bradycardia [1], pre- cordialgia [1]) | (bradycardia [5], hypotension [3]) | (paresthesia [3], gastralgia [2], pre- cordialgia [1]) | | Limited information provided on AEs.
Steardo, Marano, Barone, et al., 1986 | | Flunarizine, 10 mg/day for 5 mos | Methysergide, 6 mg/day for 5 mos | | | Limited information on AEs was reported. Investigators stated that fewer than 7% of patients reported daytime sedation/drowsiness with flunarizine. No weight gain was associated with flunarizine.
Steardo, Marano, Barone, et al., 1986 | Number of patients evaluable for AEs: | 53 | 51 | | | Limited information on AEs was reported. Investigators stated that fewer than 7% of patients reported daytime sedation/drowsiness with flunarizine. No weight gain was associated with flunarizine.
Steardo, Marano, Barone, et al., 1986 | Number of patients reporting AEs: | N/S | N/S | | | Limited information on AEs was reported. Investigators stated that fewer than 7% of patients reported daytime sedation/drowsiness with flunarizine. No weight gain was associated with flunarizine.
Steardo, Marano, Barone, et al., 1986 | Total number of AEs reported: | N/S | N/S | | | Limited information on AEs was reported. Investigators stated that fewer than 7% of patients reported daytime sedation/drowsiness with flunarizine. No weight gain was associated with flunarizine.
Steardo, Marano, Barone, et al., 1986 | Withdrawals due to AEs: | 0 | 7 (gastric disturbances [5], peripheral circulatory insufficiency [2]) | | | Limited information on AEs was reported. Investigators stated that fewer than 7% of patients reported daytime sedation/drowsiness with flunarizine. No weight gain was associated with flunarizine.
Steiner, Joseph, Hedman, et al., 1988 | | Metoprolol, 50 mg, 2x/day for 2 mos | | Placebo | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Number of patients evaluable for AEs: | 28 | | 31 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Number of patients reporting AEs: | 5 (18%) | | 4 (13%) | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Total number of AEs reported: | | | | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Number of patients reporting: | n (%) | | n (%) | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Drowsiness | (See note) | | (See note) | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Dizziness | (See note) | | (See note) | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Nightmares | 1 (4%) | | 0 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Weight increase | 1 (4%) | | 0 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Dyspnea | 1 (4%) | | 0 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Heartburn | 1 (4%) | | 0 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Milk pruritis | 0 | | 1 (3%) | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Steiner, Joseph, Hedman, et al., 1988 | Withdrawals due to AEs: | 1 (heartburn) | | 0 | | Investigators reported that drowsiness and dizziness were experienced with both treatments, but did not state how many patients reported these AEs. Metoprolol vs. placebo: 0.049 (−0.14 to 0.23)
Stellar, Ahrens, Meibohm, et al., 1984 | | Timolol, 20–30 mg/day, taken in two doses, for 2 mos | | Placebo
Stellar, Ahrens, Meibohm, et al., 1984 | Number of patients evaluable for AEs: | 107* | | 107*
Stellar, Ahrens, Meibohm, et al., 1984 | Number of patients reporting AEs: | N/S | | N/S
Stellar, Ahrens, Meibohm, et al., 1984 | Total number of AEs reported: | N/S | | N/S
Stellar, Ahrens, Meibohm, et al., 1984 | Number of patients reporting (most common AEs): | n (%) | | n (%)
Stellar, Ahrens, Meibohm, et al., 1984 | Insomnia | 7 (7%) | | 2 (2%)
Stellar, Ahrens, Meibohm, et al., 1984 | Light-headedness | 3 (3%) | | 2 (2%)
Stellar, Ahrens, Meibohm, et al., 1984 | Fatigue | 3 (3%) | | 1 (1%)
Stellar, Ahrens, Meibohm, et al., 1984 | Withdrawals due to AEs: | 2 (chest pain [1], severe epigastric distress [1]) | | 0
Stensrud and Sjaastad, 1974 | | Ketoprofen, 50 mg, 3x/day for 6 wks | | Placebo | | Investigators reported only those AEs considered to be drug-related, and appear to have reported them only for those patients who completed the trial (24/26). Two patients withdrew before completing the trial for unspecified reasons. Ketoprofen vs. placebo: 0.080 (−0.048 to 0.21)
Stensrud and Sjaastad, 1974 | Number of patients evaluable for AEs: | 24* | | 24*
Stensrud and Sjaastad, 1974 | Number of patients reporting drug-related AEs: | 2 (8%) | | 0
Stensrud and Sjaastad, 1974 | Total number of drug-related AEs reported: | 2 | | 0
Stensrud and Sjaastad, 1974 | Number of patients reporting: | n (%) | | n (%)
Stensrud and Sjaastad, 1974 | Nausea | 2 (8%) | | 0
Stensrud and Sjaastad, 1974 | Withdrawals due to AEs: | (See note) | | (See note)
Stensrud and Sjaastad, 1976b | | Propranolol, 40 mg, 4x/day for 4 wks | | Placebo | | Limited information was provided on AEs. Investigators reported only that “in practically all cases, a varying degree of bradycardia and a slight reduction in blood pressure were found during the Inderal® [propranolol] period.”
Stensrud and Sjaastad, 1976b | Number of patients evaluable for AEs: | 20* (See note) | | 20* (See note)
Stensrud and Sjaastad, 1976b | Number of patients reporting AEs: | N/S | | N/S
Stensrud and Sjaastad, 1976b | Total number of AEs reported: | N/S | | N/S
Stensrud and Sjaastad, 1976b | Withdrawals due to AEs: | 1 (dyspnoea & palpitations) | | 0
Stensrud and Sjaastad, 1979 | | Clonazepam (Rivotrll®), 1–2 mg/day for 4 wks to 1 yr | | Placebo | | Investigators did not provide separate AE data for the 1-mg/day and 2-mg/day doses of clonazepam, or for the 4-wk controlled trial treatment period and the extended open trial. The incidence of AEs associated with placebo was also not reported.
Stensrud and Sjaastad, 1979 | Number of patients evaluable for AEs: | 38* | | 38*
Stensrud and Sjaastad, 1979 | Number of patients reporting AEs: | N/S | | N/S
Stensrud and Sjaastad, 1979 | Total number of AEs reported: | N/S | | N/S
Stensrud and Sjaastad, 1979 | Number of patients reporting: | n (%) | | n (%)
Stensrud and Sjaastad, 1979 | Drowsiness | 23 (61%) | | N/S
Stensrud and Sjaastad, 1979 | Dizziness | 10 (26%) | | N/S
Stensrud and Sjaastad, 1979 | Irritability | 2 (5%) | | N/S
Stensrud and Sjaastad, 1979 | Withdrawals due to AEs: | 3 (lethargy and sleepiness [3 -- all after completing controlled portion of trial]) | | 0
Stensrud and Sjaastad, 1980a | | Atenolol, 50 mg, 2x/day for 6 wks | Propranolol, 80 mg, 2x/day for 6 wks | Placebo | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Number of patients evaluable for AEs: | 35* | 35* | 35* | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Number of patients reporting AEs: | 1 (3%) | N/S | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Total number of AEs reported: | 1 | 12 | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Number of patients reporting: | n (%) | n (%) | n (%) | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Reduced physical capacity | 1 (3%) | 6 (17%) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Nausea | 0 | 3 (9%) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Cold hands/feet | 0 | 1 (3%) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Dizziness | 0 | 1 (3%) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Sleeping difficulties | 0 | 1 (3%) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Stensrud and Sjaastad, 1980a | Withdrawals due to AEs: | 0 | 1 (dizziness) | 0 | | Atenolol vs. placebo: 0.028 (−0.047 to 0.10)
Sternieri, Bussone, Manzoni, et al., 1991 | | Lornoxicam, 4 mg, 3x/day for 2 mos | | Placebo | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Number of patients evaluable for AEs: | 48 | | 52 | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Number of patients reporting AEs: | 13 (27%) | | 5 (10%) | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Total number of AEs reported: | N/S | | N/S | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Number of patients reporting: | n (%) | | n (%) | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Abdominal discomfort | 9 (19%) | | 0 | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sternieri, Bussone, Manzoni, et al., 1991 | Withdrawals due to AEs: | 4 (causative AEs N/S) | | 2 (causative AEs N/S) | | Lornoxicam vs. placebo: 0.17 (0.021 to 0.32)
Sudilovsky, Elkind, Ryan, et al., 1987 | | Nadolol, 160 mg, 1x/day for 2 mos | Nadolol, 80 mg, 1x/day for 2 mos | Propranolol, 80 mg, 2x/day for 2 mos | | No further information provided on AEs.
Sudilovsky, Elkind, Ryan, et al., 1987 | Number of patients evaluable for AEs: | 47 | 49 | 44 | | No further information provided on AEs.
Sudilovsky, Elkind, Ryan, et al., 1987 | Number of patients reporting AEs: | N/S | N/S | N/S | | No further information provided on AEs.
Sudilovsky, Elkind, Ryan, et al., 1987 | Total number of AEs reported: | N/S | N/S | N/S | | No further information provided on AEs.
Sudilovsky, Elkind, Ryan, et al., 1987 | Withdrawals due to AEs: | 2 (fatigue and depression [1], urticaria [1]) | 2 (HA and dizziness [1], nausea [1]) | 4 (fatigue and memory disturbance [1], vertigo and urticaria [1], dyspnea and chest tightness [1], paresthesia [1]) | | No further information provided on AEs.
Sudilovsky, Stern, and Meyer, 1986b | | Nadolol, 240, 160, or 80 mg/day for 2 mos | | Placebo | | Abstract -- no data reported on AEs.
Sudilovsky, Stern, and Meyer, 1986b | Number of patients evaluable for AEs: | N/S | | N/S | | Abstract -- no data reported on AEs.
Sudilovsky, Stern, and Meyer, 1986b | Number of patients reporting AEs: | N/S | | N/S | | Abstract -- no data reported on AEs.
Sudilovsky, Stern, and Meyer, 1986b | Total number of AEs reported: | N/S | | N/S | | Abstract -- no data reported on AEs.
Sudilovsky, Stern, and Meyer, 1986b | Withdrawals due to AEs: | 0 | | 0 | | Abstract -- no data reported on AEs.
Szekely, Merryman, Croft, et al., 1989 | | Naproxen sodium, 550 mg, 2x/day, during perimenstrual period for 2 mos | | Placebo | | Data at left are for those patients who completed the trial (22/30). Investigators reported that 2 patients withdrew before completing the trial due to AEs, one with stomatitis, one with ecchymoses. There is no indication which treatment these two patients were taking at the time of their withdrawal.
Szekely, Merryman, Croft, et al., 1989 | Number of patients evaluable for AEs: | 22* | | 22*
Szekely, Merryman, Croft, et al., 1989 | Number of patients reporting AEs: | N/S | | N/S
Szekely, Merryman, Croft, et al., 1989 | Total number of AEs reported: | N/S | | N/S
Szekely, Merryman, Croft, et al., 1989 | Number of patients reporting (most common) AEs: | n (%) | | n (%)
Szekely, Merryman, Croft, et al., 1989 | Gastrointestinal symptoms | 10 (45%) | | 8 (36%)
Szekely, Merryman, Croft, et al., 1989 | Central nervous symptom complaints | 5 (23%) | | 7 (32%)
Szekely, Merryman, Croft, et al., 1989 | Withdrawals due to AEs: | (See note) | | (See note)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | | Propranolol, 80 mg, 2x/day for 3 mos | Timolol, 10 mg, 2x/day for 3 mos | Placebo | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Number of patients evaluable for AEs: | 83* | 83* | 83* 23 (28%) N/S | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Number of patients reporting AEs: | 35 (42%) | 38 (46%) N/S | | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Total number of AEs reported: | N/S | N/S | N/S | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Number of patients reporting (most common AEs): | n (%) | n (%) | n (%) | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Fatigue/tiredness | 11 (13%) | 18 (22%) | 15 (18%) | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Dizziness | 4 (5%) | 5 (6%) | 2 (2%) | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Nausea | 5 (6%) | 2 (2%) | 2 (2%) | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Sleep disturbances | 3 (4%) | 4 (5%) | 2 (2%) | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Depression | 3 (4%) | 2 (2%) | 0 | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Abnormal dreaming | 0 | 2 (2%) | 0 | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Tfelt-Hansen, Standnes, Kangasniemi, et al., 1984 | Withdrawals due to AEs: | N/S | N/S | N/S | | Propranolol vs. placebo: 0.14 (−0.0010 to 0.28) Timolol vs. placebo: 0.18 (0.033 to 0.32) Propranolol vs. timolol: −0.036 (−0.18 to 0.11)
Thomas, Behari, and Ahuja, 1991 | | Flunarizine, 10 mg/day for 12wks | Placebo | | | Limited information provided on AEs. Data at left concern only those 15 patients (of 29) who completed the crossover. One patient withdrew prematurely due to AEs associated with flunarizine (galactorrhea).
Thomas, Behari, and Ahuja, 1991 | Number of patients evaluable for AEs: | 15* | 15*
Thomas, Behari, and Ahuja, 1991 | Number of patients reporting AEs: | N/S | N/S
Thomas, Behari, and Ahuja, 1991 | Total number of AEs reported: | N/S | N/S
Thomas, Behari, and Ahuja, 1991 | Number of patients reporting: | n (%) | n (%)
Thomas, Behari, and Ahuja, 1991 | Daytime sedation | 10 (67%) | N/S
Thomas, Behari, and Ahuja, 1991 | Weight gain (2–5 kg) | 8 (53%) | N/S
Thomas, Behari, and Ahuja, 1991 | Withdrawals due to AEs: | (See note) | (See note)
Titus, Dávalos, Alom, et al., 1986 | | Oxitriptan (5-hydroxytryptophan or 5-HTP), 600 mg/day for 6 mos | | Methysergide, 3 mg/day for 6 mos | | The article reports unclear and (at least apparently) inconsistent information about the number of patients who had to “discontinue treatment” (5, all methysergide) or who had treatment “withdrawn” (4 methysergide, 5 oxitriptan) due to AEs. Methysergide VS. oxitriptan: 0.038 (−0.15 to 0.22)
Titus, Dávalos, Alom, et al., 1986 | Number of patients evaluable for AEs: | 45 | | 40
Titus, Dávalos, Alom, et al., 1986 | Number of patients reporting AEs: | 13 (29%) | | 10 (25%)
Titus, Dávalos, Alom, et al., 1986 | Total number of AEs reported: | 18 | | 10
Titus, Dávalos, Alom, et al., 1986 | Number of patients reporting: | n (%) | | n (%)
Titus, Dávalos, Alom, et al., 1986 | Abdominal pain | 6 (13%) | | 0
Titus, Dávalos, Alom, et al., 1986 | Gain in weight | 4 (9%) | | 1 (3%)
Titus, Dávalos, Alom, et al., 1986 | Nausea | 3 (7%) | | 2 (5%)
Titus, Dávalos, Alom, et al., 1986 | Diarrhea | 3 (7%) | | 0
Titus, Dávalos, Alom, et al., 1986 | Numbness or pain in legs | 0 | | 3 (8%)
Titus, Dávalos, Alom, et al., 1986 | Insomnia and anxiety | 1 (2%) | | 1 (3%)
Titus, Dávalos, Alom, et al., 1986 | Impotence | 0 | | 2 (5%)
Titus, Dávalos, Alom, et al., 1986 | Drowsiness | 0 | | 1 (3%)
Titus, Dávalos, Alom, et al., 1986 | Amenorrhea | 1 (2%) | | 0
Titus, Dávalos, Alom, et al., 1986 | Withdrawals due to AEs: | ? (See note) | | ? (See note)
Vilming, Standnes, and Hedman, 1985 | | Pizotifen, inc’d from 0.5 mg, 1x/day to 0.5 mg, 3x/day for 8 wks | | Metoprolol, 50 mg, 2x/day for 8 wks | | Data at left concern only the patients who completed the crossover trial and from whom efficacy data were obtained. The total number of patients and AEs are the sum of the numbers reported for the first and second months of treatment.
Vilming, Standnes, and Hedman, 1985 | Number of patients evaluable for AEs: | 30* (See note) | | 30* (See note)
Vilming, Standnes, and Hedman, 1985 | Number of patients reporting AEs: | Unclear | | Unclear
Vilming, Standnes, and Hedman, 1985 | Total number of AEs reported: | 76 | | 66
Vilming, Standnes, and Hedman, 1985 | Withdrawals due to AEs: | 3 (edema/lack of effect [1], sedation [1], weight gain/depression/restless legs [1]) | | 1(nightmares)
Weber and Reinmuth, 1972 | | Propranolol, 20 mg, 4x/day for 3 mos | | Placebo | | Limited data were provided on AEs. Investigators only reported that one patient complained of abdominal cramps and diarrhea, but did not specify which treatment the patient was receiving.
Weber and Reinmuth, 1972 | Number of patients evaluable for AEs: | N/S | | N/S | | Limited data were provided on AEs. Investigators only reported that one patient complained of abdominal cramps and diarrhea, but did not specify which treatment the patient was receiving.
Weber and Reinmuth, 1972 | Number of patients reporting AEs: | N/S | | N/S | | Limited data were provided on AEs. Investigators only reported that one patient complained of abdominal cramps and diarrhea, but did not specify which treatment the patient was receiving.
Weber and Reinmuth, 1972 | Total number of AEs reported: | N/S | | N/S | | Limited data were provided on AEs. Investigators only reported that one patient complained of abdominal cramps and diarrhea, but did not specify which treatment the patient was receiving.
Weber and Reinmuth, 1972 | Withdrawals due to AEs: | 0 | | 0 | | Limited data were provided on AEs. Investigators only reported that one patient complained of abdominal cramps and diarrhea, but did not specify which treatment the patient was receiving.
Welch, Ellis, and Keenan, 1985 | | Naproxen sodium, 550 mg, 2x/day for 8 wks | | Placebo | | Of the 46 patients who entered the first treatment period, 6 dropped out before ever taking naproxen sodium, and 3 dropped out before ever taking placebo. Naproxen sodium vs. placebo: 0.016 (−0.16 to 0.19)
Welch, Ellis, and Keenan, 1985 | Number of patients evaluable for AEs: | 40* | | 43*
Welch, Ellis, and Keenan, 1985 | Number of patients reporting AEs: | 9 (23%) | | 9 (21%)
Welch, Ellis, and Keenan, 1985 | Total number of AEs reported: | 14 | | 14
Welch, Ellis, and Keenan, 1985 | Number of patients reporting AEs: | n (%) | | n (%)
Welch, Ellis, and Keenan, 1985 | Gastrointestinal problems | 6 (15%) | | 3 (7%)
Welch, Ellis, and Keenan, 1985 | Dizziness/faintness | 2 (5%) | | 0
Welch, Ellis, and Keenan, 1985 | Pains | 1 (3%) | | 2 (5%)
Welch, Ellis, and Keenan, 1985 | Urinary problems | 1 (3%) | | 1 (2%)
Welch, Ellis, and Keenan, 1985 | Other | 1 (3%) | | 3 (7%)
Welch, Ellis, and Keenan, 1985 | Withdrawals due to AEs: | 4 (exacerbation of tachycardia [1], fear of developing GI problems [1], gastric burning [2]) | | 1 (“vague somatic complaints”])
Wessely, Baumgartner, Klingler, et al., 1987 | | Gabapentin, 900 mg/day for 3 mos | | Placebo | | Very limited information was reported on AEs. Withdrawals were due to nausea, tiredness, and dizziness (no breakdown by treatment group).
Wessely, Baumgartner, Klingler, et al., 1987 | Number of patients evaluable for AEs: | 16 | | 20 | | Very limited information was reported on AEs. Withdrawals were due to nausea, tiredness, and dizziness (no breakdown by treatment group).
Wessely, Baumgartner, Klingler, et al., 1987 | Number of patients reporting AEs: | N/S | | N/S | | Very limited information was reported on AEs. Withdrawals were due to nausea, tiredness, and dizziness (no breakdown by treatment group).
Wessely, Baumgartner, Klingler, et al., 1987 | Total number of AEs reported: | N/S | | N/S | | Very limited information was reported on AEs. Withdrawals were due to nausea, tiredness, and dizziness (no breakdown by treatment group).
Wessely, Baumgartner, Klingler, et al., 1987 | Withdrawals due to AEs: | 2 (See note) | | 1 (See note) | | Very limited information was reported on AEs. Withdrawals were due to nausea, tiredness, and dizziness (no breakdown by treatment group).
Widerøe and Vigander, 1974 | | Propranolol, 40 mg, 4x/day for 3 mos | | Placebo | | No information was reported on AEs from this controlled trial.
Widerøe and Vigander, 1974 | Number of patients evaluable for AEs: | 30* (See note) | | 30* (See note) | | No information was reported on AEs from this controlled trial.
Widerøe and Vigander, 1974 | Number of patients reporting AEs: | N/S | | N/S | | No information was reported on AEs from this controlled trial.
Widerøe and Vigander, 1974 | Total number of AEs reported: | N/S | | N/S | | No information was reported on AEs from this controlled trial.
Widerøe and Vigander, 1974 | Withdrawals due to AEs: | 0 | | 0 | | No information was reported on AEs from this controlled trial.
Wilkinson, 1970 | | Clonidine, 50 μg, 2x/day for 6 wks | Clonidine, 25 μg, 2x/day for 6 wks | Placebo (lactose) | | Four patients withdrew from the study, 2 for unspecified reasons, 2 because they “were worse.” Little information on AEs was reported. The investigator only stated that there were “no serious side effects” and that “a few patients ha[d] become depressed.”
Wilkinson, 1970 | Number of patients evaluable for AEs: | 23* | 23* | 23*
Wilkinson, 1970 | Number of patients reporting AEs: | N/S | N/S | N/S
Wilkinson, 1970 | Total number of AEs reported: | N/S | N/S | N/S
Wilkinson, 1970 | Withdrawals due to AEs: | N/S (See note) | N/S (See note) | N/S (See note)
Wilkinson, Agnoli, Gerber, et al., 1989 | | Lisuride (Cuyalit®), 0.05 mg, 3x/day for 3 mos | | Lisuride (Cuyalit®), 0.025 mg, 3x/day for 3 mos | | Limited data were provided on AEs. Investigators reported only that AEs were infrequent and that there were no statistically significant differences between the two treatments for AEs.
Wilkinson, Agnoli, Gerber, et al., 1989 | Number of patients evaluable for AEs: | 49 | | 43 | | Limited data were provided on AEs. Investigators reported only that AEs were infrequent and that there were no statistically significant differences between the two treatments for AEs.
Wilkinson, Agnoli, Gerber, et al., 1989 | Number of patients reporting AEs: | N/S | | N/S | | Limited data were provided on AEs. Investigators reported only that AEs were infrequent and that there were no statistically significant differences between the two treatments for AEs.
Wilkinson, Agnoli, Gerber, et al., 1989 | Total number of AEs reported: | N/S | | N/S | | Limited data were provided on AEs. Investigators reported only that AEs were infrequent and that there were no statistically significant differences between the two treatments for AEs.
Wilkinson, Agnoli, Gerber, et al., 1989 | Withdrawals due to AEs: | 6 (N/S) | | 9 (N/S) | | Limited data were provided on AEs. Investigators reported only that AEs were infrequent and that there were no statistically significant differences between the two treatments for AEs.
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | | Bisoprolol, 5 mg, 1x/day for 3 mos | | Metoprolol, 100 mg/day for 3 mos | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Number of patients evaluable for AEs: | 125* | | 125* | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Number of patients reporting AEs: | 23 (18%) | | 19 (15%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Total number of AEs reported: | N/S | | N/S | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Number of patients reporting (most common AEs only): | n (%) | | n (%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Dizziness | 8 (6%) | | 4 (3%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Tiredness/fatigue | 3 (2%) | | 7 (6%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Sleep disturbances | 2 (2%) | | 6 (5%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Cardiovascular/hypotensive reactions | 6 (5%) | | 1 (<1%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | GI disturbances | 5 (4%) | | 2 (2%) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Wörz, Reinhardt-Benmalek, Foeh, et al., 1992 | Withdrawals due to AEs: | N/S (See note) | | N/S (See note) | | 14 patients withdrew due to unspecified AEs, but no breakdown was provided by intervention. Bisoprolol vs. metoprolol: 0.032 (−0.061 to 0.12)
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | | Femoxetine, 200 mg/day for first wk, 300 mg/day therafter, for total of 12 wks | | Placebo | | These data appear to include only those patients who completed the trial or were known to have withdrawn due to AEs (48/59 patients randomized to treatment), though this is not entirely clear. Femoxetine vs. placebo: 0.22 (0.012 to 0.40)
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Number of patients evaluable for AEs: | 23 | | 25
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Number of patients reporting AEs: | 6 (26%) | | 1 (4%)
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Total number of AEs reported:
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Number of patients reporting: | n (%) | | n (%)
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Nausea | 3 (13%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Changes in mood | 2 (9%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Prolonged menstrual bleeding | 1 (4%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Tiredness, indisposition | 1 (4%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Palpitation | 1 (4%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Dry mouth | 1 (4%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Paraesthesia (tongue) | 1 (4%) | | 0
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Excessive sweating | 0 | | 1 (4%)
Zeeberg, Orholm, Dalsgaard Nielsen, et al., 1981 | Withdrawals due to AEs: | 3 (nausea and prolonged menstrual bleeding; nausea and changes in mood; tiredness and indisposition) | | 0
Ziegler and Ellis, 1985 | | Naproxen sodium, 550 mg, 2x/day for 8 wks | | Placebo | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Number of patients evaluable for AEs: | 40* | | 40* | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Number of patients reporting AEs: | 5 (13%) | | 7 (18%) | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Total number of AEs reported: | 7 | | 8 | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Number of patients reporting: | n (%) | | n (%) | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Gastrointestinal symptoms | 4 (10%) | | 4 (10%) | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Drowsiness | 1 (3%) | | 1 (3%) | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Aches and pains | 0 | | 1 (3%) | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Other (incl. uncoordination, slurred speech, blurred vision, hypertension, and itching) | 0 | | 2 | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler and Ellis, 1985 | Withdrawals due to AEs: | 1 (stomach pain and burning) | | 0 | | Naproxen sodium vs. placebo: −0.049 (−0.20 to 0.11)
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 | | Amitriptyline, 50–150 mg/day for 4–8 wks | Propranolol, 80–240 mg/day for 4–8 wks | Placebo | | Investigators stated that 3 patients withdrew prematurely due to unspecified “toxic reactions.” They did not say which of the interventions were associated with these reactions. No further information was provided on AEs.
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 | Number of patients evaluable for AEs: | N/S | N/S | N/S
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 | Number of patients reporting AEs: | N/S | N/S | N/S
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 | Total number of AEs reported: | N/S | N/S | N/S
Ziegler, Hurwitz, Hassanein, et al., 1987 and Ziegler, Hurwitz, Preskorn, et al., 1993 | Withdrawals due to AEs: | (See note) | (See note) | (See note)
Zuddas, Mulas, Del Zompo, et al., 1985 | | Lisuride, dose gradually increased until it was 0.025 mg, 3x/day on Day 7 and thereafter for 3 mos | | Placebo | | No data provided on AEs.
Zuddas, Mulas, Del Zompo, et al., 1985 | Number of patients evaluable for AEs: | 15 (See note) | | 15 (See note) | | No data provided on AEs.
Zuddas, Mulas, Del Zompo, et al., 1985 | Number of patients reporting AEs: | N/S | | N/S | | No data provided on AEs.
Zuddas, Mulas, Del Zompo, et al., 1985 | Total number of AEs reported: | N/S | | N/S | | No data provided on AEs.
Zuddas, Mulas, Del Zompo, et al., 1985 | Withdrawals due to AEs: | N/S | | N/S | | No data provided on AEs.

1 Key to abbreviations: μg = microgram; 5-HTP = oxitriptan; AEs = adverse; BP = blood pressure; CDH = chronic daily headache; CI = confidence interval; CNS = central nervous system; DEK = dihydroergokryptine; DHE = dihydroergotamine; GI = gastrointestinal; HA = headache; inc’d = increased; kg = kilogram; L-5-hydroxytryptophan = oxitriptan; max. = maximum; mg = milligram; mo = month; n = sample size; N/S = not specified; OTC = over-the-counter; tab = tablet; vs. = versus; TIS = transdermal therapeutic system; wk = week

2 An asterisk denotes a crossover trial.