# Miscellaneous Trials Not Reviewed in This Report

The following is a list of trials of miscellaneous agents which appear to meet our basic inclusion criteria but which we did not review in this report. The agents included on the list have been studied in only a small number of controlled trials and are not widely available and/or have been shown to be ineffective.

Publication | Active agent(s) studied
Anthony, Lord, and Lance (1978) | Cimetidine Cimetidine + chlorpheniramine maleate
Baxter, Marsden, Parkes, et al. (1972) | Amantadine
Burns (1965) | Prostigmine bromide Chorionic gonadotropin
Carasso and Yehuda (1984) | Migraleve® (acetaminophen + codeine phosphate + buclizine + dioctyl sodium sulphosuccinate)
Facchinetti, Sances, Borella, et al. (1991) | Magnesium
Gennari, Chierichetti, Gonnelli, et al. (1986) | Salmon calcitonin
Jorgensen, Weightman, and Foster (1974) | Buclizine Migraleve® (acetaminophen + codeine phosphate + buclizine + dioctyl sodium sulphosuccinate)
Martelletti, Bussone, Centonze, et al. (1991) | Cromolyn sodium
Matts (1974) | Metoclopramide
Micieli, Cavallini, Martignoni, et al. (1988) | Salmon calcitonin
Minervini and Pinto (1987) | Captopril
Monro, Carini, and Brostoff (1984) | Sodium cromoglycate
Nanda, Arthur, Johnson, et al. (1980) | Cimetidine Cimetidine + chlorpheniramine maleate
Opavsky (1991) | Magnesium lactate Magnesium sulphate Magnesium sulphate + cinnarizine
Scopa, Jorgensen, and Foster (1974) | Migraleve® (acetaminophen + codeine phosphate + buclizine + dioctyl sodium sulphosuccinate)