# References

Ad Hoc Committee on the Classification of Headache of the National Institute of Neurological Diseases and Blindness. Classification of headache. JAMA. 1962;179:717-8.
Anderson JA, Basker MA, Dalton R. Migraine and hypnotherapy. Int J Clin Exp Hypn. 1975;23(1):48-58. [pmid: 1110112].
Andrasik F, Blanchard EB, Neff DF, Rodichok LD. Biofeedback and relaxation training for chronic headache: a controlled comparison of booster treatments and regular contacts for long-term maintenance. J Consult Clin Psychol. 1984;52(4):609-15. [pmid: 6381563].
Andreychuk T, Skriver C. Hypnosis and biofeedback in the treatment of migraine headache. Int J Clin Exp Hypn. 1975;23(3):172-83. [pmid: 1132914].
Barrios FX. Social skills training and psychosomatic disorders. Rathjen DP, Foreyt JP, editors. Social competence: interventions for children and adults. New York. Pergamon. 1980:271-301.
Benson H. The relaxation response. New York. William Morrow & Co. 1975.
Bernstein DA, Borkovec TD. Progressive relaxation training: a manual for the helping professions. Champaign (IL). Research Press. 1973.
Bild R, Adams HE. Modification of migraine headaches by cephalic blood volume pulse and EMG biofeedback. J Consult Clin Psychol. 1980;48(1):51-7. [pmid: 7365042].
Birbaumer N, Gerber D, Miltner W, Lutzenberger W, Gluck M. Start with biofeedback, continue with behavior therapy in migraine. Biofeedback Self Regul. 1984;9(1):88.
Birbaumer N, Haag G. Behavioral treatment of migraine. Surwit RS, Williams RB, Steptoe A, et al., editors. Behavioral treatment of disease. New York. Plenum. 1982:285-97.
Blanchard EB, Andrasik F, Appelbaum KA, Evans DD, Jurish SE, Teders SJ, Rodichok LD, Barron KD. The efficacy and cost-effectiveness of minimal-therapist-contact, non-drug treatments of chronic migraine and tension headache. Headache. 1985;25(4):214-20. [pmid: 3926719].
Blanchard EB, Appelbaum KA, Guarnieri P, Neff DF, Andrasik F, Jaccard J, Barron KD. Two studies of the long-term follow-up of minimal therapist contact treatments of vascular and tension headache. J Consult Clin Psychol·. 1988;56(3):427-32. [pmid: 3294265].
Blanchard EB, Appelbaum KA, Nicholson NL, Radnitz CL, Morrill B, Michultka D, Kirsch C, Hillhouse J, Dentinger MP. A controlled evaluation of the addition of cognitive therapy to a home-based biofeedback and relaxation treatment of vascular headache. Headache. 1990;30(6):371-6. [pmid: 2196240].
Blanchard EB, Appelbaum KA, Radnitz CL, Morrill B, Michultka D, Kirsch C, Guarnieri P, Hillhouse J, Evans DD, Jaccard J, et al. A controlled evaluation of thermal biofeedback and thermal biofeedback combined with cognitive therapy in the treatment of vascular headache. J Consult Clin Psychol. 1990;58(2):216-24. [pmid: 2186067].
Blanchard EB, Kim M, Hermann C, Steffek BD, Nicholson NI, Taylor AE. The role of perception of success in the thermal biofeedback treatment of vascular headache. Headache Quarterly. 1994;5(4):231-6.
Blanchard EB, Nicholson NL, Radnitz CL, Steffek BD, Appelbaum KA, Dentinger MP. The role of home practice in thermal biofeedback. J Consult Clin Psychol. 1991;59(4):507-12. [pmid: 1918553].
Blanchard EB, Theobald DE, Williamson DA, Silver BV, Brown DA. Temperature biofeedback in the treatment of migraine headaches: a controlled evaluation. Arch Gen Psychiatry. 1978;35(5):581-8. [pmid: 365125].
Brown JM. Imagery coping strategies in the treatment of migraine. Pain. 1984;18(2):157-67. [pmid: 6709383].
Ceccherelli F, Ambrosio F, Avila M, Duse G, Munari A, Giron GP. Acupuncture vs. placebo in the common migraine: a double blind study. Cephalalgia. 1987;7(Suppl 6):499-500.
Claghorn JL, Mathew RJ, Largen JW, Meyer JS. Directional effects of skin temperature self-regulation on regional cerebral blood flow in normal subjects and migraine patients. Am J Psychiatry. 1981;138(9):1182-7. [pmid: 7270721].
Cochrane Controlled Trials Register [computer program]. The Cochrane Library, CD-ROM for Windows (IBM-PC) version. London. BMJ Publishing Group. 1997.
Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale (NJ). L Erlbaum Associates. 1988.
Cohen MJ, McArthur DL, Rickles WH. Comparison of four biofeedback treatments for migraine headache: physiological and headache variables. Psychosom Med. 1980;42(5):463-80. [pmid: 7008071].
Coulter I, Hurwitz E, Adams A, et al. The appropriateness of spinal manipulation and mobilization of the cervical spine: literature review, indications and ratings by a multidisciplinary expert panel. Santa Monica (CA). RAND. 1995. May. RAND Report No. DRU-982-1-CCR.
Daly EJ, Donn PA, Galliher MJ, Zimmerman JS. Biofeedback applications to migraine and tension headaches: a double-blinded outcome study. Biofeedback Self Regul. 1983;8(1):135-52. [pmid: 6882811].
Daly EJ, Zimmerman JS, Donn PA, Galliher MJ. Psychophysiological treatment of migraine and tension headaches: a 12-month follow-up. Rehabilitation Psychology. 1985;30(1):3-10.
Dickersin K, Scherer R, Lefebvre C. Identifying relevant studies for systematic reviews. BMJ. 1994;309(6964):1286-91. [pmid: 7718048].
Dowson DI, Lewith GT, Machin D. The effects of acupuncture versus placebo in the treatment of headache. Pain. 1985;21(1):35-42. [pmid: 3982837].
Drury RL, DeRisi WJ, Liberman RP. Temperature biofeedback treatment for migraine headache: a controlled multiple baseline study. Headache. 1979;19(5):278-84. [pmid: 381252].
Elkind A Migraines: Everything you need to know about their cause and cure New York Avon Books 1997175
Elmore AM, Tursky B. A comparison of two psychophysiological approaches to the treatment of migraine. Headache. 1981;21(3):93-101. [pmid: 7263223].
Feuerstein M, Adams HE. Cephalic vasomotor feedback in the modification of migraine headache. Biofeedback Self Regul. 1977;2(3):241-54. [pmid: 922058].
Fleiss JL. Statistical methods for rates and proportions. 2nd ed. New York. John Wiley & Sons, Inc. 1981.
Forssell H, Kirveskari P, Kangasniemi P. Changes in headache after treatment of mandibular dysfunction. Cephalalgia. 1985;5(4):229-36. [pmid: 3910260].
Friar LR, Beatty J. Migraine: management by trained control of vasoconstriction. J Consult Clin Psychol. 1976;44(1):46-53. [pmid: 1245632].
Friedman H, Taub HA. Brief psychological training procedures in migraine treatment. Am J Clin Hypn. 1984;26(3):187-200. [pmid: 6435442].
Gamble EH, Elder ST. Multimodal biofeedback in the treatment of migraine. Biofeedback Self Regul. 1983;8(3):383-92. [pmid: 6367834].
Gauthier J, Bois R, Allaire D, Drolet M. Evaluation of skin temperature biofeedback training at two different sites for migraine. J Behav Med. 1981;4(4):407-19. [pmid: 7338895].
Gauthier J, Côté G, French D. The role of home practice in the thermal biofeedback treatment of migraine headache. J Consult Clin Psychol. 1994;62(1):180-4. [pmid: 8034821].
Gauthier J, Doyon J, Lacroix R, Drolet M. Blood volume pulse biofeedback in the treatment of migraine headache: a controlled evaluation. Biofeedback Self Regul. 1983;8(3):427-42. [pmid: 6671106].
Gauthier J, Lacroix R, Côté A, Doyon J, Drolet M. Biofeedback control of migraine headaches: a comparison of two approaches. Biofeedback Self Regul. 1985;10(2):139-59. [pmid: 3914314].
Gerhards F, Rojahn J, Boxan K, Gnade C, Petrik M, Florin I. Biofeedback versus cognitive stress-coping therapy in migraine headache patients: a preliminary analysis of a comparative study. Holroyd KA, Schlote B, Zenz H, editors. Perspectives in research on headache. Toronto. Hogrefe. 1983:171-82.
Haag G, Gerber WD. The interaction of behavioural treatment and drug reduction in migraine patients. Clin Pharmacol Ther. 1987;41(2):202.
Hart JD. Predicting differential response to EMG biofeedback and relaxation training: the role of cognitive structure. J Clin Psychol. 1984;40(2):453-7. [pmid: 6373830].
Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18:37-43. [pmid: 9456207].
Headache Classification Committee of the International Headache Society. Classification and diagnostic criteria for headache disorders, cranial neuralgias and facial pain. Cephalalgia. 1988;8(Suppl 7):1-96.
Hesse J, Møgelvang B, Simonsen H. Acupuncture versus metoprolol in migraine prophylaxis: a randomized trial of trigger point inactivation. J Intern Med. 1994;235(5):451-6. [pmid: 8182401].
Holroyd KA, France JL, Cordingley GE, Rokicki LA, Kvaal SA, Lipchik GL, McCool HR. Enhancing the effectiveness of relaxation-thermal biofeedback training with propranolol hydrochloride. J Consult Clin Psychol. 1995;63(2):327-30. [pmid: 7751496].
Holroyd KA, Holm J, Hursey KG, Penzien DB, Cordingley GE, Theofanous AG, Richardson SC, Tobin DL. Recurrent vascular headache: home-based behavioral treatment versus abortive pharmacological treatment. J Consult Clin Psychol. 1988;56(2):218-23. [pmid: 3286705].
Holroyd KA, Holm J, Penzien DB, Cordingley GE, Hursey KG, Martin NJ, Theofanous A. Long-term maintenance of improvements achieved with (abortive) pharmacological and nonpharmacological treatments for migraine: preliminary findings. Biofeedback Self Regul. 1989;14(4):301-8. [pmid: 2698751].
Hurwitz EL, Aker PD, Adams AH, Meeker WC, Shekelle PG. Manipulation and mobilization of the cervical spine: a systematic review of the literature. Spine. Aug 1. 1996;21(15):1746-59. [pmid: 8855459].
Ingelfinger FJ, editor. Dorland’s medical dictionary. Shorter, editor. Philadelphia. The Saunders Press. 1980:15.
Ilacqua GE. Migraine headaches: coping efficacy of guided imagery training. Headache. 1994;34(2):99-102. [pmid: 8163375].
International Headache Society Committee on Clinical Trials in Migraine. Guidelines for controlled trials of drugs in migraine. 1st ed. Cephalalgia. 1991;11:1-12.
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
James LD, Thorn BE, Williams DA. Goal specification in cognitive-behavioral therapy for chronic headache pain. Behavior Therapy. 1993;24(2):305-20.
Janssen K, Neutgens J. Autogenic training and progressive relaxation in the treatment of three kinds of headache. Behav Res Ther. 1986;24(2):199-208. [pmid: 3964184].
Johansson J, Ost L. Temperature-biofeedback treatment of migraine headache: specific effects and the effects of “generalization training. Behav Modif. 1987;11(2):182-99. [pmid: 3508381].
Jurish SE, Blanchard EB, Andrasik F, Teders SJ, Neff DF, Arena JG. Home- versus clinic-based treatment of vascular headache. J Consult Clin Psychol. 1983;51(5):743-51. [pmid: 6630689].
Kewman D, Roberts AH. Skin temperature biofeedback and migraine headaches: a double-blind study. Biofeedback Self Regul. 1980;5(3):327-45. [pmid: 7448241].
Klawansky S, Yeung A, Berkey C, Shah N, Phan H, Chalmers TC. Meta-analysis of randomized controlled trials of cranial electrostimulation. Efficacy in treating selected psychological and physiological conditions. J Nerv Ment Dis. 1995;183:478-84. [pmid: 7623022].
Knapp TW. Treating migraine by training in temporal artery vasoconstriction and/or cognitive behavioral coping: a one-year follow-up. J Psychosom Res. 1982;26(5):551-7. [pmid: 7153946].
Kohlenberg RJ, Cahn T. Self-help treatment for migraine headaches: a controlled outcome study. Headache. 1981;21(5):196-200. [pmid: 7287417].
Lacroix JM, Clarke MA, Bock JC, Doxey N, Wood A, Lavis S. Biofeedback and relaxation in the treatment of migraine headaches: comparative effectiveness and physiological correlates. J Neurol Neurosurg Psychiatry. 1983;46(6):525-32. [pmid: 6348213].
Lake A, Rainey J, Papsdorf JD. Biofeedback and rational-emotive therapy in the management of migraine headache. J Appl Behav Anal. 1979;12(1):127-40. [pmid: 468745].
Largen JW, Mathew RJ. Cerebral blood flow and headache activity in normal volunteers and migraineurs trained in skin temperature self-regulation. Mathew RJ, editor. Treatment of migraine: pharmacological and biofeedback considerations. New York. Spectrum. 1981:91-126.
Largen JW, Mathew RJ, Dobbins K, Claghorn JL. Specific and non-specific effects of skin temperature control in migraine management. Headache. 1981;21(2):36-44. [pmid: 7239899].
Lenhard L, Waite PM. Acupuncture in the prophylactic treatment of migraine headaches: pilot study. N Z Med J. 1983;96(738):663-6. [pmid: 6576263].
Lisspers J, Ost LG. BVP-biofeedback in the treatment of migraine. The effects of constriction and dilatation during different phases of the migraine attack. Behav Modif. 1990;14(2):200-21. [pmid: 2331243].
Loh L, Nathan PW, Schott GD, Zilkha KJ. Acupuncture versus medical treatment for migraine and muscle tension headaches. J Neurol Neurosurg Psychiatry. 1984;47(4):333-7. [pmid: 6726258].
Machado HP, Gómez de Machado AML. The effectiveness of psychophysiological techniques in the treatment of migraine headaches: a cross-cultural study in a Honduran population. Unpublished MS. 1985.
Marcus DA, Scharff L, Turk DC. Nonpharmacological management of headaches during pregnancy. Psychosom Med. 1995;57(6):527-35. [pmid: 8600478].
Martin PR, Nathan PR, Milech D, van Keppel M. Cognitive therapy vs. self-management training in the treatment of chronic headaches. Br J Clin Psychol. 1989;28(Pt 4):347-61. [pmid: 2605388].
Mathew NT. Prophylaxis of migraine and mixed headache. A randomized controlled study. Headache. 1981;21(3):105-9. [pmid: 7021472].
McCrory DC, Hasselblad V. Cranial electrostimulation for headache: meta-analysis [letter]. J Nerv Ment Dis. 1997;185:766-7. [pmid: 9442190].
McGrady A, Wauquier A, McNeil A, Gerard G. Effect of biofeedback-assisted relaxation on migraine headache and changes in cerebral blood flow velocity in the middle cerebral artery. Headache. 1994;34(7):424-8. [pmid: 7928327].
Mitchell KR, Mitchell DM. Migraine: an exploratory treatment application of programmed behaviour therapy techniques. J Psychosom Res. 1971;15(2):137-57. [pmid: 5556130].
Moher D, Jadad AR, Nichol G, Penman M, Tugwell P, Walsh S. Assessing the quality of randomized controlled trials: an annotated bibliography of scales and checklists. Controlled Clin Trials. 1995;16(1):62-73. [pmid: 7743790].
Mullinix JM, Norton BJ, Hack S, Fishman MA. Skin temperature biofeedback and migraine. Headache. 1978;17:242-4. [pmid: 621143].
Myers DE, Myers RA. A preliminary report on hyperbaric oxygen in the relief of migraine headache. Headache. 1995;35(4):197-9. [pmid: 7775175].
Nicholson NL, Blanchard EB. A controlled evaluation of behavioral treatment of chronic headache in the elderly. Behav Ther. 1993;24(3):395-408.
Osterhaus JT, Gutterman DL, Plachetka JR. Healthcare resource and lost labour costs of migraine headache in the US. Pharmacoeconomics. 1992;2(1):67-76. [pmid: 10146980].
Parker GB, Pryor DS, Tupling H. Why does migraine improve during a clinical trial? Further results from a trial of cervical manipulation for migraine. Aust N Z J Med. 1980;10(2):192-8. [pmid: 6992760].
Parker GB, Tupling H, Pryor DS. A controlled trial of cervical manipulation of migraine. Aust N Z J Med. 1978;8(6):589-93. [pmid: 373735].
Passchier J, van der Helm-Hylkema H, Orlebeke JF. Lack of concordance between changes in headache activity and in psychophysiological and personality variables following treatment. Headache. 1985;25(6):310-6. [pmid: 4055364].
Penzien D, Johnson C, Carpenter D, Holroyd K. Drug vs. behavioral treatment of migraine: long-acting propranolol vs. home-based self-management training [abstract]. Headache. 1990;30(5):300.
Penzien D, Johnson C, Seville J, Rubman S, Boggess JT, Rains JC. Interrelationships among daily and global self-report measures of headache. Headache Quarterly. 1994;5:8-14.
Price KP, Tursky B. Vascular reactivity of migraineurs and non-migraineurs: a comparison of responses to self-control procedures. Headache. 1976;16(5):210-7. [pmid: 977325].
Reading C. Psychophysiological reactivity in· migraine following biofeedback. Headache. 1984;24(2):70-4. [pmid: 6715162].
Reich BA. Non-invasive treatment of vascular and muscle contraction headache: a comparative longitudinal clinical study. Headache. 1989;29(1):34-41. [pmid: 2647667].
Richardson GM, McGrath PJ. Cognitive-behavioral therapy for migraine headaches: a minimal-therapist-contact approach versus a clinic-based approach. Headache. 1989;29(6):352-7. [pmid: 2759842].
Sargent J, Solbach P, Coyne L, Spohn H, Segerson J. Results of a controlled, experimental, outcome study of nondrug treatments for the control of migraine headaches. J Behav Med. 1986;9(3):291-323. [pmid: 3746900].
Schultz JH, Luthe V. Autogenic training. New York. Grune & Stratton. 1969;1.
Sheftell F, Rapoport A, Kudrow L. Efficacy of cranial electrotherapy stimulation in the prophylactic treatment of migraine and chronic muscle contraction headaches. Cephalalgia. 1989;9(Suppl 10):379-80.
Shekelle PG, Brook RH. A community-based study of the use of chiropractic services. Am J Public Health. 1991;81:439-42. [pmid: 2003620].
Silver BV, Blanchard EB, Williamson DA, Theobald DE, Brown DA. Temperature biofeedback and relaxation training in the treatment of migraine headaches: one-year follow-up. Biofeedback Self Regul. 1979;4(4):359-66. [pmid: 393306].
Solbach P, Sargent J, Coyne L. Menstrual migraine headache: results of a controlled, experimental, outcome study of non-drug treatments. Headache. 1984;24(2):75-8. [pmid: 6370911].
Solbach P, Sargent J, Coyne L. Menstrual migraine headache: results of a controlled, experimental, outcome study of nondrug treatments. Diamond S, Maliszewski M, editors. Sexual aspects of headaches. Madison (CT). International Universities Press Inc. 1992:165-74.
Solomon S, Elkind A, Freitag F, Gallagher RM, Moore K, Swerdlow B, Malkin S. Safety and effectiveness of cranial electrotherapy in the treatment of tension headache. Headache. 1989;29:445-50. [pmid: 2668227].
Solomon S, Guglielmo KM. Treatment of headache by transcutaneous electrical stimulation. Headache. 1985;25(1):12-5. [pmid: 3871754].
Sorbi M, Tellegen B. Differential effects of training in relaxation and stress-coping in patients with migraine. Headache. 1986;26(9):473-81. [pmid: 3536801].
Sorbi M, Tellegen B. Multimodal migraine treatment: does thermal feedback add to the outcome?. Headache. 1984;24:249-55. [pmid: 6386749].
Sorbi M, Tellegen B, Du Long A. Long-term effects of training in relaxation and stress-coping in patients with migraine: a 3-year follow-up. Headache. 1989;29(2):111-21. [pmid: 2651355].
Sovak M, Kunzel M, Sternbach RA, Dalessio DJ. Mechanism of the biofeedback therapy of migraine: volitional manipulation of the psychophysiological background. Headache. 1981;21(3):89-92. [pmid: 7263222].
Stewart WF, Shechter A, Lipton RB. Migraine heterogeneity. Disability, pain intensity, and attack frequency and duration. Neurology. 1994;44(6 Suppl 4):S24-39. [pmid: 8008223].
Stewart WF, Shechter A, Rasmussen BK. Migraine prevalence: a review of population-based studies. Neurology. 1994;44(6 Suppl 4):S17-23. [pmid: 8008222].
Szekely B, Botwin D, Eidelman BH, Becker M, Elman N, Schemm R. Nonpharmacological treatment of menstrual headache: relaxation-biofeedback behavior therapy and person-centered insight therapy. Headache. 1986;26(2):86-92. [pmid: 3514550].
Tollison CD, Kunkel RS, editors. Headache diagnosis and treatment. Baltimore. Williams and Wilkins. 1993:393.
Vincent CA. A controlled trial of the treatment of migraine by acupuncture. Clin J Pain. 1989;5(4):305-12. [pmid: 2520420].
Wauquier A, McGrady A, Aloe L, Klausner T, Collins B. Changes in cerebral blood flow velocity associated with biofeedback-assisted relaxation treatment of migraine headaches are specific for the middle cerebral artery. Headache. 1995;35(6):358-62. [pmid: 7635723].
Williamson DA, Monguillot JE, Jarrell MP, Cohen RA, Pratt JM, Blouin DC. Relaxation for the treatment of headache. controlled evaluation of two group programs. Behav Modif. 1984;8(3):407-24. [pmid: 6383339].
Winkler R, Underwood P, Fatovich B, James R, Gray D. A clinical trial of a self-care approach to the management of chronic headache in general practice. Soc Sci Med. 1989;29(2):213-9. [pmid: 2665109].
Wittchen H. A biobehavioral treatment program (SEP) for chronic migraine patients. Holroyd KA, Schlote B, Zenz B, editors. Perspectives in research on headache. Toronto. Hogrefe. 1983:183-97.